# Evidence Tables and Figures

Table C1 Disease specific mortality or survival for randomized controlled trials

Study Outcomes | Treatment Group | Control Group | Analyses; p-values
RP compared to WW
Bill-Axelson, 2005 ^1^ | RP (n=347) | Watchful waiting (n=348) | p value
| | | Absolute risk reduction (ARR) [95% CI]
| | | Relative risk (RR) [ 95% CI]
Total number of PC deaths | 30 | 50 | 0.01
Cumulative Incidence of death | 2.3% [1.2 to 4.6]* at 5 years | 4.3% [2.6 to 7.1] at 5 years | ARR: 2.0 [-0.6 to 4.7] at 5 years
| 9.6% [6.5 to 14.2] at 10 years | 14.9% [11.2 to 19.8] at 10 years | ARR: 5.3 [-0.3 to 11.0] at 10 years
Median followup: 8.2 years | | | RR: 0.56 [0.36 to 0.88] at 10 years
RP compared to RP combined with neoadjuvant ADT
Klotz, 2003 ^2^ | RP (n=101) | RP + neoadjuvant ADT (n=112)
Total number of PC deaths | 0 | 1
Median followup: 6 years (0.6 to 9.8)
EBRT, comparison of different regimens
Yeoh,2006 ^3^ | Hypofractionated (55 Gy) EBRT group (n=108) | Conventional (64 Gy) EBRT (n=109)
Total number of PC deaths | 1 | 3
Median followup: 4 years (0.5 to 9)
Lukka, 2005 ^4^ | Long arm (66 Gy) EBRT (n=470) | Short arm (52.5 Gy) EBRT (n=466)
Total number of PC deaths | 3 (<1%) | 0
Median followup: 5.7 years (4.5 to 8.3)
Yeoh, 2003 ^5^ | Conventional (64 Gy) EBRT (n=61) | Hypofractionated (55 Gy) EBRT (n=59)
Total number of PC deaths | 1 (1.6%) | 0
Median followup: 3.6 years (1.9 to 5.2)
Zietman, 2005 ^6^ | Conventional dose (70 Gy) EBRT (n=197) | High dose (79.2 Gy) EBRT (n=196)
Total number of PC deaths | 2 | 0
Median followup: 5.5 years (1.2 to 8.2)
EBRT combined with ADT compared to EBRT alone
Denham, 2005 ^7^ | EBRT (66 Gy) (n=164, T2 only) | EBRT (66 Gy) Group + 6 months ADT (n=162, T2 only) | HR [95% CI]
Total number of PC deaths: T2b | 5 | 1 | 0.22 [0.03 to 1.88]
Total number of PC deaths: T2c | 12 | 7 | 0.57 [0.22 to 1.44]
Median followup: 5.9 years (0.1 to 8.5)
D'Amico, 2004 ^8^ | Conformal EBRT (70 Gy) (n=103) | Conformal EBRT (70 Gy) + adjuvant ADT (n=98) | p value
Total number of PC deaths | 6 | 0 | 0.02
Median followup: 4.5 years
Vaccine compared to nilutamide
Arlen, 2005 ^9^ | Vaccine Group (n=21) | Nilutamide Group (n=21)
Total number of deaths | 1** | 4**

* 95% Confidence intervals

** Includes crossover deaths

Table C2 Biochemical progression/reoccurrence or bNED for randomized controlled trials

Study Outcomes | Treatment Group | Control Group | Analyses; p-values
RPwith or without ADT compared to RP combined with neoadjuvant ADT
Homma, 2004 ^10^ | Definition of biochemical progression/reoccurrence or bNED: PSA above the normal level, local reoccurrence, or distant metastases.
| RP + adjuvant ADT (n=63, stage A and B) | RP + neoadjuvant and adjuvant ADT (n=69, stage A and B) | p value
Clinical relapse events at 5 years | 9 | 11 | <0.05 relapse vs. no relapse
| 1/12 stage A | 0/9 stage A
| 8/51 stage B | 11/60 stage B
Klotz, 2003 ^2^ | Definition of biochemical progression/reoccurrence or bNED: Two consecutive detectable PSAs (>2.0 ng/ml) at least 4 weeks apart, re-treatment or death from prostate cancer.
| RP (n=101) | RP + neoadjuvant ADT (n=112) | Hazard ratio [95% CI*]
Biochemical reoccurrence events at 6 years | 34 (33.7%) | 42 (37.5%) | 0.98 [0.61; 1.56]
Gleason score at biopsy: 2–6 | | | 1.00
7 | | | 1.29 [0.72; 2.31]
8–10 | | | 2.82 [1.52; 5.22]
No evidence of bNED at 5 years | 68.2% [58.5; 77.8] | 60.2% [50.4 to 70.0] | p value
Estimated bNED survival at 7 years: | | | 0.73
Gleason: 2–6 (n=142) | 0.90 | 0.89 | 0.81
7 (n=36) | 0.75 | 0.90 | 0.91
8–10 (n=22) | 0.63 | 0.79 | 0.80
Median followup: 6 years (0.6 to 9.8)
Schulman, 2000 ^11^ | Definition of biochemical progression/reoccurrence or bNED: Increase in PSA on 2 consecutive occasions of >1.0 ng/ml
| RP (n=115, T2 only) | RP + neoadjuvant ADT (n=105, T2 only) | p Value
PSA progression >1 ng/ml events at 4 years | 26/114 (22.8%) | 18/102 (17.6%) | 0.35
| T2 and PSA <20 ng/ml | T2 and PSA <20 ng/ml
| 16/94 (17.0%) | 13/84 (15.4%) | 0.78
Soloway, 2002 ^12^ | Definition of biochemical progression/reoccurrence or bNED: PSA >0.4 ng/ml
| RP (n=154) | RP + neoadjuvant ADT (n=149) | p value
Biochemical reoccurrence at 5 years
Gleason, biopsy: 2–6 (n=159) | 22/80 (27.1%) | 18/79 (22.6%) | 0.62
7 (n=56) | 10/25 (41.3%) | 15/31 (47.7%) | 0.72
8–10 (n=29) | 8/14 (57.4%) | 13/15 (89.6%) | 0.173
Gleason, specimen: 2–6 (n=105) | 18/66 (27.1%) | 10/39 (26.0%) | 1.0
7 (n=96) | 17/48 (38.9%) | 15/48 (30.5%) | 0.54
8–10 (n=38) | 4/12 (33.7%) | 17/26 (64.6%) | 0.13
bNED at 5 years | 67.6% | 64.8% | 0.66
RP compared to EBRT
Paulson, 1982 ^13^ | Definition of biochemical progression/reoccurrence or bNED: Serum prostatic acid phosphatase elevation on 2 consecutive followups or by appearance of bony or parenchymal disease with or without concomitant acid phosphatase elevation.
| RP (n=47) | EBRT (n=59) | p value
K-M estimate of failure at 5 years | 14% (estimated from graph) | 39% (estimated from graph) | 0.037
EBRT, comparison of different regimens
Peeters, 2006 ^14^ | Definition of biochemical progression/reoccurrence or bNED: Defined according to ASTRO -3 consecutive increases in PSA level after nadir or clinical evidence of failure (palpable and/or biopsy proven local relapse, regional relapse, metastases, or initiation of salvage
Biochemical reoccurrence/clinical failure events | Conventional dose (68 Gy) EBRT group (n=56 Low risk T1/2; Gleason ≤6; PSA ≤10) | High dose (78 Gy) EBRT group (n=64 Low risk T1/2; Gleason ≤ 6; PSA ≤ 10) | HR [95% CI]
Median followup: 4.2 years (0.8 to 7.6) | 7/56 (12.5%) | 10/64 (15.6%) | 1.25 [0.5; >2.0] (estimated from figure)
Yeoh, 2003 ^5^ | Definition of biochemical progression/reoccurrence or bNED: 3 consecutive increases in PSA after nadir
| Hypofractionated (55 Gy) EBRT group (n=108) | Conventional (64 Gy) EBRT (n=109) | p value
| | | HR [95% CI]
PSA relapse events | 37 | 39 | Not significant
K-M estimate of biochemical relapse-free survival at 5 years | 57.4% | 55.5% | HR: 0.92 [0.58; 1.45]
Lukka, 2005 ^4^ | Definition of biochemical progression/reoccurrence or bNED: 3 consecutive increases in PSA, clinical evidence of failure (local and distant), initiation of hormonal therapy
| Short arm (52.5 Gy) EBRT (n=466) | Long arm (66 Gy) EBRT (n=470) | ARR [95% CI], HR [95% CI]
Biochemical or clinical failure (BCF) events | 263 (56.4%) | 236 (50.2%)
K-M estimate of BCF at 5 years | 59.95% | 52.95% | ARR: -7.0 [-12.6; -1.4]
Median followup: 5.7 years (4.5 to 8.3) | | | HR: 1.18 [0.99; 1.41]
Sathya, 2005 ^15^ | Definition of biochemical progression/reoccurrence or bNED: PSA failure, clinical failure, or death from prostate cancer
| Iridium implant + EBRT (n=31, T2 only) | EBRT (n=32, T2 only) | HR [95% CI]
BCF events | 8 | 18 | 0.37 [0.16; 0.85]
K-M estimate of BCF at 5 years
Median followup: 8.2 years | 25.8% | 57.3%
Zietman, 2005 ^6^ | Definition of biochemical progression/reoccurrence or bNED: 3 consecutive increases in PSA level, with the failure backdated to a point halfway between the first increase and the last nonincreasing value
| Conventional dose (70 Gy) EBRT (n=197) | High dose (79.2 Gy) EBRT (n=196) | p value
Freedom from biochemical failure at 5 years | 61.4% [54.6 to 68.3] | 80.4% [74.7; 86.1] | <0.001
Median followup: 5.5 years (1.2 to 8.2)
EBRT combined with ADT compared to EBRT alone
Denham, 2005 ^7^ | Definition of biochemical progression/reoccurrence or bNED: Based on Houston method. Time to failure is time from end of treatment to an increase of PSA ≥2 ng/ml above the post-treatment nadir level.
| EBRT (66 Gy) (n=164, T2 only) | EBRT (66 Gy) + 6 months ADT (n=162, T2 only) | HR [95% CI]
Failure events: T2b | 48 | 34 | 0.68 [0.44; 1.06]
Failure events: T2c | 66 | 40 | 0.47 [0.32; 0.69]
Median followup: 5.9 years (0.1 to 8.5)
Crook, 2004 ^16^ | Definition of biochemical progression/reoccurrence or bNED: Biochemical (PSA) disease-free survival according to ASTRO definition.
| 3 month group | 8 month group
| (n=51, Low risk T1c–T2a; PSA <10 ng/ml; Gleason ≤6) | (n=41, Low risk T1c–T2a; PSA <10 ng/ml; Gleason ≤ 6)
K-M estimate of freedom from biochemical failure at 5 years | 61% (estimated from graph) | 72% (estimated from graph) | p-value not noted
Median followup: 3.7 years (10 months–7 years)
D'Amico, 2004 ^8^ | Definition of biochemical progression/reoccurrence or bNED: PSA >1.0 ng/ml and increasing >0.2 ng/ml on 2 consecutive visits.
| Conformal EBRT (70 Gy) group (n=103) | Conformal EBRT (70 Gy) + adjuvant ADT (n=98) | p value
| | | HR [95% CI]
PSA failure events | 46 | 21 | <0.001
| | | 2.86 [1.69; 4.86]
Survival free of salvage ADT events | 43 | 21 | 0.002
K-M estimated salvage therapy free survival at 5 years | 57% [46; 69] | 82% [73; 90] | 2.30 [1.36; 3.89]
Median followup: 4.5 years
Brachytherapy
Wallner, 2003 ^17^ | Definition of biochemical progression/reoccurrence or bNED: PSA ≤ 0.5 ng/ml at last followup
| ^125^I (144 Gy) (n=57) | ^103^Pd (125 Gy) (n=58) | p value
Biochemical failure events | 6 | 5
KM estimated biochemical freedom from failure at 3 years | 89% | 91% | 0.76
Adjuvant EBRT combined with brachytherapy
Wallner, 2005 ^18^ | Definition of biochemical progression/reoccurrence or bNED: PSA ≤ 0.5 ng/ml at last followup
| ^103^Pd + EBRT (20 Gy) (n=83) | ^103^Pd + EBRT (44 Gy) (n=76) | p value
Biochemical failure events | 12 | 9
K-M estimated biochemical freedom from failure at 3 years | 83% | 88% | 0.64
Subjects with pretreatment PSA <10 ng/ml (n=112)
K-M estimated biochemical freedom from failure at 3 years | 84% | 94% | 0.16
Subjects with pretreatment PSA >10 ng/ml (n=47)
K-M estimated biochemical freedom from failure at 3 years | 82% | 72% | 0.38
Bicalutamide versus placebo; both treatment arms combined with standard care (adjuvant RP/EBRT or WW)
Wirth, 2004 ^19^ | Definition of biochemical progression/reoccurrence or bNED: Progression-free survival defined as the time from randomization to the earliest occurrence of objective progression (confirmed by bone scan, computerized tomography/ultrasound/MRI or histological evidence of distant metastases) or death from any cause.
Localized disease population (T1/T2) | Bicalutamide and radical prostatectomy (estimated n=1365) | Placebo and radical prostatectomy (estimated n=1,369) | p value
| | | HR [95% CI]
| | | Event-to-time ratio (ETR) [95% CI]
Progression events | 115 (8.4%) | 121 (8.8%) | 0.57
| | | HR: 0.93 [0.72 to 1.20]
Median followup: 5.4 years | | | ETR: 1.06 [0.87 to 1.28]
| Bicalutamide and radiation therapy (estimated n=538) | Placebo and radiation therapy (estimated n=527)
Progression events | 114 (21.2%) | 128 (24.3%) | 0.09
| | | HR: 0.80 [0.62; 1.03]
Median followup: 5.4 years | | | ETR: 1.16 [0.98; 1.37]
Vaccine compared to nilutamide
Arlen, 2005 ^9^ | Definition of biochemical progression/reoccurrence or bNED: PSA progression, the development of secondary malignancies or toxicity, and were either removed from study or crossed over to the other arm if time it was an appropriate time to do so
| Vaccine Group (n=21) | Nilutamide Group (n=21) | p value
Median time to treatment failure, in months | 9.9 | 7.6 | 0.28
| Crossover: 12 subjects had added nilutamide | Crossover: 8 subjects had added vaccine
| 13.9 after crossover, 25.9 from initiation of therapy | 5.2 after crossover, 15.5 from initiation of therapy

* Confidence intervals

Table C3 Definitions of biochemical progression/reoccurrence or bNED for randomized controlled trials

Study | Definition
Paulson, 1982 ^13^ | Acid phosphatase elevation on 2 consecutive followups or by appearance of bony or parenchymal disease with or without concomitant acid phosphatase elevation
Homma, 2004 ^10^ | Clinical relapse defined as PSA above the normal level, local reoccurrence, or distant metastases
Klotz, 2003 ^2^ | Biochemical reoccurrence defined as 2 consecutive detectable PSAs (>2.0 ng/ml) at least 4 weeks apart, re-treatment or death from prostate cancer
Schulman, 2000 ^11^ | PSA progression defined as an increase in PSA on 2 consecutive occasions of >1.0 ng/ml
Soloway, 2002 ^12^ | Biochemical reoccurrence defined as PSA >0.4 ng/ml
Lukka, 2005 ^4^ | Biochemical or clinical failure was defined as 3 consecutive increases in PSA, clinical evidence of failure (local and distant), initiation of hormonal therapy, or death from prostate cancer
Sathya, 2005 ^15^ | Biochemical or clinical failure was defined as PSA failure, clinical failure, or death from prostate cancer
Yeoh, 2003 ^5^ | PSA relapse defined as 3 consecutive increases in PSA after nadir
Zietman, 2005 ^6^ | American Society for Therapeutic Radiology and Oncology (ASTRO) definition of 3 consecutive increases in PSA level, with the failure backdated to a point halfway between the first increase and the last nonincreasing value
Crook, 2004 ^16^ | Freedom from failure was biochemical (PSA) disease-free survival according to ASTRO definition
D'Amico, 2004 ^8^ | PSA failure defined as PSA >1.0 ng/ml and increasing >0.2 ng/ml on 2 consecutive visits
Wallner, 2003 ^17^ | Freedom from biochemical failure was defined as PSA ≤0.5 ng/ml at last followup
Wallner, 2005 ^18^ | Freedom from biochemical failure was defined as PSA ≤0.5 ng/ml at last followup
Wirth, 2004 ^19^ | Progression free survival defined as the time from randomization to the earliest occurrence of objective progression (confirmed by bone scan, computerized tomography/ultrasound/MRI or histological evidence of distant metastases) or death from any cause
Arlen, 2005 ^9^ | Treatment failure defined as PSA progression, the development of secondary malignancies or toxicity, and were either removed from study or crossed over to the other arm if time it was an appropriate time to do so

Table C4 Incidence of distant metastatic disease for randomized controlled trials

Study Outcomes | Treatment Group | Control Group | Analyses; p-values
WW versus RP
Bill-Axelson, 2005 ^1^ | RP (n=347) | WW (n=348) | p value
| | | ARR [95% CI]
| | | RR [95% CI]
Total number of events | 50 | 79 | 0.004
Cumulative incidence of metastases | 8.1% [5.7; 11.6]* at 5 years | 9.8% [7.1; 13.5] at 5 years | ARR: 1.7 [-2.5; 6.0] at 5 years
Median followup: 8.2 years | 15.2% [11.4; 20.3] at 10 years | 25.4% [20.4; 31.5] at 10 years | ARR: 10.2 [3.1; 17.2] at 10 years
| | | RR: 0.60 [0.42; 0.86] at 10 years
RP versus radiation therapy
Paulson, 1982 ^13^ | RP (n=47) | Radiation therapy (n=59)
Total number of events at followup (time unclear) | 2 (positive bone scan) | 14 (positive bone scan (11); pulmonary metastases (1); lymph node metastases (1); parenchymal metastases (1)
RP with or without neoadjuvant therapy
Klotz, 2003 ^2^ | RP (n=101) | Neoadjuvant androgen ablation + RP (n=112) | p value
Total number of events | 1 | 5 | 0.21
Median followup: 6 years (0.6 to 9.8)
Schulman, 2000 ^11^ | RP (n=115, T2 only) | Neoadjuvant androgen ablation + RP (n=105, T2 only) | p value
Total number of events at 4 years | 6/114 (5%) | 6/102 (6%) | 0.84
Soloway, 2002 ^12^ | RP (estimated n=135) | Neoadjuvant androgen ablation + RP (estimated n=133) | p value
Events at 5 years
urethral margin involvement | 23 (17%) | 8 (6%) | <0.01
seminal vesicle involvement | 30 (22%) | 20 (15%) | Not significant
positive lymph nodes | 9 (6%) | 8 (6%) | Not significant
EBRT
Lukka, 2005 ^4^ | Long arm (66 Gy in 33 fractions) EBRT (n=470) | Short arm (52.5 Gy in 20 fractions) EBRT (n=466)
Distant failure events | 4 (1%) | 10 (2%)
Median followup: 5.7 years (4.5 to 8.3)
Vaccine versus nilutamide
Arlen, 2005 ^9^ | Vaccine Group (n=21) | Nilutamide Group (n=21)
Progressive disease (metastasis on scans) | 14 (5 events after crossover addition of nilutamide) | 7 (1 event after crossover addition of nilutamide) | p value not provided

* 95% Confidence intervals

Table C5 Definitions of toxicity for randomized controlled trials

Study | Definition
Lukka, 2005 ^4^ | Toxicity was assessed using National Cancer Institute of Canada toxicity scale, grading according to specific criteria for each symptom on a 5-point scale ranging from 0 (nontoxic) to 5 (severe toxicity). Gastrointestinal (GI) system included anorexia, diarrhea, GI bleeding, nausea, pain/cramping, proctitis, and vomiting. Genitourinary (GU) system included bladder changes, cystitis, fistula formation, frequency, hematuria, ureteral obstruction, and genitourinary pain.
Yeoh, 2003 ^5^ | GI symptoms were assessed by questionnaire: stool frequency, stool consistency, rectal pain, rectal mucus discharge, urgency of defecation, and rectal bleeding. Each symptom was graded on a on a 5-point scale ranging from 0 (nontoxic) to 4 (severe). The following GU symptoms were evaluated: urinary frequency by day, urinary frequency by night, hematuria, urgency of urination, and dysuria. Each symptom was graded on the same basis as the GI symptoms.
Zietman, 2005 ^6^ | Acute GU and GI morbidity were scored using the Radiation Therapy Oncology Group (RTOG) criteria, a 0 to 5 scale in which lower scores indicate fewer symptoms.
D'Amico, 2004 ^8^ | Toxicity grades are defined as Grade 1- mild, Grade 2 - moderate, Grade 3 - severe, Grade 4 - life threatening. From Trotti et al, Common toxicity criteria: version 2.0: an improved reference for grading the acute effects of cancer treatment: impact on radiotherapy. Int J Radiat Oncol Biol Phys. 2000;47:13–47.
Herstein, 2005 ^20^ | RTOG criteria. Persistent bleeding was defined as lasting more than one month and was noted as a Grade 2 morbidity.
Wallner, 2003 ^17^

Table C6 Intra-operative outcomes and positive margins after laparoscopic vs. open retropubic radical prostatectomy

Outcomes | LRP, % | RRP, % | OR LRP vs. RRP (95% CI)
Pelvic lymphadenectomy | 40 | 45 | 0.82 (0.47; 1.43)
Bilateral nerve sparing | 41.6 | 51.6 | 0.67 (0.38; 1.17)
Monolateral nerve sparing | 18.3 | 13.3 | 1.46 (0.68; 3.15)
Autologous transfusion (no) | 13.3 | 45 | 0.19 (0.09; 0.38)
First flatus (%) | 35 | 18 | 2.45 (1.27; 4.72)
Mobilization (%) | 92 | 82 | 2.52 (1.04; 6.11)
Free ambulation (%) | 23 | 10 | 2.69 (1.21; 6.00)
5-day catheterization | 86.6 | 66.6 | 3.24 (1.59; 6.59)
Discharged on postoperative day 6 (with or without catheter) | 90 | 86.6 | 1.39 (0.58; 3.33)
Positive margins, T2 | 24.4 | 18.25 | 1.45 (0.73; 2.86)

Table C7 Complication counts

Type of Complication | Time Period^ a ^ | Used in Graphs^ c ^ | | Entire Database^ d ^
| | Number of Reports | Number of Descriptions | Number of Reports | Number of Descriptions
Bowel | ≤6 months | 6 | 3 | 17 | 30
Bladder | ≤6 months | 4 | 2 | 30 | 72
Erectile dysfunction | ≤6 months | 3 | 2 | 15 | 16
Bowel | 6–24 months | 2 | 3 | 12 | 23
Bladder | 6–24 months | 3 | 2 | 21 | 52
Erectile dysfunction | 6–24 months | 6 | 2 | 17 | 26
Bowel | >24 months | 0 | 0 | 11 | 19
Bladder | >24 months | 3 | 4 | 14 | 21
Erectile dysfunction | >24 months | 5 | 2 | 12 | 9
Other | >24 months | 0 | 0 | 3 | 8
Bowel | 999 | 3 | 2 | 34 | 53
Bladder | 999 | 14 | 3 | 51 | 109
Erectile dysfunction | 999 | 5 | 1 | 24 | 46
Bowel | Any^ b ^ | 5 | 3 | 57 | 87
Bladder | Any^ b ^ | 19 | 6 | 79 | 203
Erectile dysfunction | Any^ b ^ | 13 | 2 | 44 | 79
Other | Any^ b ^ | | | 47 | 129

a The latest month reported was selected for each report/group combination, or each report

b Maximum of 4 per report/group combination or report

c Definitions selected had 3 or more reports associated with them, needed to have percent with complication data, and were selected by treatment. Graphs include report/group combinations.

d All treatments and combinations of treatments are included in these numbers, report/group combinations were not used.

Table C8 Outcomes after cryosurgical prostatectomy in patients with localized prostate cancer

Reference Design | Population Followup Definition of Outcome | Treatment | Outcome | Occurrence
Aus, 2002 ^21^ | 54 patients without metastases, mean age 68 years, mean PSA 26 ng/ml | Liquid nitrogen system CMS AccuProbe 450 (CryoMedical Science Inc., Rockville, MD). | Progression free survival | 19 (38.9%)
Prospective phase noncontrolled II trial | 40.7% with T >2, 37.04% with Gleason scores >7, median followup 58.5 months. | The total operation time 90–180 minutes, mean 148 minutes, freezing time 33 minutes, length of stay 1.2 days | Tissue sloughing | 14.81%
| Treatment failure: positive biopsy or a serum PSA of >1 ng/ml | | TURP resection of sloughed tissue | 14.81%
| | | Stricture | 16.67%
| | | Stone formation in prostatic urethra | 9.26%
| | | Urinary tract infection | 33.33%
| | | Perennial fistula/prostatic abscess | 1.85%
| | | Self reported impotence | 72.22%
| | | Self reported potency | 7.41%
| | | Not reported potency | 20.37%
| | | Incontinence
| | | Severe (>2 pads per day) | 1.85%
| | | Mild (1–2 pads per day) | 16.67%
Lee, 1994 ^22^ | 210 patients with localized or locally advanced prostate cancer | 3.4 mm diameter cryoprobes (Endocare, Inc., Irvine, CA) inserted transperineally into the prostate under the transrectal ultrasound control | Urethrorectal fistula | 2.4%
Case series | | | Bladder outlet obstruction | 3%
| | | Incontinence | 9%
| | | Impotence | 40%
| | | Total complications | 14%
Bahn, 2002 ^23^ | 590 consecutive patients with localized or locally advanced prostate cancer, mean age 70.76 years, 1.8% - T1, 78.1% - T2, 52.5% with Gleason score of 7, and 6% >7, mean followup 5.43 years, Treatment failure: PSA level >1 and >0.5 ng/ml | 3.4 mm diameter cryoprobes (Endocare, Inc., Irvine, CA) inserted transperineally into the prostate under the transrectal ultrasound control. | Biochemical disease free survival | 89–100%
Case series | | Androgen ablation therapy 91.5% before treatment 3 months to 1 year before cryoablation | PSA <0.5 | Low risk group (T1–2)
| | | 12 months | 19.49%
| | | 24 months | 16.53%
| | | 36 months | 15.47%
| | | 48 months | 14.62%
| | | 60 months | 12.92%
| | | 72 months | 9.53%
| | | 84 months | 6.78%
| | | Impotency of 373 potent before surgery | 354 (94.9%)
| | | 16.4 months after surgery | 19 (5.1%)
| | | Incontinence | 4.3%
| | | TURP | 5.5%
| | | Fistula | <0.1%
Cohen, 1996 ^24^ | 383 patients with localized or locally advanced prostate cancer | Cryoprobes (3 mm in diameter) were placed percutaneously with a transperineal approach. Cryoprobe placement and freezing were monitored using the transrectal ultrasound | % positive biopsy | 16%
Non controlled clinical trial | 28% with T >2, 7.9 | | Initial PSA ng/ml in A stage | 9.7
| Mean PSA 10 ng/ml | | Post treatment Mean PSA ng/ml | 0.73–1.7
| 53% with Gleason ≥7, 7 (>8) | | Urethrorectal fistula | 0.4%
| | | Tissue sloughing | 9.8%
| | | Urethral stricture | 2.2%
| | | Bladder outlet obstruction | 3%
| | | Incontinence | 4%
| | | Perineal pain | 0.4%
| | | Urinary tract infection | 2.2%
| | | Epididymitis | 1.6%
| | | Sepsis | 0.7%
| | | Urethral obstruction | 2%
Coogan, 1995 ^25^ | 95 percutaneous cryoablations of the prostate on 87 patients with prostate cancer, mean age 65.4, mean PSA 12.60 ng/ml, mean Gleason score 6.03, median followup 12 months | Cryoprobes (3 mm in diameter) were placed percutaneously with a transperineal approach. Cryoprobe placement and freezing were monitored using the transrectal ultrasound. | % positive biopsy | 16–38%
Non controlled clinical trial | | Mean operative time was 129 minutes, mean length of stay 16 days | Mean PSA ng/ml | 1.58–3.22
| | | T1 | 3.55
| | | T2 | 1.9
| | | Urethrorectal fistula | 1%
| | | Tissue sloughing | 10%
| | | Urethral stricture | 1%
| | | Bladder outlet obstruction | 6%
| | | Incontinence | 3.5%
| | | Impotence | 47%
| | | Perineal pain | 1%
| | | Urinary tract infection | 4%
| | | Urethral obstruction | 2%
Cox, 1995 ^26^ | Retrospective review of the charts of 63 patients (69 procedures) performed in a single center | Cryoprobes (3 mm in diameter) were placed percutaneously with a transperineal approach. Cryoprobe placement and freezing were monitored using the transrectal ultrasound | Urethrorectal fistula | 3%
Case series | | | Tissue sloughing | 19%
| | | Urethral stricture | 3%
| | | Bladder outlet obstruction | 29%
| | | Incontinence | 27%
| | | Perineal pain | 11%
| | | Sepsis | 3%
| | | Urethral obstruction | 13%
| | | Total complications | 59%
| | | Number of operations | 43%
| | | Transient ischemic attack | 2%
| | | Cerebrovascular accident | 2%
Donnelly, 2002 ^27^ | 76 consecutive patients with adenocarcinoma of prostate mean age 65 years, 12% with T >2, mean PSA ng/ml 13, 56% Gleason ≥7, followup 50 months. Treatment failure: PSA > 1 ng/ml | Multiple percutaneous cryoprobes (5) were placed under TRUS guidance percutaneously and transperineally into the prostate | Progression free survival | 60–75%
Prospective pilot noncontrolled clinical trial | | | % positive biopsy | 1.4%
| | | Mean PSA ng/ml | 0.3–0.9
| | | Sloughing | 3 (3.9%)
| | | Incontinence | 1 (1.3%)
| | | Testicular abscess | 1 (1.3%)
Ellis, 2002 ^28^ | 75 patients with localized prostate cancer, 21% with T >2, mean PSA ng/ml 8.5, 55% Gleason ≥7 | Multiple percutaneous cryoprobes (6) were placed with Cryocare System, (Endocare, Inc., Irvine, CA), a cryosurgical device with 8 cryoprobe ports and an integrated temperature monitoring system | Progression free survival | 84%
Case series | | | Mean PSA ng/ml | 0–0.23
| | | Tissue sloughing | 6.7%
| | | Incontinence | 5.5%
| | | Impotence | 82.4%
Koppie, 1999 ^29^ | 176 patients with clinically localized (stages T1 to T4) prostate cancer, 35.8% with T >2, mean PSA ng/ml 18.4, 20% Gleason ≥7; 57% received neoadjuvant androgen deprivation; Treatment failure: PSA >0.5 ng/ml and increased by more than 0.2 ng/ml on 2 consecutive occasions. Mean followup 30.8 months | The prostate was frozen with a multiprobe cryosurgical device. 5 probes were placed with ultrasound monitoring | Progression free survival in T1–2
Case series | | | At 1 year | 82%
| | | At 3 years | 60%
Long, 1998 ^30^ | 145 consecutive patients with nonmetastatic prostate adenocarcinoma; Androgen deprivation was used for 3 to 8 months before the procedure in 30% of patients. 28% with T >2, mean PSA ng/ml 10, 53% Gleason ≥7, followup 60 months. Treatment failure: PSA >0.3 | Multiple percutaneous cryoprobes (5–8) were placed to ablate the entire prostate with real-time transrectal ultrasound monitoring | Progression free survival | 56%
Prospective pilot noncontrolled trial | | | Positive biopsy | 21%
| | | Urethrorectal fistula | 1.3%
| | | Tissue sloughing | 8.9%
| | | Urethral stricture | 3.4%
| | | Bladder outlet obstruction | 17.2%
| | | Incontinence | 2%
| | | Impotence | 88%
| | | Perineal pain | 2.3%
| | | Urinary tract infection | 2.3%
| | | Epididymitis | 1.5%
| | | Sepsis | <1%
| | | Urethral obstruction | 4.8%
| | | Total complications | 17%
| | | Number of operations | 17%
| | | Any treatment | 21%
Shinohara, 1996 ^31^ | 102 patients underwent cryosurgery as definitive therapy for localized prostate cancer, 57% with T >2, mean PSA ng/ml 21.8, 54% Gleason ≥7, followup 12 months | Multiple percutaneous cryoprobes were placed to ablate the entire prostate with real-time transrectal ultrasound monitoring | Progression free survival | 74%
Case series | | | Urethrorectal fistula | 1%
| | | Tissue sloughing | 23%
| | | Bladder outlet obstruction | 23%
| | | Incontinence | 15%
| | | Impotence | 86%
| | | Perineal pain | 3%
| | | Urinary tract infection | 3%
| | | Epididymitis | 3%
| | | Sepsis | 3%
| | | Urethral obstruction | 4%
Shinohara, 1997 ^32^ | 134 patients underwent 147 cryosurgical ablation procedures for localized prostate cancer. 35.1% with T >2, mean PSA ng/ml 19, 46.4% Gleason ≥7 biochemical failure: PSA nadir ≥0.5 ng/ml or PSA increase ≥0.2 g, followup 6 months | Multiple percutaneous cryoprobes were placed to ablate the entire prostate with real-time transrectal ultrasound monitoring | Progression free survival | 89%
Case series | | | Positive biopsy | 11%
Sosa, 1996 ^33^ | 1,467 patients with prostate cancer, 5% with Gleason score >8 | Multiple percutaneous cryoprobes were placed to ablate the entire prostate with real-time transrectal ultrasound monitoring | Urethrorectal fistula | 1.4%
Multicenter case series | | | Tissue sloughing | 9.9%
| | | Urethral stricture | 5%
| | | Bladder outlet obstruction | 6.8%
| | | Incontinence | 11%
| | | Impotence | 100%
| | | Perineal pain | 9.4%
| | | Urinary tract infection | 9.1%
| | | Sepsis | 2.3%
Wake, 1996 ^34^ | 104 patients with localized adenocarcinoma of the prostate, 46% with T >2, mean PSA ng/ml 11.3, 14% Gleason ≥7, followup 6 months, treatment failure: PSA >4 ng/ml positive biopsy | Multiple percutaneous cryoprobes (5) were placed under ultrasound guidance. Average hospital stay 36.6 hours | Progression free survival | 96%
Noncontrolled clinical trial | | | Positive biopsy | 25%
| | | Mean PSA ng/ml | 1.15
| | | Tissue sloughing | 1%
| | | Urethral stricture | 1.9%
| | | Bladder outlet obstruction | 21.2%
| | | Incontinence | 7.7%
| | | Perineal pain | 9.6%
Wieder, 1995 ^35^ | 83 patients with prostate cancer, mean age 67 years, 22.9% with T >2, mean PSA ng/ml 6.5–9.6 | Transrectal ultrasound-guided transperineal percutaneous cryoablation with an Accuprobe System cryosurgery instrument (3 to 6 probes) | Progression free survival | 92.6%
Case series | | | Positive biopsy | 19.3%
| | | Mean PSA ng/ml | 3.5
| | | Urethrorectal fistula | 0%
| | | Tissue sloughing | 3.8%
| | | Urethral stricture | 2.2%
| | | BOO | 3%
| | | Incontinence | 4%
| | | Perineal pain | 0.4%
| | | Urinary tract infection | 2.2%
| | | Epididymitis | 1.6%
| | | Sepsis | 0.7%
| | | Urethral obstruction | 2%
Robinson, 1999, 2002 ^36,^ ^37^ | 75 patients with localized prostate cancer, 11–12% with T 1–2, the Functional Assessment of Cancer Treatment-Prostate | Transrectal ultrasound-guided percutaneous radical cryosurgical ablation with multiple probes and transrectal ultrasound guidance | | Scores (SE) (max 28)
Phase 2 of noncontrolled clinical trial | | | Physical well-being | 26.01 (2.93)
| | | Social/family well-being | 23.46 (4.62)
| | | Emotional well-being | 17.92 (2.87)
| | | Functional well-being | 24.34 (3.95)
| | | Relationship with doctor | 7.40 (1.54) max 8

Table C9 Patient outcomes after cryosurgical treatment of localized prostate cancer (evidence from nonrandomized clinical trials and case series)

Author | Bahn ^38^ | Coogan ^25^ | Wieder ^35^ | Cox ^26^ | Cohen ^24^ | Sosa ^33^ | Shinohara ^31^ | Wake ^34^ | Shinohara ^32^ | Long ^30^ | Koppie ^29^ | Bahn ^23^ | Donnelly ^27^ | Ellis ^28^ | Aus ^21^
Year | 1994 | 1995 | 1995 | 1995 | 1996 | 1996 | 1996 | 1996 | 1997 | 1998 | 1999 | 2002 | 2002 | 2002 | 2002
Followup, months | NR | 12 | 3 | 12 | 24 | NR | 12 | 6 | 6 | 60 | 30.8 | 68.6 | 50 | 3 | 58.5
Number of patients | 210 | 95 | 83 | 63 | 239 | 1467 | 102 | 104 | 134* | 145 | 176 | 590 | 76 | 75 | 54
% with T >2 | NR | 7.4 | 22.9 | NR | 7.9 | NR | 57 | 46 | 35.1 | 28 | 35.8 | 17.6 | 12 | 21 | 40.7
Mean PSA ng/ml | NR | 12.6 | 6.5–9.6 | NR | 9.7 | | 21.8 | 11.3 | 19 | 10 | 18.4 | NR | 13 | 8.5 | 26
% Gleason ≥7 | NR | NR | NR | NR | 7 (>8) | 5(>8) | 54 | 14 | 46.4 | 53 | 20 | 58.5 | 56 | 55 | 37.04
Outcomes in patients with localized PC
Progression free survival, % | NR | NR | 92.6 | NR | NR | NR | 74 | 96 | 89 | 56 | 60 | 89–100 | 60–75 | 84 | 38.9
% positive biopsy | NR | 16–38 | 19.3 | NR | 16 | NR | NR | 25 | 11 | 21 | NR | 13 | 1.4 | NR | NR
Mean PSA ng/ml | NR | 1.58–3.22 | 3.5 | NR | 0.73–1.7 | NR | NR | 1.15 | NR | NR | NR | NR | 0.3–0.9 | 0–0.23 | NR
% Complications
Urethrorectal fistula | 2.4 | 1 | 0 | 3 | 0.4 | 1.4 | 1 | 0 | NR | 1.3 | NR | <0.1 | NR | 0 | 1.9
Tissue sloughing | NR | 10 | 3.8 | 19 | 9.8 | 9.9 | 23 | 1 | NR | 8.9 | NR | NR | NR | 6.7 | 14.8
Urethral stricture | NR | 1 | 2.2 | 3 | 2.2 | 5 | NR | 1.9 | NR | 3.4 | NR | NR | NR | | 11.1
BOO | 3 | 6 | 3 | 29 | 3 | 6.8 | 23 | 21.2 | NR | 17.2 | NR | NR | NR | NR | NR
Incontinence | 9 | 3.5 | 4 | 27 | 4 | 11 | 15 | 7.7 | NR | 2 | NR | 4.3 | NR | 5.5 | 18.5
Impotence | 40 | 47 | NR | NR | NR | 100 | 86 | NR | NR | 88 | NR | 94.9 | NR | 82.4 | 72.2
Perineal pain | NR | 1 | 0.4 | 11 | 0.4 | 9.4 | 3 | 9.6 | NR | 2.3 | NR | NR | NR | NR | NR
Urinary tract infection | NR | 4 | 2.2 | NR | 2.2 | 9.1 | 3 | NR | NR | 2.3 | NR | NR | NR | NR | 33.3
Epididymitis | NR | 0 | 1.6 | NR | 1.6 | NR | 3 | NR | NR | 1.5 | NR | NR | NR | NR | NR
Sepsis | NR | 0 | 0.7 | 3 | 0.7 | 2.3 | 3 | NR | NR | <1 | NR | NR | NR | NR | NR
Urethral obstruction | NR | 2 | 2 | 13 | 2 | NR | 4 | NR | NR | 4.8 | NR | NR | NR | NR | NR
Total complications | 14 | NR | NR | 59 | NR | NR | NR | NR | NR | 17 | NR | NR | NR | NR | NR
Number of operations | NR | NR | NR | 43 | NR | NR | NR | NR | NR | 17 | NR | NR | NR | NR | NR
Any treatment (n) | NR | NR | NR | NR | NR | NR | NR | NR | NR | 21 | NR | NR | NR | NR | NR

* Probably same patients

NR = not reported

BOO = Bladder outlet obstruction

Table C10 Comparative effectiveness of extraperitoneal versus transperitoneal laparoscopic prostatectomy in patients with localized prostate cancer (adapted from the systematic review by Rassweiler et al)

Author | Population | | | Treatment | N | OR-Time (Minutes) | Complication (%) | Reintervention (%) | Transfusion (%) | Catheter Time (d) | Positive Margins (%)
Hoznek, 2003 ^39^ | | A | B | Total | 40
Case series | Age (years) | 63 | 67 | A-transperiton | 20 | 224 | Not reported | 5 | 15 | 5.3 | 15
Historical controls | Mean PSA (ng/ml) | 9.5 | 11.7 | B-extraperiton | 20 | 170 | 7.3 | | 10 | 4.2 | 25
| Gleason score | 5.5 | 6.3
| T1a | 1 | 0
| T1b | 0 | 0
| T1c | 15 | 14
| T2a | 3 | 4
| T2b | 1 | 2
Cathelineau, 2004 ^40^ | | A | B | Total | 200
Case series | Age | 63 | 61 | A-transperiton | 100 | 173 | 23.8 | | 4 | 6.2 | 26.2
Historical controls | PSA | 8.9 | 10 | B-extraperiton | 100 | 163 | 16.7 | | 3 | 6 | 15.9
| T1 | 68 | 72
| T2 | 32 | 27
| T3 | 0 | 1
Ruiz, 2004 ^41^ | | A | B | Total | 330
Case series | Age | 64.1 | 63 | A-transperiton | 165 | 248 | Not reported | Not reported | 1.2 | 5.1 | 23
Historical controls | T1a–b | 8 | 5 | B-extraperiton | 165 | 220 | Not reported | Not reported | 5.4 | 6.6 | Not reported
| T1c | 110 | 106
| T2a | 42 | 50
| T2b | 5 | 4
| Mean PSA (ng/ml) | 10.8 | 9.9
| Gleason score | 5.7 | 6.2
| 2–4 | 33 | 17
| 5–6 | 95 | 84
| 7 | 28 | 53
| 8–9 | 9 | 11
Erdogru, 2004 ^42^ | | B | A | Total | 106
Case series | Age | 63 | 62.9 | A-transperiton | 53 | 187 | 24.6 | 1.8 | 13 | 7 | 20.7
Match-paired controls | PSA | 7 | 7.6 | B-extraperiton | 53 | 191 | 11.8 | - | 16 | 7 | 22.6
| T stage
| 2a | 12 | 13
| 2b | 21 | 20
| 2c | 7 | 8
| 3a | 11 | 10
| 3b | 2 | 2
| Gleason score | 6 | 6.1
Brown, 2005 ^43^ | | A | B | Total | 156
Case series | Age (years) | 58 | 56 | A-transperiton | 122 | 197 | 10.7 | Not reported | 3 | Not reported | 24
Historical controls | T1c | 103 | 23 | B-extraperiton | 34 | 191 | 11.8 | Not reported | - | Not reported | 21
| T2 | 19 | 11
| Gleason score 6 | 104 | 25
| Gleason score >7 | 18 | 9
| Gleason score (mean) | 15 | 14.9
Remzi, 2005 ^44^ | | B | A | Total | 80
Case series | Age (years) | 59 | 61 | A-transperiton | 39 | 279 | 20 | 7.7 | Not reported | Not reported | 25.6
| PSA (ng/ml) | 8.1 | 5.5 | B-extraperiton | 41 | 217 | 37 | 2.4 | Not reported | Not reported | 19.5
| Gleason score | 5.5 | 5.1

Table C11 Comparative effectiveness of laparoscopic versus retropubic radical prostatectomy (adapted from the systematic review by Rassweiler et al)

Author | Population | | | | Treatment | Sample Size | OR-Time (minutes) | Complication (%) | Reintervention (%) | Analgesics (mg) | Blood Loss (cc) | Transfusion (%)
Guilloneau, 2000 ^45^ | | | LRP | RRP | Total | 220
Case series | PSA ng/ml | | 11.2 | 11 | RRP | 100 | 135 | Not reported | Not reported | Not reported | 850 | 31
| Gleason score | | 6 | 6 | LRP | 120 | 239 | 7.3 | 2.5 | Not reported | 402 | 10
| Stage
| pT2 | | 85 | 107
| pT3a | | 8 | 7
| pT3b | | 7 | 6
Salomon, 2002 ^46^ | | RRP | PRP | LRP | Total | 401
Case series | Age | 65 | 64.6 | 64.1 | RRP | 219 | 197 | 23.8 | Not reported | Not reported | Not reported | 26.2
| PSA | 21 | 13.2 | 11.6 | PRP | 219 | 178 | 16.7 | Not reported | Not reported | Not reported | 15.9
| Gleason Score | 5.7 | 5.7 | 5.7 | LRP | 219 | 285 | 18.1 | Not reported | Not reported | Not reported | 2.9
Rassweiler, 2003 ^47^ | | RRP | LRP | LRP | Total | 657
Case series | | | Early | Later | RRP | 219 | 196 | 19.1 | 6.8 | 50.8a | 1,550 | 55.7
| Age | 65 | 64 | 64 | LRP early | 219 | 288 | 13.9 | 4.2 | 33.8 | 1,100 | 30.1
| pT1 | 5 | 5 | 1 | LRP late | 219 | 218 | 6.1 | 2 | 30.1 | 800 | 9.6
| pT2a | 55 | 43 | 39
| pT2b | 40 | 73 | 103
| pT3a | 72 | 53 | 49
| pT3b | 21 | 35 | 22
| pT4 | 24 | 10 | 5
| Gleason score | 7 | 6 | 6
| PSA (ng./ml) | 12 | 14.6 | 10.6
Bhayani, 2003 ^48^ | | | RRP | LRP | Total | 60
Case series | Age (years) | | 60.5 | 57.4 | RRP | 24 | 168 | 20.8 | 12.5 | 45 | 1,473 | Not reported
| PSA (ng/ml) | | 8.6 | 6.74 | LRP | 36 | 348 | 21.2 | 6 | 53c | 533 | Not reported
| Gleason score | | 6.13 | 6.06
| T1a | | 1 | 0
| T1c | | 14 | 21
| T2a | | 8 | 11
| T2b | | 1 | 1
Roumeguere, 2003 ^49^ | | | RRP | LRP | Total | 162
Nonrandomized clinical trial | Age | | 64 | 62.5 | RRP | 77 | 168 | 24.6 | 7.8 | Not reported | 1514 | Not reported
| PSA (ng/ml) | | 11 | 8.6 | ELRP | 85 | 288 | 11.8 | 3.5 | Not reported | 522 | Not reported
| Gleason score | | 5.4 | 5.4
Artibani, 2003 ^50^ | | | RRP | LRP | Total | 121
Case series | Age | | 64.3 | 63 | RRP | 50 | 105 | 20 | 4 | Not reported | Not reported | 34
| PSA (ng/ml) | | 11 | 16 | LRP | 71 | 180 | 37 | 4.2 | Not reported | Not reported | 63
| T1b | | 4 | 1
| T1c | | 26 | 20
| T2a | | 15 | 34
| T2b | | 4 | 10
| T3 | | 1 | 6
| Gleason score | | 5.7 | 5.8
Brown, 2004 ^51^ | | | LRP | RRP | Total | 120
Case series | Age | | 59 | 59 | RRP | 60 | Not reported | 18.3 | 3.3 | Not reported | 1355 | 52
| PSA (ng/ml) | | 6.4 | 5.6 | LRP | 60 | 330 | 25 | 3.3 | Not reported | 317 | 1.7
| T1a/b | | 0 | 1
| T1c | | 47 | 45
| T2a | | 13 | 11
| T2b | | 0 | 3
Fornara, 2004 ^52^ | | | | | Total | 64
Nonrandomized clinical trial | | | | | RRP | 32 | 140 | 9.3 | Not reported | 35 | 550 | 17
| | | | | ELRP | 32 | 220 | 3.1 | Not reported | 33 | 200 | 6
Remzi, 2005 ^44^ | | | LRP | RRP | Total | 121
Case series | Age (years) | | 59 | 60 | RRP | 41 | 195 | Not reported | 7.3 | 300 | 385 | Not reported
| PSA (ng/ml) | | 8.1 | 6.9 | LRP | 39 | 279 | Not reported | 7.7 | 290 | 290 | Not reported
| Gleason score | | 5.5 | 4.7 | ELRP | 41 | 217 | Not reported | 2.4 | 189 | 189 | Not reported
Keller, 2005 ^53,^ ^54^ | PSA >10 ng/ml | | | | Total | 150
Nonrandomized clinical trial | Gleason score >5 | | | | RRP | 50 | 150 | Not reported | Not reported | Not reported | 739 | 4
| | | | | PRP | 50 | 86 | Not reported | Not reported | Not reported | 269 | 0
| | | | | LRP | 50 | 249 | Not reported | Not reported | Not reported | 322 | 16

Table C12 Comparative effectiveness of laparoscopic, retropubic, and perineal radical prostatectomy (adapted from the systematic review by Rassweiler et al)

Author | Population | | | | Treatment | N | Continence (1 year) (%) | Potency Bilat Ns. (%) | Positive Margins (%) | PSA Relapse (%) | Overall Survival (%)
Salomon, 2002 ^46^ | | RRP | PRP | LRP | Total | 401
Case series | Age | 65 | 64.6 | 64.1 | RRP | 219 | Not reported | Not reported | 31.7 | Not reported | 75
| PSA | 21 | 13.2 | 11.6 | PRP | 219 | Not reported | Not reported | 18.5 | Not reported | 85.2
| Gleason Score | 5.7 | 5.7 | 5.7 | LRP | 219 | Not reported | Not reported | 28.5 | Not reported | 84.1
Rassweiler, 2003 ^47^ | | RRP | LRP | LRP | Total | 657
Case series | | | Early | Later | RRP | 219 | 89.9 | Not reported | 28.7 | 17.4 | 96.6
| Age | 65 | 64 | 64 | LRP early | 219 | 90.3 | Not reported | 21 | 13.2 | 98.6
| pT1 | 5 | 5 | 1 | LRP late | 219 | 91.7 | Not reported | 23.7 | Not reported | Not reported
| pT2a | 55 | 43 | 39
| pT2b | 40 | 73 | 103
| pT3a | 72 | 53 | 49
| pT3b | 21 | 35 | 22
| pT4 | 24 | 10 | 5
| Gleason score | 7 | 6 | 6
| PSA (ng/ml) | 12 | 14.6 | 10.6
Anastasidis, 2003 ^55^ | | | RRP | LRP | Total | 300
| Age | | 65 | 64.1 | RRP | 70 | 66.7 | 44% | Not reported | Not reported | Not reported
| PSA (ng/mL) | | 11 | 10.7 | LRP | 230 | 71.6 | 53% | Not reported | Not reported | Not reported
| Gleason score | | 6 | 5.8
| T1a–b | | 2 | 10
| T1c | | 50 | 156
| T2a | | 17 | 58
| T2b | | 1 | 6
| Gleason score | | 7 | 6.7
Roumeguere, 2003 ^49^ | | | RRP | LRP | Total | 162
Nonrandomized clinical trial | Age | | 64 | 62.5 | RRP | 77 | 83.9 | 54.5 | 40.2 | 6.9 | Not reported
| PSA (ng/ml) | | 11 | 8.6 | ELRP | 85 | 80.7 | 65.3 | 25.8 | 8.6 | Not reported
| Gleason score | | 5.4 | 5.4
Artibani, 2003 ^50^ | | | RRP | LRP | Total | 121
Case series | Age | | 64.3 | 63 | RRP | 50 | 78.5 | 10 | 24 | 11 | Not reported
| PSA (ng/ml) | | 11 | 16 | LRP | 71 | 60 | 8 | 30 | 19 | Not reported
| T1b | | 4 | 1
| T1c | | 26 | 20
| T2a | | 15 | 34
| T2b | | 4 | 10
| T3 | | 1 | 6
| Gleason score | | 5.7 | 5.8
Remzi, 2005 ^44^ | | | LRP | RRP | Total | 121
Case series | Age (years) | | 59 | 60 | RRP | 41 | Not reported | Not reported | 19.5 | Not reported | Not reported
| PSA (ng/m) | | 8.1 | 6.9 | LRP | 39 | Not reported | Not reported | 25.6 | Not reported | Not reported
| Gleason score | | 5.5 | 4.7 | ELRP | 41 | Not reported | Not reported | 19.5 | Not reported | Not reported
Keller, 2005 ^53,^ ^54^ | PSA >10 ng/ml | | | | Total | 150
Nonrandomized clinical trial | Gleason score > 5 | | | | RRP | 50 | 88 | Not reported | 20 | Not reported | Not reported
| | | | | PRP | 50 | 90 | Not reported | 11.7 | Not reported | Not reported
| | | | | LRP | 50 | 50 | Not reported | 16 | Not reported | Not reported

Table C13 Perioperative and pathological parameters and complication rates after three surgical treatments of prostate cancer: robotic assisted, laparoscopic, and open radical retropubic prostatectomy, pooled estimated from 24 observations

Outcomes | Robotic Assisted RP | LRP | Open RP
Installation time (minutes) | 32
Operative time (minutes) | 222 | 225 | 182
Mean EBL (ml) | 231 | 505 | 727
Blood transfusion (%) | 3.9 | 8.4 | 24
Conversion/abortion (%) | 1.1 | 1.4
Catheter time (days) | 8.1 | 6.1 | 7–21
Positive margins T2 (%) | 77.5 | 72.4 | 64
Positive margins T3 (%) | 21.6 | 26.5 | 32.2
Total positive surgical margins (%) | 15 | 19.9 | 24.1
Pathological stage 2/positive surgical margins (%) | 8.5 | 13.8 | 17.5
Overall complications (%) | 8.3 | 16.8 | 10.3
Minor complications (%) | 4.6 | 13 | 6.3
Major complications (%) | 3.8 | 4.9 | 4

Table C14 Outcomes after laparoscopic extraperitoneal, transperitoneal, robot assisted, and radical retropubic prostatectomy (from systematic review by Tooher et al) ^56^

Outcome (Number of Studies) | Effect Size
% Conversions to open procedure(12) | 0–14 (median 2)
% Total complications
Transperitoneal LRP vs. RRP (6) | 0–25 (median 17) vs. 8–25 (median 19)
Extraperitoneal endoscopic RP vs. RRP (3) | 11–37 (median 14) vs. 8–30 (median 20)
Robot assisted RP vs. RRP (2) | 5 + 7 vs. 20 + 10
Blood loss (ml)
Transperitoneal LRP vs. RRP (5) | 317–1,100 (median of means 800) vs. 1,325–1,550 (median of means 1,400)
Extraperitoneal endoscopic RP vs. RRP (2) | 795 vs. 829, 522 vs. 1,514
Robot assisted RP vs. RRP (3) | 103–382 (median of means 153), 418–1,330 (median of means 910)
% Transfusions
Transperitoneal LRP vs. RRP (5) | 0–18 (median 2) vs. 10–56 (median 26)
Extraperitoneal endoscopic RP vs. RRP (1) | 34 vs. 64
Robot assisted RP vs. RRP (3) | 0–28 (median 0) vs. 2–67 (median 38)
Operative time (minutes)
Transperitoneal LRP or extraperitoneal endoscopic RP vs. RRP (10) | 180–400 (median of means 288) vs. 105–235 (median of means 168)
Robot assisted RP vs. RRP (4) | 160–368 (median of means 231) vs. 163–242 (median of means 214)
Length of stay (days)
Transperitoneal LRP vs. RRP (8) | 2–12 (median of means 5) vs. 3–16 (median of means 7)
Extraperitoneal endoscopic RP vs. RRP (1) | 7.2 vs. 10.1
Robot assisted RP vs. RRP (3) | 1.1–2.0 (median of means 1.2) vs. 2.2–3.5 (median of means 2.7)
Catheterization (days)
Transperitoneal LRP vs. RRP (5) | 6.5–14 (median of means 7) vs. 12–19 (median of means 15)
Extraperitoneal endoscopic RP vs. RRP (2) | 6–11.8 (median of means 8) vs. 8.4–15 (median of means 14)
Robot assisted RP vs. RRP (3) | 6.3–7 (median of means 7) vs. 9–15.8 (median of means 13)
% Positive margins
Transperitoneal LRP vs. RRP (8) | 11–50 (median 23) vs. 20–34 (median 29)
Extraperitoneal endoscopic RP vs. RRP (3) | 16–30 (median 26) vs. 15–40 (median 24)
Robot assisted RP vs. RRP (4) | 6–26 (median 16) vs. 4–29 (median 20)
% Recurrence-free survival
Transperitoneal LRP vs. RRP (2) | 84 + 99 vs. 75 + 97
Extraperitoneal endoscopic RP vs. RRP (2) | 91 + 81 vs. 93 + 89
Robot assisted RP vs. RRP (2) | 92 + 95 vs. 85 + 95
Continence (% pad free)
Transperitoneal LRP vs. RRP (3) | 60–90 (median 80) vs. 67–90 (median 89)
Extraperitoneal endoscopic RP vs. RRP (3) | 79–90 (median 81) vs. 60–88 (median 83.9)
Robot assisted RP vs. RRP (3) | 76–90 (median 78) vs. 68–83 (median 75)
% Potency
Transperitoneal LRP vs. RRP (1) | 41 vs. 30
Extraperitoneal endoscopic RP vs. RRP (2) | 9 + 65 vs. 10 + 55
Robot assisted RP vs. RRP (2) | 71 + 90 vs. 59 + 40

* PSA 0.2 m/l or greater on more than 1 occasion

LRP= laparoscopic radical prostatectomy

RRP= retropubic radical prostatectomy

Table C15 Comparative effectiveness of robotic assisted laparoscopic radical prostatectomy

Author, Sample | Active vs. Control Treatment | Outcome | Outcome Rate After Active Treatment | Outcome Rate After Active Control Treatment | p
Ahlering, 2004 ^57^ | Cases 51–140, define the prostatic apex precisely vs. cases 1–50 | Positive margins | 3 | 9 | 0.003
The first 140 consecutive robot-assisted radical prostatectomies, pT2a – T2b
59 men <66 years of age with Sexual Health Inventory in Men (SHIM) score of 22 to 25 were treated with cautery-free technique (CFT) to preserve the neurovascular bundles (NVB) during robotic laparoscopic radical prostatectomy
Ahlering, 2005 ^58^ | Preservation of the NVB with CFT vs. traditional dissection using bipolar cautery | Erection adequate for vaginal penetration at 3 months | 10 | 3 | 0.003
59 men <66 years of age with Sexual Health Inventory in Men (SHIM) score of 22 to 25 were treated with cautery-free technique (CFT) to preserve the neurovascular bundles (NVB) during robotic laparoscopic radical prostatectomy | | Zero penile fullness at 3 months | 2 | 15
Ahlering, 2004 ^59^ | Robotic assisted laparoscopic RP vs. RP | Positive margins | 2 | 4
60 standard RPs and 60 robot-assisted laparoscopic RPs performed by one surgeon
Badani, 2005 ^60^ | Three-dimensional (3D) suturing frills vs. two-dimensional (2D) suturing frills | Operative time per drill | 8.5 minutes (range 4.7–12.8 minutes) | 13.1 minutes ( 6.9–21.9) | <0.001
Twenty-eight anastomotic drills performed randomly in a blinded fashion | | Major errors in performances | 2 | 5
Farnham, 2006 ^61^ | Robotic assisted laparoscopic RP vs. RP | Intraoperative blood loss | 191 | 664 | < 0.001
279 patients with localized PC made the decision which surgical approach to use | | Transfusion of blood products | 1 | 3
Hu, 2006 ^62^ | Robotic assisted laparoscopic RP vs. laparoscopic RP | Estimated blood loss | 250 (50–1,600) | 200 (0–1,500)
358 patients, 4 with T3 after LRP and 322 after RAP | | Operative time | 3.1 (1.9–8.8) | 4.1 (2.5–12.8)
| | Urological complications | 40 | 77
| | Bowel complications | 11 | 34
| | Vascular complications | 4 | 7
| | Postop blood transfusion | 5 | 8
Menon, 2002 ^63^ | Robotic assisted laparoscopic RP vs. laparoscopic RP | Mean mins. operating time (SE) | 274 | 258 | 0.4
48 laparoscopic radical prostatectomies and 50 robot assisted prostatectomies | | Mean ml. estimated blood loss (SE) | 256 | 391 | 0.013
| | Mean gm/dl hemoglobin decrease (SE) | 2.6 | 3 | 0.17
| | Mean % hematocrit decrease (SE) | 17.2 | 20.1 | 0.11
| | No. intraop. blood transfusion (%) | 0 | 1 | >0.99
| | No. conversion to open surgery (%) | 0 | 1 | >0.99
| | No. discharge home less than 24 hours (%) | 32 | 26 | 0.13
| | No. pos. margins | 5 | 5
Menon, 2002 ^64^ | Robotic assisted laparoscopic RP vs. RP | Operative time (hr) | 4.8 (4–7) | 2.3 (1.5–5)
Prospective nonrandomized comparison of RRP and RAP in 60 patients with clinically localized prostate cancer who elected s surgical treatment. | | EBL (mL) | 329 (75–1050) | 970 (400–2200)
| | Blood transfusion (%) | 7 | 30
| | Mean postoperative pain score (range) | 4 (1–9) | 7 (4–10) | <0.05
| | Hemoglobin drop (g/dL) | 1.2 (0.1–2) | 4.4 (0.5–4.8) | <0.05
| | Mean hospital stay (hr) | 36 (23–96) | 56 (48–96) | NS
| | Discharged within 24 hr (%) | 63 | 0 | <0.001
| | Mean duration of catheterization (days) | 10.7 (6–18) | 13.7 (7–18) | NS
| | Gleason score | 6.9 (2–9) | 6.6 (2–9) | NS
| | Node status (%) | 0 | 0 | NS
| | Margin positivity (%) | 26 | 29 | NS
| | Focal | 12 | 14 | NS
| | Extensive | 14 | 15 | NS
| | Seminal vesicle positivity (%) | 10 | 10 | NS
| | Intraoperative bleeding (>1,000 mL) | 1 | 5 | <0.05
| | Conversion | 1 | | NS
| | Rectal injuries | 0 | 1 | NS
| | Postoperative urinary retention | 1 | 1 | NS
| | Postoperative ileus | 3 | 3 | NS
| | Exaggeration of arthritis | 1 | 0 | NS
| | Wound dehiscence | 1 | 1 | NS
Tewari, 2003 ^65^ | Robotic assisted laparoscopic RP vs. RP | Catheterization, days | 7 (1–18) | 15.8 (7–28) | < 0.05
100 patients undergoing RRP and 200 undergoing VIP, 5.5% with T3A | | Collow-up, days | 236 | 556 | < 0.05
| | Undetectable PSA, % | 92 | 85 | NS
| | % cancer in specimen | 19 (1–80) | 18.3 (5–90) | NS
| | Complications | 5 | 20 | < 0.05
| | Time of 50% return of erection | 180 days | 440 days
| | Using sildenafil | 42% | 65%
Menon, 2004 ^66^ | Robotic assisted laparoscopic RP vs. RP | Operating room time | Crude odds ratio 0.91 | 163 min
1,100 cases of robotic radical prostatectomy in patients with localized prostate cancer and a life expectancy of over 10 year | | Estimated blood loss | 0.1 | 910 mL | <0.05
| | Positive margins | 1 | 23%
| | Complications | 0.33 | 15% | <0.05
| | Catheterization time | 0.44 | 15.8 d | <0.05
| | Hospital stay > 24 hours | 0.07 | 100% | <0.05
| | Postoperative pain score (0–10) | 0.45 | 7 | <0.05
| | Median time to continence (days) | 0.28 | 160 | <0.05
| | Median time to erection (days) | 0.4 | 440 | <0.05
| | Median time to intercourse(days) | 0.5 | >700 | <0.05
| | Detectable prostate specific | 0.5 | 15%
Rozet, 2007 ^67^ | Extraperitoneal robotic assisted laparoscopic RP vs. extraperitoneal laparoscopic RP | Mean ml blood loss | 609 (100–3,000) | 512 (70–1,800) | 0.07
133 consecutive patients who underwent extraperitoneal robot assisted radical prostatectomy compared to 133 match-paired patients treated with a pure extraperitoneal laparoscopic approach, 0.8% with T3 | | Mean operative mins | 166 (90–300) | 160 (90–270) | 0.09
| | % transfusion rate | 3 | 9.8 | 0.02
| | Hospital stay (days) | 5.4 (3–26) | 4.9 (3–20) | 0.21
| | Bladder catheter (days) | 9.2 (6–29) | 9.0 (7–31) | 0.56
| | Pos surgical margins | 19.5 | 15.8 | 0.42
| | Complications | 19.4 | 9.1 | 0.01
| | Anastomotic leakage | 0.8 | 0.8
| | Wound abscess | 0.8 | 0
| | Infected pelvic hematoma | 2.2 | 1.5
| | Urinary infection | 4.4 | 0.8
| | Postop bleeding | 4.4 | 0.8
| | Retention | 0.8 | 2.2
| | Anastomotic leakage | 0.8 | 0.8
| | Postop bleeding | 2.2 | 0
| | Urinary sepsis | 1.5 | 1.5
| | Pulmonary embolism | 0 | 0.8
| | Renal insufficiency | 1.5 | 0
Patel, 2007 ^68^ | Robotic assisted laparoscopic RP | Pos surgical margins | 9.4
500 robotically assisted laparoscopic radical prostatectomies, 22% with >T2 | | Mean Operative duration, min | 130
| | Mean EBL, mL | 50
| | Conversion rate, % | 0.6
| | % blood transfusion | 0
| | No. complications during RALP | 2
| | Mean haematocrit change, % | 3.1
| | % of patients requiring no narcotics | 85
| | Mean catheter duration, days | 6.9
| | % discharged home on day 1 | 97
| | Complete continence, %, at 3 months | 89
| | Complete continence, %, at 6 months | 95
| | % undetectable PSA level at 9.7month | 95
Zorn, 2007 ^69^ | Robotic assisted laparoscopic RP with selective use of interfascial nerve preservation | Operative time (min) | 282 (143–540)
300 consecutive cases of robotic-assisted laparoscopic radical prostatectomy with selective use of interfascial nerve preservation, all with T1–2 | | Estimated blood loss (ml) | 273 (25–1500)
| | Transfused (%) | 5 (1.7)
| | Hospital stay (days) | 1.4 (1–6)
| | Length of foley catheter | 5.9 (4–26)
| | Myocardial infarction | 0.6
| | Thromboembolic event | 0.6
| | Hemorrhage | 1
| | Rectal injury
| | Ureteral injury
| | Lymphocele | 0.6
| | Anastamotic leak | 1.4
| | Bladder neck contracture | 1.4
| | Wound infection/hernia | 2
| | Femoral nerve palsy | 1.4
| | Positive surgical margins | 20.9
| | Intra-operative complication | 2.3
| | Subjective continence at 12 months | 90.20
| | Subjective potency at 12 months | 80.4
| | Pathologic-T3 Positive surgical margins with ipsilateral interfascial nerve preservation | 73
| | Pathologic-T3 Positive surgical margins without ipsilateral interfascial nerve preservation | 33
Mikhail, 2006 ^70^ | Robotic assisted laparoscopic RP | Operative time | 200–520
nonrandomized prospective trial of initial 100 patients who underwent robotic-assisted laparoscopic radical prostatectomy, all with T1–2 | | Estimated blood loss (mL) | 25–1500
Rand 36-item health survey | | Length of hospitalization (days) | 1–6
| | Length of foley catheterization | 4–26
| | Positive margin rate | 16
| | Postoperative bleed | 1
| | Postoperative hematuria | 1
| | Bladder neck contracture | 2
| | Anastomotic leak | 3
| | Lymphocele | 2
| | Wound infection | 2
| | Pulmonary embolus | 1
| | Transient mild CHF | 1
| | Wound dehiscence (after altercation) | 1
| | Hand numbness | 1
| | Postoperative ileus | 1
| | Incisional hernia | 1
| | Total complications | 13
| | Subjective continence at 12 months | 89
| | Subjective potency, unilateral at 12 months | 68
| | Subjective potency, bilateral at 12 months | 79
| | Subjective potency, overall at 12 months | 75
| | Urinary function at 12 months | 74.8 ± 24.9 | | NS compared to baseline
| | Urinary bother at 12 months | 82.7 ± 27.3 | | NS compared to baseline
| | Sexual function, unilateral at 12 months | 52.9 ± 290 | | NS compared to baseline
| | Sexual function, bilateral at 12 months | 60.1 ± 23.6 | | NS compared to baseline
| | Sexual function, overall at 12 months | 57.3 ± 25.8 | | NS compared to baseline
Tseng, 2006 ^71^ | Robotic assisted laparoscopic RP | Urinary, function at 9.5 months | 80.8 ± 19.6
Case series of 90 patients undergoing robot-assisted laparoscopic prostatectomy, 8.9% with >T2 median followup 9.5 months | | Urinary, bother at 9.5 months | 78.6 ± 21.2
Expanded Prostate Cancer Index Composite questionnaire | | Urinary, incontinence at 9.5 months | 68.8 ± 31.9
| | Urinary, Irritative/obstructive at 9.5 months | 87.0 ± 13.6
| | Urinary, summary score at 9.5 months | 79.5 ± 19.6
| | Sexual, function at 9.5 months | 20.5 ± 17.2
| | Sexual, bother at 9.5 months r | 32.2 ± 27.7
| | Sexual, summary score at 9.5 months | 24.1 ± 19.1
| | Bowel, function at 9.5 months | 94.5 ± 7.1
| | Bowel, bother at 9.5 months | 94.6 ± 10.0
| | Bowel, summary score at 9.5 months | 94.5 ± 8.0
| | Hormonal, function at 9.5 months | 86.5 ± 12.5
| | Hormonal, bother at 9.5 months | 89.9 ± 12.0
| | Hormonal, summary score at 9.5 months | 88.4 ± 11.7
| | SF-12 component score, physical at 9.5 months | 50.5 ± 10.1
| | SF-12 component score, mental at 9.5 months | 53.0 ± 9.1
| | Recover to baseline urinary summary score at 12 months | 76.8
| | Recover to baseline sexual summary score at 12 months | 19.2

Bold - significant at 95% confidence level difference

Table C16 Comparison of task performance of AESOP (N=10) and EndoAssist (N=10) during operative steps of laparoscopic radical prostatectomy

Outcomes | AESOP Mean ± STD | EndoAssist Mean ± STD | Difference (95% CI) | P Value
Robot setup and assembly to laparoscope | 2 ± 0.8 | 5.3 ± 2.4 | -1.85 (-2.91; -0.78) | 0.001
Identification and dissection of vas deferens and seminal vesicles | 33.3 ± 13.4 | 22.7 ± 7 | 0.99 (0.06; 1.93) | 0.04
Development of space between Denonvilliers' fascia and rectum | 9.9 ±2.73 | 7.8 ± 2.6 | 0.79 (-0.13; 1.70) | 0.09
Development of prevesical space of Retzius | 8.7 ± 3.8 | 8.8 ±3.6 | -0.03 (-0.90; 0.85) | 0.95
Dissection of prostatic apex | 16.7 ± 10.3 | 11.4 ± 2.3 | 0.71 (-0.20; 1.62) | 0.13
Ligation of deep dorsal vein | 5.9 ± 1.8 | 5.8 ± 1.9 | 0.05 (-0.82; 0.93) | 0.91
Development of lateral neurovascular bundle groove | 18.7 ± 3.5 | 14.9 ± 7 | 0.69 (-0.22; 1.59) | 0.21
Bladder neck transection | 13.2 0 ±3.6 | 12 ± 3.3 | 0.35 (-0.54; 1.23) | 0.45
Antegrade preservation of neurovascular bundles | 24 0±7.5 | 23.1 ± 8.7 | 0.11 (-0.77; 0.99) | 0.81
Apical transection of prostate | 13.1 0 ±5 | 12.7 ± 6.2 | 0.07 (-0.81; 0.95) | 0.88
Urethrovesical anastomosis | 48.9 ± 12.8 | 40.3 ± 13 | 0.67 (-0.24; 1.57) | 0.15
Pelvic lymph node dissection | 11.6 ± 5.6 | 11 ± 3.4 | 0.13 (-0.75; 1.01) | 0.78
Specimen procurement and trocar site closure | 20.9 ± 7.6 | 19.5 ± 5.4 | 0.21 (-0.67; 1.09) | 0.64

AESOP = Automated Endoscope System for Optimal Positioning

Table C17 Clinical outcomes after IMRT in patients with localized prostate cancer

Author, Design | Outcomes | Rate Active, % | Rate Control, %
Kupelian, 2002 ^72^ | Freedom of biochemical relapse: 3 consecutive rising PSA after reaching a nadir | 91 | 88
Case series of 166 patients treated with IMRT 70 Gy in 28 fractions and 116 with 3D-CRT 78 Gy in 39 fractions % of >T2: 7% | Freedom of biochemical relapse: reaching and maintaining PSA of ≤0.5 ng/ml | 84 | 70
Followup: 25–32 months
Kupelian, 2005 ^73^ | Freedom of biochemical relapse: ASTRO definition (the first documented rise in PSA) | 85 | 78
Case series of 100 patients treated with IMRT 70.0 Gy at 2.5 Gy per fraction and 310 with 3D-CRT 78 Gy at 2 Gy per fraction % of >T2: 62% | Freedom of biochemical relapse: nadir PSA >2 ng/ml | 88 | 93
Followup: 66 months
Zelefsky, 2006 ^74^ | Freedom of biochemical relapse: absolute nadir plus 2 ng/ml dated at the call). | 85
Case series of 561 patients treated with IMRT 81.0 Gy % of >T2: 6% | Freedom of biochemical relapse in low risk patients | 89
Followup: 84 months | Distant metastases | 3
| Distant metastases in low risk patients | 1
| Cause specific survival in low risk | 100
De Meerleer, 2007 ^75^ | Overall survival at 5 years | 96
Case-series of 133 patients treated with IMRT 76-74 Gy % of >T2: 33% | Biochemical relapse-free survival as three consecutive PSA rises at 3 years | 88
Followup: 36 months | At 5 years | 83
| 5 years biochemical relapse-free survival for patients:
| low-risk | 100
| intermediate-risk | 94
| high-risk group | 74
| 5 years clinical relapse-free survival | 85
| 5 years clinical relapse-free survival In high-risk group, AD-naive patients | 44
| Hazard ratio of biochemical relapse free survival in high risk | 6.21 (0.96; 40.07)
| Hazard ratio of biochemical relapse
| Total Gleason score | 1.07 (0.75; 1.53)
| Pretreatment PSA | 1.02 (0.99; 1.04)
| Risk group | 3.07 (0.92; 10.3)
| Prescription dose | 0.34 (0.11; 0.98)
| Use of AD | 0.28 (0.10; 0.79)
| Segment outline weight adapting tool | 0.41 (0.13; 1.36)

Bold - significant at 95% confidence level difference

Table C18 Acute toxicity outcomes after intensity modulated radiotherapy for prostate cancer

Author, Design | Acute Toxicity Outcomes | Rate in Active Group, % | Rate in Control Group, %
Zelefsky, 2006 ^74^ | Grade 2 rectal bleeding | 1.6
Case series of 561 patients treated with IMRT 81.0 Gy % of >T2: 6%
Followup: 84 months | Grade 3 rectal toxicity | 0.1
D'Amico, 2006 ^76^
Phase II clinical trial
100 patients treated with IMRT 75.6Gy+flutamide 250 mg 3 times/day % of >T2: 8%
Followup: 12 months | Rectal bleeding | 10
Zelefsky 2002 ^77^ | Acute genitourinary toxicity Grade 1 | 37 | 46
Case series of 698 patients treated with IMRT 81.0 Gy and 74 with IMRT 86.4 Gy % of >T2: 28% | Acute genitourinary toxicity Grade 2 | 28 | 31
Followup: 29 months | Acute genitourinary toxicity Grade 3 | 0.5 | 0

Table C19 Late toxicity outcomes after intensity modulated radiotherapy for prostate cancer

Author, Design | Chronic Toxicity Outcomes | Rate Active, % | Rate Control, %
Kupelian, 2002 ^72^ | Grade 2–3 late rectal toxicity | 5 | 12
Case series of 166 patients treated with IMRT 70 Gy in 28 fractions and 116 patients treated with 3D-CRT 78 Gy in 39 fractions. % of >T2: 7% | Actuarial Grade 3 late rectal toxicity | 2 | 8
Followup: 25–32 months
Kupelian, 2005 ^73^ | Actuarial Grade2 and 3 late rectal toxicity | 11
Case series of 100 patients treated with IMRT 70.0 Gy at 2.5 Gy per fraction and 310 patients treated with 3D-CRT 78 Gy at 2 Gy per fraction % of >T2: 62% | Actuarial Grade 3 late urinary toxicity | 1
Followup: 66 months
Zelefsky 2002 ^77^ | Late Gastrointestinal toxicity grade 2 | 1.5
Case series of 698 patients treated with IMRT 81.0 Gy and 74 with IMRT 86.4 Gy % of >T2: 28% | Late Gastrointestinal toxicity grade 3 | 0.5
Followup: 29 months
Kupelian, 2002 ^72^ | Late urinary toxicity | 2.4 | 1.7
Case series of 166 patients treated with IMRT 70 Gy in 28 fractions and 116 patients treated with 3D-CRT 78 Gy in 39 fractions. % of >T2: 7%
Followup: 25–32 months
Kupelian, 2005 ^73^ | Actuarial Grade 2 and 3 late urinary toxicity | 8
Case series of 100 patients treated with IMRT 70.0 Gy at 2.5 Gy per fraction and 310 patients treated with 3D-CRT 78 Gy at 2 Gy per fraction % of >T2: 62%
Followup: 6 months
Zelefsky 2002 ^77^ | Late Genitourinary toxicity grade 1 | 22 | 24
Case series of 698 patients treated with IMRT 81.0 Gy and 74 with IMRT 86.4 Gy % of >T2: 28% | Late Genitourinary toxicity grade 2 | 9 | 12
Followup: 29 months | Late Genitourinary toxicity grade 3 | 0.5 | 0
Zelefsky 2006 ^74^ | Late grade 2 urinary toxicities | 9
Case series of 561 patients treated with IMRT 81.0 Gy % of >T2: 6% | Late grade 3 urinary toxicities | 3
Followup: 84 months | Erectile dysfunction | 49
De Meerleer, 2007 ^75^ | Late gastrointestinal morbidity grade 1 | 47
Case-series of 133 patients treated with IMRT 76-74 Gy % of >T2: 33% | Late gastrointestinal morbidity grade 2 | 17
Followup: 36 months | Late gastrointestinal morbidity grade 3 | 1
| Late genitourinary morbidity grade 1 | 43
| Late genitourinary morbidity grade 2 | 19
| Late genitourinary morbidity grade 3 | 3

Table C20 Patient outcomes after high-intensity focused ultrasound therapy for localized prostate cancer

Author, Year | Gelet, 2000 ^78^ | Gelet, 2001 ^79^ | Thuroff, 2003 ^80^ | Chaussy, 2003 ^81^ | Chaussy, 2003 ^81^ | Blana, 2004 ^82^ | Uchida, 2005 ^83^ | Blana, 2006 ^84^ | Uchida/Illig, 2006 ^85^ | Uchida/Illig, 2006 ^85^ | Uchida/Ohkusa, 2006 ^86^ | Poissonnier,2007 ^87^
Design | CS | CT | CT | CS | CS (HIFU + TURP) | CS | CT | | CS (AS before HIFU) | CS | CS | CS
Followup, months | 17.6 | 19 | 13.6 | 18.7 | 10.9 | 22.5 | 14 | 13 | 6 | 6 | 23.3 | 12–121
Number of patients | 82 | 102 | 402 | 96 | 175 | 146 | 72 | 223 | 154 | 96 | 63 | 227
Mean age | 71 | 70.8 | 69.3 | 65.8 | 68.4 | 66.9 | 72 | 68.2 | 67.9 | 69.2 | 70.5 | 68.8
% with T1–2 | 100 | 100 | 100 | 100 | 100 | 100 | 100 | | 100 | 100 | 100 | 100
Mean PSA | 8.11 | 8.38 | 10.9 | 8.6 | 8 | 7.6 | 8.1 | 11.3 | 10.5 | 8.9 | 11.2 | 6.99
% Gleason ≥7 | | 46 | 9.3 | 30 | 25.7 | | 8 | | | | 6 | 33
| | | (with 8–10) | | | | (with 8–10) | | | | (with 8–10)
Prostate volume, cm3 | 34.9 | 33.3 | 28 | 21.7 | 20.5 | 23 | 22.1 | 23.5 | 22 | 25.7 | 28.5 | 23.9
HIFU device | Ablatherm | Ablatherm | Ablatherm | Ablatherm | Ablatherm | Ablatherm | Sonablate | Ablatherm | Sonablate | Sonablate | Sonablate | Ablatherm
HIFU treatments | 1.92 | 1.7 | 1.4 | 1.25 | 1.04 | 1.17 | 1.2 | | | | | 1.4
PSA nadir | | | 0.6 | 0.48 | 0.48 | 0.07 | | | | | 1.38 | 0.33
Progression free survival,* % | 68–83 | 66 | | 84.2 | 80 | 87 | 76 | | | | 75 | 66
| | | | | | | | | | | | Initial PSA
| | | | | | | | | | | | PSA PSA
| | | | | | | | | | | | <4 – 90%
| | | | | | | | | | | | 4.1–10–57%
| | | | | | | | | | | | 10.1–15–61%
Biopsy, % negative | 78 | 75 | 87.2 | 87.7 | 81.6 | 93.4 | 68 | 22 needed second HIFU | 69 | 66 | 87 | nadir
| | | | | | | | | | | | PSA<0.5–89%
| | | | | | | | | | | | 0.51–1–76%
| | | | | | | | | | | | PSA >1.1 68%
Adverse events
Mild to moderate incontinence | 15.8 | 18.6 | 13.1 | 15.4` | 6.9 | 10.2 | 1.4 | 7.6 | | | 2 | 12
Severe incontinence | 4.8 | 4 | 1.5 | 0 | 0 | 0 | 0 | 0 | | | 0 | 1
Impotence | 23 | 24.5 | 8.7 | 40 | 31.8 | 52.7 | 39 | 49.8 | | | 23.5 | No erection-31%
Rectourethral fistula | 1.2 | 0.98 | 1.2 | | | 0.7 | 1.4 | 0 | | | 2
Urethral stenosis | 20.7 | 16.7 | 3.6 | 27.1 | 8 | 11.7 | 18 | 19.7 | | | 24 | 12
Length of stay | | | | | | | 5
Quality of life (IPSS) | | | | 2.36 | 1.86 | No change | No change | No change | | | | >16–31%
| | | | | | | | | | | | 7–15–38%

Author, Year | Definition of biochemical failure
Gelet, 2000 ^78^ | 3 successive increases of PSA with PSA velocity >0.75ng/ml/year
Gelet, 2001 ^79^ | 3 successive increases of PSA with PSA velocity >0.75ng/ml/year
Chaussy, 2003 ^81^ | Constant PSA level (ASTRO)
Chaussy, 2003 ^81^ | Constant PSA level (ASTRO)
Blana, 2004 ^82^ | Constant PSA <1ng/ml
Uchida, 2005 ^83^ | 3 consecutive increases in PSA >1ng/ml
Blana, 2006 ^84^ | increase of PSA >0.2 ng/ml after the last control
Uchida, 2006 ^86^ | 3 consecutive increases in PSA >1.38ng/ml
Poissonnier, 2007 ^87^ | Any positive biopsy or a PSA >1 ng/ml with three consecutive rises

* progression free survival definitions:

CT - clinical trial, CS - case series, HIFU - High-intensity focused ultrasound, TURP - transurethral resection of the prostate, AS - androgen suppression therapy, IPSS - International prostate symptom score

Table C21 Proton radiation for localized prostate cancer

Author | Yonemoto, 1997 ^88^ Phase I/II Clinical Trial | Slater, 1999 ^89^ Case Series | Slater, 2004 ^90^ Case Series | Rossi, 2004 ^91^ Case Series | Nihei, 2005 ^92^ Phase I/II Clinical Trial
Treatment | 45 Gy photon-beam irradiation to the pelvis and 30 CGE to the prostate with 250-MeV protons, total dose 75 CGE in 40 fractions | Conformal radiation doses of 74 to 75 CGE with protons alone or combined with photons in 40 fractions | Conformal proton boost of 30 CGE with 225–250 MeV in 15 fractions to the prostate and seminal vesicles, followed by 45 Gy of photon radiation | Conformal proton radiation with 74–75 CGE followed by 45 Gy of 3D pelvic photon radiation | 50 Gy/25 fractions photon irradiation to the prostate and the bilateral seminal vesicles followed by proton boost therapy of 26 GyE/13 fractions to the prostate alone. Phase II clinical trial
Follow up, months | 20.2 | 43 | 63 | 62 | 30
No. of patients | 106 | 319 | 1,255 | 1,000 | 30
% with T>2 | 18 | 0 | 4 | 0 | 23
% Gleason >7 | 12 | 6 | 7 | 7 | 10
Definitions of outcomes | Disease free survival; negative DRE and normalized PSA (<4.0 rig/ml). Local failure - increasing size of the tumor or nodule, or a continued abnormal prostate with rising PSA. Distant failure; any evidence of metastasis outside the primary site and regional lymph nodes. | Disease free survival; no symptoms Negative DRE and radionuclide scans. Biochemical disease-free survival; 3 consecutive PSA rises >10% or initiation of androgen therapy (American College of Radiology) | Biochemical disease-free survival; 3 consecutive rises in PSA, date of failure-midway between the nadir and first rise (ASTRO) | Biochemical disease-free survival; 3 consecutive rises in PSA, date of failure - midway between the nadir and first rise (ASTRO) | Biochemical disease-free survival; 3 consecutive rises in PSA, date of failure midway between the nadir and first rise (ASTRO)
Total survival | 96 | 100 | 100 | 100 | 100
Disease-free survival, % | 86 | 97
Biochemical disease-free survival | | 88 | 73 | In patients <60 years -75 | 77
| | | | In patients >60 years -74
Local survival, % negative biopsy | 97.2
Distant failure | 7.5 | 2.5
% complications
Urinary, Grade 1 | 0 | | | | 13.3
Urinary, Grade 2 | 3.8 | 5 | | | 20
Urinary, Grade 3 | 0 | 0 | 1 | | 0
Urinary, Grade 4 | 0 | 0 | 0 | | 0
GI, Grade 1 | 4.8 | | | | 60
GI, Grade 2 | 3.8 | 6 | | | 20
GI, Grade 3 | 0 | 0 | 1 | | 0
GI, Grade 4 | 0 | 0 | 0 | | 0
Hematuria | 3.8
Rectal bleeding | 8.7 | | 0.2

CGE = cobalt-gray equivalent

Table C22 PCOS: Reason for condition specific bother for responders reporting bother on urinary, bowel, and sexual questions* (Potosky, 2004) ^93^

Domain | RP† (n = 901) | EBR† (n = 286) | Odds Ratio (95% CI)
Urinary bother‡
Too far from the bathroom | 22.1 (24.0) | 30.1 (24.9) | 1.32 (0.83; 2.13)
Embarrassment about going too often | 14.7 (15.2) | 13.3 (11.9) | 1.32 (0.83; 2.13)
Frequent urination | 30.6 (31.6) | 34.3 (31.3) | 1.01 (0.68; 1.51)
Urination at night | 41.6 (43.2) | 51.9 (47.2) | 0.84 (0.58; 1.22)
Urgency in urination | 32.7 (34.2) | 44.6 (39.9) | 0.84 (0.58; 1.22)
Slow or difficult urination | 32.7 (34.2) | 44.6 (39.9) | 0.78 (0.53; 1.12)
Bowel bother‡
Diarrhea | 11.2 (11.5) | 16.6 (15.3) | 0.70 (0.4; 1.22)
Tenderness during bowel movements | 6.8 (7.3) | 9.7 (8.4) | 0.85 (0.46; 1.56)
Bleeding with bowel movements | 7.5 (8.0) | 14.7 (13.0) | 0.58 (0.31; 1.06)
Passing mucus from rectum | 5.1 (5.4) | 14.4 (13.1) | 0.36 (0.20; 0.66)
Sexual bother§
Lack of sexual interest | 42.7 (41.7) | 40.6 (43.8) | 0.92 (0.63; 1.32)
Lack of sexual enjoyment | 53.1 (52.2) | 45.5 (48.9) | 1.14 (0.80; 1.64)
Inability to satisfy spouse or partner | 57.5 (56.4) | 46.1 (50.3) | 1.28 (0.88; 1.86)
Orgasm difficult | 47.8 (47.2) | 43.4 (46.0) | 1.05 (0.73; 1.51)
Orgasm satisfying | 43.4 (42.4) | 38.2 (41.4) | 1.04 (0.72; 1.51)
Erectile difficulties | 63.4 (62.0) | 56.5 (61.2) | 1.03 (0.71; 1.49)

* EBR is the referent group. Adjusted percentages are from separate logistic regression models, each adjusted for treatment propensity score, age, baseline function, race, comorbidity, and educational level.

† RP = radical prostatectomy, EBR = external beam radiation. Values in columns are unadjusted percentages, in parentheses, adjusted percentages.

‡ Percentages and OR for bother are somewhat/a lot versus not at all.

§ For bother items, percentages refer to patients reporting bother of a lot versus somewhat/not at all.

Table C23 Adjusted percentage distributions for satisfaction by characteristics at 24 months* (Hoffman, 2003) ^94^

Variable | Percent Satisfied (95% CI) | Wald Chi-Square Test p Value
Treatment | | <0.01
No treatment | 50.5 (42.5; 58.8)
AD | 66.3 (58.0; 74.6)
Radiation | 69.4 (64.6; 74.2)
Free of PC | | <0.01
No | 49.1 (42.0; 56.3)
Don't know | 53.7 (48.7; 58.7)
Yes | 66.4 (63.2; 69.6)
Bowel urgency | | 0.03
Almost every day | 38.4 (22.0; 54.8)
Some days | 62.1 (56.6; 67.7)
Rarely or not at all | 60.5 (57.7; 63.3)
Urinary leakage | | <0.02
At least once a day | 53.7 (48.6; 58.8)
Once a week or less | 59.7 (55.0; 64.4)
Not at all | 64.2 (60.8; 67.7)
Erectile dysfunction | | 0.04
Cannot get any erections | 58.1 (54.6; 61.5)
Some or a lot of difficulty | 61.7 (57.2; 66.1)
No or little difficulty | 65.9 (60.8; 71.1)
General health (24 month followup) | | <0.01
Excellent | 71.3 (65.6; 77.0)
Very good | 65.2 (61.3; 69.2)
Good | 54.8 (50.5; 59.2)
Fair | 52.0 (45.3; 58.6)
Cancer or treatment limits activities | | <0.01
A lot or some | 41.7 (33.2; 50.2)
Only a little | 52.9 (47.1; 58.8)
Not at all | 65.5 (62.4; 68.5)
Cancer treatment affects relationships with spouse/friends | | <0.01
A lot or some | 43.9 (37.8; 50.0)
A little | 54.6 (49.5; 59.6)
Not at all | 68.1 (64.8; 71.3)

* Weighted to reflect all eligible PC patients in the study area

Table C24 Association of bowel, urinary, and sexual function with patients' perception of the problem and satisfaction at 24 months post diagnosis*

Function at 24 Months | No Problem % Satisfied | Small/Very Small % Satisfied | Moderate/Big % Satisfied
Urgent bowel movements
Rarely or not at all | 64.3 | 57.7 | 35.2
Some days | 65.5 | 55.1 | 29.7
Almost everyday | 45.8 | 26.1 | 19.2
Leak or drip urine
Not at all | 69.9 | 59.9 | —
Once a week or less | 67.6 | 54.0 | 47.0
Daily or more often | 73.3 | 48.8 | 31.6
Difficulty keeping an erection
None or little | 84.3 | 73.6 | 42.8
Some or a lot | 77.3 | 74.4 | 52.1
No erections | 62.8 | 63.5 | 48.2

* Weighted to reflect all eligible PC patients in the study area

Table C25 QOL studies of treatments for localized prostate cancer in nonRCTs

Study | Study Type/Patients/Interventions | Quality of Life Outcomes
Lee, 2001 ^95^ | Prospective cohort study | HRQOL scores
| N = 98 T1/T2 patients enrolled | Measure/Treatment | Mean (SD) - Baseline | Mean (SD) - 1 Month | Mean (SD) - 12 Months | p-Value Overall Within Treatment Group | p-Value B vs. 12 Months
| Interstitial brachytherapy (IB): n = 44 | FACT-P
| [I-125, 144 Gy; 11 patients received androgen deprivation therapy before IB, to reduce size of prostate gland] | IB | 138.4 (17.0) | 120.5 (21.7) | 138.5 (14.2) | 0.0001<0.01 | 0.88
| Electron beam radiotherapy (EBRT): n = 23 | EBRT | 137.1 (12.1) | 129.5 (21.0) | 136.9 (15.6) | 0.08 | 0.94
| [median dose = 70.2 Gy; 2 patients received androgen deprivation therapy before EBRT] | RP | 138.3 (14.7) | 117.7 (18.3) | 140.4 (14.9) | <0.01 | 0.39
| Radical prostatectomy (RP): n = 23 | FACT-G
| [3 patients received androgen deprivation therapy before RP] | IB | 100.7 (11.8) | 92.5 (14.7) | 102.2 (9.1) | <0.01 | 0.29
| [underlined: Age [median (range)]] | EBRT | 99.9 (7.9) | 96.1 (12.5) | 101.0 (10.1) | 0.17 | 0.56
| IB = 67.1 (49 – 79) | RP | 99.8 (9.6) | 88.9 (13.2) | 101.9 (11.3) | <0.01 | 0.28
| EBRT = 68.8 (51 – 79) | PWB
| RP = 61.0 (42 – 68) | IB | 25.9 (2.8) | 21.6 (4.7) | 25.3 (2.6) | <0.01 | 0.23
| [underlined: Response rate] | EBRT | 25.2 (2.2) | 22.6 (4.7) | 25.1 (4.1) | <0.01 | 0.91
| All patients = 91% (90 patients) | RP | 26.3 (2.3) | 20.9 (5.0) | 26.3 (2.5) | <0.01 | 0.92
| | FWB
| | IB | 23.3 (4.4) | 18.9 (6.4) | 24.1 (3.7) | <0.01 | 0.18
| | EBRT | 22.9 (3.2) | 21.7 (5.0) | 23.2 (4.8) | 0.25 | 0.65
| | RP | 23.6 (4.3) | 16.5 (5.1) | 23.3 (4.1) | <0.01 | 0.72
| | IPSS
| | IB | 8.3 (6.0) | 20.8 (7.7) | 10.4 (7.3) | <0.01 | 0.10
| | EBRT | 11.9 (6.4) | 13.8 (7.5) | 8.5 (5.4) | <0.01 | 0.01
| | RP | 12.5 (9.3) | 17.2 (10.3) | 5.5 (3.7) | <0.01 | <0.01
| | FACT-P = Functional Assessment of Cancer Therapy - Prostate; FACT-G = FACT - general; PWB = physical well-being; FWB = functional well-being; IPSS = International Prostate Symptom Score
Schapira, 2001 ^96^ | Prospective observational study | UCLA-PCI scores
| N = 122 T1/T2 patients | Domain/treatment | Mean Score - Baseline | | Mean Score - 3 Months | | Mean Score - 12 Months
| Radical prostatectomy (RP): n = 42 | Urinary bother
| [during the course of the study, 6 patients received hormonal therapy and 2 had radiation therapy] | RP | 82 | | 57 | | 67
| Radiation therapy (RT): n = 51 | RT | 80 | | 77 | | 81
| [during the course of the study, 12 patients received hormonal therapy] | EM | 86 | | 86 | | 84
| Expectant management (EM): n = 29 | p-values (across treatment groups) | NS | | NS | | NS
| [during the course of the study, 7 patients received hormonal therapy and 4 had radiation therapy] | Sexual bother
| [underlined: Age [median (range)]] | RP | 64 | | 28 | | 29
| RP = 64 (58–68) | RT | 55 | | 55 | | 60
| RT = 73 (68–75) | EM | 56 | | 67 | | 62
| EM = 73 (70–78) | p-values (across treatment groups) | NS | | 0.02* | | NS
| | Bowel bother
| | RP | 91 | | 90 | | 86
| | RT | 86 | | 76 | | 77
| | EM | 86 | | 85 | | 81
| | p-values (across treatment groups) | NS | | 0.05** | | NS
| | * RP vs. RT and RP vs. EM
| | ** RP vs. RT
| | Incontinence and impotence rates (based on UCLA-PCI responses)
| | Side-effect/treatment | Baseline - n (%) | | 3 months - n (%) | | 12 months - n (%)
| | Incontinence
| | RP | 1 (2) | | 31 (76) | | 16 (44)
| | RT | 2 (4) | | 4 (9) | | 3 (8)
| | EM | 0 (0) | | 0 (0) | | 1 (4)
| | Impotence
| | RP | 14 (35) | | 42 (100) | | 33 (89)
| | RT | 30 (61) | | 33 (77) | | 30 (75)
| | EM | 16 (55) | | 17 (63) | | 17 (68)
| | SF-36 scores
| | Domain/treatment | Mean score - baseline | | Mean score - 3 months | | Mean score - 12 months
| | General health perceptions
| | RP | 74 | | 71 | | 71
| | RT | 60 | | 62 | | 59
| | EM | 64 | | 67 | | 68
| | p-values (across treatment groups) | NS | | NS | | NS
Soderdahl, 2005 ^97^ | Prospective longitudinal comparative study | UCLA-PCI scores
| N = 452 T1c/T2 patients recruited [334 responded to baseline questionnaire; 250 completed all surveys] | Domain | Mean score - baseline | Mean 1 month | Mean 6 months | Mean 12 months * | P-values
| Open radical prostatectomy (ORP): n = 86 | Sexual bother
| Laparoscopic radical prostatectomy (LRP): n = 93 | ORP | 68 | 19 | 22 | 26
| Brachytherapy (Brachy): n = 71 | LRP | 61 | 23 | 25 | 26
| [Pd-103, 115 Gy mean dose] | Brachy | 57 | 37 | 45 | 44 | P <0.001 [brachy were significantly less bothered by sexual problems than surgery]
| [underlined: Age [median]]: | Urine bother
| ORP = 59 | ORP | 87 | 31 | 65 | 74
| LRP = 61 | LRP | 83 | 24 | 65 | 69
| Brachy = 68 | Brachy | 81 | 44 | 70 | 78 | P <0.001 [RP more bother than brachy]
| | Bowel bother
| | ORP | 89 | 76 | 90 | 87
| | LRP | 85 | 68 | 85 | 87
| | Brachy | 84 | 63 | 76 | 83 | P = 0.07 [brachy had marginally lower scores (more bother) than surgery]
| | Scale range = 0–100
| | [underlined: SF-36 scores]
| | “After each treatment, there was an initial drop-off of general domain scores, which returned to baseline over time.”
| | Profiles of changes were not different between groups for these scales
| | Physical functioning (P = 0.26); Limitations secondary to emotional problems (P = 0.57)
| | Vitality (P = 0.46); Mental health (P = 0.35); Bodily pain (P = 0.46); General health (P = 0.92); Health transition (P = 0.55).
| | Scale change profile was marginally significantly different between groups for:
| | Limitations attributable to physical problems (P = 0.052)
| | Social functioning (P = 0.06)
| | “At 12 months, there were no significant differences among groups.”
| | Potency (sexual function)
| | Treatment | Mean Score - Baseline | Mean Score - 1 Month | Mean Score - 6 Months | Mean Score - 12 Months | P-Values
| | ORP
| | Bilateral NS | 65 | 9 | 20 | 30
| | Unilateral NS | 62 | 8 | 20 | 29
| | Non NS | 56 | 15 | 20 | 26 | No statistical difference by ORP
| | LRP
| | Bilateral NS | 75 | 7 | 12 | 15
| | Unilateral | 75 | 7 | 13 | 20
| | Non NS | 53 | 6 | 12 | 19 | P <0.001 [baseline sexual function was worse in non-NS LRP]
Fulmer, 2001 ^98^ | Prospective cohort study | Voiding and sexual function scores
| N = 127 T1/T2 patients | Domain/Treatment | Baseline - Mean Score (SE) | 3 Months - Fold Change (95% CI)* | 6 Months - Fold Change (95% CI)* | 12 Months - Fold Change (95% CI)*
| Hormonobrachytherapy with external beam radiotherapy (HBTC): n = 40 [high-risk patients] | AUASS
| [received 40–45 Gy of EBRT followed by brachytherapy + antiandrogen + LHRH agonist] | RP | 7.17 (0.98) | - | - | -
| Hormonobrachytherapy (HBT): n = 45 [low-risk patients] | HBTC | 7.57 (1.06) | 1.66 (1.15; 2.40) | 1.55 (1.11; 2.17) | 1.36 (0.93; 1.98)
| [received brachytherapy + antiandrogen + flutamide] | HBT | 6.69 (0.93) | 1.40 (0.99; 1.98) | 1.38 (1.01; 1.87) | 1.32 (0.94; 1.88)
| Radical retropubic prostatectomy (RP): n = 42 | IAUA
| [underlined: Age [median]] | RP | 3.87 (0.42) | - | - | -
| HBTC = 68 | HBTC | 4.63 (0.61) | 1.26 (0.95; 1.66) | 1.26 (0.97; 1.63) | 1.27 (0.95; 1.68)
| HBT = 66 | HBT | 4.10 (0.48) | 1.02 (0.78; 1.32) | 1.04 (0.82; 1.33) | 1.10 (0.84; 1.43)
| RP = 59 | OAUA
| [underlined: Median followup (time since surgery)] | RP | 3.32 (0.62) | - | - | -
| 8.2 months (range 0.2 – 37.0 months) | HBTC | 3.25 (0.70) | 2.48 (1.63; 3.77) | 2.18 (1.50; 3.16) | 1.68 (1.10; 2.57)
| | HBT | 2.64 (0.55) | 2.28 (1.55; 3.38) | 2.17 (1.53; 3.06) | 1.95 (1.31; 2.89)
| | VB
| | RP | 3.58 (0.55) | - | - | -
| | HBTC | 4.03 (0.58) | 0.76 (0.47; 1.22) | 0.85 (0.56 – 1.30) | 1.08 (0.67; 1.73)
| | HBT | 3.30 (0.48) | 0.71 (0.46; 1.09) | 0.78 (0.53 – 1.16) | 0.96 (0.62; 1.49)
| | SF
| | RP | 4.24 (0.73) | - | - | -
| | HBTC (n = 36) | 9.75 (1.21) | - | - | 0.70 (0.52; 0.93)
| | HBT (n = 43) | 7.69 (0.96) | - | - | 0.54 (0.42; 0.69)
| | SFB
| | RP | 3.42 (0.60) | - | - | -
| | HBTC (n = 36) | 6.36 (0.76) | - | - | 0.76 (0.58; 0.99)
| | HBT (n = 43) | 4.90 (0.70) | - | - | 0.59 ( 0.47; 0.75)
| | AUASS = AUA symptom score; IAUA = AUA Irritative subscale; OAUA = AUA Obstructive subscale; VB = Voiding Bother; SF = Sexual function; SFB = Sexual Function Bother score
| | *Relative change or fold change of given BT group compared to RP (BT/RP). Numbers lower than one indicate lower scores in BT than in RP.
Galbraith, 2001 ^99^ | Longitudinal survey study | Health-related quality of life score
| N = 185 localized prostate cancer patients | Treatment | Baseline | 6 Months | | 18 Months
| Watchful waiting (WW): n = 30 | Watchful waiting | 60.4 | 58.1 | | 59.0
| Surgery (S): n = 59 | Surgery | 60.3 | 56.6 | | 57.0
| Conventional radiation (CR): n = 25 | Conventional radiation | 59.6 | 59.5 | | 57.2
| Proton beam therapy (PB): n = 24 | Mixed-beam radiation | 61.7 | 59.5 | | 60.5
| Mixed-beam radiation (MB): n = 47 | Proton-beam radiation | 60.7 | 59.0 | | 60.7
| [underlined: Age [mean]] | p value
| WW = 73 | Higher score = higher QOL (range = 0–100)
| S = 65 | Physical functioning
| CR = 71 | Treatment | Baseline | 6 Months | | 18 Months
| PB = 68 | Watchful waiting | 74 | 65 | | 75
| MB = 69 | Surgery | 80 | 78 | | 81
| | Conventional radiation | 79 | 71 | | 70
| | Mixed-beam radiation | 83 | 80 | | 78
| | Proton-beam radiation | 84 | 84 | | 78
| | p value | | <0.05 (PB vs. WW)
| | Higher score = higher functioning (range = 0–100)
| | General health
| | Treatment | Baseline | 6 Months | | 18 Months
| | Watchful waiting | 48 | 50 | | 54
| | Surgery | 57 | 61 | | 58
| | Conventional radiation | 58 | 59 | | 56
| | Mixed-beam radiation | 60 | 58 | | 59
| | Proton-beam radiation | 53 | 58 | | 60
| | p value | <0.001 (MB vs. WW) | <0.01 (S vs. WW)
| | Higher score = better health (range = 0–100)

Table C26 QOL studies of treatments for localized prostate cancer in RCTs

Study | Study Type/Patients/Interventions | Quality of Life Outcomes
Fransson, 2001 ^100^ | Randomized controlled trial | EORTC QLQ-C30 (+3) Questionnaire
| N = 166 T1/T2 patients enrolled [30 patients died by date of questionnaire submission; 11patients were excluded due to followup <6 months or progressed disease with progressive treatment before questionnaire] | Domain | EBRT Mean Scores | DT Mean Scores | p Value
| Radiation therapy (EBRT): n = 59 | Global health/QOL | 68 | 70
| Deferred therapy (DT): n = 49 | Scores were linearly transformed to a 0 to 100 scale according to EORTC recommendations
| [underlined: Age [mean (range)]] | Increasing score = higher level of functioning
| RT = 71.3 (49.1 – 83.0) | QUFW94 Questionnaire
| DT = 72.8 (58.9 – 81.9) | Variable | RT Mean Score (95% CI) | DT Mean Score (95% CI) | p Value
| [underlined: Median followup (from randomization date to time of questionnaire)] | General function
| RT = 40.6 months | Limitation to daily activity caused by prostate carcinoma | 1.8 (1.29; 2.39) | 0.7 (0.19; 1.26) | 0.001
| DT = 30.4 months [p = 0.055] | Urinary symptoms
| [underlined: Response rate] | Incontinence | 1.5 (0.55; 2.18) | 0.6 (0.13; 1.00) | 0.008
| RT = 90% | Limitation in daily activity caused by urinary problems | 1.1 (0.63; 1.62) | 0.9 (0.27; 1.47) | 0.06
| DT = 85% | Urinary problems in general | 1.8 (1.15; 2.42) | 1.2 (0.60; 1.86) | 0.227
| | Intestinal symptoms
| | Limitation in daily activity caused by intestinal problems | 1.3 (0.73; 1.85) | 0.3 (0.04; 0.48) | 0.001
| | Planning of daily activity caused by intestinal problems | 1.9 (1.19; 2.54) | 1.0 (0.22; 1.72) | 0.004
| | QUFW94 scores range from 0 (no problem/very good function) to 10 (many problems/very bad function)
Steineck, 2002 ^101^ | Randomized controlled trial: SPCG-4 | Sexual Dysfunction
| N = 376 T0/T1/T2 patients enrolled | Function - Outcome | RP [n / N Responding (%)] | WW [n / N Responding (%)] | Unadjusted Relative Risk (95% CI)
| [underlined: Age [mean (range)]]: | Desire
| RP = 64.1 (48.0 – 74.0) | Importance of sexual function - no or little importance | 79 / 159 (50) | 64 / 154 (42) | 1.2 (0.9; 1.5)
| WW = 64.8 (51.0 – 74.0) | Penile stiffness
| [underlined: Median followup (from randomization date to time of questionnaire)] | Erectile function - seldom or never sufficient for intercourse | 129 / 161 (80) | 71 / 158 (45) | 1.8 (1.5; 2.2)
| RP = 50.0 months | Distress from erectile dysfunction - moderate or great distress | 90 / 155 (58) | 65 / 152 (43) | 1.4 (1.0; 1.7)
| WW = 48.0 months | Distress from erectile dysfunction - great distress | 46 / 155 (30) | 26 / 152 (17) | 1.7 (1.1; 2.7)
| | Intercourse
| | Distress from decreased frequency - moderate or great distress | 94 / 160 (59) | 66 / 153 (43) | 1.4 (1.1; 1.7)
| | Orgasm
| | Distress from decreased frequency - moderate or great distress | 88 / 158 (56) | 65 / 152 (43) | 1.3 (1.0; 1.6)
| | Distress from compromised sexuality
| | Distress (if sexual function has declined) - moderate or great distress | 87 / 156 (56) | 62 / 154 (40) | 1.4 (1.1; 1.8)
| | For each question, some men did not respond. A number above unity indicates better function in the watchful waiting group.
| | Urinary Tract Dysfunction
| | Function - outcome | RP [n / N Responding (%)] | WW [n / N Responding (%)] | Unadjusted Relative Risk (95% CI)
| | Global features
| | Distress from obstructed voiding - moderate or great distress | 34 / 164 (21) | 34 / 157 (22) | 1.0 (0.6; 1.5)
| | Urinary leakage
| | Subjective estimation of the degree of leakage - moderate or severe leakage | 30 / 163 (18) | 3 / 152 (2) | 9.3 (2.9; 29.9)
| | Distress from urinary leakage - moderate or great distress | 47 / 164 (29) | 15 / 158 (9) | 3.0 (1.8; 5.2)
| | Regular dependence on some form of protective aid - yes | 71 / 165 (43) | 16 / 154 (10) | 4.1 (2.5; 6.8)
| | Regular dependence on diaper or urine bag - yes | 23 / 165 (14) | 1 / 154 (1) | 21.5 (2.9; 157.0)
| | Overall distress from all urinary symptoms - moderate or great distress | 44 / 163 (27) | 28 / 157 (18) | 1.5 (1.0; 2.3)
| | For each question, some men did not respond. A number above unity indicates better function in the watchful waiting group.
| | Psychological Symptoms
| | Function - outcome | RP [n / N Responding (%)] | WW [n / N Responding (%)] | Unadjusted Relative Risk (95% CI)
| | Physical function
| | Decreased general physical capacity - the lowest five of seven possible categories | 89 / 164 (54) | 89 / 157 (57) | 1.0 (0.8; 1.2)
| | Low or moderate physical well-being - the lowest five of seven possible categories | 68 / 164 (41) | 78 / 157 (50) | 0.8 (0.7; 1.1)
| | Psychological function
| | Worry (moderate or high) - the highest five of seven possible categories | 64 / 164 (39) | 71 / 157 (45) | 0.9 (0.7; 1.1)
| | Low or moderate psychological well-being - the lowest five of seven possible categories | 57 / 164 (35) | 57 / 158 (36) | 1.0 (0.7; 1.3)
| | Low or moderate subjective quality of life - the lowest five of seven possible categories | 64 / 159 (40) | 68 / 151 (45) | 0.9 (0.7; 1.2)
| | For each question, some men did not respond. CI denotes confidence interval.
| | Bowel Function
| | Function - Outcome | RP [n / N Responding (%)] | WW [n / N Responding (%)] | Unadjusted Relative Risk (95% CI)
| | Fecal leakage - once a week or more | 1 / 164 (1) | 9 / 157 (6) | -
| | Distress from fecal leakage - moderate to great | 3 / 164 (2) | 7 / 155 (5) | -
| | Distress from all bowel symptoms | 5 / 159 (3) | 10 / 156 (6) | -

Table C27 Quality (% of maximum possible) of studies that assessed the association between patient outcomes and provider volumes

Outcomes (Means ± Standard Deviation) | All Studies | Mortality | Morbidity | Urinary Complications | Incontinence | Length of Stay | Cost | Readmission | Positive Margins
Criteria to score quality of the studies
Quality, % of maximal | 65.2±10.8 | 68.3±5.9 | 73.3±11.4 | 75.0±14.6 | 64.9±0.2 | 66.7±16.7 | 54±11.8 | 69.3 | 69.5±0.7
Study question clearly focused and appropriate | 4.0±0.7 | 4.3±0.5 | 4.2±0.5 | 4.4±0.6 | 4.0±0.01 | 4.0±0.9 | 3.4±0.8 | 4 | 4
The objectives and primary hypothesis of the study clearly stated | 2.1±1.4 | 1.9±1.1 | 2.1±1.8 | 2.8±2.0 | 1±0.01 | 2.6±1.7 | 2.1±1.0 | 1 | 3.9±0.3
Description of the target population | 3.7±0.5 | 4.0±0.0 | 3.7±0.5 | 3.9±0.2 | 4±0.01 | 3.4±0.6 | 3.2±0.4 | 4 | 4
Description and clear definition of the exposure | 4.3±0.7 | 4.3±0.9 | 4.7±0.5 | 4.9±0.5 | 5±0.01 | 4.6±0.7 | 3.4±0.8 | 5 | 3.9±0.3
Description and clear definition of primary outcomes | 4.4±0.7 | 4.4±0.5 | 4.5±0.5 | 4.9±0.3 | 4.9±0.3 | 4.2±0.9 | 4.5±0.5 | 4 | 5±0.0
Description and clear definition of secondary outcomes | 3.8±1.6 | 4.4±0.9 | 3.7±0.9 | 4.0±1.0 | 3.1±0.3 | 4.0±0.9 | 3.7±0.8 | 4 | 0.3±1.3
Validation of the measurements of the exposure | 4.2±0.8 | 3.8±0.7 | 4.4±0.7 | 4.4±0.8 | 4.1±0.3 | 4.2±0.8 | 2.9±0.7 | 5 | 3.9±0.5
Validation of the measurements of the outcomes | 4.5±0.5 | 4.1±0.3 | 4.3±0.4 | 4.4±0.5 | 4±0.01 | 4.7±0.5 | 4±0.0 | 4 | 4.1±0.3
The process of the subjects selection | 3.4±0.6 | 3.3±0.5 | 3.4±0.6 | 3.4±0.6 | 3±0.01 | 3.3±0.6 | 2.9±0.7 | 4 | 3±0.0
The adequacy of the sampling (random selection or not) and selection bias | 2.9±0.8 | 2.3±0.5 | 2.6±0.9 | 2.9±1.0 | 2±0.01 | 2.8±0.8 | 3±0.0 | 2 | 2.9±0.3
Was the sample size justified | 2.0±0.1 | 2.0±0.0 | 2.0±0.2 | 1.9±0.2 | 2±0.01 | 2.0±0.2 | 1.7±0.5 | 2 | 2.0±0.0
Assessment of possible confounding factors | 3.2±0.9 | 3.6±0.5 | 3.9±0.5 | 3.8±0.7 | 4±0.01 | 2.9±1.3 | 1.1±1.6 | 4 | 4.0±0.0
Validity of the measurements of confounding factors | 4.0±1.3 | 4.2±0.4 | 4.4±0.8 | 4.3±1.0 | 4±0.01 | 3.8±1.9 | 1.3±2.0 | 4 | 5.0±0.0
Adjustment for confounding factors | 2.8±2.4 | 4.8±0.4 | 4.9±0.7 | 4.8±0.9 | 5±0.01 | 2.5±2.4 | 1.1±1.6 | 5 | 5.0±0.0
Reporting of the statistical analysis | 4.1±1.0 | 5±0.0 | 4.7±0.5 | 4.9±0.5 | 5±0.01 | 3.9±1.1 | 2.9±1.2 | 5 | 4.9±0.5
Precision of the reported estimates of the association | 3.7±1.5 | 2.4±1.9 | 2.4±1.3 | 2.2±2.0 | 0.4±1.3 | 3.5±0.7 | 3.7±0.8 | 2 | 5±0.0
Use of multivariate models to assess crude and adjusted estimation | 2.6±2.2 | 4.0±0.4 | 4.4±0.8 | 4.2±0.9 | 3.8±0.7 | 2.3±2.2 | 1.3±1.6 | 4 | 5±0.0
Justification for statistical methods used to test hypothesis | 3.2±2.1 | 4.8±0.4 | 4.9±0.7 | 4.8±0.9 | 5±0.01 | 3.1±1.9 | 1.1±1.6 | 5 | 5±0.0
Justification for subgroup analysis | 1.9±1.9 | 1.9±1.7 | 2.7±2.5 | 2.2±2.6 | | 2.8±1.8 | 2.2±1.4 | | 0.3±1.3
Assessment of the limitations of the study | 3.6±0.8 | 3.3±1.0 | 4.2±0.6 | 4.3±0.8 | 4±0.01 | 3.7±1.0 | 2.9±0.7 | 4 | 4±0.0
Results presentation | 3.9±0.8 | 3.8±0.7 | 4.0±0.9 | 4.3±0.8 | 3.8±0.7 | 3.8±0.9 | 3.2±0.4 | 5 | 4.9±0.3
Justification for the results of the study | 4.4±0.5 | 4.5±0.5 | 4.7±0.5 | 4.9±0.3 | 4.9±0.3 | 4.4±0.5 | 4±0.0 | 5 | 4.9±0.3
The appropriate conclusions of the study | 3.4±0.8 | 3.4±1.0 | 4.2±0.5 | 4.4±0.6 | 4±0.01 | 3.9±0.8 | 3.7±0.5 | 4 | 2.9±0.3
Justification for conclusions in relation to tested hypotheses | 3.7±0.9 | 3.8±1.3 | 4.6±0.6 | 4.8±0.5 | 4.9±0.3 | 4.0±0.9 | 3.7±0.5 | 5 | 2.9±0.3
Applicability of the studies findings | 3.5±0.7 | 3.0±0.9 | 3.7±0.5 | 3.4±0.5 | 3±0.01 | 3.5±0.5 | 3.2±0.4 | 4 | 4±0.0

Table C28 Quality of the studies (% of maximum possible) by sponsorship, journal of publication, data sources, and country of publication (means ± standard deviations)

| Studies | Selection of Patients | Adjustment for Confounding Factors | Quality | Applicability
Sponsorship
Grant | 7 | 3.0 ± 0.6 | 3.6 ± 2.1 | 64.0 ± 11.9 | 3.3 ± 0.8
Unknown | 8 | 3.3 ± 0.7 | 3.1 ± 2.4 | 65.0 ± 10.5 | 3.6 ± 0.5
Industry | 2 | 3.5 ± 0.7 | 5.0±0.0 | 76.4 ± 19.2 | 3.0 ± 1.4
Journal of Publication
General medicine | 2 | 3.0 ± 0.01 | 5.0 ± 0.01 | 68.2 ± 4.5 | 2.5 ± 0.7*
Oncology | 2 | 4.0 ± 0.01* | 5.0 ± 0.01 | 79.6 ± 14.6 | 4.0 ± 0.01
Other | 2 | 3.5 ± 0.7 | 2.5 ± 3.5 | 65.4 ± 9.6 | 4.0 ± 0.01*
Urology | 7 | 2.9 ± 0.7* | 3.0 ± 2.2 | 59.5±11.8 | 3.1 ± 0.7
Data used
Administrative | 10 | 3.2 ± 0.6 | 4.0 ± 1.9 | 67.4 ± 12.5 | 3.2 ± 0.8
Medical Records | 7 | 3.1 ± 0.7 | 2.9 ± 2.4 | 63.9 ± 11.5 | 3.7 ± 0.5
Country where Study was Conducted
Austria | 1 | 3.0 | 0.0 | 54.3 | 3.0
Canada | 1 | 3.0 | 5.0 | 62.9 | 2.0*
USA | 15 | 3.2 | 3.7 | 66.9 | 3.5*

* significant differences at 95% confidence interval

Table C29 Geographic variations in prostate cancer screening, incidence, and mortality

Reference Period Design | Population Data Source | Exposure Definitions | Outcomes | Analysis/Unit | Exposure Categories | Outcome Rate
Lu-Yao, 1994 ^102^ | White men 50–70 years old from 9 areas in SEER program(~10% of the USA population) | Time trends and geographical variations in the detection and treatment of prostate cancer | Age-standardized Incidence; annual % change (EAPC) in rates by calendar year | Regression analysis. Pearson correlation between the average rates of incidence and mortality for each SEER area | Area | Incidence/100,000
1983-1989 | The National Center of Health Statistics | | | Unit: Patient | | 1983
Retrospective cohort; ecologic analysis. | | | | Risk adjustment: Age | Atlanta | 279.4
Evidence II2B | | | | | Connecticut | 235.0
Quality: 0.7 | | | | | Detroit | 284.6
| | | | | Hawaii | 281.3
| | | | | Iowa | 251.0
| | | | | New Mexico | 284.6
| | | | | San Francisco | 249.3
| | | | | Seattle | 348.9
| | | | | Utah | 326.7
| | | | | | 1989
| | | | | Atlanta | 384.5
| | | | | Connecticut | 267.9
| | | | | Detroit | 361.7
| | | | | Hawaii | 502.3
| | | | | Iowa | 332.3
| | | | | New Mexico | 351.9
| | | | | San Francisco | 368.2
| | | | | Seattle | 606.8
| | | | | Utah | 374.1
| | | | | | Annual % change in rate
| | | | | Atlanta | 7.7 (4.1–11.3)
| | | | | Connecticut | 2.7 (0.6–4.8)
| | | | | Detroit | 5.2 (3.2–73)
| | | | | Hawaii | 10.0 (4.3–15.9)
| | | | | Iowa | 5.0 (3.6–83)
| | | | | New Mexico | 3.0 (0 8–5.3)
| | | | | San Francisco | 6.6 (5.0–8.3)
| | | | | Seattle | 12.0 (8.8–15.2)
| | | | | Utah | 3.0 (0.3–5.7)
Kafadar, 1997 ^103^ | The U.S. Census population from 1953-1987 | Time trends and geographic location by U.S. counties. The proportion of African-Americans | Age-standardized mortality among whites and nonwhites | Bivariate smoothing using calculation of age-specific rates; United States | Area | Mortality/100,000
1953-1987 | The state Cancer Control Maps; The National Center of Health Statistics | | | Risk adjustment: age, proportion of African Americans | | 1953-1972, Whites
Ecologic analysis | | | | | Midwest | 18.9–23.57
Evidence II2B | | | | | Northeast | 18.93–24.17
Quality: 0.9 | | | | | South | 17.16–22.02
| | | | | West | 18.45–23
| | | | | | 1953-1972, Not Whites
| | | | | Midwest | 16.34–39.12
| | | | | Northeast | 0–45.98
| | | | | South | 28.29–44.33
| | | | | West | 6.31–30.69
| | | | | | 1973-1987, Whites
| | | | | Midwest | 20.01–24.01
| | | | | Northeast | 20.5–25.59
| | | | | South | 18.73–23.32
| | | | | West | 20.06–26.86
| | | | | | 1973-1987, Not Whites
| | | | | Midwest | 12.18–45.97
| | | | | Northeast | 9.14–42.47
| | | | | South | 29.92–51
| | | | | West | 17.96–32.8
Jemal, 2002 ^104^ | Population estimates in the U.S. for the years 1970-1989 by 5-year age groups | Geographic locations, race | indirectly age-adjusted mortality | Spatial scan statistic; Poisson distribution | Areas | Age adjusted mortality/100,000 person years
1970-1989 | U.S. Bureau of Census; The National Center for Health Statistics | | | Unit: Counties | White males | Rate | Rate ratio | P value
Ecologic analysis | | | | Risk adjustment: education and agricultural employment | (United States) | 20.2 | 1 | -
Evidence II2B | | | | | Northwest quadrant | 21.5 | 1.064 | 0.0001
Quality: 0.85 | | | | | New England | 21.3 | 1.055 | 0.0001
| | | | | Maryland, Virginia, Pennsylvania | 21.7 | 1.074 | 0.0001
| | | | | Michigan, Ohio, Indiana, Illinois | 20.8 | 1.028 | 0.0001
| | | | | South Carolina, North Carolina | 22 | 1.09 | 0.0027
| | | | | Montana, North Dakota, Wyoming | 23.2 | 1.147 | 0.0001
| | | | | Minnesota, Iowa, Wisconsin | 22.8 | 1.126 | 0.0001
| | | | | California, Oregon | 21.9 | 1.084 | 0.0001
| | | | | Washington, Oregon | 21.6 | 1.068 | 0.0005
| | | | | Utah, Nevada, Colorado, Arizona | 22.4 | 1.107 | 0.017
| | | | | Iowa, Missouri | 25.3 | 1.249 | 0.0235
| | | | | Vermont, New Hampshire, Maine | 22.8 | 1.126 | 0.0001
| | | | | Massachusetts, Rhode Island | 23 | 1.139 | 0.0001
| | | | | Massachusetts, Connecticut | 21.6 | 1.07 | 0.0194
| | | | | Maryland, Delaware | 22.6 | 1.116 | 0.0001
| | | | | Kentucky, Ohio, Indiana | 23 | 1.135 | 0.0001
| | | | | Wisconsin | 21.5 | | 0.0033
| | | | | Black Males
| | | | | (United States) | 28.6 | 1 | -
| | | | | South Atlantic | 31.9 | 1.114 | 0.0001
| | | | | Alabama | 33.3 | 1.161 | 0.005
| | | | | Ohio, Indiana, Michigan, Kentucky | 30.8 | 1.077 | 0.0561
| | | | | North Carolina, South Carolina | 33.7 | 1.177 | 0.0001
| | | | | Florida, Georgia | 33.7 | 1.177 | 0.0001
| | | | | Maryland, Virginia, Delaware | 33.2 | 1.16 | 0.0001
| | | | | Georgia, North Carolina | 32.7 | 1.142 | 0.0001
| | | | | Georgia | 37.8 | 1.319 | 0.02
Jemal, 2005 ^105^ | 40% of the U.S. male population ages 40 years for 1995 to 2000 | Geographic locations; race, degree of urbanization as a proxy for access to medical care | Average age adjusted to the year 2000 U.S. population standard incidence and mortality rates/100,000 men | Poisson distribution | Location | Age adjusted mortality/100,000
1995-2000 | The National Center for Health Statistics and the North American Association of Central Cancer Registries (SEER) | | | Unit: States | White men
Retrospective cohort, ecologic analysis | | | | Risk adjustment: age and race | Alaska | 258.2
Evidence II2B | | | | | Arizona | 215.9
Quality: 0.85 | | | | | Colorado | 274.4
| | | | | Connecticut | 332.4
| | | | | District of Columbia | 320.5
| | | | | Atlanta | 311.4
| | | | | Hawaii | 315.3
| | | | | Idaho | 283.9
| | | | | Illinois | 278.7
| | | | | Iowa | 297.1
| | | | | Kentucky | 220.0
| | | | | Louisiana | 302.0
| | | | | Maine | 296.2
| | | | | Massachusetts | 353.8
| | | | | Michigan | 320.1
| | | | | Montana | 278.1
| | | | | Nebraska | 308.7
| | | | | New Hampshire | 287.3
| | | | | New Jersey | 330.1
| | | | | North Carolina | 271.2
| | | | | North Dakota | 357.4
| | | | | Oregon | 298.9
| | | | | Pennsylvania | 296.6
| | | | | Rhode Island | 266.8
| | | | | South Carolina | 286.9
| | | | | Utah | 385.8
| | | | | Washington | 298.8
| | | | | West Virginia | 250.7
| | | | | Wisconsin | 318.2
| | | | | Wyoming | 279.0
| | | | | Black men
| | | | | Arizona | 154.8
| | | | | Colorado | 172.6
| | | | | Connecticut | 167.6
| | | | | District of Columbia | 164.2
| | | | | Atlanta | 169.9
| | | | | Illinois | 167.4
| | | | | Iowa | 180.3
| | | | | Kentucky | 155.2
| | | | | Louisiana | 164.4
| | | | | Massachusetts | 142.9
| | | | | Michigan | 153.7
| | | | | Nebraska | 142.5
| | | | | New Jersey | 167.2
| | | | | North Carolina | 196.7
| | | | | Oregon | 177.3
| | | | | Pennsylvania | 172.7
| | | | | Rhode Island | 129.2
| | | | | South Carolina | 195.9
| | | | | Washington | 146.6
| | | | | West Virginia | 170.1
| | | | | Wisconsin | 145.1
| | | | | White men | Incidence of localized PC
| | | | | Alaska | 258.2
| | | | | Arizona | 215.9
| | | | | Colorado | 274.4
| | | | | Connecticut | 332.4
| | | | | District of Columbia | 320.5
| | | | | Atlanta | 311.4
| | | | | Hawaii | 315.3
| | | | | Idaho | 283.9
| | | | | Illinois | 278.7
| | | | | Iowa | 297.1
| | | | | Kentucky | 220.0
| | | | | Louisiana | 302.0
| | | | | Maine | 296.2
| | | | | Massachusetts | 353.8
| | | | | Michigan | 320.1
| | | | | Montana | 278.1
| | | | | Nebraska | 308.7
| | | | | New Hampshire | 287.3
| | | | | New Jersey | 330.1
| | | | | North Carolina | 271.2
| | | | | North Dakota | 357.4
| | | | | Oregon | 298.9
| | | | | Pennsylvania | 296.6
| | | | | Rhode Island | 266.8
| | | | | South Carolina | 286.9
| | | | | Utah | 385.8
| | | | | Washington | 298.8
| | | | | West Virginia | 250.7
| | | | | Wisconsin | 318.2
| | | | | Wyoming | 279.0
| | | | | Black men
| | | | | Alaska | 457.7
| | | | | Arizona | 255.9
| | | | | Colorado | 363.4
| | | | | Connecticut | 500.5
| | | | | District of Columbia | 516.2
| | | | | Atlanta | 481.5
| | | | | Hawaii | 351.8
| | | | | Illinois | 386.5
| | | | | Iowa | 485.2
| | | | | Kentucky | 317.4
| | | | | Louisiana | 381.8
| | | | | Massachusetts | 487.6
| | | | | Michigan | 561.9
| | | | | Nebraska | 389.7
| | | | | New Jersey | 494.8
| | | | | North Carolina | 380.7
| | | | | Oregon | 384.6
| | | | | Pennsylvania | 483.1
| | | | | Rhode Island | 309.3
| | | | | South Carolina | 454.6
| | | | | Utah | 475.8
| | | | | Washington | 421.2
| | | | | West Virginia | 400.8
| | | | | Wisconsin | 511.6
Escobedo, 2004 ^106^ | 3,274 African American men in Connecticut, Iowa, and New Mexico diagnosed with localized or regional prostate cancer in 1979-1998 | Time trends in periods before (1979-1986), during (1987-1990) and after introduction of the PSA test (1991-1998); geographic locations | Age-adjusted to the 1970 U.S. standard incidence and mortality | Poisson distribution. | Time and regions
1979-1998 | The National Center for Health Statistics (NCHS), SEER database | | | Unit: patients | Connecticut | Incidence | | Rate
Retrospective cohort | | | | Risk adjustment:: age; direct method of standardization to 1970 U.S. population | 1973-1988 | Rate | | Ratio
Evidence II2B | | | | | <54 | 3.8
Quality: 0.75 | | | | | 55–64 | 210.3
| | | | | 65–74 | 721.5
| | | | | >75 | 1157.3
| | | | | 1989-1998
| | | | | <54 | 13.7 | | 3.61
| | | | | 55–64 | 567.2 | | 2.7
| | | | | 65–74 | 1450 | | 2.01
| | | | | >75 | 1495.2 | | 1.29
| | | | | 1973-1988
| | | | | By stage
| | | | | Local/regional | 63
| | | | | Distant | 36
| | | | | Unstaged | 10.9
| | | | | 1989-1998
| | | | | Local/regional | 158.1 | | 2.51
| | | | | Distant | 26.1 | | 0.73
| | | | | Unstaged | 23.5 | | 2.16
| | | | | Overall
| | | | | Before PSA | 109.9
| | | | | During PSA | 207.8 | | 1.89
| | | | | Iowa
| | | | | 1973-1988
| | | | | <54 | 4
| | | | | 55–64 | 211.7
| | | | | 65–74 | 654.2
| | | | | >75 | 1275.1
| | | | | 1989-1998
| | | | | <54 | 13 | | 3.25
| | | | | 55–64 | 512.1 | | 2.42
| | | | | 65–74 | 1253.6 | | 1.92
| | | | | >75 | 1589.9 | | 1.25
| | | | | 1973-1988
| | | | | By stage
| | | | | Local/regional | 66.3
| | | | | Distant | 36.7
| | | | | Unstaged | 7.5
| | | | | 1989-1998
| | | | | Local/regional | 141.1 | | 2.13
| | | | | Distant | 28.6 | | 0.78
| | | | | Unstaged | 24.1 | | 3.21
| | | | | Overall
| | | | | Before PSA | 110.6
| | | | | During PSA | 193.8 | | 1.75
| | | | | New Mexico
| | | | | 1973-1988
| | | | | <54 | 3.5
| | | | | 55–64 | 257.7
| | | | | 65–74 | 475.5
| | | | | >75 | 1195.4
| | | | | 1989-1998
| | | | | <54 | 6.7 | | 1.91
| | | | | 55–64 | 295 | | 1.14
| | | | | 65–74 | 1093.7 | | 2.3
| | | | | >75 | 978.3 | | 0.82
| | | | | 1973-1988
| | | | | By stage
| | | | | Local/regional | 69.4
| | | | | Distant | 22.6
| | | | | Unstaged | 8.4
| | | | | 1989-1998
| | | | | Local/regional | 115.9 | | 1.67
| | | | | Distant | 15.2 | | 0.67
| | | | | Unstaged | 5 | | 0.6
| | | | | Overall
| | | | | Before PSA | 100.4
| | | | | During PSA | 136.1 | | 1.36
| | | | | Connecticut | Age adjusted mortality
| | | | | 1979-1986 | 78.2 (65.9–90.6)
| | | | | 1987-1990 | 81.2 (65.1–97.3) | | 1.04
| | | | | 1991-1998 | 93.1 (82.3–103.8) | | 1.19
| | | | | Iowa
| | | | | 1979-1986 | 79.5 (55.1–103.9)
| | | | | 1987-1990 | 111.1 (71.9–150.3) | | 1.4
| | | | | 1991-1998 | 93.5 (69.1–117.9) | | 1.18
| | | | | New Mexico
| | | | | 1979-1986 | 104.7 (69.4–140.0)
| | | | | 1987-1990 | 62.1 (26.9–97.4) | | 0.59
| | | | | 1991-1998 | 47.6 (29.6–65.5) | | 0.45
Lu-Yao, 2002 ^107^ | 215,521 males Medicare beneficiaries from the Seattle (94 900) and Connecticut (120,621) identified in the SEER database | Geographical variations in the detection and treatment of prostate cancer | Prostate cancer mortality, incidence, and screening intensity(prostate biopsies and PSA) | Poisson distribution | Seattle Connecticut | PSA rate ratio
1987-1997 | | | | Unit: patients | Seattle Connecticut | 5.39 (4.76–6.11)
Retrospective cohort | | | | Risk adjustment:: age; race, area of residence, study year, and an age-race interaction | Seattle Connecticut | 1 (reference)
Evidence II2B | | | | | | Biopsy rate ratio
Quality: 0.78 | | | | | | 2.2 (1.81–2.68)
| | | | | | 1 (reference)
| | | | | | Age adjusted mortality rate ratio
| | | | | | 1.03 (0.95–1.11)
| | | | | | 1 (reference)

Table C30 Geographic variations in prostate cancer treatments

Reference Period Design | Population Data Source | Outcomes | Analysis/Unit | Exposure Categories | | Outcome Rate
Lu-Yao, 1994 ^102^ | White men 50–70 years old from 9 areas in SEER program(~10% of the U.S. population) | Age adjusted rate of radical prostatectomy; proportions of cases receiving radical prostatectomy or radiation as initial treatment | Regression analysis. Pearson correlation between the average rates of incidence and mortality for each SEER area; | | | Radical Prostatectomy (rate per 100,000)
1983-1989 | The National Center of Health Statistics | | Unit: Patient | | | 1983 | 1989
Retrospective cohort | | | Risk adjustment: Age | Atlanta | | 11.9 | 118.2
Ecologic analysis | | | | Connecticut | | 7.3 | 43.4
Evidence II2B | | | | Detroit | | 16 | 61.2
Quality: 0.73 | | | | Hawaii | | 17.9 | 83.6
| | | | Iowa | | 32 | 68.5
| | | | Now Mexico | | 32.7 | 93.6
| | | | San Francisco | | 13.6 | 94.4
| | | | Seattle | | 54.6 | 224.4
| | | | Utah | | 52.6 | 118.8
| | | | | | % of prostate cancer cases receiving radical prostatectomy as initial treatment
| | | | | | 1983 | 1989
| | | | Atlanta | | 5 | 32.3
| | | | Connecticut | | 3.3 | 15.7
| | | | Detroit | | 6.1 | 17.4
| | | | Hawaii | | 7.3 | 16.8
| | | | Iowa | | 12.3 | 19.6
| | | | Now Mexico | | 11.8 | 25.7
| | | | San Francisco | | 4.8 | 25.9
| | | | Seattle | | 16 | 36.8
| | | | Utah | | 16.6 | 31.6
| | | | All areas | | 9.4 | 25.6
| | | | | | % of prostate cancer cases receiving Radiation as initial treatment
| | | | | | 1983 | 1989
| | | | Atlanta | | 35.3 | 23.7
| | | | Connecticut | | 29.4 | 28.1
| | | | Detroit | | 28.2 | 36.7
| | | | Hawaii | | 24.6 | 31.6
| | | | Iowa | | 19.3 | 29.2
| | | | Now Mexico | | 25.2 | 30
| | | | San Francisco | | 32.8 | 32.6
| | | | Seattle | | 32.1 | 31.4
| | | | Utah | | 30.2 | 19.9
| | | | All areas | | 28.5 | 30.4
Lu-Yao, 1993 ^108^ | A 20% national sample of male Medicare beneficiaries | Age adjusted radical prostatectomy rates/100,000 males to 1990 Medicare population; age and race adjusted utilization rate ratios compared with U.S. rate of prostatectomy | Poisson regression | | | Utilization rate ratio and 95% CI
1984-1990 | The Prostate Patient Outcomes Research Team | | Unit: Patient | New England | | 0.51 | 0.44–0.59
Retrospective cohort | 10,598 radical prostatectomies | | Risk adjustment: age, race, temporal trends | Mid Atlantic | | 0.5 | 0.44–0.56
Evidence II2B | | | | South Atlantic | | 1.12 | 1.01–1.23
Quality: 0.85 | | | | East North Central | | 0.84 | 0.75–0.92
| | | | East North Central | | 0.99 | 0.88–1.12
| | | | West North Central | | 1.15 | 1.03–1.28
| | | | West North Central | | 0.99 | 0.89–1.1
| | | | Mountain | | 1.49 | 1.33–1.67
| | | | Pacific | | 1.76 | 1.6–1.95
| | | | USA | | 1 (reference)
Mushinski, 1994 ^109^ | Claims data from Metropolitan Life Insurance Company, Corporate Health Strategies, Inc. Analyses | The total average hospital and physician charges; average length of stay in hospitals | ANOVA test | | | Cost $ | Length of stay in days
1994 | 1,004 radical prostatectomies | | Unit: Patient | USA | | 18680 | 5.56
Cross-sectional | | | Risk adjustment: NR | New England | | 18,500 | 5.3
Evidence III | | | | Mid-Atlantic | | 20,610 | 6.71
Quality: 0.78 | | | | East North Central | | 18,100 | 5.63
| | | | West North Central | | 17,700 | 5.17
| | | | South Atlantic | | 18,940 | 5.75
| | | | East South Central | | 12,910 | 5.62
| | | | West South Central | | 18,900 | 5.52
| | | | Mountain | | 16,220 | 4.92
| | | | Pacific | | 20,790 | 4.93
Mettlin et al, 1998 ^110^ | The National Cancer Data Base Data from 1,114 hospitals on 103,979 patients diagnosed with prostate carcinoma in 1992 and from 1,144 hospitals on 72,337 patients diagnosed in 1995 | Proportion of patients treated by radical prostatectomy and external beam radiation | Logistic regression | | | % of patients treated by radical prostatectomy
1994 | | | Unit Patient | | | 1992 | 1995
Retrospective cohort | | | Risk adjustment: age, race, American Joint Committee on Cancer stage, and tumor histologic grade | Northeast | | 22.4 | 27.5
Evidence II2B | | | | Southeast | | 30.6 | 32.8
Quality: 0.83 | | | | Midwest | | 31.3 | 34.9
| | | | South | | 33.7 | 38.9
| | | | Mountain | | 37.3 | 40.4
| | | | Pacific | | 39.4 | 39.7
| | | | | | % of patients treated by external beam radiation
| | | | | | 1992 | 1995
| | | | Northeast | | 37.5 | 31.1
| | | | Southeast | | 33.8 | 28.4
| | | | Midwest | | 29.1 | 23.8
| | | | South | | 25.5 | 25.4
| | | | Mountain | | 23.4 | 20.6
| | | | Pacific | | 26.2 | 21.8
Krupski et al, 2005 ^111^ | 104,316 men with localized/regional prostate cancer; 34,763 underwent surgical resection, 1,549 received postprostatectomy radiotherapy | Proportion of patients who received adjuvant radiation therapy after surgical resection of the prostate gland | Logistic regression | | | % of patients treated by adjuvant therapy
1995-1999 | The National Cancer Institute's Surveillance Epidemiology and End Results (SEER) | | Unit Patient | Connecticut | | 9.5
Retrospective cohort | | | Risk adjustment: patient age, race, grade of cancer | Hawaii | | 3.9
Evidence II2B | | | 2000 Census median education and income level in the county of residence and ethnicity | Iowa | | 10
Quality: 0.63 | | | | New Mexico | | 3
| | | | Utah | | 3.5
| | | | Detroit | | 6.2
| | | | San Francisco | | 10.2
| | | | Atlanta | | 5.8
| | | | Seattle | | 15.3
| | | | Los Angeles | | 25.2
| | | | San Jose-Monterey | | 7.4
| | | | | | Adjusted odds ratio of adjuvant therapy
| | | | Connecticut | | 1.21 | 0.98–1.4
| | | | Hawaii | | 1.69 | 1.2–2.3
| | | | Iowa | | 1.14 | 0.91–1.4
| | | | New Mexico | | 0.64 | 0.45– 0.89
| | | | Utah | | 0.57 | 0.42– 0.76
| | | | Detroit | | 0.46 | 0.36–0.59
| | | | San Francisco | | 1.04 | 0.83–1.3
| | | | Atlanta | | 0.9 | 0.7–1.1
| | | | Seattle | | 1.38 | 1.1–1.6
| | | | Los Angeles | | 1 reference
| | | | San Jose-Monterey | | 1.21 | 0.95–1.5
Cooperberg et al, 2003 ^112^ | 3,439 of patients diagnosed with prostate cancer since 1989 treated with radical prostatectomy, radiation therapy, or primary androgen deprivation therapy; CaPSURE database | proportion of patients treated by radical prostatectomy, external beam radiation, brachytherapy, watchful waiting, primary androgen deprivation therapy, and neoadjuvant androgen deprivation therapy | Logistic regression | | | % of patients treated by watchful waiting
1989-2001 | | | Unit Patient | West | | 15.5
Retrospective cohort | | | Risk adjustment: patient age, ethnicity, location, type of insurance, educational level, and income | East | | 8.85
Evidence II2B | | | | Midwest | | 12.5
Quality: 0.88 | | | | South | | 7.9
| | | | | | % of patients treated by radical prostatectomy
| | | | West | | 38.6
| | | | East | | 50.9
| | | | Midwest | | 44.6
| | | | South | | 43.4
| | | | | | % of patients treated by external beam radiation
| | | | West | | 13.7
| | | | East | | 22.04
| | | | Midwest | | 17.8
| | | | South | | 14.54
| | | | | | % of patients treated by Brachytherapy
| | | | West | | 5.3
| | | | East | | 2.83
| | | | Midwest | | 6.93
| | | | South | | 7.99
| | | | | | Adjusted odds ratio of primary androgen deprivation
| | | | West | | 1.0 (reference)
| | | | East | | 0.4 (0.3–0.5)
| | | | Midwest | | 0.5 (0.3–0.7)
| | | | South | | 0.8 (0.6–1.2)
| | | | | | Adjusted odds ratio of neoadjuvant androgen deprivation
| | | | West | | 1.0 (reference)
| | | | East | | 0.6 (0.4-.)
| | | | Midwest | | 1.1 (0.7–.6)
| | | | South | | 0.7 (0.5–.0)
Lai et al., 2001 ^113^ | 66,293 patients with localized prostate cancer who underwent radical prostatectomy from 1983 through 1992; the Surveillance, Epidemiology, and End Results Program (SEER) | Overall and disease-specific survival | A proportional hazards model | | | % of patients treated by radical prostatectomy
1983-1992 | | | Unit Patient | San Francisco | | 18.3
Retrospective cohort | | | Risk adjustment: age at diagnosis, year of diagnosis, marital status, tumor grade, and race/ethnicity | Connecticut | | 10
Evidence II2B | | | | Detroit | | 14.1
Quality: 0.85 | | | | Hawaii | | 14.6
| | | | Iowa | | 12.9
| | | | New Mexico | | 17.6
| | | | Seattle | | 24.2
| | | | Utah | | 31.4
| | | | Atlanta | | 16.7
| | | | | | Overall survival in patients treated with prostatectomy
| | | | San Francisco | | 1.02 (0.89–1.16)
| | | | Connecticut | | 0.85 (0.70–1.04)
| | | | Detroit | | 1.11 (0.98–1.26)
| | | | Hawaii | | 0.85 (0.65–1.26)
| | | | Iowa | | 0.99 (0.86–1.15)
| | | | New Mexico | | 1.01 (0.85–1.20)
| | | | Utah | | 1.11 (0.97–1.27)
| | | | Atlanta | | 0.97 (0.79–1.19)
| | | | | | Disease-specific survival in patients treated with prostatectomy
| | | | San Francisco | | 1.17 (0.86–1.60)
| | | | Connecticut | | 0.86 (0.52–1.41)
| | | | Detroit | | 1.25 (0.93–1.70)
| | | | Hawaii | | 1.18 (0.65–2.14)
| | | | Iowa | | 1.16 (0.83–1.63)
| | | | New Mexico | | 0.99 (0.64–1.52)
| | | | Utah | | 0.84 (0.57–1.23)
| | | | Atlanta | | 0.78 (0.44–1.38)
Bubolz et al, 2001 ^114^ | 49,978 men treated with radical prostatectomy; 20% of the national sample | Case rates of radical prostatectomy (among total discharges); population-based rates of radical prostatectomy (among all eligible men in Medicare beneficiaries regardless of whether they received treatment) | Logistic regression | | | Rates of radical prostatectomy as a % of U.S. rate
1984 to 1997 | Medicare beneficiaries; Medicare's Medicare Provider Analysis and Review file | | Unit Patient | | | 1984-1989
Retrospective cohort | | | Risk adjustment: patient co morbidity; standardized to age distribution of the Medicare male beneficiaries in 1997 | USA | | 1
Evidence II2B | | | | New England | | 0.65
Quality: 0.8 | | | | Middle Atlantic | | 0.5
| | | | East North Central | | 0.825
| | | | West North Central | | 1.19
| | | | South Atlantic | | 1.2
| | | | East South Central | | 0.96
| | | | West South Central | | 1
| | | | Pacific | | 1.68
| | | | | | 1990-1993
| | | | USA | | 1
| | | | New England | | 0.6
| | | | Middle Atlantic | | 0.62
| | | | East North Central | | 0.9
| | | | West North Central | | 1.22
| | | | South Atlantic | | 1.11
| | | | East South Central | | 0.96
| | | | West South Central | | 1
| | | | Pacific | | 1.45
| | | | | | 1994-1997
| | | | USA | | 1
| | | | New England | | 0.79
| | | | Middle Atlantic | | 0.78
| | | | East North Central | | 0.999
| | | | West North Central | | 1.275
| | | | South Atlantic | | 1.04
| | | | East South Central | | 0.96
| | | | West South Central | | 1.19
| | | | Pacific | | 1.1
Cooperberg et al, 2004 ^115^ | 2,078 men diagnosed with low risk prostate cancer | Proportion of patients receiving primary treatment alternatives: radical prostatectomy, external-beam radiotherapy, interstitial radiotherapy (brachytherapy), primary androgen deprivation therapy, watchful waiting, and neoadjuvant androgen deprivation therapy | Logistic regression | | | % of patient by primary treatment
1989 to 2001 | The Cancer of the Prostate Strategic Urologic Research Endeavor (CaPSURE) | | Unit Patient | | | RP | Brachyth.
Retrospective cohort | | | Risk adjustment: patient age, ethnicity, income, education, insurance type | West | | 48.2 | 10.3
Evidence II2B | | | | Northeast | | 59 | 8.8
Quality: 0.85 | | | | Midwest | | 57.4 | 19
| | | | South | | 48.8 | 17.9
| | | | | | EBRT | PADT
| | | | West | | 8.3 | 10.6
| | | | Northeast | | 13.4 | 7
| | | | Midwest | | 6.2 | 9.6
| | | | South | | 7.5 | 15
| | | | | | Watchful waiting
| | | | West | | 22.6
| | | | Northeast | | 11.8
| | | | Midwest | | 7.9
| | | | South | | 10.8
Saigal et al, 2002 ^116^ | 17,586 Medicare beneficiaries newly diagnosed with clinically localized prostate cancer | Proportion of patients received combination of radical prostatectomy and radiation therapy with tomography (CT), magnetic resonance imaging (MRI), or bone scans | Multivariate logistical regression | | | % of patients received RP with CT scan
1991 to 1996 | Health Care Financing Administration database | | Unit Patient | Midwest | | 52.9
Retrospective cohort | Random sample of 5% of all Medicare beneficiaries | | Risk adjustment: Charlson index score, age group, race, geographic region, and year of diagnosis | Northeast | | 56.5
Evidence II2B | | | | South | | 46.5
Quality: 0.9 | | | | West | | 42.1
| | | | | | % of patients received RP with CT scan
| | | | Midwest | | 1.5
| | | | Northeast | | 3
| | | | South | | 2.9
| | | | West | | 2.7
| | | | | | % of patients received RP with bone scan
| | | | Midwest | | 57.4
| | | | Northeast | | 61
| | | | South | | 57.7
| | | | West | | 54.4
| | | | | | % of patients received radiation therapy with CT
| | | | Midwest | | 29.3
| | | | Northeast | | 33.1
| | | | South | | 20.2
| | | | West | | 15.2
| | | | | | % of patients received radiation therapy with MRI
| | | | Midwest | | 1.1
| | | | Northeast | | 2.6
| | | | South | | 2
| | | | West | | 1.8
| | | | | | % of patients received radiation therapy with bone scan
| | | | Midwest | | 54.7
| | | | Northeast | | 57.7
| | | | South | | 51.4
| | | | West | | 48.1
Wilt et al., 1999 ^117^ | 13,398 men ages 45 to 84 years who underwent RP at a VAMC; the Department of Veterans Affairs Patient Treatment File and Outpatient Clinic File | RP utilization per 100,000 veteran users | Logistic regression | | | Adjusted odds ratio of RP (95% CI)
1986-1996 | | | Unit Patient | Northeast | | 0.784 | 0.755; 0.814
Retrospective cohort | | | Risk adjustment: patient age and years of diagnosis | New England | | 0.725 | 0.67; 0.784
Evidence II2B | | | | Middle Atlantic | | 0.803 | 0.763; 0.846
Quality: 0.9 | | | | Midwest | | 1.117 | 1.085; 1.15
| | | | East North Central | | 0.76 | 0.725; 0.797
| | | | West North Central | | 1.7 | 1.63; 1.774
| | | | South | | 1.028 | 1.001; 1.056
| | | | South Atlantic | | 0.968 | 0.93; 1.008
| | | | East South Central | | 1.012 | 0.952; 1.076
| | | | West South Central | | 1.097 | 1.053; 1.148
| | | | West | | 1.11 | 1.075; 1.146
| | | | Mountain | | 1.141 | 1.079; 1.206
| | | | Pacific | | 1.081 | 1.032; 1.132
| | | | USA | | 1 (reference)
| | | | | | RP rate/100,000
| | | | Northeast | | 46.8
| | | | New England | | 43.7
| | | | Middle Atlantic | | 48.1
| | | | Midwest | | 67.1
| | | | East North Central | | 46.1
| | | | West North Central | | 102.1
| | | | South | | 60.8
| | | | South Atlantic | | 57.4
| | | | East South Central | | 60.2
| | | | West South Central | | 65.7
| | | | West | | 64.3
| | | | Mountain | | 68
| | | | Pacific | | 62
| | | | USA | | 60.5
| | | | | | Odds ratio of 30 days mortality after RP
| | | | West | | 1 | 1–1
| | | | Northeast | | 1.18 | 0.76; 1.81
| | | | South | | 1.23 | 0.9; 1.69
| | | | Midwest | | 1.06 | 0.74; 1.51
Hu, 2003 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | In-hospital complications; Means length of stay | Multiple regression | | | Adjusted odds ratio of in hospital complications after RP
1997-1998 | Medicare claims data | | Unit: Patient | Northeast | | 1 | 1–1
Retrospective cohort | | | Risk adjustment: patient age, race, co morbidities, hospital type | South | | 1.05 | 0.76; 1.46
Evidence: II-2C | | | | West | | 0.58 | 0.38; 0.88
Quality: 0.86 | | | | Midwest | | 0.86 | 0.62; 1.2
| | | | | | Adjusted odds ratio of anastomatic stricture after RP
| | | | Northeast | | 1 | 1 | 1
| | | | South | | 1.18 | 0.82 | 1.7
| | | | West | | 1.04 | 0.68 | 1.58
| | | | Midwest | | 0.94 | 0.65 | 1.35
| | | | | | Mean length of stay
| | | | Northeast | | Reference
| | | | South | | -0.93 (-1.36; 0.5)
| | | | West | | -1.63 (-2.19; 1.07)
| | | | Midwest | | -1.19 (-1.66; 0.72)
Litwin et al, 1998 ^119^ | 688,000 men Medicare beneficiaries treated with radical prostatectomy; national 5% simple random sample from the Health Care Financing Administration | Radical prostatectomy rates per 100,000 male Medicare beneficiaries | Descriptive statistics and chi-square t | | | Radical prostatectomy rates/100,000
1991-1993 | | | Unit Patient | USA | 1991 | 216
Retrospective cohort | | | Risk adjustment: stratification by patient age and race | USA | 1992 | 284
Evidence: II-2C | | | | USA | 1993 | 235
Quality: 0.78 | | | | Northeast | 1991 | 136
| | | | Northeast | 1992 | 206
| | | | Northeast | 1993 | 151
| | | | South | 1991 | 223
| | | | South | 1992 | 305
| | | | South | 1993 | 250
| | | | Midwest | 1991 | 233
| | | | Midwest | 1992 | 290
| | | | Midwest | 1993 | 241
| | | | West | 1991 | 295
| | | | West | 1992 | 346
| | | | West | 1993 | 313
Escobedo, 2004 ^106^ | 3,274 African American men in Connecticut, Iowa, and New Mexico diagnosed with localized or regional prostate cancer in 1979-1998 | Prostate cancer treatment strategies: prostatectomy, transurethral resection of the prostate, radiation only, prostatectomy plus radiation, observation, and all other (diagnostic categories, non-cancer directed surgery, subtotal/simple prostatectomy, pelvic surgery, node surgery, radioactive implants, radioisotopes) | Poisson distribution. | Connecticut | | % of patients who received therapy
1979-1998 | The National Center for Health Statistics (NCHS), SEER database | | Unit: patients | 1983-1988
Retrospective cohort | | | Risk adjustment: age; direct method of standardization to 1970 U.S. population | Prostatectomy | | 6.6
Evidence II2B | | | | Transurethral resection of the prostate | | 54.1
Quality: 0.75 | | | | Radiation only | | 0
| | | | Prostatectomy plus radiation | | 0.8
| | | | Observation | | 1.7
| | | | All other | | 36.8
| | | | Connecticut
| | | | 1989-1994
| | | | Prostatectomy | | 21.3
| | | | Transurethral resection of the prostate | | 19.4
| | | | Radiation only | | 0.6
| | | | Prostatectomy plus radiation | | 2.7
| | | | Observation | | 1.3
| | | | All other | | 54.7
| | | | Iowa | | 1983-1988 | 1989-1994
| | | | Prostatectomy | | 11.1 | 25
| | | | Transurethral resection of the prostate | | 72.2 | 15.6
| | | | Radiation only | | 0 | 0
| | | | Prostatectomy plus radiation | | 0 | 9.4
| | | | Observation | | 1.9 | 1
| | | | All other | | 14.8 | 49
| | | | New Mexico | | 1983-1988 | 1989-1994
| | | | Prostatectomy | | 5.9 | 28.8
| | | | Transurethral resection of the prostate | | 55.9 | 15
| | | | Radiation only | | 0 | 0
| | | | Prostatectomy plus radiation | | 2.9 | 7.5
| | | | Observation | | 0 | 1.3
| | | | All other | | 35.3 | 47.5
Brandeis, 2000 ^120^ | 10,107 Medicare beneficiaries treated for early stage prostate carcinoma from inpatient, outpatient, and part B claims | Proportion of patients treated with Brachytherapy, external beam radiation therapy, radical prostatectomy, and its combinations | Descriptive statistic, chi-square test | | | % of patients treated by Brachytherpay
1991-1993 | The Health Care Financing Administration | | Unit: patients | Midwest | | 2.3
Retrospective cohort | | | Risk adjustment: comorbidity | Northeast | | 4.8
Evidence: II-2C | | | | South | | 5.7
Quality: 0.78 | | | | West | | 3.3
| | | | Other | | 1.8
| | | | | | % of patients treated by Brachytherpay + external beam radiation therapy
| | | | Midwest | | 1
| | | | Northeast | | 2.8
| | | | South | | 3.1
| | | | West | | 3.5
| | | | Other | | 0
| | | | | | % of patients treated by radical prostatectomy
| | | | Midwest | | 33.2
| | | | Northeast | | 23.1
| | | | South | | 32.8
| | | | West | | 44.2
| | | | Other | | 38.2
| | | | | | % of patients treated by radical prostatectomy +external beam radiation therapy
| | | | Midwest | | 3.9
| | | | Northeast | | 2.1
| | | | South | | 3.5
| | | | West | | 4
| | | | Other | | 1.8
| | | | | | % of patients treated by external beam radiation therapy
| | | | Midwest | | 59.7
| | | | Northeast | | 67.2
| | | | South | | 54.9
| | | | West | | 45.1
| | | | Other | | 58.2

Table C31 Association between hospital volumes (radical prostatectomy) and surgery related mortality

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis/Units | Risk Adjustment | Volume Categories | Outcome Rate (%) | Adjusted Volume Effect
Ellison, 2000 ^121^ | 66,693 patients after prostatectomy; 1,334 hospitals | Nationwide Inpatient Sample database | In-hospital death after radical prostatectomy | Multiple logistic regression | Patient age and comorbidity | Annual Hospital Volume (% hospitals) | | Odds ratio
1989-1996 | | Average number of procedures/year | | Unit: patient | | <25 (76) | 0.3 | 1.78 (1.2; 2.7)
Retrospective cohort | | | | Goodness-of-fit: Yes | | 25–54 (17) | 0.28 | 1.71 (1.2; 2.6)
Evidence: II-2C | | | | Discrimination: Not reported | | >54 (7) | 0.17 | 1 (reference)
Quality: 0.75 | | | | | | Subgroups by patient age
| | | | | | >65 years
| | | | | | Volume
| | | | | | <25 | 0.4
| | | | | | 25–54 | 0.38
| | | | | | >54 | 0.25
| | | | | | <65 years
| | | | | | Volume
| | | | | | <25 | 0.15
| | | | | | 25–54 | 0.15
| | | | | | >54 | 0.5
Begg,2002 ^122^ | 11,522 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims. | Postoperative death within 30–60 days after radical prostatectomy | GEE-logistic regression | Patient age, race, stage of cancer, comorbidities | Annual Hospital Volume (% hospitals) | 30 days mortality
1992-1996 | 6,421 with localized PC | Average number of procedures/year | | Unit: Patient | Hospital - surgeon correlations | <16 (69) | 0.5
Retrospective cohort | 403 hospitals | | | Goodness-of-fit: Not reported | | 17–28 (17) | 0.5
Evidence: II-2C | | | | Discrimination: Not reported | | 29–50 (9) | 0.5
Quality: 0.63 | | | | | | 51–120 (5) | 0.5
| | | | | | | 60 days mortality
| | | | | | <16 | 0.6
| | | | | | 17–28 | 0.6
| | | | | | 29–50 | 0.6
| | | | | | 51–120 | 0.5
Yao, 1999 ^123^ | 101,604 Medicare beneficiaries after radical prostatectomy | Medicare claims data | Postoperative death within 30–90 days after radical prostatectomy | Logistic regression | Patient age, race, comorbidities; surgeon specialty, hospital teaching status | Hospital Volume
1991-1994 | | Number of procedures/time of the study | | Unit: Patient | | <38 (9/year) | 0.63 | 1.51 (1.25; 1.77)
Retrospective cohort | | | | Goodness-of-fit: Not reported | | 39–74 (14/year) | 0.59 | 1.43 (1.17; 1.69)
Evidence: II-2C | | | | Discrimination: Not reported | | 75–140 (27/year) | 0.56 | 1.42 (1.16; 1.68)
Quality: 0.677 | | | | | | >141 (36/year) | 0.39 | 1 (reference)
Wennberg, 1987 ^124^ | 4,570 Medicare beneficiaries after prostatectomy | Medicare claims data: 16 hospitals | Postoperative death within 90 days after prostatectomy | Logistic regression | Patient age, comorbidities | Annual Hospital Volume
1974-1977 | | Number of procedures/time of the study | | Unit: Patient | Hospital size and teaching status | <40 | | 1 (reference)
Retrospective cohort | | | | Goodness-of-fit: Not reported | | 40–90 | | 1.26 (0.69; 2.32)
Evidence: II-2C | | | | Discrimination: Not reported | | >91 | | 1.66 (0.95; 2.89)
Quality: 0.655

Table C32 Association between hospital volumes (radical prostatectomy) and complications (cardiac, respiratory or vascular events, the need for reoperation, bleeding, renal failure, and shock)

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis/Units | Risk Adjustment | Volume Categories | Outcome Rate (%) | Adjusted Volume Effect
Yao, 1999 ^123^ | 101,604 Medicare beneficiaries after radical prostatectomy | Medicare claims data | In-hospital complications | Logistic regression | Patient age, race, comorbidities; surgeon specialty, hospital teaching status | Hospital Volume | | Serious complications
1991-1994 | | Number of procedures/time of the study | | Unit: Patient | | <38 (9/year) | | 1.4 3(1.37; 1.48)
Retrospective cohort | | | | Goodness-of-fit: Not reported | | 39–4 (14/year) | | 1.25 (1.19; 1.31)
Evidence: II-2C | | | | Discrimination: Not reported | | 75–140 (27/year) | | 1.09 (1.03; 1.15)
Quality: 0.677 | | | | | | >141 (36/year) | | 1(reference)
| | | | | | | Any complications
| | | | | | <38 (9/year) | 31.3(30.8–31.9) | 1.28 (1.24; 1.32)
| | | | | | 39– 4 (14/year) | 28.7(28.2–29.3) | 1.13 (1.08; 1.17)
| | | | | | 75– 140 (27/year) | 27.8(27.2–28.3) | 1.08 (1.04; 1.12)
| | | | | | >141 (36/year) | 26.3(25.8–26.9) | 1 (reference)
Hu, 2003 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | Medicare claims data. | In-hospital complications | Multiple regression | Patient age, race, comorbidities, hospital type, region | Hospital volume (% of procedures) | Postoperative complications
1997-1998 | | Number of procedures/time of the study | | Unit: Patient | | Low (85.2) (<60/year) | 21.6 | 1 (reference)
Retrospective cohort | | | | Goodness-of-fit: Not reported | | High (14.8) | 16.8 | 0.84(0.59; 1.19)
Evidence: II-2C | | | | Discrimination: Yes | | (>60 /year)
Quality: 0.86
Begg, 2002 ^122^ | 11,522 Medicare beneficiaries (Parts A and B) after radical prostatectomy, | SEER data base linked to Medicare claims | Postoperative complications during 30 days after surgery | GEE-logistic regression | Patient age, race, stage of cancer, co morbidities; hospital - surgeon correlations | Annual Hospital Volume (% hospitals)
1992-1996 | 6,421 with localized PC; 403 hospitals | Average number of procedures/year | | Unit: Patient | | <16 (69) | 32
Retrospective cohort | | | | Goodness-of-fit: Not reported | | 17–28 (17) | 31
Evidence: II-2C | | | | Discrimination: Not reported | | 29–50 (9) | 30
Quality: 0.63 | | | | | | 51–120 (5) | 27

Table C33 Association between hospital volumes (radical prostatectomy) and quality measures (cancer control, late urinary complications, or long term incontinence, operative quality)

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis/Units | Risk Adjustment | Volume Categories | Outcome Rate (%) | Adjusted Volume Effect
Ellison, 2000 ^125^ | 12,635 Medicare beneficiaries after radical prostatectomy | SEER database | Style of cancer control: use of adjuvant therapy more than 6 months after radical prostatectomy | Cox model; Kaplan-Meier | Patient age histological grade, pathological stage, and comorbidity | Annual Hospital Volume (% hospitals) | Cancer control (Adjuvant therapy) | Adjusted for tumor stage and grades
1990-1999 | 5,837 with localized PC | Number of procedures/time of the study | | Unit: Patient | | <16 (64) | 31.9 | 1.24 (1.13; 1.37)
Retrospective cohort | 348 hospitals | | | Goodness-of-fit: Yes | | 17–28 (17) | 26.9 | 1.09 (0.99; .19)
Evidence: II-2C | | | | Discrimination: Not reported | | 29–50 (11) | 27.7 | 1.02 (0.94; .12)
Quality: 0.745 | | | | | | 51–120 (8) | 26.9 | 1 (reference)
| | | | | | | | Adjusted for tumor stage and grades and patients co morbidities
| | | | | | <16 | | 1.25 (1.14; .38)
| | | | | | 17–28 | | 1.11 (1.01; .21)
| | | | | | 29–50 | | 1.03 (0.94; .12)
| | | | | | 51–120 | | 1 (reference)
Begg, 2002 ^122^ | 11,522 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims | Late urinary complications from 30 to 365 days after radical prostatectomy | GEE-logistic regression | Patient age, race, stage of cancer, comorbidities | Annual Hospital Volume (% hospitals) | Late urinary complications (events)
1992-1996 | 6,421 with localized PC; | Average number of procedures/year | Long term incontinence | Unit: Patient | Hospital - surgeon correlations | <16 (69) | 18
Retrospective cohort | 403 hospitals | | | Goodness-of-fit: Not reported | | 17–28 (17) | 19
Evidence: II-2C | | | | Discrimination: Not reported | | 29–50 (9) | 16
Quality: 0.63 | | | | | | 51–120 (5) | 13
| | | | | | | Late urinary complications (symptoms)
| | | | | | <16 | 28
| | | | | | 17–28 | 29
| | | | | | 29–50 | 23
| | | | | | 51–120 | 20
| | | | | | | Long term incontinence (events)
| | | | | | <16 | 6.5
| | | | | | 17–28 | 6.4
| | | | | | 29–50 | 7
| | | | | | 51–120 | 7.6
| | | | | | | Long term incontinence (symptoms)
| | | | | | <16 | 19
| | | | | | 17–28 | 19
| | | | | | 29–50 | 18
| | | | | | 51–120 | 18
Hu, 2003 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | Medicare claims data | Late urinary complications 12 months after radical prostatectomy | Multiple regression | Patient age, race, comorbidities, hospital type, region | Hospital volume(% of procedures) | Late urinary complications (events)
1997-1998 | | Number of procedures/time of the study | | Unit: Patient | | Low (85.2) (<60/year) | 26.8 | 1 (reference)
Retrospective cohort | | | | Goodness-of-fit: Not reported | | High (14.8) | 19.8 | 0.72 (0.49; 1.04)
Evidence: II-2C | | | | Discrimination: Yes | | (>60/year)
Quality: 0.86
Imperato, 2000 ^126^ | 583 Medicare beneficiaries living in New York State after radical prostatectomy | Medicare claims data | Operative quality indicators | Chi square - test | Not applicale | Hospital volume(% hospitals) | Scores of Operative quality indicators
1996 | 113 hospitals | Number of procedures/time of the study | | Unit: Patient | | 1–4 (67) | 49.1
Cross-sectional | | | | Goodness-of-fit: Not reported | | 5–9 (22) | 47.6
Evidence: III | | | | Discrimination: Not reported | | >10 (10) | 58.4
Quality:0.52

Table C34 Association between hospital volumes (radical prostatectomy) and length of stay in the hospital

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis Units | Risk Adjustment | Volume Categories | LOS (Days) | Adjusted Volume Effect
Ellison, 2000 ^125^ | 66,693 patients after prostatectomy | Nationwide Inpatient sample database | Length of stay | Multiple logistic regression | Patient age and comorbidity | Annual hospital volume | Mean (median) | Odds ratio
1989-1996 | | Average number of procedures/year | | Unit: patient | | <25 | 5.4 (5)
Retrospective cohort | | | | Goodness-of-fit: Yes | | 25–54 | 4.8 (4)
Evidence: II-2C | | | | Discrimination: Not reported | | >54 | 4.2 (4)
Quality: 0.75 | | | | | | Annual hospital volume | Hospital charges
| | | | | | <25 | $15,600
| | | | | | 25–54 | $15,100
| | | | | | >54 | $13,500
Yao, 1999 ^123^ | 101,604 Medicare beneficiaries after radical prostatectomy | Medicare claims data | Length of stay | Logistic regression | Patient age, race, comorbidities; surgeon specialty, hospital teaching status | Hospital volume (annual median) | Mean (95% CI)
1991-1994 | | Number of procedures/time of the study | Changes in length of stay from 1991 to 1994 | Unit: Patient | | Low <38(9) | 8.51 (8.47; 8.56)
Retrospective cohort | | | Readmission in 30 days | Goodness-of-fit: Not reported | | Medium-low | 8.18
Evidence: II-2C | | | | Discrimination: Not reported | | 39–4 (14) | (8.14; 8.22)
Quality: 0.677 | | | | | | Medium-high | 7.7
| | | | | | 75–140 (27) | (7.66; 7.74)
| | | | | | High 141(36) | 7.81 (7.77; 7.85)
| | | | | | Increase in volume (1991-1994) | Decrease in LOS in days
| | | | | | Low | 1.62 (1.33; 1.91)
| | | | | | Medium-low | 1.42
| | | | | | | 1.18; 1.67)
| | | | | | Medium-High | 1.5
| | | | | | | (1.29; 1.72)
| | | | | | High | 1.49 (1.27; 1.7)
| | | | | | Unchanged volume
| | | | | | Low | 1.34
| | | | | | | (1.12; 1.57)
| | | | | | Medium-low | 1.38
| | | | | | | (1.21; 1.55)
| | | | | | Medium-high | 1.29
| | | | | | | (1.12; 1.47)
| | | | | | High | 1.37
| | | | | | | (1.17; 1.57)
| | | | | | Decreased Volume
| | | | | | Low | 0.9
| | | | | | | (0.63; 1.17)
| | | | | | Medium-low | 1.07
| | | | | | | (0.89; 1.24)
| | | | | | Medium-high | 1.19
| | | | | | | (1.02; 1.36)
| | | | | | High | 1.2
| | | | | | | 4 (0.93; 1.55)
| | | | | | Hospital volume | | Readmission
| | | | | | Low | | 1.3
| | | | | | | | (1.21; 1.39)
| | | | | | Medium-low | | 1.16
| | | | | | | | (1.07; 1.25)
| | | | | | Medium-high | | 1.08
| | | | | | | | (0.99; 1.17)
| | | | | | High | | 1 (Reference)
Hu, 2003 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | Medicare claims data | Length of stay | Multiple regression | Patient age, race, comorbidities, hospital type, region | Hospital volume | LOS Mean (SD) | Regression coefficient for mean LOS
1997-1998 | | Number of procedures/time of the study | | Unit: Patient | | Low (<60/year) | 5.2 (3.8) | 1
Retrospective cohort | | | | Goodness-of-fit: Not reported | | High | 4.4 (2.1) | -0.42
Evidence: II-2C | | | | Discrimination: Not reported | | (>60/year) | | (-0.89; 0.05)
Quality: 0.86

Table C35 Association between hospital status and outcomes

Reference Period Design | Population | Data Source Status Definition | Outcome | Analysis Units | Risk Adjustment | Status Categories | Crude Outcomes Rates | Adjusted Status Effect
Wennberg, 1987 ^124^ | 4,570 Medicare beneficiaries after prostatectomy | Medicare claims data | Postoperative death within 90 days after prostatectomy | Logistic regression | Patient age, comorbidities hospital size and teaching status | Hospital status | | Surgery related mortality
1974-1977 | | 16 hospitals | | Unit: Patient | | No teaching programs | | 1.10 (0.69; 1.76)
Retrospective cohort | | Presence of the teaching programs | | Goodness-of-fit: Not reported | | Teaching hospitals | | 1
Evidence: II-2C | | | | Discrimination: Not reported
Quality: 0.655
Karakiewicz, 1998 ^127^ | 4,997 beneficiaries of the Quebec Healthcare Plan after radical retropubic prostatectomy, assumed all with localized PC | Quebec Healthcare Plan database (insurance plane in the province of Quebec. | Postoperative death within 30 days after radical prostatectomy | Cox proportional hazards regression model | Patient age, physician age and volume, hospital type | Hospital affiliated with academic centers | 30 days mortality
1988-1996 | 104 urologists | Affiliation with academic center | Cumulative survival (31 months) | Unit: Patient | | Nonacademic institutions | 0.45
Retrospective cohort | | | | Goodness-of-fit: Not reported | | | 0.72
Evidence: II-2C | | | | Discrimination: Not reported
Quality: 0.6
Gheiler, 1999 ^128^ | 1,129 patients after radical prostatectomy | Records of all patients admitted to the hospital in 1990-1996 before and after implementation of clinical care pathway | Average hospital stay | ANOVA test, Chi square test | NR | Urologists affiliated with academic center | LOS in days
1990-1996 | Single hospital study | Urologists affiliated with academic center | | Goodness-of-fit: Not reported | | Private urologists | 9
Descriptive baseline analysis of planned implementation of clinical pathway | 24 urologists | Private urologists | | Discrimination: Not reported | | | 13
Evidence: III
Quality: 0.46
Hu, 2003 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | Medicare claims data. | Late urinary complications 12 months after radical prostatectomy | Multiple regression | Patient age, race, comorbidities, hospital type, region | Hospital status | | In hospital complications
1997-1998 | | Academic affiliation | Anastomotic stricture | Unit: Patient | | Academic affiliation | | 1.0 (0.8; 1.37)
Retrospective cohort | | Government hospitals vs. nonprofit institutions | Length of stay | Goodness-of-fit: Not reported | | Nonacademic | | 1
Evidence: II-2C | | | | Discrimination: Yes | | | | Anastomotic stricture
Quality: 0.86 | | | | | | Academic affiliation | | 1.1
| | | | | | | | (0.83; 1.46)
| | | | | | Nonacademic | | 1
| | | | | | | | Reduction in LOS
| | | | | | Academic affiliation | | 0.03
| | | | | | | | (0.39; 0.34)
| | | | | | Government Hospitals vs. Nonprofit | | In hospital complications
| | | | | | | | 1.32
| | | | | | | | (0.96; 1.82)
| | | | | | Government Hospitals vs. Nonprofit | | Anastomotic stricture
| | | | | | | | 1.45
| | | | | | | | (1.03; 2.04)
| | | | | | Government Hospitals vs. nonprofit | | Increase in LOS
| | | | | | | | 0.51
| | | | | | | | (0.04; 0.98)
Gaylis, 1998 ^129^ | 116 patients after radical retropubic prostatectomy; two hospitals study | Records of all patients admitted to hospitals in 1990-1996 | Length of stay | T-test | Not reported | Hospital status | Cost 1990-1995
1990-1996 | | Hospitals ownership: profit and not-for-profit | Hospital charges | Unit patient | | Not for profit | $17,743
Case-series | | | | Goodness-of-fit: Not reported | | For profit | $24,481
Evidence: III | | | | Discrimination: Not reported | | | 1996
Quality: 0.41 | | | | | | Not for profit | $13,233
| | | | | | For profit | $25,979
Yuan, 2000 ^130^ | 17,260 Medicare beneficiaries after prostatectomy | The Health Care Financing Administration (HCFA) database | 30-day mortality | Multiple regression | Year of admission, patient age and race, and major comorbidities | Hospital status | 30 day mortality | 30 day mortality
1984-1993 | | Teaching hospitals by a membership in the Council of Teaching Hospitals of the Association of American Medical Colleges | 6-month mortality | Unit patient | | For profit | 1.1
Retrospective cohort | | | | Goodness-of-fit: Yes | | Not for profit | 1
Evidence: II-2C | | | | Discrimination: Yes | | Public | 1.2
Quality: 0.7 | | Types of hospitals (American Hospital Association File): for-profit, not-for-profit, non teaching public, teaching not-for-profit, and teaching public hospitals | | | | Teaching not for profit | 0.9
| | | | | | Teaching public | 0.9
| | | | | | For profit vs. Teaching not for profit | | 1.18
| | | | | | | | (1.1; 1.22)
| | | | | | Not for profit vs. Teaching not for profit | | 1.1
| | | | | | | | (1.05; 1.15)
| | | | | | Public vs. Teaching not | | 1.2
| | | | | | | | (1.15; 1.23)
| | | | | | Teaching public vs. Teaching not for profit | | 1 (0.9; 1.2)
| | | | | | | LOS | LOS
| | | | | | For profit | 6.6
| | | | | | Not for profit | 6.9
| | | | | | Public | 6.4
| | | | | | Teaching not for profit | 7.9
| | | | | | Teaching public | 8.2
| | | | | | For profit vs. teaching not for profit | | 0.875
| | | | | | Not for profit vs. teaching not for profit | | 0.9
| | | | | | Public vs. teaching not for profit | | 0.85
| | | | | | Teaching public vs. teaching not for profit | | 1

Table C36 Association between surgeon volumes (radical prostatectomy) and surgery related mortality

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis Units | Risk Adjustment | Volume Categories | Crude Rate (%) | Adjusted Volume Effect
Begg, 2002 ^122^ | 11,522 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims | Postoperative death within 30–60 days after radical prostatectomy | GEE logistic regression | Patient age, race, stage of cancer, comorbidities; hospital-surgeon correlations | Annual surgeon volume (% surgeons) | 30 days Mortality
1992-1996 | 6,421 with localized PC | 403 hospitals | | Unit: Patient | | 1–4 (64) | 0.4
Retrospective cohort | 999 surgeons | Average number of procedures/year | | Goodness-of-fit: Not reported | | 5–9 (20) | 0.5
Evidence: II-2C | | | | Discrimination: Not reported | | 10–15 (10) | 0.5
Quality: 0.63 | | | | | | 16–58 (6) | 0.5
| | | | | | Annual surgeon volume | 60 days Mortality
| | | | | | 1–4 (64) | 0.5
| | | | | | 5–9 (20) | 0.5
| | | | | | 10–15 (10) | 0.6
| | | | | | 16–58 (6) | 0.6
Karakiewicz, 1998 ^127^ | 4,997 beneficiaries of the Quebec Healthcare Plan after radical retropubic prostatectomy, assumed all with localized PC | Quebec Healthcare Plan database (insurance plans in the province of Quebec | Postoperative death within 30 days after radical prostatectomy | Cox proportional hazards regression model | Patient age, physician age and volume, hospital type | Surgeon age/volume | Adjusted 30 days mortality
1988-1996 | 104 urologists | Number of procedures during the study | Cumulative survival (31 months) | Unit: Patient | | 28–37/4 | 0.28
Retrospective cohort | | | | Goodness-of-fit: Not reported | | 38–47/8 | 0.45
Evidence: II-2C | | | | Discrimination: Not reported | | 48–57/5 | 0.57
Quality: 0.6 | | | | | | 58–67/6 | 0.99
| | | | | | 68–77/0.5 | 0
| | | | | | Surgeon age/volume | Cumulative survival, %
| | | | | | 28–37/4 | 97.2
| | | | | | 38–47/8 | 92.2
| | | | | | 48–57/5 | 91.7
| | | | | | 58–67/6 | 87.3
| | | | | | 68–77/0.5 | 0
Bianco, 1999 ^131^ | 5,238 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims | Postoperative death within 30–60 days after prostatectomy | Logistic regression | Patient age, cancer stage, comorbidities, hospital volume | Surgeon volume 20–121 | 60 days mortality
1993-1996 | 159 surgeons | Number of procedures during the study | | Unit Patient | | Annual average volume 17 | 0.5
Retrospective cohort | | | | Goodness-of-fit: Not reported
Evidence: II-2C | | | | Discrimination: Not reported
Quality:0.63

Table C37 Association between surgeon volumes (radical prostatectomy) and complications (cardiac, respiratory or vascular events, the need for reoperation, bleeding, renal failure, and shock)

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis Units | Risk Adjustment | Volume Categories | Crude Rate (%) | Adjusted Volume Effect
Begg, 2002 ^122^ | 11,522 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims | Postoperative complications during 30 days after surgery | GEE logistic regression | Patient age, race, stage of cancer, comorbidities | Annual surgeon volume (% surgeons) | Postoperative complications
1992-1996 | 6,421 with localized PC | 403 hospitals | | Unit: Patient | Hospital - surgeon correlations | 1–4 (64) | 32
Retrospective cohort | 999 surgeons | Average number of procedures/year | | Goodness-of-fit: Not reported | | 5–9 (20) | 31
Evidence: II-2C | | | | Discrimination: Not reported | | 10–15 (10) | 30
Quality: 0.63 | | | | | | 16–58 (6) | 26
Hu, 2002 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | Medicare claims data | Postoperative in hospital complications | Multiple regression | Patient age, race, comorbidities, hospital type, region | Surgeon volume (% of procedures) | Postoperative complications
1997-1998 | | Number of procedures/time of the study | | Unit: Patient | | Low (92.2) | 21.9 | 1 (reference)
Retrospective cohort | | | | Goodness-of-fit: Not reported | | (<40/year)
Evidence: II-2C | | | | Discrimination: Yes | | High (7.8) | 11.8 | 0.53 (0.32; 0.89)
Quality: 0.86 | | | | | | (>40/year)
| | | | | | Subgroups by hospital/surgeon volume
| | | | | | Low-low | 22.4
| | | | | | High-low | 18.6
| | | | | | Low-high | 13.6
| | | | | | High-high | 10.5
Bianco, 1999 ^131^ | 5,238 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims | Postoperative in-hospital complications | Logistic regression | Patient age, cancer stage, comorbidities, hospital volume | Surgeon volume | Postoperative complications
1993-1996 | 159 surgeons | Number of procedures/time of the study | Variability in outcome among high volume surgeons | Unit Patient | | 20–121
Retrospective cohort | | | | Goodness-of-fit: Not reported | | Annual average volume = 17 | 28.6
Evidence: II-2C | | | | Discrimination: Not reported | | 4 surgeons | <15
Quality:0.63 | | | | | | 12 surgeons | >50
| | | | | | Annual average volume = 17 | Late urinary complication 25.2
| | | | | | Annual average volume = 17 | Long term urinary complications 6.7
Dash, 2004 ^132^ | 1,123 patients after radical retropubic prostatectomy | Consecutive cases prospectively enrolled in the IRB approved study | Surgery related blood transfusion | Logistic regression | Patient age, race, hormone therapy use, clinical stage and grade, and prostate size; type of anesthesia | Annual surgeon Volume (% of patients) | Homologous transfusion rate
1994-2000 | Single academic center; 9 surgeons | Average number of procedures/year | | Unit Patient | | >15/year (94) | 3 | 1
Prospective cohort | | | | Goodness-of-fit: Not reported | | <15/year (6) | 18.2 | 8.63 (3.95; 18.86)
Evidence: II-2B | | | | Discrimination: Not reported | | | (range 0–20.6)
Quality: 0.69
Litwiller, 1995 ^133^ | 428 patients after radical retropubic prostatectomy | Records of all patients admitted to the hospital from 1984-1994; number of procedures performed by surgeon / study period | Surgery related blood loss and transfusion | Linear regression | Patient age, stage of cancer, comorbidities | Average surgeon volume | Average blood loss 1,327 ml
1984-1994 | Single academic center; 18 surgeons | | | Goodness-of-fit: Not reported | | 3 procedures (rank 1–9)
Design: Retrospective analysis of cases | | | | Discrimination: Not reported | | Correlation with blood loss | -0.31 (Not significant)
Evidence: III | | | | | | Correlation with transfusion | Average blood transfusions 1.57U
Quality: 0.47 | | | | | | | -0.37 (Not significant)

Table C38 Association between surgeon volumes (radical prostatectomy) and quality measures (late urinary complications or long term incontinence and operative quality)

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis Units | Risk Adjustment | Volume Categories | Crude Rate (%) | Adjusted Volume Effect
Begg, 2002 ^122^ | 11,522 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims | Late urinary complications from 30 to 365 days after radical prostatectomy | GEE logistic regression | Patient age, race, stage of cancer, comorbidities | Annual surgeon volume (% surgeons) | Late urinary complications (events)
1992-1996 | 6,421 with localized PC | 403 hospitals | Long term incontinence | Unit: Patient | Hospital - surgeon correlations | 1–4 (64) | 19
Retrospective cohort | 999 surgeons | Average number of procedures/year | | Goodness-of-fit: Not reported | | 5–9 (64) | 18
Evidence: II-2C | | | | Discrimination: Not reported | | 10–15 (10) | 17
Quality: 0.63 | | | | | | 16–58 (6) | 14
| | | | | | | Late urinary complications (symptoms)
| | | | | | 1–4 (64) | 28
| | | | | | 5–9 (20) | 26
| | | | | | 10–15 (10) | 27
| | | | | | 16–58 (6) | 20
| | | | | | | Long term incontinence (events)
| | | | | | 1–4 (64) | 7.3
| | | | | | 5–9 (20) | 7.2
| | | | | | 10–15 (10) | 6.7
| | | | | | 16–58 (6) | 6.6
| | | | | | | Long term incontinence (symptoms)
| | | | | | 1–4 (64) | 20
| | | | | | 5–9 (20) | 20
| | | | | | 10–15 (10) | 19
| | | | | | 16–58 (6) | 16
Hu, 2003 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | Medicare claims data | Late urinary complications (anastomotic strictures) 12 months after surgery | Multiple regression | Patient age, race, comorbidities, hospital type, region | Surgeon volume (% of procedures) | Anastomotic stricture
1997-1998 | | Number of procedures/time of the study | | Unit: Patient | | <40/year (92.2) | 27.7
Retrospective cohort | | | | Goodness-of-fit: Not reported | | >40/years (7.8) | 22
Evidence: II-2C | | | | Discrimination: Yes | | Subgroups by hospital/surgeon volume
Quality: 0.86 | | | | | | Low-low | 28.4
| | | | | | High-low | 22.7
| | | | | | Low-high | 29.6
| | | | | | High-high | 17.7
Bianco, 1999 ^131^ | 5,238 Medicare beneficiaries (Parts A and B) after radical prostatectomy | SEER data base linked to Medicare claims | Late urinary complications within 30 days-1 year after surgery | Logistic regression | Patient age, cancer stage, comorbidities, hospital volume | Surgeon volume | Late urinary complications
1993-1996 | 159 surgeons | Number of procedures/time of the study | Long term incontinence | Unit: Patient | | 20–121 (17/year) | 25.2
Retrospective cohort | | | Variability in outcomes among high volume surgeons | Goodness-of-fit: Not reported | | | Long term incontinence
Evidence: II-2C | | | | Discrimination: Not reported | | | 6.7
Quality: 0.63 | | | | | | | Late urinary complications
| | | | | | 19 surgeons | <5
| | | | | | 11 surgeons | >55
| | | | | | | Long-term incontinence
| | | | | | 38 surgeons | <10
| | | | | | 11 surgeons | >40
Eastham, 2003 ^134^ | 4,629 patients after radical prostatectomy | Records of all patients admitted to hospitals from 1983-2002 | Positive surgical margins | Logistic regression | Cancer clinical stage and grade; surgeon and institution | Surgeon volume | Positive surgical margins rate | Regression coefficient for positive surgical margins
1983-2002 | Two large urban centers; 44 surgeons | Number of procedures performed by surgeon/study period | | Unit: Patient | | <8 | 14 | -0.0007
Retrospective analysis of cases | | | | Goodness-of-fit: Not reported | | 10–16 | 10–48 | (SE0.0002)
Evidence: III | | | | Discrimination: Not reported | | 20–23 | 12–48 | RR 0.99
Quality: 0.68 | | | | | | >50 | 12 | (0.9996; 0.998)
| | | | | | Increment
| | | | | | 1 procedure
Hernandez, 2005 ^135^ | 204 patients after radical retropubic prostatectomy | Records of all patients admitted to the hospital from 1996-2002 | Positive surgical margins | Chi square test | Not reported | Surgeon volume (per year) | Positive surgical margins rate
1996-2002 | Single hospital study; 2 surgeons | Number of procedures/time of study | Bundle spring | Unit: Patient | | 101 (16.83) | 5.9
Retrospective analysis of cases | | | | Goodness-of-fit: Not reported | | 10,317.17) | 5.8
Evidence: III | | | | Discrimination: Not reported | | | Bundle nerve sparing
Quality: 0.69 | | | | | | | Bilateral
| | | | | | 101 | 84.2
| | | | | | 103 | 36.9
| | | | | | | Unilateral
| | | | | | 101 | 15.8
| | | | | | 103 | 54.4
| | | | | | | Both bundles excised
| | | | | | 101 | 0
| | | | | | 103 | 8.7

Table C39 Association between surgeon volumes (radical prostatectomy) and length of stay in the hospital

Reference Period Design | Population | Data Source Volume Definition | Outcome | Analysis Units | Risk Adjustment | Volume Categories | Length of Stay (%) | Adjusted Volume Effect
Hu, 2003 ^118^ | 2,292 Medicare beneficiaries after radical prostatectomy | Medicare claims data | Average hospital stay | Multiple regression | Patient age, race, comorbidities, hospital type, region | Surgeon volume (% of procedures) | LOS Mean (SD) | Regression coefficient for mean LOS
1997-1998 | | Number of procedures/time of the study | | Unit: Patient | | <40/year (92.2) | 5.2 (3.7) | -0.66
Retrospective cohort | | | | Goodness-of-fit: Not reported | | >40/years (7.8) | 4.1 (2.6) | (-0.06; 1.26)
Evidence: II-2C | | | | Discrimination: Not reported | | Subgroups by hospital/surgeon volume
Quality: 0.86 | | | | | | Low-low | 5.2 (3.8)
| | | | | | High-low | 4.7 (3.5)
| | | | | | Low-high | 4.8 (3.7)
| | | | | | High-high | 3.7 (1.1)
Litwiller, 1995 ^133^ | 428 patients after radical retropubic prostatectomy | Records of all patients admitted to the hospital from 1984-1994 | Average hospital stay | Linear regression | Patient age, stage of cancer, comorbidities | Average surgeon volume 3 procedures (rank 1–9) | Average hospital stay
1984-1994 | Single academic center; 18 surgeons | Number of procedures performed by surgeon/study period | | Goodness-of-fit: Not reported | | Correlation LOS | 7.71
Retrospective analysis of cases | | | | Discrimination: Not reported | | | (rank 3–24)
Evidence: III | | | | | | | -0.51
Quality: 0.47
Gheiler, 1999 ^128^ | 1,129 patients after radical prostatectomy | Records of all patients admitted to the hospital from 1990-1996 before and after implementation of clinical care pathway; an average numbers of procedures performed annually by surgeons | Average hospital stay | ANOVA test, Chi square test | Not reported | Surgeon volume (% procedures) | Average hospital stay (nights)
1990-1996 | Single hospital study | | | Goodness-of-fit: Not reported | | High (41) - 53/year | 7.2
Descriptive baseline analysis of planned implementation of clinical pathway | 24 urologists | | | Discrimination: Not reported | | Low (59) - 7/year | 8.2
Evidence: III
Quality: 0.46
Leibman, 1998 ^136^ | 856 patients after radical retropubic prostatectomy | Records of all patients admitted to the hospital from 1990-1996 before and after implementation of clinical care pathway; an average number of procedures performed annually by surgeons | Average hospital length of stay | T-test to compare outcomes between groups | Not reported | Annual surgeon volume (% procedures) | LOS in days, Median
1994-1997 | Single hospital study; 24 surgeons | | Average hospital charges | Goodness-of-fit: No | | <12/year (21) | 5.8
Descriptive baseline analysis of planned implementation of clinical pathway | | | | Discrimination: No | | >12/year (79) | 5.3
Evidence: III | | | | | | | Charges in 1994
Quality: 0.46 | | | | | | <12/year (21) | $11,798
| | | | | | >12/year (79) | $11,113
| | | | | | | Charges from 1994-1997
| | | | | | < 12/year (21) | $10,208
| | | | | | >12/year (79) | $9,388

Table C40 Sampling sources of studies that evaluated associations between providers' volumes (radical prostatectomy) and patients' outcomes

Source | Author | Time | Size | Hospital Volume | Surgeon Volume | Mortality | Morbidity | Urinary Complications | Long term Incontinence | LOS | Operational Quality
Single hospital | Hernandez ^135^ | 1996-2002 | 506 | | X | | | | | | X
Single hospital | Dash ^132^ | 1994-2000 | 1,123 | X | X | | X
Single hospital | Litwiller ^133^ | 1984-1994 | 428 | X | X | | | | | X
Single hospital | Leibman ^136^ | 1994-1998 | 856 | | X | | | | | X
Single hospital | Gheiler ^128^ | 1990-1994 | 1,129 | | X | | | | | X
SEER-Medicare | Bianco ^131^ | 1992-1996 | 5,238 | | X | X | X | X | X
SEER-Medicare* | Ellison ^125^ | 1990-2005 | 12,635 | X | | | X
SEER-Medicare* | Begg ^122^ | 1992-1996 | 11,522 | X | X | X | X | X | X
Quebec Healthcare Plan | Karakiewicz ^127^ | 1988-1996 | 4,997 | | X | X
Nationwide inpatient sample | Ellison ^121^ | 1989-1995 | 66,693 | X | | X | | | | X
Multihospital study | Imperato ^126^ | 1996 | 583 | X | | | | | | | X
Multihospital study | Gaylis ^129^ | 1990-1996 | 116 | Type | | X | X | X | | X
Multihospital study | Eastham ^134^ | 1983-2002 | 6,542 | | X | | | | | | X
Medicare | Yao ^123^ | 1991-1997 | 10,1604 | X | | X | X | | | X
Medicare | Wennberg ^124^ | 1974-1977 | 4,570 | X | | X
Medicare | Yuan ^130^ | 1984-1993 | 17,260 | Type | | X | | | | X
Medicare | Hu ^118^ | 1997-1998 | 2,292 | X | X | | X | X | | X

LOS = length of stay

* Studies used the same data base at the same period of time but followup was different

Table C41 Sampling sources of studies that evaluated associations between provider's locations and patient outcomes

Author | Source | Time | Incidence | Incidence of Localized Cancer | Mortality | Cancer Specific Mortality | Standardized Rate of Treatments | Probability of Treatments | Probability of PSA | Complications | LOS
Cooperberg ^112^ | CaPSURE* | 1989-2001 | | | | | | X
Cooperberg ^115^ | CaPSURE* | 1989-2001 | | | | | | X
Lu-Yao ^108^ | Medicare | 1990 | | | | | X | X
Bubolz ^114^ | Medicare | 1984-1989 | | | | | | X
Saigal ^116^ | Medicare | 1991-1996 | | | | | | X
Hu ^118^ | Medicare | 1997-1998 | | | | | | | | X | X
Litwin ^119^ | Medicare | 1991 | | | | | X
Brandeis ^120^ | Medicare | 1993-1996 | | | | | | X
Mushinski ^109^ | MetLife | 1994 | | | | | | | | | X
Mettlin ^110^ | National Cancer Database | 1992 | | | | | | X
Jemal ^105^ | NCHS | 1995-2000 | X | X | X | X
Jemal ^104^ | NCHS | 1970-1989 | | | | X
Lu-Yao ^102^ | SEER | 1983 | X | | | | X | X
Krupski ^111^ | SEER | 1995-1999 | | | | | | X
Lai ^113^ | SEER | 1983-1992 | | | X | X | | X
Escobedo ^106^ | SEER | 1989-1998 | X | X | | X | | X
Shaw ^137^ | SEER | 1991-1998 | | | | | | X
Kafadar ^103^ | State Cancer Control Map | 1953-1972 | | | | X
Wilt ^117^ | VAMC | 1986-1994 | | | X | | X | X
CDC ^138^ | CDC | 1999-2004 | X | | | X | | | X

LOS = length of stay

* Studies used the same database at the same period of time, the second study evaluated the association between provider's location in interaction with patient's health insurance

Table C42 Studies that evaluated association between other provider's factors (specialty, facility structure, awareness) and patient outcomes (no overlapping in samples detected)

Author | Source | Year | Provider's Factors | Screening | Treatment | Cost | Survival | Complication | Operation Quality | Satisfaction
Kim ^139^ | Survey | 2002 | Specialty | X
McNight ^140^ | Survey | 1996 | Specialty | X
Fowler ^141^ | Survey | 1998 | Specialty | X | X
Shay ^142^ | Survey | 2002 | Specialty | | X
Plawker ^143^ | Survey | 1997 | Specialty | X
Gee ^144^ | Survey | 1995 | Specialty | | X
Hanna ^145^ | Survey | 2002 | Specialty | | X
Salminen ^146^ | Survey | 2004 | Specialty | | X
McNaughton Collins ^147^ | Survey | 2002 | Specialty/location | X | X
Fowler ^148^ | Survey | 2000 | Specialty | | X
Kramolowsky ^149^ | Multi hospital | 1995 | Education | | | X
Kramolowsky ^150^ | Single hospital | 1995 | Education | | | X
Diamond ^151^ | The patterns of care study | 1990 | Facility structure | | | | X | X
Cazzaniga ^152^ | Survey | 1998 | Inter physician variability | | | | | | X
Van Poppel ^153^ | Survey | 2001 | Inter physician variability | | | | | X | X
Votron ^154^ | Survey | 2004 | Inter physician variability | | X
Maliski ^155^ | Single hospital | 2005 | Facility structure | | | | | X
Maliski ^156^ | IMPACT study | 2004 | Physician communication | | | | | X | | X

Table C43 Association between physician specialty and patient outcomes

Reference Design | Data Source Population | Analysis Risk Adjustment | Specialt | Outcomes | P Values
Kim, 2002 ^139^ | Members of the Academy of Family Physicians | Chi-square test | | Recommended PC screening for patient >50 years old
Internet-based survey | 381 primary care physicians in 3 states: | Logistic regression | | DRE
| 113 family physicians | Not reported | Family physician | 87% | <0.01
| 238 general internists | | General internist | 69%
| 11.76 years of practice | | | PSA screening
| | | Family physician | 67% | <0.01
| | | General internist | 40%
| | | | Not PC screening for patient >60 years old
| | | Family physician | 10% | 0.01
| | | General internist | 20%
| | | | Do not use age as a criteria
| | | Family physician | 51% | <0.01
| | | General internist | 33%
| | | | Recommendations for patients with PSA 4.1–10 ng/ml
| | | | Repeat PSA at 4–6 weeks
| | | Family physician | 40 | 0.06
| | | General internist | 29
| | | | Repeat PSA at 6–12 months
| | | Family physician | 13 | 0.93
| | | General internist | 14
| | | | Prostate ultrasound
| | | Family physician | 5 | 0.48
| | | General internist | 7
| | | | Referral to urologist
| | | Family physician | 42 | 0.15
| | | General internist | 50
| | | | Referral to radiation oncologist
| | | | Yes (all patients)
| | | Family physician | 10
| | | General internist | 14
| | | | Yes, poor surgical candidates
| | | Family physician | 9
| | | General internist | 10
| | | | By patient's request
| | | Family physician | 17
| | | General internist | 21
| | | | By urologist's request
| | | Family physician | 88
| | | General internist | 78
| | | | Use of alternative therapies for prevention and management of PC
| | | Family physician | 15
| | | General internist | 7
McNight, 1996 ^140^ | Board certified physicians in three states | Chi-square test | | Screening practices
Survey | 231 urologists and 205 family physicians | Not reported | | DRE
| Urologists: 99% males; | | Urologist | 99% | 0.14
| mean age 50 years | | Primary care physicians | 98%
| city of practice >100,000 - 55% | | | Age at initial DRE (mean)
| Primary care physicians: 89% males; | | Urologist | 45 | <0.01
| mean age 46 years; | | Primary care physicians | 43
| city of practice >100,000 - 28% | | | Median Interval for DRE (months)
| | | Urologist | 12
| | | Primary care physicians | 12
| | | | PSA
| | | Urologist | 98% | <0.01
| | | Primary care physicians | 87%
| | | | Age at initial PSA
| | | Urologist | 49
| | | Primary care physicians | 49
| | | | Median Interval for PSA (months)
| | | Urologist | 12
| | | Primary care physicians | 12
| | | | Single best screening tool
| | | Urologist | 69% PSA
| | | Primary care physicians | 59% DRE
| | | | Screening for asymptomatic patients <age 50 with negative family history
| | | Urologist | 14% | <0.01
| | | Primary care physicians | 29%
| | | | Screening for patients age <40 with a positive family history
| | | Urologist | 2% | <0.01
| | | Primary care physicians | 19%
| | | | Strategy in positive tests
| | | Urologist | 66% biopsy
| | | Primary care physicians | 55% referral
| | | | Screening cessation
| | | Urologist | 61% | <0.01
| | | Primary care physicians | 14%
| | | | Age for screening cessation
| | | Urologist | 79
| | | Primary care physicians | 79
Fowler, 1998 ^141^ | Random sample of the American Medical Association Registry of Physicians | Chi-square test | | Use of PSA almost always for patients at age
Survey | 444 primary care physicians | Not reported | | 40–49 years
| 394 urologists | | Urologists | 33%
| Urologists: 99% males | | Primary care physicians | 19% | Not significant
| More than 90% if time devoted to clinical practice - 88% | | | 50–59 years
| Solo practice - 31%; | | Urologists | 97%
| Single specialty group - 53%; | | Primary care physicians | 55% | <0.05
| Multi specialty group - 16% | | | 60–69 years
| Primary care physicians: 84% males | | Urologists | 98%
| More than 90% if time devoted to clinical practice - 88% | | Primary care physicians | 66% | Not significant
| Solo practice - 35%; | | | 70–74 years
| Single specialty group - 42%; | | Urologists | 88%
| Multi specialty group - 23% | | Primary care physicians | 65% | Not significant
| | | | 75–79 years
| | | Urologists | 50%
| | | Primary care physicians | 58% | Not significant
| | | | 80+ years
| | | Urologists | 25%
| | | Primary care physicians | 53% | Not significant
| | | | Referral to urologists for a biopsy if PSA 4–10ng/ml
| | | | 50–59 years
| | | Urologists | 81%
| | | Primary care physicians | 69%
| | | | 60–69 years
| | | Urologists | 66%
| | | Primary care physicians | 67%
| | | | 70–74 years
| | | Urologists | 33%
| | | Primary care physicians | 58%
| | | | 75–79 years
| | | Urologists | 13%
| | | Primary care physicians | 52%
| | | | 80+ years
| | | Urologists | 3%
| | | Primary care physicians | 45%
| | | | Perception which therapy is better
| | | | Patients life expectancy >10 years
| | | | Radical PE
| | | Urologist | 98%
| | | Primary care physicians | 73%
| | | | External bean radiotherapy
| | | Urologist | 53%
| | | Primary care physicians | 67%
| | | | Patients life expectancy <10 years
| | | | Radical PE
| | | Urologist | 13%
| | | Primary care physicians | 13%
| | | | External beam radiotherapy
| | | Urologist | 36%
| | | Primary care physicians | 48%
| | | | Watchful waiting
| | | | Patients life expectancy <10 years
| | | Urologist | Definitely 13%; probably 55%
| | | Primary care physicians | Definitely 17%; probably 52%
| | | | Patients life expectancy >10 years
| | | Urologist | Definitely 1%; probably 2%
| | | Primary care physicians | Definitely 2%; probably 11%
Shay, 2000 ^142^ | 61 urologists after residency in single medical center | Descriptive statistic | Training in RPP | Use of RPP
Survey | Urologists practice: | Chi-square test Not reported | Yes (86%) | 41%
| Private group 66% | | No | 13% | 0.12
| Solo 20% | | Intensity of training
| Academic 7% | | >10 RPP in residency | 53%
| | | <10 RPP | 21% | 0.03
| | | | Reasons of not using RPP
| | | Training in RPP | Length of operation
| | | Yes (86%) | 4%
| | | No | 25% | 0.03
| | | | Difficulty of operation
| | | Yes (86%) | 20%
| | | No | 25% | 0.75
| | | | Partner preference
| | | Yes (86%) | 28%
| | | No | 12.50% | 0.35
| | | | Concerns to preserve potency
| | | Yes (86%) | 12
| | | No | 0 | 0.3
| | | | Inability to obtain lymph nodes
| | | Yes (86%) | 12%
| | | No | 0% | 0.3
| | | | Use of RPP
| | | Practice
| | | Private group 66% | 29%
| | | Solo 20% | 50%
| | | Academic 7% | 100% | 0.11
Fowler, 2000 ^148^ | Random sample of physicians in the United States listed as urologists and radiation oncologists in the American Medical Association Registry of Physicians and practicing at least 20 hours per week | Chi-square test | | Recommending routine PSA for men in average risk of prostate cancer
Survey | 504 urologists (response rate 64) | Not reported | | Patient age 40–49 years
| 559 radiation oncologists (response rate 76) | | Radiation oncologists | 24%
| | | Urologists | 25% | 0.93
| | | | 50–59 years
| | | Radiation oncologists | 90%
| | | Urologists | 96% | <0.01
| | | | 60–69 years
| | | Radiation oncologists | 98
| | | Urologists | 98 | 0.92
| | | | 70–74 years
| | | Radiation oncologists | 95%
| | | Urologists | 89% | <0.01
| | | | 75–79 years
| | | Radiation oncologists | 77%
| | | Urologists | 51% | <0.01
| | | | >80 years
| | | Radiation oncologists | 43%
| | | Urologists | 16% | <0.01
| | | | Survival benefits of different treatments
| | | | Brachytherapy
| | | | Baseline life expectancy <10 years
| | | Urologists | 38%
| | | Radiation oncologists | 35%
| | | | Baseline life expectancy >10 years
| | | Urologists | 66%
| | | Radiation oncologists | 82%
| | | | External beam radiation
| | | | Baseline life expectancy <10 years
| | | Urologists | 46%
| | | Radiation oncologists | 39%
| | | | Baseline life expectancy >10 years
| | | Urologists | 67%
| | | Radiation oncologists | 86%
| | | | Radical prostatectomy
| | | | Baseline life expectancy <10 years
| | | Urologists | 14%
| | | Radiation oncologists | 22%
| | | | Baseline life expectancy >10 years
| | | Urologists | 98%
| | | Radiation oncologists | 79%
| | | | Comparison of treatments benefits in patients with clinically localized PC and life expectancy <10 years
| | | | Radiation is better compared with prostatectomy
| | | Radiation oncologists | 10%
| | | Urologists | 9% | <0.01
| | | | Both therapy are the same
| | | Radiation oncologists | 68%
| | | Urologists | 40% | <0.01
| | | | Prostatectomy better
| | | Radiation oncologists | 2%
| | | Urologists | 17% | <0.01
| | | | Neither offer survival benefit
| | | Radiation oncologists | 19%
| | | Urologists | 32% | <0.01
| | | | External beam radiation is better than radical prostatectomy
| | | Radiation oncologists | 3%
| | | Urologists | 0% | <0.01
| | | | Both therapy are the same
| | | Radiation oncologists | 72%
| | | Urologists | 6% | <0.01
| | | | Prostatectomy better
| | | Radiation oncologists | 20%
| | | Urologists | 93% | <0.01
| | | | Neither offer survival benefit
| | | Radiation oncologists | 3%
| | | Urologists | 0% | <0.01
| | | | Brachytherapy is better than External beam radiation
| | | Radiation oncologists | 21%
| | | Urologists | 30% | <0.01
| | | | Both the same
| | | Radiation oncologists | 53%
| | | Urologists | 33% | <0.01
| | | | Neither offer survival benefit
| | | Radiation oncologists | 2%
| | | Urologists | 4% | <0.01
| | | | Perceived rates of use the treatments for PC
| | | | Radical prostatectomy overused
| | | Radiation oncologists | 82%
| | | Urologists | 34% | <0.01
| | | | Radical prostatectomy underused
| | | Radiation oncologists | 16%
| | | Urologists | 51% | <0.01
| | | | Use at about the right rate
| | | Radiation oncologists | 16%
| | | Urologists | 51% | <0.01
| | | | External beam radiation overused
| | | Radiation oncologists | 13%
| | | Urologists | 37% | <0.01
| | | | External beam radiation underused
| | | Radiation oncologists | 50%
| | | Urologists | 5% | <0.01
| | | | Use at about the right rate
| | | Radiation oncologists | 35%
| | | Urologists | 51% | <0.01
| | | | Brachytherapy overused
| | | Radiation oncologists | 26%
| | | Urologists | 30% | <0.01
| | | | Brachytherapy underused
| | | Radiation oncologists | 44%
| | | Urologists | 27% | <0.01
| | | | Use at about the right rate
| | | Radiation oncologists | 20%
| | | Urologists | 21% | <0.01
Vorton, 2004 ^154^ | 676 participating in national meetings general practitioners | Logistic regression | | Referring elderly patient with PC to a specialist
Survey | 546 completed questionnaire | Patient age, sex, comorbidity, physician characteristics | Physician sex | Odds ratio 0.44 | 0.03
| | | Males | 1
| | | Females | Non curative approach (hormone therapy and watchful waiting)
| | | Ages physicians vs. young | Odds ratio 1.1 (1.02–1.09) | <0.01
| | | Physician sex | Not significant
| | | Physician place to work | Not significant
| | | | Treatments of prostate cancer in elderly patients
| | | | Surgical treatment vs. Hormone therapy
| | | Physician age | Not significant
| | | Physician sex | Not significant
| | | Physician place to work | Not significant

Table C44 Variability in management of prostate cancer (compared with recommended guidelines)

Reference/Design | Data Source Population | Analysis Risk Adjustment | Management Options | Frequency of Practice | | | P Values
Hanna, 2002 ^145^ | Oncology departments treated urological malignancy | Not reported | Treatment of localized | Local PC, patient age 55
Survey | 169 clinical oncologists | | RP | 52%
| | | External beam radiotherapy | 19%
| | | Brachy therapy | 7%
| | | Hormone therapy
| | | Medical | 0%
| | | Surgical | 0%
| | | Surveillance only | 5%
| | | Surveillance + hormone | 0%
| | | | Bladder outlet obstruction
| | | RP | 15%
| | | External beam radiotherapy | 68%
| | | | Poorly differentiated local tumor
| | | RP | 9%
| | | External beam radiotherapy | 77%
| | | Brachytherapy | 1
| | | Hormone therapy | 3
| | | medical
McNaughton Collins, 2002 ^147^ | The American Medical Association Master List of Physicians | Chi-square test | | PSA screening for men 75–79 years
Survey | A random sample of radiation oncologists (559) and urologists (504) working in clinical practice for at least 20 hours weekly | Not reported | Radiation oncologists | 92% | | | <0.01
| | | Urologists | 68–81%
| | | Radiation oncologists | Northeast | Midwest
| | | Brachytherapy for 20% of patients last year | 35% | 28% | | <0.01
| | | Brachytherapy offers a survival benefit for patients with >10 year life expectancy | 87% | 2% | | 0.6
| | | Brachytherapy has survival value for patients with <10 year life expectancy | 29% | 28% | | 0.05
| | | Urologists
| | | Brachytherapy for 20% of patients last year | 40% | 17% | | <0.01
| | | Brachytherapy offers a survival benefit for patients with >10 year life expectancy | 71% | 0% | | 0.4
| | | Brachytherapy has survival value for patients with <10 year life expectancy | 40% | 36% | | <0.01
| | | | West | South
| | | Brachytherapy for 20% of patients last year | 28% | 26%
| | | Brachytherapy offers a survival benefit for patients with >10 year life expectancy | 0% | 79%
| | | Brachytherapy has survival value for patients with <10 year life expectancy | 38% | 35%
| | | Urologists
| | | Brachytherapy for 20% of patients last year | 24% | 28%
| | | Brachytherapy offers a survival benefit for patients with >10 year life expectancy | 63% | 69%
| | | Brachytherapy has survival value for patients with <10 year life expectancy | 23% | 43%
Plawker, 1997 ^143^ | The American Urological Association (AUA) data | Chi-square | Ultrasound use for all biopsy | 95.8%
Survey | 1,500 randomly selected urologists | Not reported | Sextant biopsy | 79.5%
| | | Biopsy of transition zone | 46.7%
| | | Use of age specific PSA in patients with normal exams | 69.7%
| | | Use PSA density when PSA >4 ngg/dL/dl | 40.3%
| | | Radiological staging | CT | MRI | Bone scan
| | | All patients regardless of PSA | 28.6 | 3.5 | 52.4
| | | PSA >10 ng/dL | 12.6 | 1.7 | 29.5
| | | PSA >20 ng/dL | 12.4 | 4.2 | 11.9
| | | PSA >30 ng/dL | 4.9 | 0.9 | 0.3
| | | PSA >50 ng/dL | 2.5 | 1.3 | 0.2
Gee, 1995 ^144^ | The American Urological Association data | Not reported | Radiological staging In patients >70 years with PC and PSA <10 ng/dL
Survey | A random sample of 514 urologists who had completed a urological residency, practiced urology at least 20 hours a week in 1994, and practiced urology in 1993 | | Bone scan | 72%
| | | CT | 40%
| | | Cystoscopy | 33%
| | | IVP | 25%
| | | Laparoscopic lymph node dissection | 6%
| | | Pelvic MRI | 5%
| | | Rectal coil MRI | 4%
| | | | Treatment of PC in patients <70 years
| | | Radical prostatectomy | 95%
| | | External beam radiation | 36%
| | | Observation | 10%
| | | Hormone therapy | 7%
| | | Brachytherapy | 5%
| | | Cryosurgery | 2%
| | | | Treatment of PC in patients >70 years
| | | Radical prostatectomy | 48%
| | | External beam radiation | 74%
| | | Observation | 38%
| | | Hormone therapy | 17%
| | | Brachy therapy | 10%
| | | Cryosurgery | 4%
Shahinian, 2006 ^157^ | 61,717 men with incident prostate cancer (1/1992–12/1999) identified in the SEER-Medicare database. | Chi-square statistics and logistic regression models adjusted for patient age, comorbidity, ethnicity, socioeconomic status, SEER region, and year of diagnosis and tumor stage and grade. | | The % of the total variance in the use of androgen deprivation therapy attributable to the urologist
Retrospective cohort | 1,802 urologists providing care within 1 year of cancer diagnosis identified by the Unique Physician Identifier numbers on Medicare physician claims. | | The evidence-based group: radiation therapy for T3 tumors (regardless of grade) or T2 tumors with high-grade histology (Gleason score of 8–10) | 25.38
| Rate of ADT in evidence-based group: | | Uncertain benefit group | 22.68
| Mean - 71.3% | | All patients
| 4.6% of urologists >71.3% | | 1992-1999 | 16
| 11.8% of urologists <71.3% | | 1992-1996 | 15.6
| Rate of ADT in uncertain-benefit group: | | 1997-1999 | 22.56
| Mean - 36.% | | | % of variance in the use of ADT attributable to stage and grade: 6.63
| 15.2% of urologists >36% | | Evidence-based group | 5.34
| 8.4% of urologists <36% | | Uncertain benefit group
| | | All patients | 13.06
| | | 1992-1999 | 15.4
| | | 1992-1996 | 9.71
| | | 1997-1999 | To patient characteristics
| | | | 7.27
| | | Evidence-based group
| | | Uncertain benefit group | 4.99
| | | All patients
| | | 1992-1999 | 8.99
| | | 1992-1996 | 6.58
| | | 1997-1999 | 4.29

Table C45 Association between provider characteristics and patient outcomes

Reference/Design | Data Source Population | Analysis Risk Adjustment | Outcomes | Provider Characteristics | | | P Values
Kramolowsky, 1995 ^150^ | 14 board certified urologists 34 to 62 years old performed 256 consecutive radical retropubic prostatectomies at a 401-bed, community, not for profit hospital | Student's t test and chi-square test | | Time 1 (baseline) | Time 2 (after intervention)
Non randomized intervention: physician education on factors that may decrease charges | | Not reported | Total charge | $17134 ± 653 | $13,826 ± 260 | | <0.01
| | | Length of stay (days) | 7.8 ± 0.3 | 5.8 ± 0.2 | | <0.01
| | | Charges/day | $2229 ± 54 | $2,622 ± 70 | | <0.01
| | | Operation time (minutes) | 193 ± 5 | 154 ± 4
| | | Estimated blood loss | 1053 ± 67 | 915 ± 50
| | | Units transfused | 2.5 ± 0.2 | 1.7 ± 0.1
| | | Central arterial lines | 43% | 21%
| | | ICU used | 51% | 19%
| | | Epidural used | 68% | 91%
Kramolowsky, 1995 ^149^ | 625 males diagnosed with carcinoma of the prostate gland undergoing radical prostatectomy by one of 20 urologists at 5 community hospitals in VA 1991-1993 | Student's t test and chi-square test | | Time 1 (baseline) | Time 2 (after intervention)
Non randomized intervention: physician education on factors that may decrease charges | | Not reported | Total charge | $17,201 ± 943 | $15,931 ± 420 | | <0.01
| | | | $16,798 ± 683 | $15,286 ± 506
| | | | $18,601 ± 694 | $14,084 ± 621 | | <0.01
| | | Length of stay (days) | 7.7 ± 0.2 | 5.6 ± 0.1
| | | Charges/day | $2,314 ± 37 | $2,846 ± 40 | | <0.01
Maliski, 2004 ^156^ | 286 California patients with biopsy-proven prostate cancer, uninsured, with household income less than 200% of the Federal Poverty Level. 233 (81%) consented and completed the surveys. All were participants in the Improving Access, Counseling, and Treatment for Californians with Prostate Cancer (IMPACT), a state-funded program providing free prostate cancer treatment to indigent men | Multivariate logistic regression | Patient outcomes: | High self-efficacy | Low self efficacy
Survey | | Patient age and treatment | SF-12
| | Scales: Perceived Efficacy in Patient-Physician Interactions (PEPPI) to assess a person's confidence in his ability to communicate with his physician; prostate-specific HRQOL; the Medical Outcomes Study five-item Mental Health Index (MHI-5) | Physical function | 64.7 ± 32.9 | 53.8 ± 35.8 | | 0.03
| | | Role-physical | 62.4 ± 33.0 | 57.0 ± 33.1 | | 0.30
| | | Mental health | 47.5 ± 12.6 | 44.3 ± 13.6 | | 0.12
| | | Role-emotional | 73.3 ± 27.2 | 63.0 ± 27.8 | | 0.02
| | | Social function | 72.7 ± 31.7 | 52.9 ± 35.2 | | <0.01
| | | Vitality | 53.1 ± 28.2 | 45.8 ± 28.1 | | 0.10
| | | Bodily pain | 69.9 ± 30.2 | 62.0 ± 29.1 | | 0.10
| | | General health | 51.6 ± 29.7 | 44.6 ± 24.5 | | 0.12
| | | UCLA PCI
| | | Urinary function | 74.5 ± 28.0 | 61.9 ± 32.5 | | 0.01
| | | Urinary bother | 73.0 ± 34.0 | 56.6 ± 34.4 | | <0.01
| | | Bowel function | 77.4 ± 24.7 | 65.4 ± 24.2 | | <0.01
| | | Bowel bother | 75.4 ± 31.7 | 63.0 ± 27.3 | | 0.01
| | | Sexual function | 34.5 ± 31.5 | 23.4 ± 26.8 | | 0.02
| | | Sexual bother | 35.6 ± 38.9 | 23.0 ± 31.6 | | 0.04
| | | Symptom distress scale | 19.2 ± 6 .6 | 24.7 ± 7.9 | | <0.01
| | | Satisfaction with care
| | | Satisfaction with healthcare received | 1.2 ± 0.7 | 2.1 ± 1.5 | | <0.01
| | | Some things could have been better | 3.1 ± 2.1 | 3.6 ± 1.9 | | 0.10
| | | Have not had as much contact as should have | 3.3 ± 2.2 | 3.8 ± 1.8 | | 0.11
| | | Amount of time adequate | 4.2 ± 2.1 | 3.6 ± 1.9 | | 0.09
| | | Could have listened more carefully | 5.4 ± 1.2 | 4.6 ± 1.7 | | <0.01
| | | Have explained completely | 1.2 ± 0.9 | 1.9 ± 1.4 | | <0.01
| | | Have treated me with respect | 4.3 ± 2.2 | 4.1 ± 1.8 | | 0.41
| | | Could have been kinder | 5.7 ± 0.8 | 4.1 ± 1.8 | | <0.01
| | | Have extraordinary confidence in provider | 1.6 ± 1.2 | 2.7 ± 1.6 | | <0.00
Diamond, 1991 ^151^ | The Patterns of Care Study (PCS) of all facilities in the U.S. where 770 males were treated for PC in 1978 | Logistic regression | | Facility structure | Annual number of new patients
Facility survey | | Not reported | | per physician | per physician
| | | In hospital mortality | Not significant | Positive | | <0.01
| | | Major complication | Positive | Not significant | | <0.01
| | | Local Recurrence | Not significant | Not significant
| | | Any recurrence | Not significant | Not significant
Maliski, 2005 ^155^ | 149 males with a biopsy positive for prostate cancer in a large tertiary medical center, an urban Veterans Affairs medical center, and an urban public hospital. | Multivariate logistic regression | Patient fatigue | Facility
Secondary analysis of prospective cohort the utilities study | Subjects were followed for 6 and 12 months to complete the UCLA Prostate Cancer Index (PCI) questionnaire to measure prostate-specific HRQOL | Patient age and treatment | | Public | Private
Survey | | | Fatigued | 67.83% | 32.14%
| | | Not fatigued | 35.29% | 64.71% | | <0.01
| | | Progression of fatigue | 53.49% | 46.51% | | 0.06
| | | | Odds ratio
| | | Progression >10 points in fatigue from baseline | 5.82 (1.78–19.07) | 1 (reference) | | <0.01
Greenwald, 1992 ^158^ | 264 males diagnosed with PC from 1980-1982, identified in the Cancer Surveillance System (CSS), a part of the SEER Program | Cox regression | Sample 1 | HMO members vs. fee for service
Prospective cohort with two overlapping samples | 1,000 consecutive cases of newly diagnosed prostatic cancer from the CSS | Patient age, income, education, treatment, cancer stage, HMO membership | Treatment received | Relative risk 95% CI
| | | Surgery | 0.26 | 0.11 | 0.58
| | | Radiation | 2.99 | 1.26 | 7.09
| | | Mortality | 0.334 | 0.196 | 0.734
| | | Sample 2
| | | Treatment received
| | | Surgery | 0.45 | 0.28 | 0.71
| | | Radiation | 4.08 | 2.49 | 6.69
| | | Mortality | 0.736 | 0.547 | 0.991
Potosky, 1999 ^159^ | 21,741 men age 65 and over diagnosed with prostate cancer between 1985 and the end of 1992 and followed through 1994 in 5 county San Francisco-Oakland metropolitan area, and 13-county Seattle-Puget Sound area participating in SEER Program | Logistic regression to estimate the odds ratios of receiving one of two treatments for men with nonmetastatic prostate cancer (local and regional stage) | Treatment received | California
Prospective cohort | | Patient age, race, education level, and clinical characteristics. | | HMO | Medicare
| | The Cox proportional hazards regression model was used to estimate the relative risk of overall and cause-specific 10-year mortality among HMO cases relative to those in the Medicare FFS setting. Patient age at diagnosis, race, stage, grade, comorbidity, and group educational status | Prostatectomy | 13.6% | 28.3%
| | | Radiation | 53.7% | 25.2%
| | | Conservative management | 31.3% | 41.3% | | <0.01
| | | | Seattle
| | | | HMO | Medicare
| | | Prostatectomy | 17.3% | 36.3%
| | | Radiation | 53.3% | 31.3% | | <0.01
| | | Conservative management | 27% | 29.3%
| | | | Relative risk HMO vs. Medicare
| | | All cause mortality | 1.01 (0.94–1.08)
| | | PC mortality | 1.25 (1.13–1.39)

Table C46 Association between physician characteristics and learning curves for treatment of prostate cancer

Reference Procedure | Physician Experience, Training | Cases/Curves | Operative Time (hours) | % Open Surgery | % Complications | Blood Loss (ml) | % Transfusions | LOS (days) | % Positive Margins | Catheterization (Days) | % Continence | % Potency
Ahlering, 2003 ^160^ | 1 fellowship trained urological oncologist; 1-day da Vinci LRP course + 2 cadaveric robotic LRP | 45/12 | 3.45 | 0 | 13.3 | 145 | 2.2 | 1.6 | 35.5 | 2.2% in 1 week | 1 week-33% pad free | Not reported
Robot assisted LRP (June 2002–March 2003)
Arai, 2003 ^161^ | 6 centers | 148 | 6.7 | 10.8 | 37.2 | 856 | 6 | Not reported | Not reported | Removed in 1 week in 49.3% of cases | Not reported | Not reported
LRP (December 1999 and September 2001) | Several surgeons with no previois experience on LRP
Baumert, 2004 ^162^ | 1 surgeon | 50 | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | 62.5* | Not reported | Not reported | Not reported
LRP (December 2000–April 2002) | 30 laparoscopic procedures, assisting in 20 LRP | 50 | | | | | | | 11.1*
| | Total | | | | | | | 12.8-T2
| | 100/50 | | | | | | | 31.8-T3
Cathelineau, 2004 ^40^ | 1 surgeon with >400 Transperitoneal LRP | 200
A Transperitoneal and; B extraperitoneal LRP (2002) | 1 surgeon with >80 Transperitoneal LRP | A. 100 | 2.8 | | 10 | 360 | 4 | 5.8 | 15
| | B. 100 | 2.7 | | 9 | 375 | 3 | 6.1 | 21
Dahl, 2003 ^163^ | No previous experience | 70 | 4.6 | | 20 | 449 | | | 11.4 | | At 3 months, 85% used 0–1 pad/day
LRP (May 2000 to May 2001) | | 1–10 | 6.4 | 1.4 | | 811 | 5.7 | 2.5
| | 11–70 | 4.6 | | | 295
Eden, 2004 ^164^ | 1 surgeon, unknown experience | 200 | | | | | | | | Days | Pad free (3m) | Erection (3m)
Transperitoneal laparoscopic radical prostatectomy (TLRP) and extraperitoneal approach (ELRP) | | TLRP | 4.0* | 0.5 | 4 | 310 | 1 | 3.8* | 16 | 11.3 | 60 | 10
| | ELRP | 3.2* | 0 | 2 | 201.5 | 0 | 2.6* | 16 | 10.1 | 70 | 60
| | 1–100
| | TLRP | | 0 | 2 | 320 | 0 | 3.5 | 14 | 10
| | ELRP | | 0 | | 246.2 | 0 | 2.5 | 10 | 10
| | 150–200
| | TLRP | 3.6 | | | | | | | | 56 | 20
| | ELRP | 3.1 | | | | | | | | 80 | 70
El-Feel, 2003 ^165,^ ^166^ | A 2 surgeons (>100 cases); B 2 junior surgeons (<30 cases) | 100 randomly assigned among 4 surgeons
LRP (November 2001 to May 2002) | | LRP | 3.6
| | LRP with | 4.9
| | robot | 3
| | A. LRP | 4.9
| | LRP/robot
| | B. LRP | 4.8
| | LRP+ nerve sparing
| | A. | 3*
| | B. | 4.1*
| | LPR+ pelvic lymphadenectomy
| | A. | 3.7*
| | B. | 5.4*
| | LPR+ sural nerve grafting
| | A. | 4.6*
| | B. | 7.7*
El-Feel, 2003 ^165^ | A 2 surgeons (>100 cases); B 2 junior surgeons (<30 cases) | 100 randomly assigned among 4 surgeons
(November 2001 to May 2002) | | A. | 3.6* | | | | | | 19*
| | B. | 5.8* | | | | | | 34*
| | | | | | | | | Adjusted OR 2 (Not significant)
Fabrizio, 2003 ^167^ | A 12 cases - the mentor (>200 LRP) with assisting trainee; B 18 cases - the trainee with assisting mentor; C 30 cases - the trainee alone with assisting urological residents | 30
Transperitoneal LPR (March 2001–September 2001) | | A. | 4.1 | | | 150 | | 3 | 16 | 13
| | B. | 4.3 | | | 250 | 5.6 | 3 | 22 | 11
| | C. | 5.2 | | | 250 | | 3 | 39 | 9
Freder, 2005 ^168^ | A 1 surgeon (600 cases open retropubic RP and laparoscopy); B 1 surgeon (150 cases open retropubic RP and laparoscopy); C 1 surgeon (150 cases in laparoscopis).; D fellows in laparoscopic program | 1,000 | | | | | | | | <14 days
LPR | | A.
| | 1–50 | 5.5* | | 16 | | | | 4.3 | 66*
| | 51–100 | 5.0* | | 8 | | | | 0 | 92*
| | 101–150 | 3.3* | | 12 | | | | 10.3 | 88*
| | B.
| | 1–50 | 4.8* | | 12 | | | | 0 | 70*
| | 51–100 | 3.9* | | 16 | | | | 12.5 | 66*
| | 101–150 | 3.5) | | 4 | | | | 8.5 | 68*
| | C.
| | 1–50 | 4.5* | | 20 | | | | 9.3 | 70*
| | 51–100 | 3.9* | | 36 | | | | 0 | 64*
| | 101–150 | 3.9* | | 0 | | | | 6.3 | 84*
| | D.
| | 1–50 | 4.1 | | 4 | | | | 15.3 | 40*
| | 51–100 | | | 4 | | | | NA
| | 101–150 | | | 0
Ghavamian, 2004 ^169^ | 1 surgeon with fellowship in urologic oncology with laparoscopic experience | 60
LPR transperitoneal LRP and extraperitoneal LRP (May 2001–Spetember 2002) | | 1–10 | 6.9* | | 80 | 316
| | 11–20 | 4.7 | | 40 | 398
| | 21–30 | 4.1 | | 30 | 252
| | 31–40 | 3.7 | | 30 | 291
| | 41–60 | 3.3 | | 5 | 277
Hoznek, 2001 ^170^ | 1 surgeon with unknown experience | 134
LPR (May 1998–December 2000) | | 1–10 | 8.1 | | | | | 9.1
| | 11–20 | 7.8 | | | | | 5.5
| | 21–40 | 5.1 | | | | | 7.3
| | 41–60 | 4.2 | | | | | 4.8
| | 61–80 | 3.9 | | | | | 6.5
| | 81–100 | 4.0 | | | | | 6.8
| | 101–120 | 4.8 | | | | | 5.8
| | 121–134 | 4.5 | | | | | 5.6
Keyes, 2006 ^171^ | Seven oncologists with >20 procedures experience | 805 | | | Acute urinary retention
Prostate brachytherapy (July 1998–Novemebr 2002) | | 1–200 cases | | | 1
| | 201–400 | | | 1.2 (0.7–1.9)
| | 401–600 | | | 0.5 (0.3–0.9)
| | 601–805 | | | 0.3 (0.2–0.7)
| | | | | Prolonged AUR
| | 1–200 cases | | | 1
| | 201–400 | | | 0.9 (0.4–1.9)
| | 401–600 | | | 0.4 (0.2–1)
| | 601–805 | | | 0.4 (0.1–0.9)
Rassweiler, 2003 ^47^ | 2 surgeons performed both operations | 1–219 | 4.8 | 3.7 | 6.4 | 1,100 | 30.1 | 12 | | 12.8% (7) | 9.7
LPR vs. radical prostatectomy (March 1999–September 2002) | | 220–439 | 3.6* | 0.5 | 4.1* | 800* | 9.6* | 11 | | 13.2% (7) | 8.3
Stolzenburg, 2005 ^172^ | 4 trainees in mentor-initiated program | Camera holders/assist
Endoscopic extraperitoneal radical prostatectomy | | 4/140 | | | 4 | | 4 | | 14 | 7.6 (4; 20)
| | 62/15 | | | 0 | | 0 | | 12 | None
| | 20/45 | | | 0 | | 0 | | 15 | 5.9 (5; 10)
| | 5/18 | | | 0 | | 0 | | 7 | 5.4 (5; 7)
| | Mentor | | | 0 | | 0 | | 12 | 6.2 (4; 14)

* Significant difference at 95% confidence interval

Table C47 Distribution of urologists and radiation oncologists in the United States*

| Total Number of Urologists | | Total Number of Radiation Oncologists
| Mean | Standard Error | Mean | Standard Error
East North | 465 | 39 | 207 | 16
East South | 207 | 50 | 68 | 20
Middle Atlantic | 878 | 48 | 336 | 19
Mountain | 295 | 31 | 118 | 12
New England | 351 | 34 | 177 | 14
Pacific | 460 | 39 | 199 | 16
South Atlantic | 492 | 31 | 177 | 12
West North | 154 | 35 | 64 | 14
West South | 396 | 43 | 139 | 17
Midwest | 298 | 28 | 3,903 | 39
Northeast | 534 | 30 | 233 | 12
South | 418 | 24 | 148 | 10
West | 364 | 26 | 151 | 10
USA | 10,026 | 102 | 3,903 | 41

* An average of absolute number of physicians identified themselves as urologists in the U.S. were obtained from the surveys conducted by the American Medical Association from 1999-2005 ^173^ – ^176^

Table C48 Significant geographic differences in total numbers of urologists

Regions | | Mean Differences in Total Number | Standard Error | p
East North | East South | 258 | 64 | <0.01
East North | Middle Atlantic | -414 | 62 | <0.01
East North | Mountain | 169 | 50 | <0.01
East North | New England | 114 | 52 | 0.03
East North | West North | 311 | 52 | <0.01
East South | Middle Atlantic | -671 | 70 | <0.01
East South | New England | -144 | 61 | 0.02
East South | Pacific | -253 | 64 | <0.01
East South | South Atlantic | -285 | 59 | <0.01
East South | West South | -189 | 66 | <0.01
Middle Atlantic | Mountain | 583 | 57 | <0.01
Middle Atlantic | New England | 527 | 59 | <0.01
Middle Atlantic | Pacific | 418 | 62 | <0.01
Middle Atlantic | South Atlantic | 387 | 57 | <0.01
Middle Atlantic | West North | 725 | 60 | <0.01
Middle Atlantic | West South | 482 | 64 | <0.01
Mountain | Pacific | -165 | 50 | <0.01
Mountain | South Atlantic | -196 | 44 | <0.01
Mountain | West North | 142 | 47 | <0.01
New England | Pacific | -109 | 52 | 0.04
New England | South Atlantic | -141 | 46 | <0.01
New England | West North | 197 | 49 | <0.01
Pacific | West North | 306 | 52 | <0.01
South Atlantic | West North | 338 | 47 | <0.01
West North | West South | -242 | 55 | <0.01
Midwest-Northeast | Northeast | -236 | 41 | <0.01
Midwest-South | South | -120 | 37 | <0.01
Northeast-South | South | 116 | 38 | <0.01
Northeast-West | West | 169 | 39 | <0.01

Table C49 Significant geographic differences in total numbers of radiation oncologists

Regions | Mean Differences in Total Number | Standard Error | p
East North - East South | 139 | 25 | <0.01
East North - Middle Atlantic | -129 | 25 | <0.01
East North - Mountain | 89 | 20 | <0.01
East North - West North | 143 | 21 | <0.01
East North - West South | 68 | 23 | <0.01
East South - Middle Atlantic | -268 | 28 | <0.01
East South - Mountain | -50 | 24 | 0.04
East South - New England | -109 | 24 | <0.01
East South - Pacific | -130 | 25 | <0.01
East South - South Atlantic | -108 | 24 | <0.01
East South - West South | -71 | 26 | 0.01
Middle Atlantic - Mountain | 218 | 23 | <0.01
Middle Atlantic - New England | 159 | 24 | <0.01
Middle Atlantic - Pacific | 137 | 25 | <0.01
Middle Atlantic - South Atlantic | 160 | 23 | <0.01
Middle Atlantic - West North | 272 | 24 | <0.01
Middle Atlantic - West South | 197 | 26 | <0.01
Mountain - New England | -59 | 18 | <0.01
Mountain - Pacific | -81 | 20 | <0.01
Mountain - South Atlantic | -59 | 18 | <0.01
Mountain - West North | 54 | 19 | <0.01
New England - West North | 113 | 20 | <0.01
Pacific - West North | 134 | 21 | <0.01
Pacific - West South | 60 | 23 | 0.01
South Atlantic - West North | 112 | 19 | <0.01
West North - West South | -75 | 22 | <0.01
Midwest - Northeast | -103 | 16 | <0.01
Northeast - South | 85 | 15 | <0.01
Northeast - West | 81 | 16 | <0.01

Table C50 Significant geographic differences in % of males >40 years of age who had PSA test during last 2 years

Regions | | Differences in % of PSA Testing | | | P Value
| | Mean % | Lower 95% CI | Upper 95% CI
East North | Pacific | 4.07 | 0.49 | 7.65 | 0.03
East North | South Atlantic | -5.77 | -9.02 | -2.52 | <0.01
East South | Pacific | 6.16 | 2.40 | 9.92 | <0.01
East South | South Atlantic | -3.67 | -7.12 | -0.23 | 0.04
Mountain | New England | 3.57 | 0.36 | 6.79 | 0.03
Mountain | Pacific | 6.14 | 2.77 | 9.50 | <0.01
Mountain | South Atlantic | -3.70 | -6.71 | -0.69 | 0.02
New England | South Atlantic | -7.27 | -10.72 | -3.83 | <0.01
Pacific | South Atlantic | -9.84 | -13.42 | -6.26 | <0.01
Pacific | West North | -3.90 | -7.48 | -0.33 | 0.03
Pacific | West South | -6.18 | -9.94 | -2.42 | <0.01
South Atlantic | West North | 5.93 | 2.69 | 9.18 | <0.01
South Atlantic | West South | 3.66 | 0.21 | 7.10 | 0.04
Midwest | South | -3.60 | -5.97 | -1.22 | <0.01
Northeast | South | -4.39 | -7.37 | -1.42 | <0.01
South | West | 3.49 | 1.14 | 5.84 | <0.01

Table C51 Significant geographic differences in % of males who ever had PSA test

Regions | | Differences in % of PSA Testing | | | P Value
| | Mean % | Lower 95% CI | Upper 95% CI
East North | Mountain | -3.49 | -6.37 | -0.62 | 0.02
East North | South Atlantic | -5.65 | -8.76 | -2.55 | <0.01
East North | West South | -3.58 | -6.88 | -0.29 | 0.03
East South | New England | 4.26 | 0.78 | 7.73 | 0.02
East South | Pacific | 4.41 | 0.81 | 8.00 | 0.02
East South | South Atlantic | -3.79 | -7.09 | -0.50 | 0.02
Middle Atlantic | New England | 5.77 | 0.28 | 11.26 | 0.04
Middle Atlantic | Pacific | 5.92 | 0.36 | 11.49 | 0.04
Mountain | New England | 5.89 | 2.81 | 8.97 | <0.01
Mountain | Pacific | 6.04 | 2.83 | 9.26 | <0.01
Mountain | West North | 4.05 | 1.18 | 6.93 | 0.01
New England | South Atlantic | -8.05 | -11.35 | -4.76 | <0.01
New England | West South | -5.98 | -9.45 | -2.51 | <0.01
Pacific | South Atlantic | -8.20 | -11.63 | -4.78 | <0.01
Pacific | West South | -6.13 | -9.73 | -2.54 | <0.01
South Atlantic | West North | 6.21 | 3.11 | 9.32 | <0.01
West North | West South | -4.14 | -7.44 | -0.85 | 0.01
Midwest | South | -4.13 | -6.44 | -1.81 | <0.01

Table C52 Incidence of prostate cancer in the U.S. regions reported in individual studies

Region | Incidence | Lower 95% CI | Upper 95% CI
East North
Lu-Yao, 1994 ^102^ | 323.2 | 192.3 | 454.0
Jemal, 2005 ^105^ | 487.3 | 396.1 | 578.4
CDC, 1999-2004 ^178^ | 183.2 | 175.4 | 191.0
East South
Jemal, 2005 ^105^ | 383.0 | 225.1 | 540.8
CDC, 1999-2004 ^178^ | 167.8 | 150.8 | 184.9
Middle Atlantic
Jemal, 2005 ^105^ | 514.5 | 402.9 | 626.1
CDC, 1999-2004 ^178^ | 199.4 | 188.5 | 210.4
Mountain
Lu-Yao, 1994 ^102^ | 334.3 | 241.8 | 426.8
Jemal, 2005 ^105^ | 401.5 | 327.1 | 475.9
Escobedo, 2004 ^106^ | 118.3 | 42.8 | 193.7
CDC, 1999-2004 ^178^ | 161.8 | 154.0 | 169.7
New England
Lu-Yao, 1994 ^102^ | 251.5 | 120.6 | 382.3
Jemal, 2005 ^105^ | 434.6 | 355.7 | 513.6
Escobedo, 2004 ^106^ | 158.9 | 83.4 | 234.3
CDC, 1999-2004 ^178^ | 192.0 | 183.7 | 200.4
Pacific
Lu-Yao, 1994 ^102^ | 392.8 | 317.3 | 468.3
Jemal, 2005 ^105^ | 447.6 | 368.7 | 526.5
CDC, 1999-2004 ^178^ | 177.9 | 169.8 | 185.9
South Atlantic
Lu-Yao, 1994 ^102^ | 332.0 | 201.1 | 462.8
Jemal, 2005 ^105^ | 467.7 | 397.1 | 538.2
CDC, 1999-2004 ^178^ | 186.0 | 178.2 | 193.7
USA
Lu-Yao, 1994 ^102^ | 329.5 | 198.7 | 460.3
CDC, 1999-2004 ^178^ | 175.1 | 153.9 | 196.4
West North
Lu-Yao, 1994 ^102^ | 291.7 | 160.8 | 422.5
Jemal, 2005 ^105^ | 444.6 | 344.8 | 544.4
Escobedo, 2004 ^106^ | 152.2 | 76.8 | 227.6
CDC, 1999-2004 ^178^ | 169.0 | 160.2 | 177.7
West South
Jemal, 2005 ^105^ | 438.1 | 280.2 | 595.9
CDC, 1999-2004 ^178^ | 166.9 | 156.7 | 177.2

Table C53 Regional variations in age-standardized prostate cancer incidence/100,000 male population (CDC data, 1999-2004) (pair-wise comparisons between U.S. Census regions)

Regions | | Difference | Standard Error | P Value
East North | East South | 15.13 | 9.54 | 0.11
East North | Middle Atlantic | -16.33 | 6.86 | 0.02
East North | Mountain | 21.32 | 5.64 | 0.00
East North | New England | -8.91 | 5.82 | 0.13
East North | Pacific | 5.42 | 5.69 | 0.34
East North | South Atlantic | -2.89 | 5.60 | 0.61
East North | West North | 14.38 | 5.98 | 0.02
East North | West South | 16.17 | 6.56 | 0.01
East North | USA | 8.01 | 11.56 | 0.49
East South | Middle Atlantic | -31.46 | 10.33 | 0.00
East South | Mountain | 6.19 | 9.56 | 0.52
East South | New England | -24.04 | 9.67 | 0.01
East South | Pacific | -9.71 | 9.59 | 0.31
East South | South Atlantic | -18.02 | 9.54 | 0.06
East South | West North | -0.75 | 9.76 | 0.94
East South | West South | 1.04 | 10.13 | 0.92
East South | USA | -7.12 | 13.90 | 0.61
Middle Atlantic | Mountain | 37.65 | 6.89 | <.01
Middle Atlantic | New England | 7.42 | 7.04 | 0.29
Middle Atlantic | Pacific | 21.75 | 6.93 | 0.00
Middle Atlantic | South Atlantic | 13.44 | 6.86 | 0.05
Middle Atlantic | West North | 30.71 | 7.17 | <.01
Middle Atlantic | West South | 32.50 | 7.67 | <.01
Middle Atlantic | USA | 24.34 | 12.22 | 0.05
Mountain | New England | -30.23 | 5.85 | <.01
Mountain | Pacific | -15.90 | 5.72 | 0.01
Mountain | South Atlantic | -24.21 | 5.64 | <.01
Mountain | West North | -6.94 | 6.01 | 0.25
Mountain | West South | -5.15 | 6.59 | 0.43
Mountain | USA | -13.31 | 11.57 | 0.25
New England | Pacific | 14.34 | 5.90 | 0.02
New England | South Atlantic | 6.02 | 5.81 | 0.30
New England | West North | 23.30 | 6.18 | 0.00
New England | West South | 25.08 | 6.74 | 0.00
New England | USA | 16.92 | 11.66 | 0.15
Pacific | South Atlantic | -8.31 | 5.69 | 0.14
Pacific | West North | 8.96 | 6.06 | 0.14
Pacific | West South | 10.74 | 6.64 | 0.11
Pacific | USA | 2.59 | 11.60 | 0.82
South Atlantic | West North | 17.27 | 5.98 | 0.00
South Atlantic | West South | 19.06 | 6.56 | 0.00
South Atlantic | USA | 10.90 | 11.55 | 0.35
West North | West South | 1.78 | 6.89 | 0.80
West North | USA | -6.37 | 11.74 | 0.59
West South | USA | -8.16 | 12.05 | 0.50

Table C54 Significant geographic differences in incidence of prostate cancer among differences races (CDC data, 1999-2004) (pair-wise comparisons between the US Census regions)

Region | | Difference | Standard Error | P Value
African American
East North | East South | 25.93 | 9.50 | 0.01
East North | Mountain | 52.58 | 6.65 | <.01
East North | West North | 42.25 | 6.49 | <.01
East North | West South | 31.80 | 7.09 | <.01
East South | Middle Atlantic | -38.44 | 10.40 | 0.00
East South | Mountain | 26.66 | 9.92 | 0.01
East South | New England | -20.86 | 10.05 | 0.04
East South | Pacific | -24.19 | 9.76 | 0.01
East South | Atlantic tic | -29.25 | 9.41 | 0.00
Middle Atlantic | Mountain | 65.09 | 7.89 | <.01
Middle Atlantic | New England | 17.57 | 8.06 | 0.03
Middle Atlantic | West North | 54.76 | 7.75 | <0.01
Middle Atlantic | West South | 44.31 | 8.26 | <0.01
Mountain | New England | -47.52 | 7.42 | <0.01
Mountain | Pacific | -50.85 | 7.02 | <0.01
Mountain | Atlantic tic | -55.90 | 6.53 | <0.01
Mountain | West South | -20.78 | 7.64 | 0.01
Mountain | USA | -43.42 | 13.06 | 0.00
New England | West North | 37.19 | 7.27 | <0.01
New England | West South | 26.74 | 7.81 | 0.00
Pacific | West North | 40.51 | 6.87 | <0.01
Pacific | West South | 30.06 | 7.43 | <0.01
South Atlantic | West North | 45.57 | 6.37 | <0.01
South Atlantic | West South | 35.12 | 6.97 | <0.01
West North | USA | -33.09 | 12.97 | 0.01
Hispanic
East North | Middle Atlantic | -41.19 | 8.49 | <0.01
East North | New England | -61.49 | 7.27 | <0.01
East South | New England | -56.60 | 24.43 | 0.02
Middle Atlantic | Mountain | 37.78 | 8.33 | <0.01
Middle Atlantic | New England | -20.30 | 8.77 | 0.02
Middle Atlantic | Pacific | 37.81 | 8.49 | <0.01
Middle Atlantic | South Atlantic | 55.78 | 9.30 | <0.01
Middle Atlantic | West North | 47.96 | 9.17 | <0.01
Middle Atlantic | West South | 28.93 | 9.31 | 0.00
Middle Atlantic | USA | 36.08 | 13.87 | 0.01
Mountain | New England | -58.08 | 7.08 | <0.01
Mountain | South Atlantic | 18.00 | 7.73 | 0.02
New England | Pacific | 58.11 | 7.27 | 0.01
New England | South Atlantic | 76.08 | 8.20 | <0.01
New England | West North | 68.25 | 8.05 | <0.01
New England | West South | 49.23 | 8.21 | <0.01
New England | USA | 56.38 | 13.16 | <0.01
Pacific | South Atlantic | 17.97 | 7.90 | 0.02
South Atlantic | West South | -26.85 | 8.77 | 0.00
West North | West South | -19.03 | 8.63 | 0.03
Whites
East North | East South | 27.68 | 9.50 | 0.00
East North | West South | 16.42 | 7.09 | 0.02
East South | Middle Atlantic | -37.33 | 10.40 | 0.00
East South | Mountain | -25.03 | 9.44 | 0.01
East South | New England | -38.43 | 9.50 | <0.01
East South | Pacific | -31.19 | 9.50 | 0.00
East South | South Atlantic | -21.13 | 9.41 | 0.03
East South | West North | -27.00 | 9.67 | 0.01
Middle Atlantic | South Atlantic | 16.20 | 7.25 | 0.03
Middle Atlantic | West South | 26.07 | 8.26 | 0.00
Mountain | New England | -13.40 | 5.91 | 0.02
Mountain | West South | 13.77 | 7.01 | 0.05
New England | South Atlantic | 17.30 | 5.88 | 0.00
New England | West South | 27.17 | 7.09 | 0.00
Pacific | West South | 19.92 | 7.09 | 0.01
West North | West South | 15.74 | 7.32 | 0.03

Table C55 Incidence of localized prostate cancer reported in individual studies

Region | Incidence | Lower 95% CI | Upper 95% CI
East North
Jemal, 2005 ^105^ | 396.2 | 325.7 | 466.7
East South
Jemal, 2005 ^105^ | 268.7 | 146.6 | 390.8
Middle Atlantic
Jemal, 2005 ^105^ | 401.2 | 314.8 | 487.5
Mountain
Jemal, 2005 ^105^ | 312.5 | 254.9 | 370.0
Escobedo, 2004 ^106^ | 92.7 | 19.3 | 166.0
New England
Jemal, 2005 ^105^ | 354.2 | 293.2 | 415.3
Escobedo, 2004 ^106^ | 110.6 | 37.2 | 183.9
Pacific
Jemal, 2005 ^105^ | 348.3 | 287.3 | 409.4
South Atlantic
Jemal, 2005 ^105^ | 367.5 | 312.9 | 422.0
West North
Jemal, 2005 ^105^ | 367.6 | 290.4 | 444.8
Escobedo, 2004 ^106^ | 103.7 | 30.4 | 177.0

Table C56 Correlation between incidence, mortality, and physicians' distribution in geographic regions (state level)

Race | Outcome | | Number of Urologists | Number of Radiation Oncologists
Whites | Incidence | Correlation coefficient | -0.04 | -0.03
| | p value | 0.57 | 0.66
| Mortality | Correlation coefficient | -0.16 | -0.15
| | p value | 0.01 | 0.02
Blacks | Incidence | Correlation coefficient | 0.08 | 0.09
| | p value | 0.26 | 0.20
| Mortality | Correlation coefficient | -0.04 | -0.06
| | p value | 0.63 | 0.44
Combined | Incidence | Correlation coefficient | -0.02 | -0.02
| | p value | 0.74 | 0.82
| Mortality | Correlation coefficient | -0.07 | -0.09
| | p value | 0.23 | 0.17
| PSA testing | Correlation coefficient | 0.14 | 0.09
| | p value | 0.16 | 0.36

Table C57 Correlation between incidence and mortality in different races in geographic regions (state level) (CDC data)

Race | Outcome | | Mortality
Whites | Incidence | Correlation coefficient | 0.5
| | p value | 0.0002
Blacks | Incidence | Correlation coefficient | -0.14
| | p value | 0.41

Table C58 Correlation between incidence, mortality, and screening in geographic regions (state level) (CDC data)

| | Incidence | Mortality | PSA Test Last 2 Years | PSA Test Ever
Incidence | Correlation coefficient | 1
| p value
Mortality | Correlation coefficient | 0.2 | 1
| p value | 0.13
PSA test last 2 years | Correlation coefficient | 0.27 | 0.43 | 1
| p value | 0.06 | 0.0018
PSA test ever | Correlation coefficient | 0.18 | 0.44 | 0.94 | 1
| p value | 0.23 | 0.0012 | <0.01

Table C59 Proportion of patients treated with external beam therapy, brachytherapy, primary androgen deprivation therapy, radiation, and watchful waiting (%) pooled analysis

| External Beam Therapy | Brachytherapy | Primary Androgen Deprivation Therapy | Radiation Therapy | Watchful Waiting
Midwest | 25.92 | 10.02 | 15.70 | 27.38 | 7.24
Northeast | 33.72 | 4.86 | 17.14 | 27.72 | 6.57
South | 27.42 | 10.69 | 13.39 | 28.58 | 5.34
West | 22.74 | 6.36 | 14.11 | 28.10 | 14.00
East North | 25.97 | 9.55 | 17.64 | 30.69 | 7.04
East South | 24.14 | 10.83 | 18.68 | | 5.34
Middle Atlantic | 33.72 | 4.18 | 8.50 | | 6.22
Mountain | 21.54 | 6.43 | 11.81 | 24.51 | 13.77
New England | 33.76 | 5.11 | 17.34 | 26.88 | 6.69
Pacific | 24.21 | 6.27 | 15.70 | 29.09 | 14.45
South Atlantic | 29.85 | 10.63 | 13.11 | 27.74 | 5.34
West North | 25.94 | 10.58 | 13.80 | 22.40 | 7.38
West South | 24.14 | 10.83 | 18.68 | | 5.34

Table C60 Correlation between proportion of patients with different primary treatments and total number of urologists and radiation oncologists in geographic regions (state level)

| | Radical Prostatectomy | External Beam Radiotherapy | Brachytherapy | Primary Androgen Deprivation | Watchful Waiting
Urologists | Correlation coefficient | -0.57065 | 0.58002 | -0.54 | -0.56 | -0.10
| p value | 0.1086 | 0.1016 | 0.13 | 0.11 | 0.79
Radiation Oncologists | Correlation coefficient | -0.66288 | 0.63121 | -0.65 | -0.50 | -0.02
| p value | 0.0517 | 0.0683 | 0.06 | 0.17 | 0.95

Table C61 Significant variations in proportion of patients treated with external beam therapy

Region | | Mean Differences | Lower 95% CI | Upper 95% CI | P Value
East North | East South | 1.83 | 0.06 | 3.59 | 0.04
East North | Middle Atlantic | -7.75 | -9.68 | -5.82 | <0.01
East North | Mountain | 4.43 | 2.96 | 5.90 | <0.01
East North | New England | -7.79 | -9.30 | -6.27 | <0.01
East North | Pacific | 1.76 | 0.24 | 3.29 | 0.02
East North | South Atlantic | -3.88 | -5.27 | -2.50 | <0.01
East North | West South | 1.83 | 0.06 | 3.59 | 0.04
East South | Middle Atlantic | -9.58 | -11.67 | -7.49 | <0.01
East South | Mountain | 2.60 | 0.93 | 4.28 | <0.01
East South | New England | -9.61 | -11.33 | -7.90 | <0.01
East South | South Atlantic | -5.71 | -7.31 | -4.11 | <0.01
East South | West North | -1.79 | -3.51 | -0.08 | 0.04
Middle Atlantic | Mountain | 12.18 | 10.33 | 14.03 | <0.01
Middle Atlantic | Pacific | 9.52 | 7.63 | 11.40 | <0.01
Middle Atlantic | South Atlantic | 3.87 | 2.09 | 5.65 | <0.01
Middle Atlantic | West North | 7.79 | 5.90 | 9.67 | <0.01
Middle Atlantic | West South | 9.58 | 7.49 | 11.67 | <0.01
Mountain | New England | -12.22 | -13.63 | -10.81 | <0.01
Mountain | Pacific | -2.67 | -4.08 | -1.25 | <0.01
Mountain | South Atlantic | -8.31 | -9.58 | -7.05 | <0.01
Mountain | West North | -4.40 | -5.81 | -2.98 | <0.01
Mountain | West South | -2.60 | -4.28 | -0.93 | <0.01
New England | Pacific | 9.55 | 8.09 | 11.01 | <0.01
New England | South Atlantic | 3.91 | 2.59 | 5.22 | <0.01
New England | West North | 7.82 | 6.36 | 9.28 | <0.01
New England | West South | 9.61 | 7.90 | 11.33 | <0.01
Pacific | South Atlantic | -5.65 | -6.97 | -4.32 | <0.01
Pacific | West North | -1.73 | -3.19 | -0.27 | 0.02
South Atlantic | West North | 3.92 | 2.59 | 5.24 | <0.01
South Atlantic | West South | 5.71 | 4.11 | 7.31 | <0.01
West North | West South | 1.79 | 0.08 | 3.51 | 0.04
Midwest | Northeast | -7.79 | -9.15 | -6.44 | <0.01
Midwest | South | -1.50 | -2.66 | -0.34 | 0.01
Midwest | West | 3.18 | 1.96 | 4.40 | <0.01
Northeast | South | 6.30 | 5.04 | 7.56 | <0.01
Northeast | West | 10.97 | 9.66 | 12.29 | <0.01
South | West | 4.68 | 3.56 | 5.79 | <0.01

Table C62 Significant variations in proportion of patients treated with watchful waiting

Region | | Mean Differences | Lower 95% CI | Upper 95% CI | p Value
East North | Mountain | -6.73 | -8.40 | -5.07 | <0.01
East North | Pacific | -7.41 | -9.36 | -5.47 | <0.01
East North | South Atlantic | 1.70 | 0.04 | 3.36 | 0.04
East South | Mountain | -8.43 | -10.34 | -6.53 | <0.01
East South | Pacific | -9.11 | -11.27 | -6.96 | <0.01
East South | West North | -2.04 | -4.02 | -0.07 | 0.04
Middle Atlantic | Mountain | -7.55 | -9.67 | -5.43 | <0.01
Middle Atlantic | Pacific | -8.23 | -10.58 | -5.89 | <0.01
Mountain | New England | 7.08 | 5.57 | 8.59 | <0.01
Mountain | South Atlantic | 8.43 | 6.99 | 9.88 | <0.01
Mountain | West North | 6.39 | 4.88 | 7.90 | <0.01
Mountain | West South | 8.43 | 6.53 | 10.34 | <0.01
New England | Pacific | -7.76 | -9.60 | -5.92 | <0.01
Pacific | South Atlantic | 9.11 | 7.36 | 10.87 | <0.01
Pacific | West North | 7.07 | 5.23 | 8.91 | <0.01
Pacific | West South | 9.11 | 6.96 | 11.27 | <0.01
South Atlantic | West North | -2.04 | -3.58 | -0.51 | 0.01
West North | West South | 2.04 | 0.07 | 4.02 | 0.04
Midwest | South | 1.90 | 0.77 | 3.03 | <0.01
Midwest | West | -6.76 | -7.92 | -5.60 | <0.01
Northeast | South | 1.23 | 0.01 | 2.44 | 0.05
Northeast | West | -7.43 | -8.67 | -6.19 | <0.01
South | West | -8.66 | -9.76 | -7.55 | <0.01

Table C63 Significant variations in proportion of patients treated with brachytherapy

Region | | Mean Differences | Lower 95% CI | Upper 95% CI | P Value
East North | Middle Atlantic | 5.37 | 3.66 | 7.08 | <0.01
East North | Mountain | 3.12 | 1.95 | 4.29 | <0.01
East North | New England | 4.44 | 3.21 | 5.66 | <0.01
East North | Pacific | 3.27 | 1.83 | 4.72 | <0.01
East South | Middle Atlantic | 6.65 | 4.74 | 8.55 | <0.01
East South | Mountain | 4.40 | 2.93 | 5.87 | <0.01
East South | New England | 5.71 | 4.20 | 7.23 | <0.01
East South | Pacific | 4.55 | 2.88 | 6.22 | <0.01
Middle Atlantic | Mountain | -2.25 | -3.88 | -0.61 | 0.01
Middle Atlantic | Pacific | -2.10 | -3.91 | -0.28 | 0.02
Middle Atlantic | South Atlantic | -6.45 | -8.07 | -4.84 | <0.01
Middle Atlantic | West North | -6.40 | -8.12 | -4.68 | <0.01
Middle Atlantic | West South | -6.65 | -8.55 | -4.74 | <0.01
Mountain | New England | 1.31 | 0.19 | 2.44 | 0.02
Mountain | South Atlantic | -4.21 | -5.25 | -3.16 | <0.01
Mountain | West North | -4.15 | -5.37 | -2.93 | <0.01
Mountain | West South | -4.40 | -5.87 | -2.93 | <0.01
New England | South Atlantic | -5.52 | -6.63 | -4.41 | <0.01
New England | West North | -5.47 | -6.74 | -4.19 | <0.01
New England | West South | -5.71 | -7.23 | -4.20 | <0.01
Pacific | South Atlantic | -4.36 | -5.70 | -3.02 | <0.01
Pacific | West North | -4.30 | -5.76 | -2.85 | <0.01
Pacific | West South | -4.55 | -6.22 | -2.88 | <0.01
Midwest | Northeast | 5.16 | 4.19 | 6.12 | <0.01
Midwest | West | 3.66 | 2.76 | 4.55 | <0.01
Northeast | South | -5.83 | -6.74 | -4.92 | <0.01
Northeast | West | -1.50 | -2.45 | -0.55 | <0.01
South | West | 4.33 | 3.50 | 5.16 | <0.01

Table C64 Significant variations in proportion of patients treated with primary androgen deprivation

Region | | Mean Differences | Lower95% CI | Upper95% CI | P Value
East North | Middle Atlantic | 9.14 | 3.26 | 15.02 | <0.01
East North | Mountain | 5.83 | 4.81 | 6.85 | <0.01
East North | Pacific | 1.94 | 0.97 | 2.90 | <0.01
East North | South Atlantic | 4.53 | 3.37 | 5.70 | <0.01
East North | West North | 3.84 | 2.67 | 5.01 | <0.01
East South | Middle Atlantic | 10.18 | 2.72 | 17.65 | <0.01
East South | Mountain | 6.87 | 1.74 | 12.01 | 0.01
East South | South Atlantic | 5.57 | 0.43 | 10.72 | 0.03
Middle Atlantic | New England | -8.84 | -14.72 | -2.96 | <0.01
Middle Atlantic | Pacific | -7.20 | -13.06 | -1.35 | 0.02
Middle Atlantic | West South | -10.18 | -17.65 | -2.72 | <0.01
Mountain | New England | -5.53 | -6.55 | -4.52 | <0.01
Mountain | Pacific | -3.89 | -4.66 | -3.13 | <0.01
Mountain | South Atlantic | -1.30 | -2.31 | -0.29 | 0.01
Mountain | West North | -1.99 | -3.01 | -0.97 | <0.01
Mountain | West South | -6.87 | -12.01 | -1.74 | <0.01
New England | Pacific | 1.64 | 0.68 | 2.60 | <0.01
New England | South Atlantic | 4.23 | 3.07 | 5.40 | <0.01
New England | West North | 3.54 | 2.38 | 4.71 | <0.01
Pacific | South Atlantic | 2.59 | 1.64 | 3.55 | <0.01
Pacific | West North | 1.90 | 0.94 | 2.86 | <0.01
South Atlantic | West South | -5.57 | -10.72 | -0.43 | 0.03
West North | West South | -4.88 | -10.04 | 0.27 | 0.06
Midwest | South | 2.30 | 0.77 | 3.84 | <0.01
Midwest | West | 1.59 | 0.51 | 2.67 | <0.01
Northeast | South | 3.75 | 1.98 | 5.52 | <0.01
Northeast | West | 3.03 | 1.64 | 4.43 | <0.01

Table C65 Significant variations in proportion of patients treated with radical prostatectomy

Region | | Mean | Lower 95% CI | Upper 95% CI | P Value
Midwest | Northeast | 6.19 | 3.26 | 9.12 | <0.01
Midwest | West | -5.17 | -7.45 | -2.90 | <0.01
Northeast | South | -8.38 | -11.34 | -5.41 | <0.01
Northeast | West | -11.36 | -14.06 | -8.66 | <0.01
South | West | -2.99 | -5.41 | -0.57 | 0.02
East North | Mountain | -7.76 | -11.05 | -4.47 | <0.01
East North | New England | 4.91 | 1.29 | 8.54 | 0.01
East North | Pacific | -5.00 | -8.18 | -1.82 | <0.01
East South | Middle Atlantic | 10.84 | 3.59 | 18.08 | <0.01
East South | New England | 10.08 | 4.63 | 15.53 | <0.01
Middle Atlantic | Mountain | -13.43 | -19.39 | -7.48 | <0.01
Middle Atlantic | Pacific | -10.67 | -16.60 | -4.74 | <0.01
Middle Atlantic | South Atlantic | -8.27 | -14.22 | -2.31 | 0.01
Middle Atlantic | West North | -7.80 | -13.90 | -1.70 | 0.01
Middle Atlantic | West South | -10.84 | -18.08 | -3.59 | <0.01
Mountain | New England | 12.68 | 9.46 | 15.90 | <0.01
Mountain | Pacific | 2.76 | 0.08 | 5.45 | 0.04
Mountain | South Atlantic | 5.17 | 2.14 | 8.19 | <0.01
Mountain | West North | 5.63 | 2.41 | 8.85 | <0.01
New England | Pacific | -9.91 | -13.03 | -6.80 | <0.01
New England | South Atlantic | -7.51 | -10.87 | -4.15 | <0.01
New England | West North | -7.05 | -10.60 | -3.49 | <0.01
New England | West South | -10.08 | -15.53 | -4.63 | <0.01

Table C66 Geographic variations in radical prostatectomy. Age adjusted Rate/100,000 male population (pooled analysis)

Region | Mean | Lower 95% CI | Upper 95% CI
New England | 63.63 | 29.41 | 156.68
Northeast | 67 | 25.46 | 159.45
Middle Atlantic | 102.02 | 3.02 | 207.07
East North | 117 | 23.95 | 210.05
East South | 118.84 | 14.8 | 222.88
Midwest | 120.78 | 28.56 | 213.01
West North | 125.95 | 31.83 | 220.07
West South | 127.9 | 23.86 | 231.94
South | 129.25 | 36.96 | 221.54
South Atlantic | 129.5 | 36.52 | 222.48
Pacific | 150.24 | 57.18 | 243.3
West | 156.43 | 64.4 | 248.45
Mountain | 159.57 | 66.79 | 252.34
USA | 121.79 | 28.5 | 215.09

Table C67 Significant differences in age adjusted rate/100,000 male population (pooled analysis)

Region | | Mean | Lower 95% CI | Upper 95% CI | P Value
Midwest | Northeast | 53.79 | 36.61 | 70.97 | <0.01
Midwest | West | -35.64 | -49.74 | -21.55 | <0.01
Northeast | South | -62.25 | -80.24 | -44.27 | <0.01
Northeast | West | -89.43 | -105.38 | -73.49 | <0.01
Northeast | USA | -55.98 | -75.36 | -36.61 | <0.01
South | West | -27.18 | -42.76 | -11.59 | <0.01
West | USA | 33.45 | 16.50 | 50.40 | <0.01
East North | Mountain | -42.57 | -60.36 | -24.77 | <0.01
East North | New England | 53.37 | 34.30 | 72.44 | <0.01
East North | Pacific | -33.24 | -52.67 | -13.81 | <0.01
East South | New England | 55.21 | 2.78 | 107.64 | 0.04
Middle Atlantic | Mountain | -57.54 | -111.42 | -3.67 | 0.04
Mountain | New England | 95.93 | 78.16 | 113.71 | <0.01
Mountain | South Atlantic | 30.07 | 12.39 | 47.74 | <0.01
Mountain | West North | 33.62 | 10.36 | 56.88 | <0.01
Mountain | USA | 37.78 | 19.38 | 56.17 | <0.01
New England | Pacific | -86.61 | -106.02 | -67.20 | <0.01
New England | South Atlantic | -65.87 | -84.82 | -46.91 | <0.01
New England | West North | -62.32 | -87.00 | -37.64 | <0.01
New England | West South | -64.27 | -116.70 | -11.83 | 0.02
New England | USA | -58.16 | -77.80 | -38.52 | <0.01
Pacific | South Atlantic | 20.74 | 1.43 | 40.06 | 0.04
Pacific | West North | 24.29 | 0.90 | 47.68 | 0.04
Pacific | USA | 28.45 | 8.44 | 48.46 | 0.01

Table C68 Differences in utilization of radical prostatectomy compared with the national average (pooled analysis)

Region | Relative Risk | Lower 95% CI | Upper 95% CI | P Value
Midwest | 1.08 | 0.93 | 1.25 | 0.33
Northeast | 0.65 | 0.56 | 0.75 | <0.01
South | 1.05 | 0.91 | 1.21 | 0.53
West | 1.38 | 1.19 | 1.60 | <0.01
USA | 1.00

Table C69 Length of hospital stay after radical prostatectomy

Region | Mean | Lower 95% CI | Upper 95% CI
West | 3.7 | 1.6 | 5.8 | A
Midwest | 4.6 | 2.6 | 6.7 | B
South | 4.7 | 2.7 | 6.8 | B
Northeast | 5.2 | 3.1 | 7.3 | B
USA | 4.6 | 2.1 | 7 | AB

Different letters assigned for statistically significant differences at 95% confidence level

Table C70 Cost of radical prostatectomy in $ U.S

Region | Mean | Lower 95% CI | Upper 95% CI
West* | 16,043 | 13,767 | 18,319
South | 16,672 | 14,872 | 18,472
Midwest | 17,718 | 15,548 | 19,888
Northeast* | 20,003 | 17,284 | 22,722
USA | 18,680 | 11,488 | 25,872

* statistically significant differences at 95% confidence level

Table C71 Differences in hospital charges for radical prostatectomy in U.S, regions

Region | | Differences | Lower 95% CI | Upper 95% CI
Midwest | Northeast | -2,285 | -5,762 | 1,192
Midwest | South | 1,046 | -1,770 | 3,863
Midwest | West | 1,675 | -1,467 | 4,817
Midwest | USA | -962 | -8,473 | 6,549
Northeast* | South | 3,331 | 72 | 6,590
Northeast* | West | 3,960 | 416 | 7,504
Northeast | USA | 1,323 | -6,365 | 9,011
South | West | 629 | -2,270 | 3,528
South | USA | -2,008 | -9,421 | 5,404
West | USA | -2,637 | -10,179 | 4,905
East North | East South | 3,333 | -1,314 | 7,979
East North | Middle Atlantic | -3,480 | -8,126 | 1,166
East North | Mountain | 2,595 | -1,561 | 6,751
East North | New England | -1,352 | -6,442 | 3,738
East North | Pacific | -413 | -5,059 | 4,234
East North | South Atlantic | -288 | -4,293 | 3,717
East North | West North | -623 | -4,982 | 3,736
East North | West South | 179 | -4,180 | 4,538
East North | USA | -1245 | -9,020 | 6,530
East South* | Middle Atlantic | -6,813 | -11,902 | -1,723
East South | Mountain | -738 | -5,384 | 3,909
East South | New England | -4,684 | -10,182 | 814
East South | Pacific | -3,745 | -8,835 | 1,345
East South | South Atlantic | -3,620 | -8,132 | 891
East South | West North | -3,956 | -8,784 | 873
East South | West South | -3,154 | -7,982 | 1,675
East South | USA | -4,578 | -12,625 | 3,470
Middle Atlantic* | Mountain | 6,075 | 1,429 | 10,721
Middle Atlantic | New England | 2,128 | -3,369 | 7,626
Middle Atlantic | Pacific | 3,068 | -2,022 | 8,157
Middle Atlantic | South Atlantic | 3,192 | -1,320 | 7,704
Middle Atlantic | West North | 2,857 | -1,972 | 7,686
Middle Atlantic | West South | 3,659 | -1,170 | 8,488
Middle Atlantic | USA | 2,235 | -5,813 | 10,283
Mountain | New England | -3,947 | -9,037 | 1,143
Mountain | Pacific | -3,008 | -7,654 | 1,639
Mountain | South Atlantic | -2,883 | -6,888 | 1,122
Mountain | West North | -3,218 | -7,577 | 1,141
Mountain | West South | -2,416 | -6,775 | 1,943
Mountain | USA | -3,840 | -11,615 | 3,935
New England | Pacific | 939 | -4,559 | 6,437
New England | South Atlantic | 1,064 | -3,903 | 6,031
New England | West North | 729 | -4,528 | 5,986
New England | West South | 1,531 | -3,726 | 6,788
New England | USA | 107 | -8,205 | 8,418
Pacific | South Atlantic | 125 | -4,387 | 4,636
Pacific | West North | -211 | -5,039 | 4,618
Pacific | West South | 592 | -4,237 | 5,420
Pacific | USA | -833 | -8,880 | 7,215
South Atlantic | West North | -335 | -4,550 | 3,880
South Atlantic | West South | 467 | -3,748 | 4,682
South Atlantic | USA | -957 | -8,652 | 6,738
West North | West South | 802 | -3,751 | 5,355
West North | USA | -622 | -8,507 | 7,263
West South | USA | -1,424 | -9,309 | 6,461

Table C72 Age adjusted mortality from prostate cancer per 100,000 male population in U.S. regions reported in individual studies

Region | Mortality | Lower 95% CI | Upper 95% CI
East North
Kafadar, 1997 ^103^ | 29.6 | 25.7 | 33.4
CDC, 1999-2004 ^178^ | 38.1 | 34.7 | 41.4
Jemal, 2005 ^105^ | 115.6 | 76.7 | 154.6
Jemal, 2002 ^104^ | 24.2 | 21.7 | 26.6
East South
Kafadar, 1997 ^103^ | 27.7 | 23.5 | 32.0
CDC, 1999-2004 ^178^ | 45.9 | 41.7 | 50.1
Jemal, 2005 ^105^ | 116.2 | 48.6 | 183.7
Jemal, 2002 ^104^ | 29.0 | 24.4 | 33.7
Middle Atlantic
Kafadar, 1997 ^103^ | 29.4 | 24.4 | 34.3
CDC, 1999-2004 ^178^ | 36.2 | 32.0 | 40.4
Jemal, 2005 ^105^ | 121.5 | 73.8 | 169.3
Jemal, 2002 ^104^ | 21.7 | 13.6 | 29.8
Mountain
Kafadar, 1997 ^103^ | 20.7 | 17.7 | 23.7
CDC, 1999-2004 ^178^ | 33.1 | 30.0 | 36.2
Jemal, 2002 ^104^ | 100.0 | 66.2 | 133.7
Escobedo, 2004 ^106^ | 71.5 | 48.9 | 94.0
Jemal, 2005 ^105^ | 22.7 | 19.4 | 26.0
New England
Kafadar, 1997 ^103^ | 24.9 | 21.4 | 28.4
CDC, 1999-2004 ^178^ | 33.3 | 29.8 | 36.7
Jemal, 2005 ^105^ | 101.5 | 67.8 | 135.3
Escobedo, 2004 ^106^ | 84.2 | 61.6 | 106.7
Jemal, 2002 ^104^ | 22.4 | 19.5 | 25.2
Pacific
Kafadar, 1997 ^103^ | 20.7 | 15.8 | 25.7
CDC, 1999-2004 ^178^ | 32.6 | 28.6 | 36.6
Jemal, 2005 ^105^ | 101.9 | 62.9 | 140.9
Jemal, 2002 ^104^ | 21.8 | 17.7 | 25.8
South Atlantic
Kafadar, 1997 ^103^ | 30.9 | 28.1 | 33.7
CDC, 1999-2004 ^178^ | 41.9 | 39.1 | 44.6
Jemal, 2005 ^105^ | 125.4 | 95.2 | 155.6
Jemal, 2002 ^104^ | 29.5 | 27.6 | 31.5
West North
Kafadar, 1997 ^103^ | 24.6 | 21.4 | 27.8
CDC, 1999-2004 ^178^ | 34.5 | 30.8 | 38.3
Jemal, 2005 ^105^ | 109.5 | 66.8 | 152.2
Escobedo, 2004 ^106^ | 94.7 | 72.1 | 117.3
Jemal, 2002 ^104^ | 23.5 | 20.2 | 26.8
West South
Kafadar, 1997 ^103^ | 26.3 | 22.0 | 30.6
CDC, 1999-2004 ^138,^ ^178^ | 39.6 | 35.6 | 43.5
Jemal, 2005 ^105^ | 118.7 | 51.2 | 186.2
USA
CDC, 1999-2004 ^178^ | 36.7 | 28.5 | 44.8
Jemal, 2005 ^105^ | 24.4 | 18.7 | 30.1

Table C73 Geographic differences in prostate cancer age adjusted mortality per100,000 male population (CDC data, 1999-2004)

Region | | Difference | Standard Error | P Value
East North | East South | -7.86 | 2.74 | 0.00
East North | Middle Atlantic | 1.83 | 2.74 | 0.51
East North | Mountain | 4.92 | 2.31 | 0.03
East North | New England | 4.79 | 2.46 | 0.05
East North | Pacific | 5.43 | 2.66 | 0.04
East North | South Atlantic | -3.81 | 2.22 | 0.09
East North | West North | 3.50 | 2.56 | 0.17
East North | West South | -1.51 | 2.64 | 0.57
East North | USA | 1.36 | 4.49 | 0.76
East South | Middle Atlantic | 9.69 | 3.04 | 0.00
East South | Mountain | 12.78 | 2.65 | <0.01
East South | New England | 12.65 | 2.78 | <0.01
East South | Pacific | 13.30 | 2.96 | <0.01
East South | South Atlantic | 4.05 | 2.57 | 0.12
East South | West North | 11.36 | 2.87 | <0.01
East South | West South | 6.35 | 2.95 | 0.03
East South | USA | 9.22 | 4.68 | 0.05
Middle Atlantic | Mountain | 3.09 | 2.65 | 0.24
Middle Atlantic | New England | 2.97 | 2.78 | 0.29
Middle Atlantic | Pacific | 3.61 | 2.96 | 0.22
Middle Atlantic | South Atlantic | -5.63 | 2.57 | 0.03
Middle Atlantic | West North | 1.67 | 2.87 | 0.56
Middle Atlantic | West South | -3.34 | 2.95 | 0.26
Middle Atlantic | USA | -0.47 | 4.68 | 0.92
Mountain | New England | -0.13 | 2.36 | 0.96
Mountain | Pacific | 0.51 | 2.57 | 0.84
Mountain | South Atlantic | -8.73 | 2.10 | <0.01
Mountain | West North | -1.42 | 2.46 | 0.56
Mountain | West South | -6.43 | 2.55 | 0.01
Mountain | USA | -3.56 | 4.44 | 0.42
New England | Pacific | 0.64 | 2.71 | 0.81
New England | South Atlantic | -8.60 | 2.27 | 0.00
New England | West North | -1.29 | 2.60 | 0.62
New England | West South | -6.30 | 2.68 | 0.02
New England | USA | -3.43 | 4.52 | 0.45
Pacific | South Atlantic | -9.24 | 2.49 | 0.00
Pacific | West North | -1.93 | 2.80 | 0.49
Pacific | West South | -6.95 | 2.87 | 0.02
Pacific | USA | -4.08 | 4.63 | 0.38
South Atlantic | West North | 7.31 | 2.38 | 0.00
South Atlantic | West South | 2.30 | 2.46 | 0.35
South Atlantic | USA | 5.17 | 4.39 | 0.24
West North | West South | -5.01 | 2.78 | 0.07
West North | USA | -2.14 | 4.57 | 0.64
West South | USA | 2.87 | 4.62 | 0.53

Table C74 Significant geographic differences in prostate cancer age adjusted mortality/100,000 among different races (CDC data, 1999-2004)

Region | | Difference | Standard Error | p Value
African American
East North | East South | -9.11 | 1.50 | <0.01
East North | New England | 9.37 | 1.60 | <0.01
East North | Pacific | 5.90 | 1.82 | 0.00
East North | South Atlantic | -8.27 | 1.27 | <0.01
East North | West South | -3.01 | 1.50 | 0.05
East South | Middle Atlantic | 11.24 | 1.71 | <0.01
East South | Mountain | 10.70 | 1.77 | <0.01
East South | New England | 18.48 | 1.71 | <0.01
East South | Pacific | 15.02 | 1.91 | <0.01
East South | West North | 8.94 | 1.86 | <0.01
East South | West South | 6.11 | 1.61 | 0.00
East South | USA | 6.39 | 2.79 | 0.02
Middle Atlantic | New England | 7.25 | 1.80 | <0.01
Middle Atlantic | South Atlantic | -10.39 | 1.50 | <0.01<.0001
Middle Atlantic | West South | -5.13 | 1.71 | 0.00
Mountain | New England | 7.78 | 1.86 | <0.01
Mountain | Pacific | 4.31 | 2.05 | 0.04
Mountain | South Atlantic | -9.86 | 1.58 | <0.01
Mountain | West South | -4.60 | 1.77 | 0.01
New England | South Atlantic | -17.64 | 1.50 | <0.01
New England | West North | -9.54 | 1.94 | <0.01
New England | West South | -12.37 | 1.71 | <0.01
New England | USA | -12.09 | 2.84 | <0.01
Pacific | South Atlantic | -14.17 | 1.73 | <0.01
Pacific | West North | -6.08 | 2.12 | 0.00
Pacific | West South | -8.91 | 1.91 | <0.01
Pacific | USA | -8.63 | 2.97 | 0.00
South Atlantic | West North | 8.09 | 1.67 | <0.01
South Atlantic | West South | 5.26 | 1.39 | 0.00
South Atlantic | USA | 5.55 | 2.67 | 0.04
Hispanic
East North | Middle Atlantic | -5.34 | 2.08 | 0.01
East North | Mountain | -9.27 | 1.85 | <0.01
East North | New England | -5.74 | 2.32 | 0.01
East North | South Atlantic | -5.14 | 2.08 | 0.01
East North | West South | -4.77 | 2.32 | 0.04
Middle Atlantic | Mountain | -3.93 | 1.85 | 0.03
Mountain | Pacific | 5.49 | 2.12 | 0.01
Mountain | South Atlantic | 4.13 | 1.85 | 0.03
Mountain | West South | 4.50 | 2.12 | 0.03
Whites
Mountain | South Atlantic | 2.97 | 1.12 | 0.01
New England | South Atlantic | 2.39 | 1.19 | 0.05
Pacific | South Atlantic | 3.37 | 1.32 | 0.01

Table C75 Distribution of hospital and surgeon annual volumes of radical prostatectomy

| Hospital Volume | Surgeon Volume
Mean | 43.6 | 12.2
Standard deviation | 37.0 | 13.5
Median | 40.0 | 10.0
Quartile 1 | 8–22 | 0.1–3.3
Quartile 2 | 23–39 | 3.5–8.75
Quartile 3 | 40–43 | 10–14
Quartile 4 | >85 | 15–75.6

Table C76 Odds ratio and attributable events of clinical outcomes after different treatments I patients with localized prostate cancer

Design | Quality | Studies Reference | Active | Control | Outcomes | Effect: Odds Ratio (95%CI) | Attributable Fraction of Events (%) | Rate (%) in Active Group | Rate (%) in Control Group | NNT | Number of Avoided (Excessive) Events per 1,000 Hospitalized
RCT | Moderate | Bill-Axelson, 2005 ^179^ | Radical prostatectomy at 10 years | Watchful waiting at 10 years | Overall mortality | 0.74 (0.56; 0.99)** | 26 | 27 | 32 | 20 | 50
RCT | Moderate | Wirth, 2004 ^19^ | Bicalutamide and watchful waiting | Placebo and adjuvant therapy | Overall mortality | 1.31 (1.04; 1.65) | 23.7 | 30 | 20 | -21 | -47
RCT | Moderate | Zietman, 2005 ^6^ | External beam radiation: high dose (79.2 Gy) | External beam radiation: conventional dose (70 Gy) | 3 consecutive increases in PSA level, with the failure backdated to a point halfway between the first increase and the last non-increasing value | 0.40 (0.25; 0.62) | 60.5 | 20 | 40 | 5 | 190
RCT | Moderate | D'Amico, 2004 ^8^ | Conformal radiation therapy and androgen suppression therapy | Conformal radiation therapy (70 Gy) | PSA >1.0 ng/ml and increasing >0.2 ng/ml on 2 consecutive visits | 0.34 (0.18; 0.63) | 66.2 | 20 | 40 | 4 | 232
RCT | Moderate | Paulson, 1982 ^13^ | Radical prostatectomy | Radiation therapy | Acid phosphatase elevation on 2 consecutive followups or by appearance of bony or parenchymal disease with or without concomitant acid phosphatase elevation | 0.27 (0.11; 0.71) | 72.6 | 10 | 40 | 4 | 250
RCT | Moderate | Sathya, 2005 ^15^ | EBRT | Iridium implant + EBRT | PSA failure, clinical failure | 3.70 (1.27; 10.73) | 72.9 | 60 | 30 | -3 | -315

Table C77 Comparative effectiveness of adverse events after different treatments in patients with localized prostate cancer

Design | Study Quality | Outcomes: Adverse Events and Quality of Life | WW % (n=230) | AD % (n=179) | EBRT/Brachy % (n=583) | RP % (n=1,373)
Large population | Moderate | Satisfied with treatment: delighted/pleased** | 17.6/30.8 | 22.9/40.3 | 32.1/37.8 | 22.5/36.1
Large population based | Moderate | Make same decision again: definitely yes*/probably yes* | 51.2/40.8 | 64.4/30.6 | 62.4/31.4 | 56.2/34.5
Large population based | Moderate | Bowel urgency: almost everyday* | 0.2 | 3.3 | 3.2 | 0.9
Large population based | Moderate | Urinary leakage: daily or more often* | 7 | 10.8 | 11.8 | 34.8
Large population based | Moderate | Erectile dysfunction: no erections at all* | 32.5 | 85.8 | 42.7 | 58.4
| | | n=326, % | | | n = 376, %
RCT | Moderate | Erectile dysfunction ˆ | 45 | | | 80
RCT | Moderate | Urinary leakage ˆ | 21 | | | 49
RCT | Moderate | Urinary obstruction ˆ | 44 | | | 28
RCT | Moderate | Diarrhea ˆ | 0.9 | | | 5
RCT | Moderate | Fecal leakage ≥once/weekˆ | 7 | | | 6

WW = watchful waiting; AD = androgen deprivation; EBRT/Brachy = external beam radiation/brachytherapy; RP = radical prostatectomy

* PCOS study;

ˆ Steineck study

Table C78 Odds ratio of outcomes, attributable proportion of events among exposed, number needed to treat to harm one patient, and the number of avoided events per 1000 treated patients: radical prostatectomy vs. watchful waiting

Design | Study Quality | Outcomes | Effect: Odds ratio of events, 95% CI | | | Attributable Fraction of Events (%) | NNT to Harm | Number of Avoided (Excessive) Events
Large population based study | Moderate | Satisfied with treatment: delighted* | 1.34 | 0.68 | 2.73 | 26.4 | -20 | -49
Large population based study | Moderate | Satisfied with treatment: pleased* | 1.27 | 0.70 | 2.29 | 21.2 | -19 | -53
Large population based study | Moderate | Would make same decision again: definitely yes* | 1.22 | 0.70 | 2.13 | 18.2 | -20 | -50
Large population based study | Moderate | Would make same decision again: probably yes* | 0.76 | 0.43 | 1.36 | -30.9 | 16 | 63
Large population based study | Moderate | Bowel urgency: almost every day* | 4.53 | 0.04 | 580.71 | 77.9 | -143 | -7
Large population based study | Moderate | Urinary leakage: daily or more often* | 7.09 | 2.97 | 16.95 | 85.9 | -4 | -278
Large population based study | Moderate | Erectile dysfunction: no erections at all* | 2.92 | 1.64 | 5.19 | 65.7 | -4 | -259
RCT | Moderate | Erectile dysfunctionˆ | 4.89 | 2.61 | 9.17 | 79.5 | -3 | -350
RCT | Moderate | Urinary leakageˆ | 3.61 | 1.94 | 6.72 | 72.3 | -4 | -280
RCT | Moderate | Urinary obstructionˆ | 0.49 | 0.28 | 0.89 | -102.0 | 6 | 160
RCT | Moderate | Diarrheaˆ | 5.79 | 0.60 | 55.64 | 82.7 | -24 | -41
RCT | Moderate | Fecal leakage ≥ once/weekˆ | 0.85 | 0.28 | 2.62 | -17.9 | 100 | 10

* -PCOS study

ˆ Steineck study

Figure C1 Flow of articles reviewed

Figure C2 Disease-specific survival at time points by treatment

Figure C3 Comparative studies of LRP vs. RRP; operative data (from the systematic review of nonrandomized clinical trials and case series by Rassweiler et al)

Figure C4 Comparative studies of transperitoneal vs. extraperitoneal radical prostatectomy; operative data (from the systematic review of nonrandomized clinical trials and case series by Rassweiler et al)

Figure C5 Quality of life measures after IMRT vs. 3D-CRT} (Kupelian, 2002) ^72^

Figure C6 Search strategy

Figure C7 Percentage of responses by family physicians and general internists to the question: “Do you recommend the following for prostate cancer screening for patients 50 years old and older?” (Kim, 2002) ^139^

Figure C8 Percentage of responses by urologists and primary care physicians to the question “Which test do you believe is the single best screening tool? Do you screen for prostate cancer patients older than 79 years? Do you screen young asymptomatic patients?” (McKnight, 1996) ^140^

Figure C9 Percentage of responses by urologists and radiation oncologists to the question: “Do you recommend that primary care physicians include PSA testing as a part of the routine physician examinations for men who are at average risk of prostate cancer in each age category?” (Fowler, 2000) ^148^

Figure C10 Percentage of responses by urologists and primary care physicians to the question whether radical prostatectomy or external beam radiation “probably” or “definitely” offers survival benefit for patients with clinically localized prostate cancer (Fowler, 1998) ^141^

Figure C11 Which therapy offers the best survival to patients with clinically localized prostate cancer? Treatment recommendations by urologists and radiation oncologists (Fowler, 2000) ^148^

Figure C12 Percentage of responses by urologists and radiation oncologists to the question whether they believed that three main potentially curative prostate cancer therapies are overused or underused in the United States (Fowler, 2000) ^148^

Figure C13 Distribution of urologists* in the U.S. regions (pooled analysis from 1999-2004)

* An average of absolute number of physicians identified themselves as urologists in the U.S. were obtained from the surveys conducted by the American Medical Association from 1999-2005 ^173^ – ^177^

Figure C14 Distribution of radiation oncologists* in U.S. regions

* An average of absolute number of physicians identified themselves as radiation oncologists in the U.S. were obtained from the surveys conducted by the American Medical Association from 1999-2005. ^173^ – ^177^

Figure C15 Ratio* of urologists (1999-2004) per 100,000 adult population (2002) in U.S. regions

* The ratio was calculated with an average of number of urologists in each state from 1999-2004 in numerator and the Census 2002 adult population in each state in denominator.

Figure C16 Ratio* of radiation oncologists (1999-2004) per 100,000 adult population (2002) in U.S. regions

* The ratio was calculated with an average number of radiation oncologists in each state from 1999-2004 in numerator and the Census 2002 adult population in each state in denominator.

Figure C17 Geographic variations in PSA testing*

* Average responses in U.S. regions to the BRFSS questionnaire ^138^ having PSA test during last 2 years in males older than 40 years

Figure C18 Geographic differences in PSA testing in U.S. regions*

* Average responses in U.S. regions to the BRFSS questionnaire ^138^ having PSA test ever and during last 2 years in males older than 40 years

Figure C19 Geographic variations in age adjusted incidence of prostate cancer per 100,000 male population (pooled analysis from 4 studies and CDC data)

Figure C20 Incidence of prostate cancer (per 100,000 male population) in U.S. regions (CDC data, 1999-2004) (U.S. Cancer Statistics Working Group, 2005)

Figure C21 Percentage of patients with prostate cancer treated with external beam radiation as an initial therapy in the U.S. regions (pooled analysis)

Figure C22 Percentage of patients with prostate cancer treated with radiation as an initial therapy in U.S. regions (pooled analysis)

Figure C23 Percentage of patients with localized prostate cancer treated with watchful waiting as an initial therapy in U.S. regions (pooled analysis)

Figure C24 Percentage of patients with prostate cancer treated with brachytherapy as an initial therapy in U.S. regions (pooled analysis)

Figure C25 Percentage of patients with prostate cancer treated with primary androgen deprivation as an initial therapy in U.S. regions (pooled analysis)

Figure C26 Relative risk of primary androgen deprivation as an initial therapy (polled analysis)

Figure C27 Percentage of patients with localized prostate cancer treated with radical prostatectomy as an initial therapy in the U.S. regions (pooled analysis)

Figure C28 Age adjusted rate of radical prostatectomy per 100,000 male population (results from individual studies)

Figure C29 Length of stay in hospital after radical prostatectomy in U.S. regions (pooled analysis)

Figure C30 Hospital charges for radical prostatectomy in U.S. regions (results from one study)

Figure C31 Mortality from prostate cancer (per 100,000 male population) among different races in U.S. regions (CDC data, 1999-2004)

Figure C32 Positive correlation between PSA testing among males older than 40 years and adjusted prostate cancer mortality in the USA. Ecologic analysis

Figure C33 Difference in surgery-related death rate corresponding to an increase by 10 radical prostatectomies performed in hospital

Figure C34 Relative risk of surgery related death corresponding to an increase by 10 radical prostatectomies performed in hospital

Figure C35 Relative risk of surgery related death in quartile and above and below mean of annual hospital volume (pooled analysis)

Figure C36 Number of avoided and excessive deaths in quartiles and above and below mean of annual hospital volume (pooled analysis)

Figure C37 Difference in surgery related complications rate corresponding to an increase by 10 radical prostatectomies performed in hospital

Figure C38 Relative risk of adjuvant therapy 6 months after radical prostatectomy in relation to hospital volume (results from one cohort study)

Figure C39 Difference in surgery related complication rates corresponding to an increase by 10 radical prostatectomies performed in hospital

Figure C40 Difference in length of stay and readmission rate corresponding to an increase by 10 procedures in annual hospital volume (results from individual studies)

Figure C41 Difference in length of stay and readmission rate corresponding to an increase by ten procedures in annual hospital volume (pooled analysis)

Figure C42 Difference in length of stay and readmission rate in categories of hospital volume (pooled analysis)

Figure C43 Difference in rates of surgery-related urinary complications, long term incontinence, and positive surgical margins corresponding to an increase by one radical prostatectomy performed by a surgeon (the results from individual studies)

Figure C44 Disease-specific survival at time points by treatment and PSA level (ng/ml)

## References for Appendix C

(Note that reference numbers are different than those in the text of the report)

1 Bill-Axelson A, Holmberg L, Ruutu M, et al. Scandinavian Prostate Cancer Screening Group Study No. 4. Radical prostatectomy versus watchful waiting in early prostate cancer. N Engl J Med. May 12. 2005;12(19):1977-84. [pmid: 15888698].
2 Klotz LH, Goldenberg SL, Jewett MA, et al. Canadian Uro-Oncology Group: Long-term followup of a randomized version of 0 versus 3 months of neoadjuvant androgen ablation before radical prostatectomy. J Urol. Sep. 2003;170(3):791-4. [pmid: 12913699].
3 Yeoh EE, Holloway RH, Fraser RJ, et al. Hypofractionated versus conventionally fractionated radiation therapy for prostate carcinoma: Updated results of a phase III randomized trial. Int J Radiat Oncol Biol Phys. Nov 15. 2006;66(4):1072-83. [pmid: 16965866].
4 Lukka H, Hayter C, Julian JA, et al. Randomized trial comparing two fractionation schedules for patients with localized prostate cancer. J Clin Oncol. Sep 1. 2005;23(25):6132-8. [pmid: 16135479].
5 Yeoh EE, Fraser RJ, McGowan RE, et al. Evidence for efficacy without increased toxicity of hypofractionated radiotherapy for prostate carcinoma: early results of a Phase III randomized trial. Int J Radiat Oncol Biol Phys. Mar 15. 2003;55(4):943-55. [pmid: 12605972].
6 Zietman AL, DeSilvio ML, Slate JD, et al. Comparison of conventional-dose vs. high-dose conformal radiation therapy in clinically localized adenocarcinoma of the prostate. A randomized controlled trial. JAMA. 2005;294:1233-9. [pmid: 16160131].
7 Denham JW, Steigler A, Lamb DS, et al. Short-term androgen deprivation and radiotherapy for locally advanced prostate cancer: results from the Trans-Tasman Radiation Oncology Group 96.01 randomised controlled trial. Lancet Oncol. Nov. 2005;6(11):841-50. [pmid: 16257791].
8 D'Amico A, Manola J, Loffredo M, et al. 6-month androgen suppression plus radiation therapy vs radiation therapy alone for patients with clinically localized prostate cancer: a randomized controlled trial. JAMA. 2004;292(7):821-7. [pmid: 15315996].
9 Arlen PM, Gulley JL, Todd N, et al. Antiandrogen, vaccine and combination therapy in patients with nonmetastatic hormone refractory prostate cancer. J Urol. Aug. 2005;174(2):539-46. [pmid: 16006888].
10 Homma Y, Azaka H, Okada K, et al. Prostate cancer study group radical prostatectomy and adjuvant endocrine therapy for prostate cancer with or without preoperative androgen deprivation: Five-year results. Int J Urol. 2004;11(5):295-303. [pmid: 15147545].
11 Schulman CC, Debruyne FM, Forster G, et al. 4-Year follow-up results of a European prospective randomized study on neoadjuvant hormonal therapy prior to radical prostatectomy in T2–3N0M0 prostate cancer: European Study Group on Neoadjuvant Treatment of Prostate Cancer. Eur Urol. Dec. 2000;38(6):706-13. [pmid: 11111188].
12 Soloway MS, Pareek K, Sharifi R, et al. Lupron Depot Neoadjuvant Prostate Cancer Study Group. Neoadjuvant androgen ablation before radical prostatectomy in cT2bNxMo prostate cancer: 5-year results. J Urol. Jan. 2002;167(1):112-6. [pmid: 11743286].
13 Paulson DF, Lin GH, Hinshaw W, et al. Radical surgery versus radiotherapy for adenocarcinoma of the prostate. J Urol. 1982;128:502-4. [pmid: 6811766].
14 Peeters ST, Heemsbergen WD, Koper PC, et al. Dose-response in radiotherapy for localized prostate cancer: results of the Dutch multicenter randomized phase III trial comparing 68 Gy of radiotherapy with 78 Gy. J Clin Oncol. May 1. 2006;24(13):1990-6. [pmid: 16648499].
15 Sathya JR, Davis IR, Julian JA, et al. Randomized trial comparing inidium implant plus external-beam radiation therapy with external-beam radiation therapy alone in node-negative locally advanced cancer of the prostate. J Clin Oncol. Feb 20. 2005;23(6):1192-9. [pmid: 15718316].
16 Crook J, Ludgate C, Malone S, et al. Report of a multicenter Canadian phase III randomized trial of 3 months vs. 8 months neoadjuvant androgen deprivation before standard-dose radiotherapy for clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. Sep 1. 2004;60(1):15-23. [pmid: 15337535].
17 Wallner K, Merrick G, Tru L, et al. 125I versus 103Pd for low-risk prostate cancer preliminary PSA outcomes from a prospective randomized multicenter trial. Int J Radiat Oncol Biol Phys. Dec 1. 2003;57(5):1297-303. [pmid: 14630265].
18 Wallner K, Merrick G, True L, et al. 20 Gy versus 44 Gy supplemental beam radiation with Pd-103 prostate brachytherapy: Preliminary biochemical outcomes from a prospective randomized multi-center trial. Radiother Oncol. Jun. 2005;75(3):307-10. [pmid: 16086912].
19 Wirth MP, See WA, McLeod DG, et al. Casodex Early Prostate Cancer Trialists' Group. Bicalutamide 150 mg in addition to standard care in patients with localized or locally advanced prostate cancer: results from the second analysis of the early prostate cancer program at median followup of 5.4 years. J Urol. Nov. 2004;172(5 Pt 1):1865-70. [pmid: 15540740].
20 Herstein A, Wallner K, Merrick G, et al. I-125 versus Pd-103 for low-risk prostate cancer: Long-term morbidity outcomes from a prospective randomized multicenter controlled trial. Cancer J. Sep–Oct. 2005;11(5):385-9. [pmid: 16259869].
21 Aus G, Pileblad E, Hugosson J. Cryosurgical ablation of the prostate: 5-year follow-up of a prospective study. Eur Urol. Aug. 2002;42(2):133-8. [pmid: 12160583].
22 Lee F, Bahn DK, McHugh TA, et al. US-guided percutaneous cryoablation of prostate cancer. Radiology. Sep. 1994;192(3):769-76. [pmid: 8058945].
23 Bahn DK, Lee F, Badalamet R, et al. Targeted cryoablation of the prostate: 7-year outcomes in the primary treatment of prostate cancer. Urology. Aug. 2002;60(2 Suppl):3-11. [pmid: 12206842].
24 Cohen JK, Miller RJ, Rooker GM, et al. Cryosurgical ablation of the prostate: two-year prostate-specific antigen and biopsy results. Urology. Mar. 1996;47(3):395-401. [pmid: 8633408].
25 Coogan CL, McKiel CF. Percutaneous cryoablation of the prostate: preliminary results after 95 procedures. J Urol. Nov. 1995;154(5):1813-7. [pmid: 7563354].
26 Cox RL, Crawford ED. Complications of cryosurgical ablation of the prostate to treat localized adenocarcinoma of the prostate. Urology. Jun. 1995;45(6):932-5. [pmid: 7771025].
27 Donnelly BJ, Saliken JC, Ernst DS, et al. Prospective trial of cryosurgical ablation of the prostate: five-year results. Urology. Oct. 2002;60(4):645-9. [pmid: 12385926].
28 Ellis DS. Cryosurgery as primary treatment for localized prostate cancer: a community hospital experience. Urology. Aug. 2002;60(2 Suppl 1):3-39. [pmid: 12206842].
29 Koppie TM, Shinohara K, Grossfeld GD, et al. The efficacy of cryosurgical ablation of prostate cancer: the University of California, San Francisco experience. J Urol. Aug. 1999;162(2):427-32. [pmid: 10411051].
30 Long JP, Fallick ML, LaRock DR, et al. Preliminary outcomes following cryosurgical ablation of the prostate in patients with clinically localized prostate carcinoma. J Urol. Feb. 1998;159(2):477-84. [pmid: 9649266].
31 Shinohara K, Connolly JA, Presti JCJ, et al. Cryosurgical treatment of localized prostate cancer (stages T1 to T4: preliminary results. J Urol. Jul. 1996;156(1):115-20. [pmid: 8648771].
32 Shinohara K, Rhee B, Presti JCJ, et al. Cryosurgical ablation of prostate cancer: patterns of cancer recurrence. J Urol. Dec. 1997;158(6):2206-9. discussion 9–10. [pmid: 9366345].
33 Sosa RE, Martin T, Lynn K. Cryosurgery Users' Group: Cryosurgical treatment of prostate cancer: a multicenter review of complications. J Urol. 1996;155:A361. [pmid: 7490887].
34 Wake RW, Hollabaugh RSJ, Bond KH. Cryosurgical ablation of the prostate for localized adenocarcinoma: a preliminary experience. J Urol. May. 1996;155(5):1663-6. [pmid: 8627849].
35 Wieder J, Schmidt JD, Casola G, et al. Transrectal ultrasound-guided transperineal cryoablation in the treatment of prostate carcinoma: preliminary results. J Urol. 1995;154(2 Pt 1):435-41. [pmid: 7541861].
36 Robinson JW, Saliken JC, Donnelly BJ, et al. Quality-of-life outcomes for men treated with cryosurgery for localized prostate carcinoma. Cancer. Aug. 1999;86(9):1793-801. [pmid: 10547553].
37 Robinson JW, Donnelly BJ, Saliken JC, et al. Quality of life and sexuality of men with prostate cancer 3 years after cryosurgery. Urology. Aug. 2002;60(2 Suppl 1):12-8. [pmid: 12206843].
38 Bahn DK, Lee F, Solomon MH, et al. Prostate cancer: US-guided percutaneous cryoablation. Work in progress. Radiology. Feb. 1995;194(2):551-6. [pmid: 7529937].
39 Hoznek A, Antiphon P, Borkowski T, et al. Assessment of surgical technique and perioperative morbidity associated with extraperitoneal versus transperitoneal laparoscopic radical prostatectomy. Urology. Mar. 2003;61(3):617-22. [pmid: 12639658].
40 Cathelineau X, Cahill D, Widmer H, et al. Transperitoneal or extraperitoneal approach for laparoscopic radical prostatectomy: a false debate over a real challenge. J Urol. Feb. 2004;171(2 Pt 1):714-6. [pmid: 14713793].
41 Ruiz L, Salomon L, Hoznek A, et al. Comparison of early oncologic results of laparoscopic radical prostatectomy by extraperitoneal versus transperitoneal approach. Eur Urol. Jul. 2004;46(1):50-4. discussion 4–6. [pmid: 15183547].
42 Erdogru T, Teber D, Frede T, et al. Comparison of transperitoneal and extraperitoneal laparoscopic radical prostatectomy using match-pair analysis. Eur Urol. Sep. 2004;46(3):312-9. discussion 20. [pmid: 15306100].
43 Brown JA, Rodin D, Lee B, et al. Transperitoneal versus extraperitoneal approach to laparoscopic radical prostatectomy: an assessment of 156 cases. Urology. Feb. 2005;65(2):320-4. [pmid: 15708046].
44 Remzi M, Klingler HC, Tinzl MV, et al. Morbidity of laparoscopic extraperitoneal versus transperitoneal radical prostatectomy verus open retropubic radical prostatectomy. Eur Urol. Jul. 2005;48(1):83-9. discussion 9. [pmid: 15967256].
45 Guillonneau B, Vallancien G. Laparoscopic radical prostatectomy: the Montsouris experience. J Urol. Feb. 2000;163(2):418-22. [pmid: 10647644].
46 Salomon L, Levrel O, de la Taille A, et al. Radical prostatectomy by the retropubic, perineal and laparoscopic approach: 12 years of experience in one center. Eur Urol. Aug. 2002;42(2):104-10. discussion 10–1. [pmid: 12160579].
47 Rassweiler J, Seemann O, Schulze M, et al. Laparoscopic versus open radical prostatectomy: a comparative study at a single institution. J Urol. May. 2003;169(5):1689-93. [pmid: 12686809].
48 Bhayani SB, Pavlovich CP, Hsu TS, et al. Prospective comparison of short-term convalescence: laparoscopic radical prostatectomy versus open radical retropubic prostatectomy. Urology. Mar. 2003;61(3):612-6. [pmid: 12639657].
49 Roumeguere T, Bollens R, Vanden Bossche M, et al. Radical prostatectomy: a prospective comparison of oncological and functional results between open and laparoscopic approaches. World J Urol. May. 2003;20(6):360-6. [pmid: 12682770].
50 Artibani W, Grosso G, Novara G, et al. Is laparoscopic radical prostatectomy better than traditional retropubic radical prostatectomy? An analysis of peri-operative morbidity in two contemporary series in Italy. Eur Urol. Oct. 2003;44(4):401-6. [pmid: 14499672].
51 Brown JA, Garlitz C, Gomella LG, et al. Perioperative morbidity of laparoscopic radical prostatectomy compared with open radical retropubic prostatectomy. Urol Oncol. Mar–Apr. 2004;22(2):102-6. [pmid: 15082005].
52 Fornara P, Zacharias M. [Minimal invasiveness of laparoscopic radical prostatectomy: reality or dream?]. Aktuelle Urol. Sep. 2004;35(5):395-405. [pmid: 15368129].
53 Keller H, Janetschek G, Abukora F, et al. Technique of radical prostatectomy - a head to head comparison of retropubic, peineal and laparoscopic access - data on perioperative morbidity. Eur Urol. 2005;Suppl 4(3):247. abstract No. 980.
54 Keller H, Schmeller N, Janetschek G. Urinary continence after retropubic, perineal, and laparoscopic radical prostatectomy: prospective comparative study. Eur Urol. 2005;Suppl 4(3):103. (abstract No. 403).
55 Anastasiadis AG, Salomon L, Katz R, et al. Radical retropubic versus laparoscopic prostatectomy: a prospective comparison of functional outcome. Urology. Aug. 2003;62(2):292-7. [pmid: 12893338].
56 Tooher R, Swindle P, Woo H, et al. Laparoscopic radical prostatectomy for localized prostate cancer: a systematic review of comparative studies. J Urol. Jun. 2006;175(6):2011-7. [pmid: 16697787].
57 Ahlering TE, Eichel L, Edwards RA, et al. Robotic radical prostatectomy: a technique to reduce pT2 positive margins. Urology. Dec. 2004;64(6):1224-8. [pmid: 15596205].
58 Ahlering TE, Eichel L, Skarecky D. Rapid communication: early potency outcomes with cautery-free neurovascular bundle preservation with robotic laparoscopic radical prostatectomy. J Endourol. Jul–Aug. 2005;19(6):715-8. [pmid: 16053361].
59 Ahlering TE, Woo D, Eichel L, et al. Robot-assisted versus open radical prostatectomy: a comparison of one surgeon's outcomes. Urology. May. 2004;63(5):819-22. [pmid: 15134953].
60 Badani KK, Bhandari A, Tewari A, et al. Comparison of two-dimensional and three-dimensional suturing: is there a difference in a robotic surgery setting?. J Endourol. Dec. 2005;19(10):1212-5. [pmid: 16359218].
61 Farnham SB, Webster TM, Herrell SD, et al. Intraoperative blood loss and transfusion requirements for robotic-assisted radical prostatectomy versus radical retropubic prostatectomy. Urology. Feb. 2006;67(2):360-3. [pmid: 16461085].
62 Hu JC, Nelson RA, Wilson TG, et al. Perioperative complications of laparoscopic and robotic assisted laparoscopic radical prostatectomy. J Urol. Feb. 2006;175(2):541-6. discussion 6. [pmid: 16406991].
63 Menon M, Shrivastava A, Tewari A, et al. Laparoscopic and robot assisted radical prostatectomy: establishment of a structured program and preliminary analysis of outcomes. J Urol. Sep. 2002;168(3):945-9. [pmid: 12187196].
64 Menon M, Tewari A, Baize B, et al. Prospective comparison of radical retropubic prostatectomy and robot-assisted anatomic prostatectomy: the Vattikuti Urology Institute experience. Urology. Nov. 2002;60(5):864-8. [pmid: 12429317].
65 Tewari A, Srivasatava A, Menon M. A prospective comparison of radical retropubic and robot-assisted prostatectomy: experience in one institution. BJU Int. Aug. 2003;92(3):205-10. [pmid: 12887468].
66 Menon M, Hemal AK. Vattikuti Institute prostatectomy: a technique of robotic radical prostatectomy: experience in more than 1000 cases. J Endourol. Sep. 2004;18(7):611-9. discussion 9. [pmid: 15597646].
67 Rozet F, Jaffe J, Braud G, et al. A direct comparison of robotic assisted versus pure laparoscopic radical prostatectomy: a single institution experience. J Urol. Aug. 2007;178(2):478-82. [pmid: 17561160].
68 Patel VR, Thaly R, Shah K. Robotic radical prostatectomy: outcomes of 500 cases. BJU Int. May. 2007;99(5):1109-12. [pmid: 17437441].
69 Zorn KC, Gofrit ON, Orvieto MA, et al. Robotic-assisted laparoscopic prostatectomy: functional and pathologic outcomes with interfascial nerve preservation. Eur Urol. Mar. 2007;51(3):755-62. discussion 63. [pmid: 17084520].
70 Mikhail AA, Orvieto MA, Billatos ES, et al. Robotic-assisted laparoscopic prostatectomy: first 100 patients with one year of follow-up. Urology. Dec. 2006;68(6):1275-9. [pmid: 17169649].
71 Tseng TY, Kuebler HR, Cancel QV, et al. Prospective health-related quality-of-life assessment in an initial cohort of patients undergoing robotic radical prostatectomy. Urology. Nov. 2006;68(5):1061-6. [pmid: 17113898].
72 Kupelian PA, Reddy CA, Carlson TP, et al. Preliminary observations on biochemical relapse-free survival rates after shoft-course intensity-modulated radiotherapy (70 Gy at 2.5 Gy/fraction) for localized prostate cancer. Int J Radiat Oncol Biol Phys. Jul 15. 2002;53(4):904-12. [pmid: 12095556].
73 Kupelian PA, Thakkar VV, Khuntia D, et al. Hypofractionated intensity-modulated radiotherapy (70 gy at 2.5 Gy per fraction) for localized prostate cancer: long-term outcomes. Int J Radiat Oncol Biol Phys. Dec 1. 2005;63(5):1463-8. [pmid: 16169683].
74 Zelefsky MJ, Chan H, Hunt M, et al. Long-term outcome of high dose intensity modulated radiation therapy for patients with clinically localized prostate cancer. J Urol. Oct. 2006;176(4 Pt 1):1415-9. [pmid: 16952647].
75 De Meerleer GO, Fonteyne VH, Vakaet L, et al. Intensity-modulated radiation therapy for prostate cancer: late morbidity and results on biochemical control. Radiother Oncol. Feb. 2007;82(2):160-6. [pmid: 17222931].
76 D'Amico AV, Manola J, McMahon E, et al. A prospective evaluation of rectal bleeding after dose-escalated three-dimensional conformal radiation therapy using an intrarectal balloon for prostate gland localization and immobiliation. Urology. Apr. 2006;67(4):780-4. [pmid: 16584760].
77 Zelefsky MJ, Fuks Z, Hunt M, et al. High-dose intensity modulated radiation therapy for prostate cancer: early toxicity and biochemical outcome in 772 patients. Int J Radiat Oncol Biol Phys. Aug 1. 2002;53(5):1111-6. [pmid: 12128109].
78 Gelet A, Chapelon JY, Bouvier R, et al. Transrectal high-intensity focused ultrasound: minimally invasive therapy of localized prostate cancer. J Endourol. Aug. 2000;14(6):519-28. [pmid: 10954310].
79 Gelet A, Chapelon JY, Bouvier R, et al. Transrectal high intensity focused ultrasound for the treatment of localized prostate cancer: factors influencing the outcome. Eur Urol. Aug. 2001;40(2):124-9. [pmid: 11528187].
80 Thuroff S, Chaussy C, Vallancien G, et al. High-intensity focused ultrasound and localized prostate cancer: efficacy results from the European multicentric study. J Endourol. Oct. 2003;17(8):673-7. [pmid: 14622488].
81 Chaussy C, Thuroff S. The status of high-intensity focused ultrasound in the treatment of localized prostate cancer and the impact of a combined resection. Curr Urol Rep. Jun. 2003;4(3):248-52. [pmid: 12756090].
82 Blana A, Walter B, Rogenhofer S, et al. High-intensity focused ultrasound for the treatment of localized prostate cancer: 5-year experience. Urology. Feb. 2004;63(2):297-300. [pmid: 14972475].
83 Uchida T, Baba S, Irie A, et al. Transrectal high-intensity focused ultrasound in the treatment of localized prostate cancer: a multicenter study. Hinyokiki Kiyo. Oct. 2005;51(10):651-8.
84 Blana A, Rogenhofer S, Ganzer R, et al. Morbidity associated with repeated transrectal high-intensity focused ultrasound treatment of localized prostate cancer. World J Urol. Nov. 2006;24(5):585-90. [pmid: 16850340].
85 Uchida T, Illing RO, Cathcart PJ, et al. The effect of neoadjuvant androgen suppression on prostate cancer-related outcomes after high-intensity focused ultrasound therapy. BJU Int. Oct. 2006;98(4):770-2. [pmid: 16879448].
86 Uchida T, Ohkusa H, Nagata Y, et al. Treatment of localized prostate cancer using high-intensity focused ultrasound. BJU Int. Jan. 2006;97(1):56-61. [pmid: 16336329].
87 Poissonnier L, Chapelon JY, Rouviere O, et al. Control of prostate cancer by transrectal HIFU in 227 patients. Eur Urol. Feb. 2007;51(2):381-7. [pmid: 16857310].
88 Yonemoto LT, Slater JD, Rossi CJ Jr, et al. Combined proton and photon conformal radiation therapy for locally advanced carcinoma of the prostate: preliminary results of a phase I/II study. Int J Radiat Oncol Biol Phys. Jan 1. 1997;37(1):21-9. [pmid: 9054873].
89 Slater JD, Rossi CJ Jr, Yonemoto LT, et al. Conformal proton therapy for early-stage prostate cancer. Urology. May. 1999;53(5):978-84. [pmid: 10223493].
90 Slater JD, Rossi CJ Jr, Yonemoto LT, et al. Proton therapy for prostate cancer: the initial Loma Linda University experience. Int J Radiat Oncol Biol Phys. Jun 1. 2004;59(2):348-52. [pmid: 15145147].
91 Rossi CJ Jr, Slater JD, Yonemoto LT, et al. Influence of patient age on biochemical freedom from disease in patients undergoing conformal proton radiotherapy of organ-confined prostate cancer. Urology. Oct. 2004;64(4):729-32. [pmid: 15491710].
92 Nihei K, Ogino T, Ishikura S, et al. Phase II feasibility study of high-dose radiotherapy for prostate cancer using proton boost therapy: first clinical trial of proton beam therapy for prostate cancer in Japan. Jpn J Clin Oncol. Dec. 2005;35(12):745-52. [pmid: 16314345].
93 Potosky AL, Davis WW, Hoffman RM, et al. Five-year outcomes after prostatectomy or radiotherapy for prostate cancer: The prostate cancer outcomes study. JNCI. 2004;96(18):1358-67. [pmid: 15367568].
94 Hoffman RM, Hunt WC, Gilliland FD, et al. Patient satisfaction with treatment decisions for clinically localized prostate carcinoma. Results from the Prostate Cancer Outcomes Study. Cancer. 2003;97(7):1653-62. [pmid: 12655522].
95 Lee WR, Hall MC, McQuellon RP, et al. A prospective quality-of-life study in men with clinically localized prostate carcinoma treated with radical prostatectomy, external beam radiotherapy, or interstitial brachytherapy. Int J Radiat Oncol Biol Phys. 2001;51(3):614-23. [pmid: 11597800].
96 Schapira MM, Lawrence WF, Katz DA, et al. Effect of treatment on quality of life among men with clinically localized prostate cancer. Med Care. Mar. 2001;39(3):243-53. [pmid: 11242319].
97 Soderdahl DW, Davis JW, Schellhammer PF, et al. Prospective longitudinal comparative study of health-related quality of life in patients undergoing invasive treatments for localized prostate cancer. Journal of Endourology. 2005;19(3):318-26. [pmid: 15865521].
98 Fulmer BR, Bissonette EA, Petroni GR, et al. Prospective assessment of voiding and sexual function after treatment for localized prostate carcinoma: Comparison of radical prostatectomy to hormonobrachytherapy with and without external beam radiotherapy. Cancer. Jun 1. 2001;90(11):2046-55. [pmid: 11391584].
99 Galbraith ME, Ramirez JM, Pedro LW. Quality of life, health outcomes, and identity for patients with prostate cancer in five different treatment groups. Oncology Nursing Forum. Apr. 2001;28(3):551-60. [pmid: 11338762].
100 Fransson P, Damber JE, Tomic R, et al. Quality of life and symptoms in a randomized trial of radiotherapy versus deferred treatment of localized prostate carcinoma. Cancer. Dec 15. 2001;92(12):3111-9. [pmid: 11753990].
101 Steineck G, Helgesen F, Adolfsson J, et al. Quality of life after radical prostatectomy or watchful waiting. N Engl J Med. 2002;347(11):790-6. [pmid: 12226149].
102 Lu-Yao GL, Greenberg ER. Changes in prostate cancer incidence and treatment in USA. Lancet. Jan 29. 1994;343(8892):251-4. [pmid: 7905093].
103 Kafadar K. Geographic trends in prostate cancer mortality: An application of spatial smoothers and the need for adjustment. Annals of Epidemiology. 1997;7(1):35-45. [pmid: 9034405].
104 Jemal A, Kulldorff M, Devesa SS, et al. A geographic analysis of prostate cancer mortality in the United States, 1970-89. International Journal of Cancer. 2002;101(2):168-74. [pmid: 12209994].
105 Jemal A, Ward E, Wu X, et al. Geographic Patterns of Prostate Cancer Mortality and Variations in Access to Medical Care in the United States. Cancer Epidemiol Biomarkers Prev. March 1. 2005;14(3):590-5. [pmid: 15767335].
106 Escobedo LG, Rivas SD, Holmes MD. Prostate cancer mortality in Connecticut, Iowa and New Mexico African American men. Cancer Detection and Prevention. 2004;28(5):375-80. [pmid: 15542264].
107 Lu-Yao G, Albertsen PC, Stanford JL, et al. Natural experiment examining impact of aggressive screening and treatment on prostate cancer mortality in two fixed cohorts from Seattle area and Connecticut. BMJ. Oct 5. 2002;325(7367):740. [pmid: 12364300].
108 Lu-Yao GL, McLerran D, Wasson J, et al. An assessment of radical prostatectomy. Time trends, geographic variation, and outcomes. The Prostate Patient Outcomes Research Team. JAMA. May 26. 1993;269(20):2633-6. [pmid: 8487445].
109 Mushinski M. Average charges for a radical prostatectomy and a transurethral resection of the prostate (TURP): geographic variations, 1994. Oncology (Williston Park) 1996 Aug; 10(8):1162–4, 9, 73–6 passim.
110 Mettlin CJ, Murphy GP, Rosenthal DS, et al. The National Cancer Data Base report on prostate carcinoma after the peak in incidence rates in the U.S. The American College of Surgeons Commission on Cancer and the American Cancer Society. Cancer. Oct 15. 1998;83(8):1679-84. [pmid: 9781963].
111 Krupski TL, Kwan L, Litwin MS. Sociodemographic factors associated with postprostatectomy radiotherapy. Prostate Cancer and Prostatic Diseases. 2005;8(2):184-8. [pmid: 15809671].
112 Cooperberg MR, Grossfeld GD, Lubeck DP, et al. National practice patterns and time trends in androgen ablation for localized prostate cancer. J Natl Cancer Inst. Jul 2. 2003;95(13):981-9. [pmid: 12837834].
113 Lai S, Lai H, Krongrad A, et al. Overall and disease-specific survival after radical prostatectomy: geographic uniformity. Urology. 2001;57(3):504-9. [pmid: 11248629].
114 Bubolz T, Wasson JH, Lu-Yao G, et al. Treatments for prostate cancer in older men: 1984-1997. Urology. 2001;58(6):977-82. [pmid: 11744472].
115 Cooperberg MR, Lubeck DP, Meng MV, et al. The Changing Face of Low-Risk Prostate Cancer: Trends in Clinical Presentation and Primary Management. J Clin Oncol. June 1. 2004;22(11):2141-9. [pmid: 15169800].
116 Saigal CS, Pashos CL, Henning JM, et al. Variations in use of imaging in a national sample of men with early-stage prostate cancer. Urology. 2002;59(3):400-4. [pmid: 11880080].
117 Wilt TJ, Cowper DC, Gammack JK, et al. An evaluation of radical prostatectomy at Veterans Affairs Medical Centers: time trends and geographic variation in utilization and outcomes. Med Care. Oct. 1999;37(10):1046-56. [pmid: 10524371].
118 Hu JC, Gold KF, Pashos CL, et al. Role of surgeon volume in radical prostatectomy outcomes. J Clin Oncol. Feb 1. 2003;21(3):401-5. [pmid: 12560426].
119 Litwin MS, Pasta DJ, Stoddard ML, et al. Epidemiological trends and financial outcomes in radical prostatectomy among Medicare beneficiaries, 1991 to 1993. J Urol. Aug. 1998;160(2):445-8. [pmid: 9679895].
120 Brandeis J, Pashos CL, Henning JM, et al. A nationwide charge comparison of the principal treatments for early stage prostate carcinoma. Cancer. Oct 15. 2000;89(8):1792-9. [pmid: 11042575].
121 Ellison LM, Heaney JA, Birkmeyer JD. The effect of hospital volume on mortality and resource use after radical prostatectomy. J Urol. Mar. 2000;163(3):867-9. [pmid: 10687994].
122 Begg CB, Riedel ER, Bach PB, et al. Variations in morbidity after radical prostatectomy. N Engl J Med. Apr 11. 2002;346(15):1138-44. [pmid: 11948274].
123 Yao SL, Lu-Yao G. Population-Based Study of Relationships Between Hospital Volume of Prostatectomies, Patient Outcomes, and Length of Hospital Stay. J Natl Cancer Inst. Nov 17. 1999;91(22):1950-6. [pmid: 10564679].
124 Wennberg JE, Roos N, Sola L, et al. Use of claims data systems to evaluate health care outcomes. Mortality and reoperation following prostatectomy. JAMA. Feb 20. 1987;257(7):933-6. [pmid: 3543419].
125 Ellison LM, Trock BJ, Poe NR, et al. The effect of hospital volume on cancer control after radical prostatectomy. J Urol. Jun. 2005;173(6):2094-8. [pmid: 15879850].
126 Imperato PJ, Waisman J, Wallen M, et al. The use of quality indicators for assessing radical prostatectomy specimens. Am J Med Qual. Sep–Oct. 2000;15(5):212-20. [pmid: 11022368].
127 Karakiewicz PI, Bazinet M, Aprikian AG, et al. Thirty-day mortality rates and cumulative survival after radical retropubic prostatectomy. Urology. 1998;52(6):1041-6. [pmid: 9836552].
128 Gheiler EL, Lovisolo JA, Tiguert R, et al. Results of a clinical care pathway for radical prostatectomy patients in an open hospital - multiphysician system. Eur Urol. 1999;35(3):210-6. [pmid: 10072622].
129 Gaylis FD, Friedel WE, Armas OA. Radical retropubic prostatectomy outcomes at a community hospital. J Urol. Jan. 1998;159(1):167-71. [pmid: 9400463].
130 Yuan Z, Cooper GS, Einstadter D, et al. The association between hospital type and mortality and length of stay: a study of 16.9 million hospitalized Medicare beneficiaries. Med Care. Feb. 2000;38(2):231-45. [pmid: 10659696].
131 Bianco FJ Jr, Riedel ER, Begg CB, et al. Variations among high volume surgeons in the rate of complications after radical prostatectomy: further evidence that technique matters. J Urol. Jun. 2005;173(6):2099-103. [pmid: 15879851].
132 Dash A, Dunn RL, Resh J, et al. Patient, surgeon, and treatment characteristics associated with homologous blood transfusion requirement during radical retropubic prostatectomy: multivariate nomogram to assist patient counseling. Urology. 2004;64(1):117-22. [pmid: 15245947].
133 Litwiller SE, Djavan B, Klopukh BV, et al. Radical retropubic prostatectomy for localized carcinoma of the prostate in a large metropolitan hospital: changing trends over a 10-year period (1984-1994). Dallas Outcomes Research Group for Urological Disorders. Urology. May. 1995;45(5):813-22. [pmid: 7747373].
134 Eastham JA, Kattan MW, Riedel E, et al. Variations among individual surgeons in the rate of positive surgical margins in radical prostatectomy specimens. J Urol. Dec. 2003;170(6 Pt 1):2292-5. [pmid: 14634399].
135 Hernandez DJ, Epstein JI, Trock BJ, et al. Radical retropubic prostatectomy. How often do experienced surgeons have positive surgical margins when there is extraprostatic extension in the region of the neurovascular bundle?. J Urol. Feb. 2005;173(2):446-9. [pmid: 15643199].
136 Leibman BD, Dillioglugil O, Abbas F, et al. Impact of a clinical pathway for radical retropubic prostatectomy. Urology. Jul. 1998;52(1):94-9. [pmid: 9671877].
137 Shaw PA, Etzioni R, Zeliadt SB, et al. An Ecologic Study of Prostate-specific Antigen Screening and Prostate Cancer Mortality in Nine Geographic Areas of the United States. Am J Epidemiol. Dec 1. 2004;160(11):1059-69. [pmid: 15561985].
138 Centers for Disease Control and Prevention (CDC). Behavioral Risk Factor Surveillance System Survey Data. Atlanta, Georgia: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. http://www.cdc.gov/brfss/technical_infodata/; 2005.
139 Kim HL, Benson DA, Stern SD, et al. Practice trends in the management of prostate disease by family practice physicians and general internists: an internet-based survey. Urology. 2002;59(2):266-71. [pmid: 11834400].
140 McKnight JT, Tietze PH, Adcock BB, et al. Screening for prostate cancer: a comparison of urologists and primary care physicians. South Med J. Sep. 1996;89(9):885-8. [pmid: 8790311].
141 Fowler FJ Jr, Bin L, Collins MM, et al. Prostate cancer screening and beliefs about treatment efficacy: a national survey of primary care physicians and urologists. Am J Med. Jun. 1998;104(6):526-32. [pmid: 9674714].
142 Shay BF, Schmidt JD, Thomas R, et al. Urology practice patterns after residency training in radical perineal prostatectomy. Urology. 2002;60(5):766-9. [pmid: 12429292].
143 Plawker MW, Fleisher JM, Vapnek EM, et al. Current trends in prostate cancer diagnosis and staging among United States urologists. J Urol. Nov. 1997;158(5):1853-8. [pmid: 9334616].
144 Gee WF, Holtgrewe HL, Albertsen PC, et al. Practice trends in the diagnosis and management of prostate cancer in the United States. J Urol. Jul. 1995;154(1):207-8. [pmid: 7539862].
145 Hanna CL, Mason MD, Donovan JL, et al. Clinical oncologists favour radical radiotherapy for localized prostate cancer: a questionnaire survey. BJU International. 2002;90(6):558-60. [pmid: 12230617].
146 Salminen EK, Wickstrom JE, Vahlberg T, et al. Trends in the use of androgen deprivation in prostate cancer. Acta Oncol. 2004;43(4):382-7. [pmid: 15303500].
147 McNaughton-Collins M, Barry MJ, Zietman A, et al. United States radiation oncologists and urologists opinions about screening and treatment of prostate cancer vary by region. Urology. 2002;60(4):628-33. [pmid: 12385923].
148 Fowler FJ Jr, McNaughton-Collins M, Albertsen PC, et al. Comparison of Recommendations by Urologists and Radiation Oncologists for Treatment of Clinically Localized Prostate Cancer. JAMA. June 28. 2000;283(24):3217-22. [pmid: 10866869].
149 Kramolowsky EV, Wood NL, Rollins KL, et al. The role of the physician in effecting change in hospital charge for radical prostatectomy. J Am Coll Surg. May. 1995;180(5):513-8. [pmid: 7749525].
150 Kramolowsky EV, Wood NL, Rollins KL, et al. Impact of physician awareness on hospital charges for radical retropubic prostatectomy. J Urol. Jul. 1995;154(1):139-42. [pmid: 7776408].
151 Diamond JJ, Steinfeld AD, Hanks GE. The relationship between facility structure and outcome in cancer of the prostate and uterine cervix. Int J Radiat Oncol Biol Phys. Sep. 1991;21(4):1085-7. [pmid: 1917606].
152 Cazzaniga LF, Marinoni MA, Bossi A, et al. Interphysician variability in defining the planning target volume in the irradiation of prostate and seminal vesicles. Radiother Oncol. Jun. 1998;47(3):293-6. [pmid: 9681893].
153 Van Poppel H, Collette L, Kirkali Z, et al. Quality control of radical prostatectomy: a feasibility study. Eur J Cancer. May. 2001;37(7):884-91. [pmid: 11313177].
154 Votron L, D'Hoore W, Swine C, et al. The opinion of general practitioners on the treatment of prostate and breast cancer in elderly people: results of a survey based on clinical models. Clin Oncol (R Coll Radiol). Oct. 2004;16(7):474-8. [pmid: 15490809].
155 Maliski SL, Kwan L, Orecklin JR, et al. Predictors of fatigue after treatment for prostate cancer. Urology. Jan. 2005;65(1):101-8. [pmid: 15667873].
156 Maliski SL, Kwan L, Krupski T, et al. Confidence in the ability to communicate with physicians among low-income patients with prostate cancer. Urology. 2004;64(2):329-34. [pmid: 15302489].
157 Shahinian VB, Kuo YF, Freeman JL, et al. Determinants of Androgen Deprivation Therapy Use for Prostate Cancer: Role of the Urologist. J Natl Cancer Inst. June 21. 2006;98(12):839-45. [pmid: 16788157].
158 Greenwald HP, Henke CJ. HMO membership, treatment, and mortality risk among prostatic cancer patients. Am J Public Health. Aug. 1992;82(8):1099-104. [pmid: 1636829].
159 Potosky AL, Merrill RM, Riley GF, et al. Prostate cancer treatment and ten-year survival among group/staff HMO and fee-for-service Medicare patients. Health Serv Res. Jun. 1999;34(2):525-46. [pmid: 10357289].
160 Ahlering TE, Skarecky D, Lee D, et al. Successful transfer of open surgical skills to a laparoscopic environment using a robotic interface: initial experience with laparoscopic radical prostatectomy. J Urol. Nov. 2003;170(5):1738-41. [pmid: 14532766].
161 Arai Y, Egawa S, Terachi T, et al. Morbidity of laparoscopic radical prostatectomy: summary of early multi-institutional experience in Japan. Int J Urol. Aug. 2003;10(8):430-4. [pmid: 12887364].
162 Baumert H, Fromont G, Adorno Rosa J, et al. Impact of learning curve in laparoscopic radical prostatectomy on margin status: prospective study of first 100 procedures performed by one surgeon. J Endourol. Mar. 2004;18(2):173-6. [pmid: 15072626].
163 Dahl DM, L'Esperance JO, Trainer AF, et al. Laparoscopic radical prostatectomy: initial 70 cases at a U.S. university medical center. Urology. Nov. 2002;60(5):859-63. [pmid: 12429316].
164 Eden CG, King D, Kooiman GG, et al. Transperitoneal or extraperitoneal laparoscopic radical prostatectomy: does the approach matter?. J Urol. Dec. 2004;172(6 Pt 1):2218-23. [pmid: 15538235].
165 El-Feel A, Davis JW, Deger S, et al. Laparoscopic radical prostatectomy—an analysis of factors affecting operating time. Urology. Aug. 2003;62(2):314-8. [pmid: 12893342].
166 El-Feel A, Davis JW, Deger S, et al. Positive margins after laparoscopic radical prostatectomy: a prospective study of 100 cases performed by 4 different surgeons. Eur Urol. Jun. 2003;43(6):622-6. [pmid: 12767362].
167 Fabrizio MD, Tuerk I, Schellhammer PF. Laparoscopic radical prostatectomy: decreasing the learning curve using a mentor initiated approach. J Urol. Jun. 2003;169(6):2063-5. [pmid: 12771720].
168 Frede T, Erdogru T, Zukosky D, et al. Comparison of training modalities for performing laparoscopic radical prostatectomy: experience with 1,000 patients. J Urol. Aug. 2005;174(2):673-8. discussion 8. [pmid: 16006945].
169 Ghavamian R, Schenk G, Hoenig DM, et al. Overcoming the steep learning curve of laparoscopic radical prostatectomy: single-surgeon experience. J Endourol. Aug. 2004;18(6):567-71. [pmid: 15333224].
170 Hoznek A, Salomon L, Olsson LE, et al. Laparoscopic radical prostatectomy. The Creteil experience. Eur Urol. Jul. 2001;40(1):38-45. [pmid: 11528175].
171 Keyes M, Schellenberg D, Moravan V, et al. Decline in urinary retention incidence in 805 patients after prostate brachytherapy: the effect of learning curve?. Int J Radiat Oncol Biol Phys. Mar 1. 2006;64(3):825-34. [pmid: 16458775].
172 Stolzenburg JU, Schwaibold H, Bhanot SM, et al. Modular surgical training for endoscopic extraperitoneal radical prostatectomy. BJU Int. Nov. 2005;96(7):1022-7. [pmid: 16225521].
173 Pasko T. Physician characteristics and distribution in the U.S. 2001-2002 ed. Chicago, IL: Dept. of Physician Practice and Communications Information, Division of Data Survey and Data Resources, American Medical Association; 2001.
174 Pasko T, Seidman B. Physician characteristics and distribution in the U.S. 2002-2003 ed. Chicago, IL: American Medical Association; Survey & Data Resources. AMA Press; 2002.
175 Pasko T, Smart DR. Physician characteristics and distribution in the US. 2003-2004 ed. Chicago, IL: American Medical Association; Survey & Data Resources, AMA Press; 2003.
176 Pasko T, Smart DR. Physician characteristics and distribution in the US. 2005 ed. Chicago, IL: American Medical Association; Survey & Data Resources. AMA Press; 2005.
177 Pasko T, Smart DR. Physician characteristics and distribution in the US. 2004 ed. Chicago, IL: American Medical Association; Survey & Data Resources. AMA Press; 2004.
178 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999-2002 Incidence and Mortality Web-based Report Version. Department of Health and Human Services, Centers for Disease Control and Prevention, and National Cancer Institute. Available at: Available at: www.cdc.gov/cancer/npcr/uscs/.
179 Bill-Axelson A, Holmberg L, Ruutu M, et al. Radical prostatectomy versus watchful waiting in early prostate cancer. N Engl J Med. 2005;352(19):1977-84. [pmid: 15888698].