# Peer Reviewers

- Richard M. Hoffman, MD
- Associate Professor
- Department of Internal Medicine
- University of New Mexico Health Sciences Center
- Albuquerque, New Mexico

- John Wei, MD
- Associate Professor
- Department of Urology at the Michigan Urology Center
- University of Michigan Health System
- Ann Arbor, Michigan