# Search Strategy

Question 3. How do provider/hospital characteristics affect outcomes overall and differentially (e.g., geographic region and volume)?

Search Strings | Studies Identified
“Outcome assessment (health care)”[MeSH] AND “prostatic neoplasms”[MeSH] AND hospital volume | 29
“Outcome assessment (health vare)”[MeSH] AND “prostatic neoplasms”[MeSH] AND surgeon volume | 11
“Cryotherapy”[MeSH] AND “prostatic neoplasms”[MeSH] AND “outcome and process assessment (health care)”[MeSH] | 7
“Brachytherapy”[MeSH] AND “prostatic neoplasms”[MeSH] AND “outcome and process assessment (health care)”[MeSH] | 249
“Radiotherapy”[MeSH] “prostatic neoplasms”[MeSH] AND “outcome and process assessment (health care)”[MeSH] | 624
“Radiotherapy”[MeSH] “Prostatic Neoplasms”[MeSH] AND “outcome and process assessment (health care)”[MeSH] AND hospital volume | 9
“Prostatic neoplasms”[MeSH] AND “outcome and process assessment (health care)”[MeSH] AND “prostatectomy”[MeSH], Limits: humans, English, published from 01/01/1993 to 01/12/2005 | 702
“Health care quality, access, and evaluation”[MeSH] AND “prostatic neoplasms”[MeSH] AND hospital volume | 100
“Health care quality, access, and evaluation”[MeSH] AND “prostatic neoplasms”[MeSH] AND “clinical competence”[MeSH] | 6
“Prostatic neoplasms”[MeSH] AND “clinical competence”[MeSH] | 47
Physician's practice patterns”[MeSH] AND “prostatic neoplasms”[MeSH] Limit: human, English | 142
“Health services research/organization and administration”[MeSH] OR “health Services research/standards”[MeSH] OR “health services research/statistics and numerical data”[MeSH] OR “health services research/trends”[MeSH]) AND “prostatic neoplasms”[MeSH] | 20
“United States/epidemiology”[MeSH] AND “prostatic neoplasms”[MeSH] NOT review, English, human | 608
“Physicians”[MeSH] AND “prostatic neoplasms”[MeSH] | 20
“Hospitals”[MeSH] AND “prostatic neoplasms”[MeSH] NOT review NOT letter NOT editorials | 75
“Prostatic neoplasms”[MeSH] AND “malpractice”[MeSH] | 17
Hospital volume AND prostate cancer | 132
“Prostatic neoplasms”[MeSH] AND “learning curve” Limits: English, humans | 67
“Physicians”[MeSH] AND “prostatic neoplasms”[MeSH] AND “learning curve” Limits: English, humans | 0
“Prostatic neoplasms”[MeSH] AND “learning curve” Limits: English, randomized controlled trial, humans | 0
“Prostatic neoplasms”[MeSH] AND “learning curve” | 84

Quality of Life. The literature search was done on MEDLINE (via OVID) using the following combination of MeSH headings, keywords, and publication types (search results were limited to: human studies; English-language articles; year of publication = 2000 to 2006; not comments, letters or reviews; and clinical trials, clinical trials phase I, clinical trials phase II, clinical trials phase III, clinical trials phase IV, controlled clinical trials, meta analyses, or randomized controlled trials):

((((quality of life or qol or hrqol).mp. OR exp “quality of life”/ OR health status.mp. OR exp health status/) AND exp prostatic neoplasms/) NOT (metastat$ or advanced).mp.)

HIFU. The literature search was done on PubMed using the following combination of MeSH headings, keywords and limits:

“Prostatic Neoplasms”[MeSH] AND “Ultrasound, High-Intensity Focused, Transrectal” [MeSH] Limits: English, Clinical Trial, Randomized Controlled Trial, Male, Humans

IMRT. The literature search was done on PubMed using the following combination of MeSH headings, keywords and limits:

“Prostatic Neoplasms”[MeSH] AND “Radiotherapy, Intensity-Modulated”[MeSH] NOT review NOT case-reports NOT letter NOT editorial Limits: Entrez Date from 2004/01/01 to 2007/04/31, English, Clinical Trial, Randomized Controlled Trial, Male, Humans

PBRT. The literature search was done on PubMed using the following combination of MeSH headings, keywords and limits:

(“Prostatic Neoplasms/radiotherapy”[MeSH] OR “Prostatic Neoplasms/therapy”[MeSH]) AND proton NOT Review NOT Comment NOT letter NOT editorial NOT Case-reports Limits: English, Clinical Trial, Randomized Controlled Trial, “Clinical Trial, Phase II”, “Clinical Trial, Phase III”, “Clinical Trial, Phase IV”, Comparative Study, Male, Humans

Cryosurgery. The literature search was done on PubMed using the following combination of MeSH headings, keywords and limits:

“Prostatic Neoplasms”[MeSH] AND “Cryosurgery”[MeSH] NOT Review NOT Comment NOT letter NOT editorial NOT Case-reports Limits: English, Clinical Trial, Randomized Controlled Trial, Male, Humans

Laparoscopic Surgery. The literature search was done on PubMed using the following combination of MeSH headings, keywords and limits:

“Prostatic Neoplasms”[MeSH] AND “Laparoscopy”[MeSH] AND “Prostatectomy” [MeSH] NOT Review NOT Comment NOT letter NOT editorial NOT Case-reports Limits: English, Clinical Trial, Randomized Controlled Trial, Male, Humans

Robotic Surgery. The literature search was done on PubMed using the following combination of MeSH headings, keywords and limits:

“Prostatic Neoplasms”[MeSH] AND “Robotics”[MeSH] AND “Prostatectomy”[MeSH] NOT Review NOT Comment NOT letter NOT editorial NOT Case-reports Limits: English, Clinical Trial, Randomized Controlled Trial, Male, Humans