# Abbreviations

ADT | Androgen Deprivation Therapy
AE | Adverse effects
AHRQ | Agency for Healthcare Research and Quality
AJCC stages | American Joint Committee on Cancer
Stage I | T1a,N0,M0,G1
Stage II | T1a,N0,M0,G2–4
| T1b,N0,M0,any G
| T1c,N0,M0,any G
| T1,N0,M0,any G
| T2,N0,M0,any G
Stage III | T3,N0,M0,any G
Stage IV | T4,N0,M0,any G
| Any T,N1,M0,any G
| Any T,anyN,M1,any G
ARR | Absolute Risk Reduction
ASTRO | American Society of Therapeutic Radiation Oncologists
AUA | American Urological Association
bNED | biochemical No Evidence of Disease
Brachy | Brachytherapy
CaPSURE | Cancer of the Prostate Strategic Urologic Research Endeavor
C-EBRT | Conformal External Beam Radiotherapy
CI | Confidence Interval
CRT | Conformed Radiation Therapy
CT | Computerized Tomography
DRE | Digital Rectal Examination
EBRT | External Beam Radiotherapy
ED | Erectile Dysfunction
EPC | Evidence-based Practice Center
ERSPC | European Randomized Study of Screening for Prostate Cancer
FACT-G | Functional Assessment of Cancer Therapy-General
FACT-P | Functional Assessment of Cancer Therapy-Prostate
G | Histopathologic grade of the tumor
G1 | Well differentiated (slight anaplasia) (Gleason 2–4)
G2 | Moderately differentiated (moderate anaplasia) (Gleason 5,6)
G3,4 | Poorly differentiated or undifferentiated (marked anaplasia) (Gleason 7–10)
GX | Grade cannot be assessed
GI | Gastrointestinal
GU | Gentiourinary
HIFU | High Intensity Focused Ultrasound
HMO | Health Maintenance Organization
HR | Hazard Ratio
HRQOL | Health-Related Quality of Life
IMRT | Intensity Modulated Radiation Therapy
^125^I | Iodine (I)-125
IPSS | International Prostate Symptom Scores
Jewett stages
Stage A | A clinically undetectable tumor confined to the prostate gland and is an incidental finding at prostatic surgery
Substage A1 | Well differentiated with focal involvement, usually left untreated
Substage A2 | Moderately or poorly differentiated or involves multiple foci in the gland
Stage B | Tumor is confined to the prostate gland
Substage B0 | Nonpalpable, PSA detected
Substage B1 | Single nodule in one lobe of the prostate
Substage B2 | More extensive involvement of one lobe or involvement of both lobes
Stage C | Tumor clinically localized to the periprostatic area but extending through the prostatic capsule
Substage C1 | Clinical Extracapsular extension
Substage C2 | Extracapsular tumor producing bladder outlet or ureteral obstruction
Stage D | Metastatic disease
Substage D0 | Clinically localized disease (prostate only) but persistently elevated enzymatic serum acid phosphatase titers
Substage D1 | Regional lymph nodes only
Substage D2 | Distant lymph nodes, metastases to bone or visceral organs
Substage D3 | D2 prostate cancer patients who relapsed after adequate endocrine therapy
LHRH | Luteinizing Hormone-Releasing Hormone
LHRHa | Luteinizing Hormone-Releasing Hormone agonist
LRP | Laparoscopic Radical Prostatectomy
MESH | Medical Subheading Subjects
M | Distant metastasis presence
M0 | No distant metastasis
M1 | Distant metastasis
M1a | Nonregional lymph node(s)
M1b | Bone(s)
M1c | Other site(s) with or without bone disease
MX | Distant metastasis cannot be assessed (not evaluated by any modality)
MRI | Magnetic Resonance Imaging
N | Regional lymph nodes involvement
N0 | No regional lymph node metastasis
N1 | Metastasis in regional lymph node(s)
NX | Regional lymph nodes were not assessed
NCIC | National Cancer Institute of Canada
NHT | Neoadjuvant Hormonal Therapy
NSP | Nerve-Sparing Prostatectomy
OR | Odds Ratio
^103^Pd | Palladium (P)-103
P | Prostatectomy
PC | Prostate Cancer
PCI | Prostate Cancer Instrument
PCOS | Prostate Cancer Outcomes Study
PIVOT | Prostate Cancer Intervention Versus Observation Trial
PLCO | Prostate, Lung, Colorectal, and Ovarian
ProtecT | Prostate Testing for Cancer and Treatment
PSA | Prostate Specific Antigen
QOL | Quality of Life
RCT | Randomized Controlled Trial
RLRP | Robotic Assisted Laparoscopic Radical Prostatectomy
RP | Radical Prostatectomy
RR | Relative Risk
RRP | Retropubic Radical Prostatectomy
RTOG | Radiation Therapy Oncology Group
SEER | Surveillance, Epidemiology, and End Results
SELECT | Selenium and Vitamin E Chemoprevention Trial
SPCG | Scandinavian Prostate Cancer Group
TEP | Technical Expert Panel
T | Primary tumor staging
T0 | No evidence of primary tumor
T1 | Clinically inapparent tumor not palpable nor visible by imaging
T1a | Tumor incidental, histologic finding in ≤5% of tissue resected
T1b | Tumor incidental, histologic finding in >5% of tissue resected
T1c | Tumor identified by needle biopsy
T2 | Tumor confined within prostate
T2a | Tumor involves 50% of one lobe or less
T2b | Tumor involves >50% of one lobe but not both lobes
T2c | Tumor involves both lobes
T3 | Tumor extends through the prostate capsule
T3a | Extracapsular extension (unilateral or bilateral)
T3b | Tumor invades seminal vesicle(s)
T4 | Tumor is fixed or invades adjacent structures other than seminal vesicles: bladder neck, external sphincter, rectum, levator muscles, and/or pelvic wall
TX | Primary tumor cannot be assessed
TURP | Transurethral Resection of the Prostate
UI | Urinary incontinence
VACURG | Veterans Administration Cooperative Urological Research Group
WHO | World Health Organization
WW | Watchful Waiting