# Appendixes

Appendix A Search Strategy

Appendix B Peer Reviewers

Appendix C Evidence Tables and Figures

Appendix D List of Excluded Studies

Appendix E Sample Abstraction Forms

Appendix F Definitions of Outcomes