# Results

## Introduction

In what follows, we begin by describing the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by KQ. For each KQ, we begin by listing the key points of the findings, followed by a brief description of included studies and a more detailed synthesis of the evidence.

In the initial phases of title-and-abstract screening, we focused on identifying articles on the UA/NSTEMI population; therefore, citations that included the ACS population were moved forward to the full-text screening phase. In examining these citations, we found 59 articles that addressed an exclusively UA/NSTEMI population and 110 articles that addressed an ACS population that included the UA/NSTEMI population but did not report separate results for that population. The investigative team felt that limiting our review to the pure UA/NSTEMI population would result in a narrow focus on the antiplatelet and anticoagulant therapies that are used in clinical practice. Therefore, we have chosen to include studies of either the UA/NSTEMI population or the ACS population that included UA/NSTEMI patients. Note that any studies that were exclusively in the STEMI or stable angina population are excluded.

Also, we found studies that were not easily grouped into the early invasive, initial conservative, or postdischarge strategies. There was substantial overlap in the treatment strategies within these studies. For example, in a study comparing antithrombotic therapies, a proportion of patients in each treatment arm could have undergone PCI or conservative treatment. The results were reported by each treatment arm but not by the subgroups that received PCI or conservative treatment. For these reasons, this review is structured in the following manner:

- In KQ 1 (early invasive), we focus on studies that assessed dosage, timing, and combinations of antiplatelet and anticoagulant therapies delivered at the time of PCI. We present the findings of studies comparing (1) upstream versus deferred GPI, (2) different loading doses of clopidogrel, (3) clopidogrel versus ticagrelor or prasugrel, (4) bivalirudin versus a heparin-based strategy, (5) enoxaparin versus UFH versus fondaparinux, and (6) upstream or deferred clopidogrel administration.
- In KQ 2 (initial conservative), we present the findings of studies that either focused on the conservatively managed patient or presented information about antiplatelet and anticoagulant therapies in UA/NSTEMI or ACS populations who were not included in KQ 1. Thus we present the findings of studies comparing (1) UFH versus enoxaparin or fondaparinux (full UA/NSTEMI cohort), (2) GPI plus UFH versus UFH alone in a patient population for whom coronary angiography was discouraged in the first 24 to 60 hours after study drug administration or in populations who did not receive PCI, and (3) clopidogrel versus ticagrelor or prasugrel.
- In KQ 3 (postdischarge), we present the findings of studies comparing (1) low-dose versus high-dose aspirin, (2) single antiplatelet versus dual antiplatelet therapy, (3) short-term versus long-term clopidogrel, (4) antiplatelet therapy with or without the addition of a PPI, and (5) dual antiplatelet versus triple antiplatelet therapy in patients with an indication for long-term anticoagulation (e.g., atrial fibrillation, prosthetic valve).

Across all KQs we present any relevant subgroup or harms data. We conducted quantitative syntheses where possible, as described in the Methods section. A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

In Figure 3, we depict the flow of articles through the literature search and screening process for the review. Searches of PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews from January 1995 to July 2012 yielded 26,279 citations, 3206 of which were duplicates. Manual searching and contacts with drug manufacturers identified 42 additional citations, for a total of 23,115. After applying inclusion/exclusion criteria at the title-and-abstract level, 1576 full-text articles were retrieved and screened. Of these, 1274 were excluded at the full-text screening stage, leaving 302 articles (representing 175 unique studies) for data abstraction. Note that several articles/studies were relevant to more than one KQ.

Figure 3 Literature flow diagram

KQ = Key Question; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

^a^ Studies/articles could be relevant to more than 1 KQ.

Figure 3 depicts the flow of articles through the literature search and screening process for the review. Searches of PubMed®, Embase®, and the Cochrane Database of Systematic Reviews from January 1995 to July 2012 yielded 26,279 citations, 3206 of which were duplicates. Manual searching and contacts to drug manufacturers identified 42 additional citations, for a total of 23,115. After applying inclusion/exclusion criteria at the title-and-abstract level, 1576 full-text articles were retrieved and screened. Of these, 1274 were excluded at the full-text screening stage, leaving 302 articles (representing 174 unique studies) for data abstraction. There were 87 studies (187 articles) relevant to KQ 1; 33 studies (103 articles) relevant to KQ 2; and 70 studies (83 articles) relevant to KQ 3. Note that several articles/studies were relevant to more than one Key Question.

## Description of Included Studies

Of the included 175 studies, 87 were relevant to KQ 1, 33 to KQ 2, and 71 to KQ 3. Studies were conducted wholly or in part in Europe (41%); Asia (13%); the United States or Canada (34%); Australia or New Zealand (6%); other international settings (18%); and 3% did not report the setting. Further details are provided in the relevant KQ results sections that follow.

As described in the Methods chapter, we searched ClinicalTrials.gov to identify completed but unpublished studies as a mechanism for ascertaining publication bias. Our search yielded 503 trial records, 270 of which were completed at least 1 year prior to our search of the database and review of the published literature. A single reviewer identified 29 of these records as potentially relevant. We identified and screened publications for 23 of the 29 trial records. We also identified publications for two additional trial records that were not captured by our search. After reviewing these publications, neither would have been included in this report: one did not report any outcomes of interest, and the other had no comparisons of interest. Of the four trial records for which we did not identify publications, two were considered potentially relevant to KQ 1, one was considered potentially relevant to both KQs 1 and 2, and one was of indeterminate relevance.

Of the two trial records with potential relevance to KQ 1, one has been completed while the other has been suspended. The completed trial is a platelet inhibition study using two doses of prasugrel. The only potentially applicable data would be if the study is collecting adverse events of interest to this report, as the main study outcomes are not clinical outcomes of interest. As there is only one study reporting outcomes of interest associated with prasugrel, relevant adverse event data would bolster the SOE in this report. The suspended trial has greater potential applicability, given that it is a study of the efficacy and safety of tirofiban versus placebo in patients undergoing PCI. If data were to be published, it would add to and possibly help clarify the data from the upstream versus deferred GPI section of KQ 1, as the SOE was rated insufficient or low for nine of 11 outcomes analyzed.

The trial record of potential relevance to either or both KQs 1 and 2 was a study comparing the efficacy and safety of enoxaparin to unfractionated heparin for patients diagnosed with ACS in the emergency department. There was no information in the record regarding early invasive or conservative management, so the trial may relate more to one KQ than the other. The trial has been completed, with a primary completion date of February 2005, and was last updated in October 2009. A summary of this trial, published by Sanofi-Aventis on November 9, 2009, indicates that it was terminated early due to low event rates and slow recruitment. This summary also contained some of the collected safety data, which cannot be used in this report since they are not peer-reviewed data.

The trial record of indeterminate relevance contained an insufficient amount of information for us to give a KQ designation. This trial is a retrospective observational study on anti-thrombotic treatment patterns in India. Since the patterns of medication use between India and the United States vary greatly, it is unlikely that data published from this trial will be applicable to the target audience of this report.

Based on our search of ClinicalTrials.gov and the four trial records without publications in peer-reviewed literature, we do not believe that there is significant publication bias in the evidence base that would impact our overall findings.

### Study Characteristics Tables

Tables F-1, F-2, and F-3 in Appendix F provide details and quality ratings for the included studies by population and comparison for each KQ.

## Key Question 1 Early Invasive Approach for UA/NSTEMI

KQ 1: In patients undergoing an early invasive approach for treating unstable angina/non-ST elevation myocardial infarction (UA/NSTEMI):

a. What are the comparative effectiveness (dose and timing) and comparative safety of an intravenous (IV) glycoprotein IIb/IIIa inhibitor versus oral antiplatelet agent as initial therapy before going to the catheterization laboratory?
b. What are the comparative effectiveness (dose and timing) and comparative safety of coadministration of IV or oral antiplatelet agents in patients undergoing percutaneous coronary intervention for improving cardiovascular outcomes? Do the effectiveness and safety vary based on which initial anticoagulant is used or the combination of anticoagulant and antiplatelet agents?
c. Based on demographic and other clinical characteristics, are there subgroups of patients for whom the effectiveness and safety differ?

### Key Points

- Upstream (precatheterization) treatment with GPIs was associated with lower rates of revascularization (high SOE) but with a higher risk of major bleeding events at 30 days compared with deferred (periprocedural) GPI administration (high SOE). However, we found no statistically significant difference between upstream and deferred GPI therapy for the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days (low SOE).
- Evidence for the comparative effect of upstream versus deferred GPI therapy on all-cause mortality and nonfatal MI at 30 days was rated insufficient due to inconsistency and imprecision, despite the large number of studies and total number of enrolled patients.
- A 600 mg loading dose of clopidogrel was associated with lower rates of nonfatal MI and lower incidences of stent thrombosis at 30 days than a 300 mg loading dose (low SOE).
- Ticagrelor was associated with mixed results for the composite outcome of cardiovascular death, nonfatal MI, or nonfatal stroke compared with clopidogrel at 30 days (insufficient SOE for a reduction in the composite outcome for ticagrelor) and had similar rates of major bleeding events (low SOE) at 1 year.
- Prasugrel showed a reduction in the event rate of the above composite outcome at 30 days (moderate SOE) and the individual outcome of revascularization at 6 months (moderate SOE), but an increase in major bleeding events at 1 year (moderate SOE) when compared with clopidogrel.
- After 1 year, ticagrelor was associated with lower composite ischemic endpoints (moderate SOE) and individual endpoints (all-cause mortality, cardiovascular mortality, nonfatal MI, stent thrombosis; all moderate SOE) when compared with clopidogrel.
- After 1 year, prasugrel was associated with lower composite ischemic endpoints (moderate SOE), individual endpoints (all-cause mortality, cardiovascular mortality; both low SOE), and nonfatal MI and stent thrombosis (moderate SOE) when compared with clopidogrel.
- Without planned GPI use, there was a statistically significantly lower incidence in major and minor bleeding at 30 days favoring bivalirudin when compared with heparin (high SOE for major bleeding; low SOE for minor bleeding).
- With planned GPI use, bivalirudin reduced the rate of the composite outcome of all-cause mortality, nonfatal MI, revascularization, or major bleeding, and the individual endpoint of minor bleeding compared with heparin at 30 days (high SOE).
- At 30 days, there were no significant differences in the incidence of the composite ischemic endpoints in PCI patients treated with enoxaparin versus UFH and enoxaparin versus fondaparinux (low SOE).
- There was a statistically significantly lower incidence of major bleeding at 30 days favoring fondaparinux over enoxaparin in the PCI cohort (moderate SOE).
- In patients pretreated with clopidogrel, there was no statistically significant difference in composite ischemic endpoints at 30 days between bivalirudin-treated patients and heparin-treated patients (low SOE).
- In both clopidogrel pretreated and clopidogrel deferred patients, bivalirudin resulted in fewer major bleeding events at 30 days than heparin-based treatment (moderate SOE for clopidogrel pretreated patients and low SOE for clopidogrel deferred patients).
- In both clopidogrel pretreated and clopidogrel deferred patients, deferred GPI use resulted in fewer major bleeding events at 30 days when compared with upstream GPI use (moderate SOE for clopidogrel pretreated and high SOE for clopidogrel deferred).

### Description of Included Studies

We identified 87 unique studies that evaluated the comparative effectiveness of antiplatelet medications and anticoagulant medications in 354,511 patients with UA/NSTEMI treated with an early invasive approach or PCI-based strategy.23-109 Of these studies, 54 were RCTs (25 good quality, 23 fair, 6 poor) and 33 were observational (2 good quality, 24 fair, 7 poor) (see Table E-1 in Appendix E for quality and applicability of each included study). The majority of studies were published from 2000 through 2012, with two studies28,73 published in 1999. Thirty-eight studies were single-center,23,28,31,32,34,35,38,39,41,42,44,45,48,49,70,71,76,83,84,86-96,98,100-102,105,107-109 and 40 were multicenter;24,25,29,30,33,36,43,46,47,50-56,59-63,65-69,72-75,77,80-82,85,97,99,103,104,106 in 9 studies,26,27,37,40,57,58,64,78,79 the number of sites was unclear or not stated. Forty-four studies included sites in the United States or Canada,24,25,29,30,33,43,46,48,53-55,58-63,65-69,72-74,78-80,83-85,88,90-92,96,98-100,103,104,107-109 46 included sites in Europe,23,26,28,30-32,34,36,39,42-44,46,49-52,54,55,57,58,61-63,65,66,68-70,73-77,80-82,86,93-95,97,101,102,104,106 9 included sites in Asia,27,35,38,40,41,45,66,71,74 8 included sites in Australia or New Zealand,30,47,55,62,65,80,87,104 1 was in Israel,89 and 4 included locations that were either unreported or unclear.37,56,64,105 A total of 37 studies used industry funding,23-25,29,30,32,36,37,43,46,47,50,53-56,58-68,73,74,77-80,96,97,103,104 1 was government-only funded,26 6 were funded by nongovernment/nonindustry sources,33,52,57,75,81,93 and funding was unclear or not reported in 43 studies.27,28,31,34,35,38-42,44,45,48,49,51,69-72,76,82-92,94,95,98-102,105-109

As stated in the Introduction, a large number of studies reported findings in patients treated with antiplatelets and/or anticoagulants as part of a PCI-based strategy and therefore did not delineate the findings into early invasive and initial conservative populations. In addition, results for the UA/NSTEMI population were often not presented separately from the acute coronary syndrome (ACS) population (including STEMI). The study characteristics table for KQ 1 (Table F-1 in Appendix F) contains details about the proportion of UA/NSTEMI patients, the proportion of patients undergoing PCI, and the proportion of patients undergoing an early invasive approach.

The majority of UA/NSTEMI studies assessed the comparative effectiveness of GPIs. We identified and abstracted 44 studies (25 RCTs, 19 observational) that evaluated the use of GPIs in 184,946 patients with UA/NSTEMI.23-45,77-96,110

- Five RCTs and five observational studies assessed the effectiveness of GPI versus placebo at the time of PCI.24-28,83,93-96 In general, the studies assessing GPI at the time of PCI versus placebo reported a statistically significant reduction in the incidence of composite ischemic endpoints, in favor of GPI use, at 30 days (4% to 6%) versus placebo (8% to 10%).
- Three RCTs and seven observational studies assessed the effectiveness of upstream GPI versus GPI at the time of PCI.29-31,86-92 In these studies, the incidence of composite ischemic endpoints varied dramatically across studies due to inclusion of stable angina, unstable angina, and MI patients. Additionally, there were multiple comparisons of GPI (abciximab versus abciximab, tirofiban versus tirofiban, abciximab versus tirofiban, abciximab versus eptifibatide, eptifibatide versus eptifibatide, eptifibatide versus tirofiban) that precluded direct comparison of a treatment effect of a specific GPI. No conclusions were made based on these observations.
- Two RCTs assessed the effectiveness of differential GPI treatment duration after PCI.32,33 One study32 involved the use of abciximab bolus versus abciximab bolus plus 12-hour infusion in 73 patients. There was no statistically significant difference in the incidence of outcomes in these patients at 30 days. In the other study,33 624 patients with stable angina and ACS were randomly assigned to eptifibatide double bolus and 2-hour infusion versus eptifibatide double bolus and 18-hour infusion. There was no statistically significant difference in the occurrence of the composite or individual ischemic endpoints; however, there was significantly lower major bleeding in the 2-hour infusion group.
- Two RCTs assessed the effectiveness with unique comparisons. One RCT evaluated high versus low tirofiban dose,35 and one RCT evaluated GPI only in patients who had saphenous vein graft stenoses.34 The study by Lin et al.35 showed significantly higher platelet inhibition in the high-dose group, but similar rates of angiographic success between the two groups. Major bleeding events were higher in the high-dose group (10.4% versus 0%), but major adverse cardiac events were similar between groups. The study by Ozkan et al.34 showed a significantly lower rate of no-flow or slow-flow through the vein graft in the treated group compared with the non-treated group (1 patient vs. 9 patients), but no significant differences in major adverse cardiac events or major bleeding.
- Five observational studies (including one study discussed above)83 assessed the effectiveness of GPI treatment within specific subgroups of patients: patients with diabetes mellitus,82,83 patients undergoing saphenous vein graft PCI,84 patients undergoing rotational atherectomy,85 and patients on chronic warfarin treatment.81 Despite current guidelines, Bauer et al.82 found that only 22.2 percent of diabetic patients received GPI, but found no difference in hospital mortality between those who received treatment and those who did not. They did find higher rates of postprocedural MI in patients receiving treatment prior to intervention. Velianou et al.83 found significantly lower rates of 30-day mortality (0.6% vs. 3.0%) and repeat PCI (0% vs. 1.1%) in diabetic patients receiving GPI versus those who did not, but no significant differences in 30-day or 1-year rates of bypass surgery, MI, or a composite cardiac endpoint. Karha et al.84 showed that in patients undergoing saphenous vein graft PCI there was no significant difference in survival, myonecrosis, in-hospital morality, Q wave MI, or bleeding between those receiving GPI and those not. Berger et al.85 found no significant differences in PCI success rates, major adverse cardiac events, or mortality in patients undergoing rotational atherectomy treated with GPI versus those who were not. In patients on chronic warfarin undergoing PCI, Lahtela et al.81 showed higher rates of major bleeding (9.0% vs 1.5) in patients treated with GPI compared with those not treated, but no significant differences in rates of MACE.
- Twelve RCTs and four observational studies assessed the effectiveness of upstream versus deferred administration of GPI and are further described in comparison 1, below.

In the next section, we present the following six comparisons that were assessed in the included studies for KQ 1:

1. Upstream versus deferred administration of GPI (KQ 1a)
  - 16 studies (12 RCTs, 4 observational; 149,847 total patients)
2. Clopidogrel loading dose (KQ 1b)
  - 11 studies (8 RCTs, 3 observational; 36,347 total patients)
3. Clopidogrel versus ticagrelor or prasugrel (PCI cohort; KQ 1b)
  - 3 studies (3 RCTs; 33,216 total patients)
4. Bivalirudin versus a heparin-based strategy, without or with planned GPI (KQ 1b)
  - 13 studies (8 RCTs, 5 observational; 30,486 total patients)
5. Enoxaparin versus UFH versus fondaparinux (KQ 1b)
  - 13 studies (10 RCTs, 3 observational; 41,201 total patients)
6. Upstream or deferred clopidogrel administration (before or after PCI) in studies with a defined anticoagulant strategy (comparing bivalirudin versus a heparin-based therapy; KQ 1b) or a defined intravenous antiplatelet strategy (comparing upstream versus deferred GPI use; KQ 1a)
  - 18 studies (16 RCTs, 2 observational; 40,218 patients)

The subgroup findings (KQ 1c) are presented after each comparison.

### Detailed Synthesis

#### 1 Upstream Versus Deferred Glycoprotein Inhibitor Administration (KQ 1a)

Sixteen studies (12 RCTs and 4 observational) compared upstream versus deferred GPI administration in 149,847 patients.23,36-45,77-80,110 The terms upstream and pretreatment both refer to the time before the PCI is begun, whereas deferred treatment means that GPI medications are delayed or given at the same time as the PCI.

Of the 16 studies, we were able to pool 11 RCTs23,36,38-45,110 for meta-analysis (detailed in the next section). One RCT37 was not analyzed since it was a pilot study of early versus late administration of eptifibatide with a primary outcome of serial cardiac marker release and infarct size in NSTEMI patients. The clinical and bleeding events (death, reinfarction, recurrent ischemia, composite endpoint, major bleeding) were measured at 72 hours, and no statistically significant differences were found between early and late GPI administration. The four observational studies (all rated fair quality) were not included in the meta-analysis due to the lack of clarity regarding the timing of PCI and early invasive management strategy.77-80 In each of these studies, eptifibatide, tirofiban, and abciximab were used. The rate of composite ischemic endpoints was inconsistent between groups and ranged from 4 to 9 percent in the upstream GPI group and 3 to 10 percent in the deferred GPI group.

##### Upstream (Precatheterization) Versus Deferred (Periprocedural) GPI Administration

Eleven RCTs (20,743 patients) compared an upstream versus deferred use of GPI and were included in our meta-analyses for one or more outcomes.23,36,38-45,110 Of these 11 RCTs, 3 (27%) were rated good quality, 6 (55%) fair, and 2 (18%) poor. Sample sizes ranged from 100 to 9378 patients. Study duration ranged from 3 days to 319 days, and all reported 30 day outcomes. The GPIs administered included eptifibatide in 4 studies, tirofiban in 8 studies, and abciximab in 2 studies.

The mean age of study participants ranged from 53 to 68 years. The proportion of female patients ranged from 27 to 54 percent. None of the studies reported the racial and ethnic demographics of study participants. No studies (0%) were conducted within the United States or Canada; they were all international with the exception of one study where the location was not reported. Funding source was reported in four studies (36%), all of which were funded by an industry source.

The following outcomes were quantitatively assessed: composite ischemic endpoints at 30 days and 6 months, all-cause mortality at 30 days, nonfatal MI at 30 days, revascularization at 30 days and 6 months, major bleeding at 30 days, and minor bleeding at 30 days. Outcomes including all-cause mortality at 6 months, nonfatal MI at 6 months, and revascularization at 6 months did not have sufficient data to be meta-analyzed and have been qualitatively described below. Results for all studies in this comparison are included in Table G-1 in Appendix G.

###### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, or Revascularization at 30 Days

A random-effects meta-analysis of six RCTs36,39-41,43,110 (2 good quality, 3 fair, 1 poor) including 19,662 UA/NSTEMI patients reporting the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days found that the odds ratio was 0.88 (95% CI, 0.77 to 1.01), demonstrating no statistically significant difference between upstream GPI and deferred GPI (Figure 4). There was no evidence of heterogeneity, with a Q-value of 6.35 for 5 degrees of freedom, p=0.27.

Figure 4 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on composite endpoint of all-cause mortality, nonfatal myocardial infarction, or revascularization at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of six studies that shows an odds ratio of 0.88 (95% CI, 0.77 to 1.01), demonstrating no statistically significant difference between upstream glycoprotein inhibitor use and deferred glycoprotein inhibitor use.

The result from one fair-quality study by Momtahen40 was different from the other studies. Potential reasons for this difference include that the study was conducted at a single center in Iran, did not clearly enroll consecutive patients, and had a small sample size (n=196). We performed sensitivity analyses to understand the impact of the Momtahen study by running a fixed-effects model and another with that study removed. A fixed-effects model resulted in a summary odds ratio of 0.89 (95% CI, 0.81 to 0.97, p=0.01) favoring upstream GPI administration, which suggests that the summary estimate is sensitive to a random-effects versus a fixed-effects model. Removal of the Momtahen study resulted in an odds ratio of 0.89 (95% CI, 0.81 to 0.98, p=0.02) favoring upstream GPI administration in both the fixed- and random-effects models. There was no evidence of heterogeneity by Q-value or I^2^ statistic with the fixed- or random-effects models, with or without the Momtahen study. Study quality affected the individual study precision, with the poor study39 and fair studies36,40,41 having wider CIs. The studies were consistent with fewer composite events occurring in the upstream GPI group.

The SOE was rated low for the composite endpoint at 30 days based on imprecise results across the six RCTs (although the two large, good-quality RCTs were consistent) that upstream GPI is not superior to deferred GPI.

###### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, or Revascularization After 6 Months

A random-effects meta-analysis of four RCTs23,36,41,45 (all fair quality) including 773 UA/NSTEMI patients reporting the composite outcome of all-cause mortality, nonfatal MI, or revascularization after 6 months found that the odds ratio was 0.77 (95% CI, 0.46 to 1.28) demonstrating no significant difference between upstream or deferred GPI use (Figure 5). There was no evidence of heterogeneity, with a Q-value of 4.68 for 3 degrees of freedom, p=0.20. The results from one fair-quality study by Kim45 were different from the other studies. Potential reasons for this difference include that the study was conducted at a single center in Asia, did not clearly enroll consecutive patients, and had a small sample size (n=120). The SOE was rated insufficient for the composite outcome after 6 months based on four fair-quality RCTs with mostly consistent results of a direct outcome and a wide confidence interval that crossed 1.

Figure 5 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on composite endpoint of all-cause mortality, nonfatal myocardial infarction, or revascularization after 6 months

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of four studies that shows an odds ratio of 0.77 (95% CI, 0.46 to 1.28).

###### Effect on All-Cause Mortality at 30 Days

A random-effects meta-analysis of 10 RCTs36,38-45,110 (3 good quality, 5 fair, 2 poor) including 20,521 UA/NSTEMI patients reporting all-cause mortality at 30 days found that the odds ratio was 0.80 (95% CI, 0.57 to 1.11), demonstrating no statistically significant difference between upstream GPI and deferred GPI (Figure 6). There was no evidence of heterogeneity, with a Q-value of 12.31 for 9 degrees of freedom, p=0.20. The inclusion of one good, four fair, and two poor quality single-center studies likely contributed to the inconsistent results.38-42,44,45 Removal of the two poor-quality studies39,42 resulted in a similar summary estimate (OR 0.76; 95% CI, 0.50 to 1.14) when compared with the full model, and there was no evidence of heterogeneity. The overall SOE was rated insufficient for all-cause mortality at 30 days based on three good-, five fair-, and two poor-quality RCTs with inconsistent results of a direct outcome and a wide confidence interval.

Figure 6 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on all-cause mortality at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of 10 studies that shows an odds ratio of 0.80 (95% CI, 0.57 to 1.11).

###### Effect on All-Cause Mortality at 6 Months

Of the three RCTs (all fair quality) that reported the incidence of all-cause mortality at 6 months, one study involving 120 patients reported no deaths in either treatment arm,45 and one study involving 160 patients reported a single death in the upstream GPI arm.41 The remaining study36 included 393 UA/NSTEMI patients and reported similar all-cause mortality rates at 6 months of 2.0 percent and 3.6 percent (p=0.36) for upstream and deferred GPI use, respectively. The SOE was rated insufficient for all-cause mortality at 6 months based on a low event rate in three RCTs, which rendered the trials underpowered to answer the question.

###### Effect on Nonfatal MI at 30 Days

Nine RCTs36,38-41,43-45,110 (three good quality, five fair, and one poor) involving 20,263 UA/NSTEMI patients reported the incidence of nonfatal MI at 30 days. The study by Kim et al.45 had no events in either treatment arm and was not included in the random-effects meta-analysis. Figure 7 shows the odds ratio was 0.84 (95% CI, 0.65 to 1.10), demonstrating no statistically significant difference between upstream GPI and deferred GPI. There was evidence of some heterogeneity, with a Q-value of 14.37 for 7 degrees of freedom, p=0.05. The I^2^ value was 51.29. The inclusion of one good-quality, three fair-quality, and one poor-quality single-center studies38-41,44 likely contributed to the inconsistent results and heterogeneity. In the two largest studies (good quality)43,110 by Giugliano and Stone of 18,585 patients, the results were consistent but still not statistically significant. We performed sensitivity analyses to understand the impact of the Momtahen study by running a fixed-effects model and another with that study removed.

Figure 7 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on nonfatal myocardial infarction at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of eight studies that shows an odds ratio of 0.84 (95% CI, 0.65 to 1.10).

A fixed-effects model resulted in a summary odds ratio of 0.90 (95% CI, 0.81 to 1.00, p=0.06) favoring upstream GPI administration, while removal of the Momtahen study resulted in a fixed-effects odds ratio of 0.91 (95% CI, 0.81 to 1.01, p=0.26) and a random-effects odds ratio of 0.88 (95% CI, 0.71 to 1.10, p=0.26). Heterogeneity was reduced to an I^2^ of 40.25. The SOE was rated insufficient for nonfatal MI at 30 days based on three good-, five fair-, and one poor-quality RCTs with inconsistent results of a direct outcome and a statistically nonsignificant confidence interval.

###### Effect on Nonfatal MI at 6 Months

Of the three RCTs (all fair quality) that reported the incidence of nonfatal MI, one study involving 120 patients reported a single MI in the deferred GPI treatment arm.45 The remaining two studies36,41 included 553 UA/NSTEMI patients and reported similar nonfatal MI rates (12% vs. 15%, p=0.65;^41^ 10% vs. 9%, p=0.59^36^) at 6 months for upstream versus deferred GPI use, respectively. The SOE was rated insufficient for nonfatal MI at 6 months based on three RCTs with inconsistent results.

###### Effect on Revascularization at 30 Days

A random-effects meta-analysis of six RCTs36,40,41,43,45,110 (2 good quality, 4 fair) including 19,454 UA/NSTEMI patients reporting the need for revascularization at 30 days found that the odds ratio was 0.77 (95% CI, 0.65 to 0.92), demonstrating a statistically significant reduction in revascularization favoring upstream GPI compared with deferred GPI (Figure 8). There was no evidence of heterogeneity, with a Q-value of 0.49 for 5 degrees of freedom, p=0.99. The SOE was rated high for revascularization at 30 days based on three good- and three fair-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 8 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on revascularization at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of six studies that shows an odds ratio of 0.77 (95% CI, 0.65 to 0.92), demonstrating a statistically significant reduction in revascularization favoring upstream glycoprotein inhibitor.

###### Effect on Revascularization at 6 Months

Of the three RCTs (all fair quality) that included 673 UA/NSTEMI patients reporting the incidence of revascularization at 6 months, there were similar pooled rates of revascularization at 6 months in the upstream GPI (10.7%) versus deferred GPI (13.3%) treatment arms.36,41,45 A random-effects model of three studies comparing upstream with deferred GPI use resulted in a summary odds ratio of 0.69 (95% CI, 0.34 to 1.39, p=0.30) (Figure 9). There was no evidence of heterogeneity with a Q-value of 3.09 for 2 degrees of freedom, p=0.21. The SOE was rated insufficient for revascularization at 6 months based on three RCTs with an imprecise estimate and inconsistent results.

Figure 9 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on revascularization at 6 months

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 0.69 (95% CI, 0.34 to 1.39).

###### Effect on Major Bleeding at 30 Days

Nine RCTs23,36,39,40,42-45,110 (2 good quality, 5 fair, 2 poor) including 20,242 UA/NSTEMI patients reported the incidence of major bleeding at 30 days. Two studies were excluded from the meta-analysis because no endpoints occurred in either treatment group.40,45Figure 10 shows that the odds ratio was 1.24 (95% CI, 1.08 to 1.43), demonstrating a statistically significant reduction in major bleeding favoring deferred GPI. There was no evidence of heterogeneity, with a Q-value of 1.43 for 6 degrees of freedom, p=0.96. The SOE was rated high for major bleeding at 30 days based on two good-, five fair-, and two poor-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 10 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on major bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of seven studies that shows an odds ratio of 1.24 (95% CI, 1.08 to 1.43), demonstrating a statistically significant reduction in major bleeding favoring deferred glycoprotein inhibitor.

###### Effect on Minor Bleeding at 30 Days

A random-effects meta-analysis of five RCTs23,36,40,41,45 (all fair quality) including 969 UA/NSTEMI patients reporting minor bleeding at 30 days found that the odds ratio was 1.58 (95% CI, 0.95 to 2.64), showing a reduction in minor bleeding with deferred GPI which did not reach statistical significance (Figure 11). There was no evidence of heterogeneity, with a Q-value of 3.028 for 4 degrees of freedom, p=0.553. One study by Momtahen40 reported no minor bleeding events in the deferred GPI treatment arm and seven minor bleeding events in the upstream GPI arm, thus contributing to inconsistency and imprecision of results. The SOE was rated insufficient for minor bleeding at 30 days based on five fair-quality RCTs with inconsistent results of a direct outcome and a wide confidence interval.

Figure 11 Meta-analysis of upstream versus deferred glycoprotein inhibitor use on minor bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of five studies that shows an odds ratio of 1.58 (95% CI, 0.95 to 2.64).

##### Findings by Subgroup (KQ 1c)

Two studies43,110 (both good quality) reported variations in treatment effectiveness by subgroup. Subgroups analyzed were age, sex, diabetes, chronic renal disease, troponin positivity, and TIMI risk score. Prespecified subgroup analyses of intended clopidogrel pretreatment are covered in a separate section of this report. Race, type of coronary stent, presence of smoking, geographic location, and other patient and demographic characteristics were not clearly described. The SOE for subgroup findings was rated insufficient since there are only two studies that looked at subgroups, and some of the subgroup definitions were heterogeneous (e.g., age grouping, or definition of renal insufficiency) which did not allow for direct comparison. Table H-1 in Appendix H presents the results data for these subgroups.

###### Age

There were two studies comparing the efficacy of upstream GPI use versus deferred GPI use in different age subgroups. In the first study, in a subgroup of 7026 patients under age 75, composite ischemic endpoints in patients treated with upstream GPI use (8.6%) was lower when compared with deferred GPI use (9.5%) but was statistically nonsignificant. In the other subgroup of 2377 patients over age 75, there was no difference in ischemic event rates in those who were treated with upstream GPI use (11.4%) or deferred GPI use (11.4%).43

Similar composite ischemic event rates occurred in the subgroup of 5054 patients under age 65 in the ACUITY TIMING study treated with upstream GPI use (6.4%) versus deferred GPI use (6.6%). There was no difference in major bleeding events in this subgroup (upstream GPI=3.7%; deferred GPI=4.1%). In the subgroup of 4153 patients over age 65, there was a reduction in ischemic events with upstream GPI use (7.7%) when compared with deferred GPI use (9.8%). In patients over age 65, there was a statistically significant reduction in major bleeding favoring treatment with deferred GPI use (6.3%) versus upstream GPI use (8.5%).110

###### Sex

There were two studies of upstream versus deferred GPI use reporting subgroup results for men versus women. In the first study, in a subgroup of 6431 male patients, there was a statistically nonsignificant reduction in the incidence of composite ischemic endpoints for men treated with upstream GPI use (9.1%) when compared with deferred GPI use (9.8%). A similar statistically nonsignificant reduction in ischemic events was observed in the 2975 female patients in this study who were treated with upstream GPI use (9.7%) versus deferred GPI use (10.4%).43

In the other study, there was a similar statistically nonsignificant trend toward a reduction in ischemic events in the 6467 male patients who were treated with upstream GPI use (7.0%) when compared with deferred GPI use (8.5%). The lower rate of major bleeding was statistically significant in men treated with deferred GPI use (3.4%) when compared with upstream GPI use (4.6%). However, there was a slightly higher rate of ischemic events in the 2740 female patients treated with upstream GPI use (7.2%) when compared with deferred GPI use (6.5%), p=NS. There was no difference in major bleeding in women (upstream GPI=9.7%; deferred GPI=8.3%).110

###### Diabetes Mellitus

Two studies compared the efficacy of upstream versus deferred GPI use among patients with and without diabetes mellitus. In one study of 2860 patients with diabetes, there was a statistically nonsignificant reduction in the incidence of composite ischemic events when diabetic patients were treated with upstream GPI use (8.9%) versus deferred GPI use (10.6%).43 In the other study of 2565 patients with diabetes, a similar nonsignificant reduction in ischemic events was observed in patients treated with upstream GPI use (8.4%) when compared with deferred GPI use (9.7%). There was a nonsignificant reduction in major bleeding in patients treated with deferred GPI use (4.4%) versus upstream GPI use (5.6%).110

###### Chronic Kidney Disease

There were two studies reporting subgroup results for patients with chronic kidney disease (CKD) treated with upstream versus deferred GPI use. In the EARLY ACS study, there was no statistically significant difference in composite ischemic endpoints or bleeding events in patients with CrCl<50 ml/min.43 In ACUITY TIMING, there was a statistically nonsignificant trend toward higher ischemic event rates in patients with CrCl less than 60 ml/min treated with upstream GPI use (11.8%) when compared with deferred GPI use (9.2%). A statistically significant reduction in major bleeding events was observed in patients with CrCl less than 60 ml/min favoring patients treated with deferred GPI use (8.5%) versus upstream GPI use (12.8%).110

###### Serum Biomarker Level

Two studies of upstream versus deferred GPI use reported results for patients with elevated serum biomarkers (CK-MB or troponin) on presentation. In 7650 patients with an abnormal troponin level in EARLY ACS, there was a statistically nonsignificant trend toward a reduction in composite ischemic events with upstream GPI use (9.5%) when compared with deferred GPI use (10.6%).43 In 4962 patients with an abnormal CK-MB or troponin level in ACUITY TIMING, there was no difference in composite ischemic events with upstream GPI use (9.1%) versus deferred GPI use (8.3%). There was a statistically significant difference in major bleeding events favoring patients treated with deferred GPI use (5.6%) when compared with upstream GPI use (7.2%).110

###### TIMI Risk Score

Two studies of upstream versus deferred GPI use reported results for patients' TIMI risk score on presentation. In both EARLY ACS and ACUITY TIMING, there was no difference in the incidence of composite ischemic endpoints between any level of TIMI risk score (low, intermediate, high).43,110 There were statistically nonsignificant reductions in major bleeding favoring deferred GPI use in patients with intermediate (upstream GPI 5.6%; deferred GPI 4.4%) and high (upstream GPI 8.2%; deferred GPI 6.3%) TIMI risk score.110

##### Summary of Results for Upstream Versus Deferred GPI Administration

In our analysis of upstream versus deferred GPI administration, we found no statistically significant difference between upstream and deferred GPI therapy for the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days and 6 months. For the individual outcomes of all-cause mortality and nonfatal MI, there was no statistically significant difference between upstream and deferred GPI therapy at 30 days, but the results are less certain at 6 months since fewer trials reported results at this time point, although the ones that did report outcomes also showed no difference. For revascularization, there was a statistically significant difference favoring upstream GPI therapy at 30 days, but the results are less certain at 6 months due to a small number of trials that showed no difference in outcomes. For bleeding outcomes, there was a statistically significant difference favoring deferred GPI therapy in major bleeding events at 30 days but no statistically significant differences between therapies in minor bleeding events at 30 days. No studies reported the occurrence of stent thrombosis during study followup. In summary, upstream GPI reduced short-term revascularization at the cost of increased short-term major bleeding, and the final impact on clinical outcomes is likely somewhere in the middle, although the studies are too inconsistent or imprecise to determine whether the net benefit is truly zero or whether there is a small benefit from either therapy.

Subgroups analyzed in two studies included age, sex, diabetes, chronic renal disease, troponin positivity, and TIMI risk score and most findings showed statistically nonsignificant reductions in ischemic outcomes from upstream GPI; the only statistically significant findings were a lower risk of major bleeding favoring treatment with deferred GPI use in patients over age 65, CrCl less than 60 ml/min, and elevated serum biomarkers (all findings from one RCT). Detailed SOE ratings are shown in Table 5. Odds ratios less than 1 favor upstream GPI; odds ratios greater than 1 favor deferred GPI.

Table 5 Detailed strength of evidence for UA/NSTEMI patients treated with upstream versus deferred glycoprotein inhibitor

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 30 Days | | | | | Low SOE
6 (19,662) | 6 RCTs/2 good quality, 3 fair, 1 poor | Consistent | Direct | Imprecise | OR 0.88 (0.77 to 1.01) No difference
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization After 6 Months | | | | | Insufficient SOE
4 (773) | 4 RCTs/All fair quality | Consistent | Direct | Imprecise | OR 0.77 (0.46 to 1.28)
All-cause Mortality at 30 Days | | | | | Insufficient SOE
10 (20,521) | 10 RCTs/3 good quality, 5 fair, 2 poor | Inconsistent | Direct | Imprecise | OR 0.80 (0.57 to 1.11)
All-Cause Mortality at 6 Months | | | | | Insufficient SOE
3 (673) | 3 RCTs/All fair quality | Inconsistent | Direct | Imprecise | 1 study reported no deaths in both arms; 1 study reported 1 death in the upstream GPI arm; 1 study reported similar rates (2.0% upstream GPI, 3.6% deferred GPI)
Nonfatal MI at 30 Days | | | | | Insufficient SOE
9 (20,263) | 9 RCTs/3 good quality, 5 fair, 1 poor | Inconsistent | Direct | Imprecise | OR 0.84 (0.65 to 1.10)
Nonfatal MI at 6 Months | | | | | Insufficient SOE
3 (673) | 3 RCTs/All fair quality | Inconsistent | Direct | Imprecise | 1 study reported 1 MI in the deferred GPI arm only; 2 other studies reported MI rates of 12% upstream vs. 15% deferred, and 10% upstream and 9% deferred
Revascularization at 30 Days | | | | | High SOE
6 (19,454) | 6 RCTs/3 good quality, 3 fair | Consistent | Direct | Precise | OR 0.77 (0.65 to 0.92) Favors upstream GPI
Revascularization at 6 Months | | | | | Insufficient SOE
3 (673) | 3 RCTs/3 fair quality | Inconsistent | Direct | Imprecise | OR 0.69 (0.34 to 1.39)
Major Bleeding at 30 Days | | | | | High SOE
9 (20,242) | 9 RCTs/2 good quality, 5 fair, 2 poor | Consistent | Direct | Precise | OR 1.24 (1.08 to 1.43) Favors deferred GPI
Minor Bleeding at 30 Days | | | | | Insufficient SOE
5 (969) | 5 RCTs/All fair quality | Inconsistent | Direct | Imprecise | OR 1.58 (0.95 to 2.64)
Stent thrombosis at 30 Days | | | | | Insufficient SOE
0 | NA | NA | NA | NA | NA

CI = confidence interval; GPI = glycoprotein inhibitor; MI = myocardial infarction; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

#### 2 Clopidogrel Loading Dose (KQ 1b)

Eleven studies (8 RCTs, 3 observational) compared loading doses of clopidogrel in 36,347 UA/NSTEMI patients undergoing an invasive strategy.46-53,97-99 Outcomes assessed in this comparison included composite ischemic endpoints, all-cause mortality, cardiovascular mortality, nonfatal MI, nonfatal stroke, revascularization, stent thrombosis, major bleeding, and minor bleeding. Results for all studies in this comparison are included in Table G-2 in Appendix G. We outline below the types of comparisons in these clopidogrel loading studies and describe qualitatively those studies which were too heterogeneous in terms of dose or population to synthesize quantitatively:

- Two studies of clopidogrel versus placebo.52,53 One RCT of clopidogrel loading dose (600 mg) versus placebo (0 mg) in 647 ACS and stable patients previously treated with clopidogrel.52 In this study, those treated with an additional dose of clopidogrel had an incidence of 30-day composite ischemic endpoints of 5 percent compared with 7 percent in those receiving a placebo loading dose. Another RCT, of an additional clopidogrel loading dose (600 mg) in patients with poor clopidogrel responsiveness to an initial clopidogrel loading dose versus placebo in patients with standard clopidogrel responsiveness.53 In this study of 2214 ACS and stable patients, there was no difference in the incidence of 30-day composite ischemic endpoints between the groups at 2.3 percent.
- Three observational studies (one good quality, two fair).97-99 lacked a standard loading dose (300 mg or 600 mg) in one treatment arm or had heterogeneity in the patient populations (an unselected PCI population), and we therefore describe these qualitatively. One study97 reported fewer all-cause deaths (7.9% vs. 10.2%) and similar major bleeding (3.2% vs. 3.7%) in patients who received a loading dose of clopidogrel (300 mg or 600 mg) versus patients who did not receive a loading dose, respectively. In another study,98 the incidence of composite ischemic endpoints was statistically significantly lower (2.9% vs. 5.2%), and the incidence of major bleeding was not different (0.2% vs. 0.5%) in unselected PCI patients receiving 600 mg clopidogrel loading dose versus 300 mg clopidogrel loading dose, respectively. The last observational study99 reported statistically significantly higher rates of composite ischemic endpoints (37.1% vs. 20.5%) in ACS patients treated with greater than 300 mg clopidogrel loading dose versus a 300 mg clopidogrel loading dose, respectively.
- Six RCTs compared clopidogrel 300 mg loading dose with clopidogrel 600 mg loading dose and included a total of 26,211 patients.46-51 One RCT50 was the only study to also randomly assign patients to clopidogrel 900 mg loading dose. These six RCTs are synthesized below

Of the six RCTs included in the endpoint findings described below, two (33%) were rated good quality and four (66%) fair. Sample sizes for included individual studies ranged from 103 to 25,806 patients. All included RCTs reported 30 day outcomes, while two observational studies reported 30 day outcomes and one study reported 6 month outcomes.

The mean age of study participants ranged from 57 to 65 years of age. The proportion of female patients ranged from 23 to 35 percent. Two studies (33%) reported the racial and ethnic demographics of study participants. Two studies (33%) were conducted within the United States or Canada, with the rest international. Funding source was reported in three studies (50%), with all three studies funded by industry source.

##### Effect on Composite Ischemic Endpoints at 30 Days and 6 Months

Five RCTs reported composite ischemic endpoints at 30 days in patients treated with a clopidogrel loading dose of 600 mg versus 300 mg; however, each of the five studies reported different composite endpoints.46,48-51 Because of this, a meta-analysis was not performed and the results are described qualitatively below. In the largest study of 25,086 UA/NSTEMI patients (good quality), the incidence of cardiovascular mortality, nonfatal MI, or nonfatal stroke was not different in the clopidogrel 600 mg loading dose group (4.2%) versus 300 mg loading dose group (4.4%) (HR 0.94; 95% CI, 0.83 to 1.06; p=0.30).46 The SOE was rated low for this composite outcome at 30 days based on a large, good-quality RCT that was sufficiently powered to assess this endpoint.

Four single-center RCTs reported a lower incidence of a composite ischemic outcome with clopidogrel 600 mg loading dose. One fair-quality study of 119 patients reported a lower incidence of cardiovascular mortality, nonfatal MI, or revascularization in the clopidogrel 600 mg loading dose group (10.4%) versus 300 mg loading dose group (23.8%).48 One fair-quality study of 387 patients reported a lower incidence of cardiovascular mortality, nonfatal stroke, or recurrent ACS in the clopidogrel 600 mg loading dose group (4.8%) versus 300 mg loading dose group (12.3%).49 Similarly, another fair-quality study of 103 patients reported a lower incidence of all-cause mortality, nonfatal MI, revascularization, or rehospitalization in the clopidogrel 600 mg loading dose group (5.9%) versus 300 mg loading dose group (11.4%).50 Of note, there were no occurrences of the same composite endpoint in 34 patients receiving clopidogrel 900 mg loading dose (third treatment arm). In the final good-quality study of 255 patients reporting a 30-day composite ischemic endpoint, there was a lower incidence of all-cause mortality, nonfatal MI, or revascularization in the clopidogrel 600 mg loading dose group (4.0%) versus 300 mg loading dose group (11.6%).51 The SOE was rated insufficient for the four other single-center studies at 30 days due to smaller sample sizes and imprecise estimates of effect, which may be due to the composite endpoint definition; i.e., inclusion of revascularization, recurrent ACS, or rehospitalization.

Only one good-quality study of 256 UA/NSTEMI patients reported a composite ischemic endpoint at 6 months in different clopidogrel loading doses. There was a similar incidence of all-cause mortality, nonfatal MI, nonfatal stroke, or rehospitalization for recurrent ischemia at 6 months in the clopidogrel 600 mg loading dose group (13.3%) versus 300 mg loading dose group (13.2%).47 The SOE was rated insufficient for composite ischemic endpoints at 6 months based on findings from one small trial and an imprecise estimate.

##### Effect on All-Cause Mortality at 30 Days and 6 Months

Of the three RCTs (two good quality, one fair) that reported the incidence of all-cause mortality at 30 days, two studies involving 358 patients reported no deaths in either treatment arm.50,51 The remaining study (good quality)46 included 25,086 UA/NSTEMI patients and reported similar all-cause mortality rates at 30 days for clopidogrel 300 mg loading dose versus 600 mg loading dose (2.3% vs. 2.4%) (HR 0.93; 95 % CI, 0.83 to 1.05, p=0.25). The SOE was rated low for no difference in all-cause mortality at 30 days based on a single large, good-quality RCT.

Only one study (fair quality) in 256 patients reported the incidence of all-cause mortality at 6 months.47 There were only four deaths in the overall cohort (three in 300 mg loading dose group, one in 600 mg loading dose group). The SOE was rated insufficient for all-cause mortality at 6 months based on a single small, fair-quality RCT.

##### Effect on Cardiovascular Mortality at 30 Days

Of these three RCTs (one good quality, two fair) with 25,497 patients that reported the incidence of cardiovascular mortality at 30 days, there was one good-quality study46 that included 25,086 patients and reported similar outcomes in the 300 mg loading dose group (2.2%) versus 600 mg loading dose (2.1%), HR 0.95 (95% CI, 0.81 to 1.13). The results of one fair-quality study reported one cardiovascular death in the clopidogrel 300 mg loading dose group and no deaths in the 600 mg loading dose group.49 The other fair-quality study reported a higher rate of cardiovascular mortality at 30 days in patients treated with clopidogrel 300 mg loading dose (2.4%) when compared with 600 mg loading dose (1.3%).48 The SOE was rated low for no difference in cardiovascular mortality at 30 days based on one good- and two fair-quality RCTs with inconsistent results of a direct outcome.

##### Effect on Nonfatal MI at 30 Days

A random-effects meta-analysis of five RCTs46,48-51 (two good quality, three fair) including 25,855 UA/NSTEMI patients reporting nonfatal MI at 30 days found that the odds ratio was 1.74 (95% CI, 0.99 to 3.05) showing a reduction in nonfatal MI favoring clopidogrel 600 mg, which did not reach statistical significance (Figure 12). There was some evidence of heterogeneity, with a Q-value of 7.832 for 4 degrees of freedom, p=0.098. The I^2^ value was 48.927. The largest RCT by Mehta resulted in an odds ratio of 1.16 (95% CI, 0.98 to 1.38). The inclusion of four single-center studies of fair-quality with a diverse patient population (not entirely UA/NSTEMI patients) likely contributed to the inconsistent and imprecise results. The SOE was rated low for nonfatal MI at 30 days based on two good- and three fair-quality RCTs with inconsistent and imprecise results of a direct outcome.

Figure 12 Meta-analysis of 300 mg versus 600 mg clopidogrel loading dose on nonfatal myocardial infarction at 30 days

CI = confidence interval; Clop = clopidogrel; mg = milligram

This figure displays a forest plot of a random-effects meta-analysis of five studies that shows an odds ratio of 1.74 (95% CI, 0.99 to 3.05), showing a reduction in nonfatal myocardial infarction favoring clopidogrel 600 mg that did not reach statistical significance.

##### Effect on Nonfatal MI at 6 Months

Only one RCT (fair quality) with 256 patients reported the incidence of nonfatal MI at 6 months.47 The lower incidence of nonfatal MI was statistically not significant in the 300 mg loading dose group (5.0% in 300 mg loading dose group, 8.6% in 600 mg loading dose group), p=0.26. The SOE was rated insufficient for nonfatal MI at 6 months based on one small, fair-quality RCT that was underpowered to answer the question.

##### Effect on Nonfatal Stroke at 30 Days and 6 Months

Two RCTs (one good quality, one fair) with 25,378 patients reported the incidence of nonfatal stroke at 30 days in patients treated with clopidogrel 600 mg loading dose versus 300 mg loading dose.46,49 In the largest study,46 the event rate was 0.5% in both loading dose groups (HR 1.19; 95% CI, 0.84 to 1.68). In the other study of 292 patients,49 there were two strokes in 300 mg loading dose group and one stroke in the 600 mg loading dose group. The SOE was rated insufficient for nonfatal stroke at 30 days since the total number of stroke events was insufficient to make a definitive conclusion.

Only one RCT (fair quality) in 256 patients reported the incidence of nonfatal stroke at 6 months.47 There was only one stroke in the entire cohort (600 mg loading dose group). The SOE was rated insufficient for nonfatal stroke at 6 months based on a single fair-quality RCT.

##### Effect on Revascularization at 30 Days and 6 Months

Three RCTs (one good quality, two fair) with 477 patients reported the incidence of revascularization at 30 days in patients treated with clopidogrel 600 mg loading dose versus 300 mg loading dose.48,50,51 Overall, there was a low event rate that was different among the studies. In one study,48 the higher rate of revascularization in patients treated with a 300 mg loading dose (4.8%) was not statistically significant when compared with those receiving a 600 mg loading dose (1.3%), p=0.61. In another study,50 there were no revascularization events in one treatment arm (600 mg loading dose group) and one revascularization in the other arm (300 mg loading dose group). In the third study,51 there was only one revascularization event (600 mg loading dose group) in the entire cohort. The SOE was rated insufficient for revascularization at 30 days based on one good- and two fair-quality RCTs with inconsistent results of a direct outcome.

Only one RCT (fair quality) in 256 patients reported the incidence of revascularization at 6 months.47 The lower incidence of revascularization was statistically nonsignificant in the 600 mg loading dose group (3.3% in 300 mg loading dose group, 2.3% in 600 mg loading dose group, p=0.64). The SOE was rated insufficient for revascularization at 6 months based on only one fair-quality RCT.

##### Effect on Major Bleeding at 30 Days

Of the six RCTs (two good quality, four fair) that reported the incidence of major bleeding at 30 days in 26,111 UA/NSTEMI patients, three studies reported no major bleeding in either treatment arm.49-51 In two of the remaining studies,47,48 there were more major bleeding events in the group treated with clopidogrel 300 mg loading dose (2.4% in both studies) compared with 600 mg loading dose (1.5%^47^ and 1.3%^48^) which were not statistically significant. In the largest study46 involving 25,086 UA/NSTEMI patients, there was a statistically nonsignificant difference in TIMI major bleeding favoring clopidogrel 300 mg loading dose (1.4%) compared with clopidogrel 600 mg loading dose (1.6%), p=0.39 (HR 1.09; 95% CI, 0.89 to 1.34). The SOE was rated insufficient for major bleeding at 30 days based on low event rates in two RCTs and inconsistent findings.

##### Effect on Minor Bleeding at 30 Days

Five RCTs (two good quality, three fair) including 25,819 UA/NSTEMI patients reported minor bleeding at 30 days.46-48,50,51 Of the five studies, three studies reported minor bleeding according to TIMI criteria47,48,51 and two studies reported minor bleeding according to non-TIMI criteria.46,50 Based on this, we did not perform meta-analysis of minor bleeding.

Of the three studies that reported TIMI minor bleeding, one study of 119 patients reported statistically significant higher bleeding rates in the 300 mg loading dose group (9.5%) when compared with 600 mg loading dose group (3.9%).48 In the other two studies reporting TIMI minor bleeding, there was no statistically significant difference in the incidence of minor bleeding (range 0.8% to 2.3% vs. 0.8% to 2.4%).47,51

In the studies that used non-TIMI criteria, the largest study of 25,086 patients found a lower incidence of minor bleeding that was statistically significant lower in the 300 mg loading dose group (4.3%) when compared with the 600 mg loading dose group (5.1%) (HR 1.13; 95% CI, 1.00 to 1.27, p=0.04).46 Conversely, in the other study, there was a lower incidence of minor bleeding in the clopidogrel 600 mg loading dose group (29.4%) when compared with the 300 mg loading dose group (31.4%).50 The SOE was rated insufficient for minor bleeding at 30 days based on two good- and three fair-quality RCTs with inconsistent results of a direct outcome and a wide confidence interval.

##### Effect on Stent Thrombosis at 30 Days

In the subgroup of 17,263 patients receiving PCI in a single, good-quality RCT (a prespecified subgroup),46 there was a lower incidence of stent thrombosis at 30 days in patients treated with clopidogrel 600 mg loading dose (1.6%) when compared with clopidogrel 300 mg loading dose (2.6%) (HR 0.68; 95% CI, 0.55 to 0.85, p<0.0001). The SOE was rated low for stent thrombosis at 30 days based on one large good-quality RCT.

##### Findings by Subgroup (KQ 1c)

Only one study (good quality) of 25,086 patients reported variations in treatment effectiveness by subgroup.46 Subgroups analyzed were age, sex, diabetes mellitus, GRACE risk score, the performance of PCI after randomization, and the presence of smoking. Prespecified subgroup analyses of intended clopidogrel pretreatment and the use of proton pump inhibitors after randomization are covered in separate sections of this report. Race, chronic kidney disease, troponin positivity, the type of coronary stent, geographic location, and other patient and demographic characteristics were not clearly described. The SOE for subgroup findings was rated insufficient since there was only one study reporting these results for this comparison. Table H-1 in Appendix H presents the results data for these subgroups.

###### Age

In 9321 patients over age 65, there was a statistically nonsignificant reduction in the incidence of composite ischemic events favoring clopidogrel 600 mg loading dose (6.3%) when compared with clopidogrel 300 mg loading dose (7.1%), p=0.15.

###### Sex

In 18,213 male patients, there was no difference in the incidence of composite ischemic events between those treated with clopidogrel 600 mg loading dose (4.1%) when compared with clopidogrel 300 mg loading dose (4.1%). In 6871 female patients, there was a statistically nonsignificant reduction in the incidence of composite ischemic events favoring clopidogrel 600 mg loading dose (4.5%) when compared with clopidogrel 300 mg loading dose (5.4%), p=0.09.

###### Diabetes Mellitus

In 5880 patients with diabetes mellitus, there was a statistically nonsignificant reduction in the incidence of composite ischemic events favoring clopidogrel 600 mg loading dose (5.2%) when compared with clopidogrel 300 mg loading dose (6.1%), p=0.16.

###### GRACE Risk Score

In 17,410 patients with a GRACE risk score less than 140, there was a statistically nonsignificant reduction in the incidence of composite ischemic events favoring treatment with clopidogrel 600 mg loading dose (2.5%) when compared with clopidogrel 300 mg loading dose (3.0%), p=0.06. In 6317 patients with a GRACE risk score more than 140, there was no difference in the incidence of composite ischemic events in those treated with clopidogrel 600 mg loading dose (7.7%) when compared with clopidogrel 300 mg loading dose (7.4%).

###### PCI After Randomization

In 17,263 patients who underwent PCI after randomization, there was a statistically significant reduction in the incidence of composite ischemic events favoring clopidogrel 600 mg loading dose (3.9%) when compared with clopidogrel 300 mg loading dose (4.5%), p=0.04.

###### Presence of Smoking

In 8373 patients who were smokers at the time of randomization, there was a statistically nonsignificant reduction in the incidence of composite ischemic events favoring clopidogrel 600 mg loading dose (2.9%) when compared with clopidogrel 300 mg loading dose (3.6%), p=0.07.

##### Summary of Results for Clopidogrel Loading Dose of 300 mg Versus 600 mg

In our analysis of clopidogrel loading doses (300 mg vs. 600 mg), each of the six studies reported different composite ischemic outcomes, thus prohibiting a meta-analysis. One large RCT reported no differences by loading dose for the composite endpoint of cardiovascular mortality, nonfatal MI, or nonfatal stroke at 30 days. For the individual outcomes of all-cause mortality and cardiovascular mortality, there were no statistically significant differences between clopidogrel loading doses. For nonfatal MI, there was a statistically nonsignificant difference in event rate but a trend favoring clopidogrel 600 mg loading dose at 30 days. There was a statistically significant lower rate of stent thrombosis favoring a clopidogrel loading dose of 600 mg versus 300 mg. Insufficient SOE exists for the comparative effectiveness of clopidogrel loading doses on composite ischemic endpoints, cardiovascular mortality at 30 days, nonfatal MI at 6 months, nonfatal stroke, revascularization, major bleeding, and minor bleeding, with most of these outcomes reported in smaller trials with imprecise estimates,

Subgroups analyzed in one study included age, sex, diabetes mellitus, GRACE risk score, the performance of PCI after randomization, and the presence of smoking. The analyses showed nonsignificant reductions in composite ischemic events favoring clopidogrel 600 mg for five subgroup categories, with statistically significant findings in patients who underwent PCI after randomization. Detailed SOE ratings are shown in Table 6.

Table 6 Detailed SOE for UA/NSTEMI patients treated with 300 mg versus 600 mg clopidogrel loading dose

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of Cardiovascular Mortality, Nonfatal MI, or Nonfatal Stroke at 30 Days | | | | | Low SOE
1 (25,086) | RCT/Good quality | NA | Direct | Precise | HR 0.94 (0.83 to 1.06) No difference
Composite of Cardiovascular Mortality, Nonfatal MI, or Revascularization at 30 Days | | | | | Insufficient SOE
1 (119) | RCT/Fair quality | NA | Direct | Imprecise | Lower rate in 600 mg group (10.4% vs. 23.8%)
Composite of Cardiovascular Mortality, Nonfatal MI, or Recurrent ACS at 30 Days | | | | | Insufficient SOE
1 (387) | RCT/Fair quality | NA | Direct | Imprecise | Lower rate in 600 mg group (4.8% vs. 12.3%)
Composite of All-Cause Mortality, Nonfatal MI, Revascularization, or Rehospitalization at 30 Days | | | | | Insufficient SOE
1 (103) | RCT/Fair quality | NA | Direct | Imprecise | Lower rate in 600 mg group (5.9% vs. 11.4%)
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 30 Days | | | | | Insufficient SOE
1 (255) | RCT/Good quality | NA | Direct | Imprecise | Lower rate in 600 mg group (4.0% vs. 11.6%)
Composite of All-Cause Mortality, Nonfatal MI, Nonfatal Stroke, or Rehospitalization at 6 Months | | | | | Insufficient SOE
1 (256) | RCT/Good quality | NA | Direct | Imprecise | No difference in event rates between groups (13.3% vs. 13.2 %)
All-Cause Mortality at 30 Days | | | | | Low SOE
3 (25,444) | 3 RCTs/2 good quality, 1 fair | Consistent | Direct | Precise | 2 small studies reported no deaths in both groups; largest study reported HR 0.93 (0.83 to 1.05) No difference
All-Cause Mortality at 6 Months | | | | | Insufficient SOE
1 (256) | RCT/Fair quality | NA | Direct | Imprecise | 3 deaths in 300 mg group; 1 death in 600 mg group
Cardiovascular Mortality at 30 Days | | | | | Low SOE
3 (25,497) | 3 RCTs/1 good quality, 2 fair | Inconsistent | Direct | Precise | Largest study reported HR 0.95 (0.81 to 1.13) No difference
Nonfatal MI at 30 Days | | | | | Low SOE
5 (25,855) | 5 RCTs/2 good quality, 3 fair | Inconsistent | Direct | Imprecise | OR 1.74 (0.99 to 3.05) Favors 600 mg dose
Nonfatal MI at 6 Months | | | | | Insufficient SOE
1 (256) | RCT/Fair quality | NA | Direct | Imprecise | Higher MI rate in 600 mg dose group (8.6% vs. 5.0%, p=0.26)
Nonfatal Stroke at 30 Days | | | | | Insufficient SOE
2 (25,378) | 2 RCTs/1 good quality, 1 fair | Consistent | Direct | Imprecise | Largest study reported HR 1.19 (0.84 to 1.68); smaller study reported 2 strokes in 300 mg group and 1 stroke in 600 mg group
Nonfatal Stroke at 6 Months | | | | | Insufficient SOE
1 (256) | RCT/Fair quality | NA | Direct | Imprecise | Only 1 stroke in overall cohort (600 mg group)
Revascularization at 30 days | | | | | Insufficient SOE
3 (477) | 3 RCTs/1 good quality, 2 fair | Inconsistent | Direct | Imprecise | Low overall event rate, ranging from 0 to 1.3% in 600 mg group and from 0 to 4.8% in 300 mg group
Revascularization at 6 months | | | | | Insufficient SOE
1 (256) | RCT/Fair quality | NA | Direct | Imprecise | Lower incidence in 600 mg dose group (2.3% vs. 3.3%, p=0.64)
Major bleeding at 30 days | | | | | Insufficient SOE
6 (26,111) | 6 RCTs/2 good quality, 4 fair | Inconsistent | Direct | Imprecise | 3 studies reported no bleeding events; inconsistent findings from 3 other studies, with largest study reporting HR 1.09 (0.89 to 1.34)
Minor bleeding at 30 days | | | | | Insufficient SOE
5 (25,819) | 5 RCTs/2 good quality, 3 fair | Inconsistent | Direct | Imprecise | Incidence ranged from 0.8% to 9.5% in 300 mg group, and from 0.8% to 3.9% in 600 mg group
Stent thrombosis at 30 days | | | | | Low SOE
1 (17,263) | RCT/Good quality | NA | Direct | Precise | HR 0.68 (0.55 to 0.85) Favors 600 mg dose

CI = confidence interval; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

#### 3 Clopidogrel Versus Ticagrelor or Prasugrel (KQ 1b)

Two RCTs compared ticagrelor with clopidogrel in 19,608 patients with ACS undergoing an early invasive strategy: one fair-quality study of 984 patients for 3 months' duration56 and a good-quality study of 18,624 patients for 277 days' median duration.54 One good-quality RCT of 13,608 patients compared prasugrel with clopidogrel for a median duration of 15 months.55

All three RCTs reported 30-day outcomes. The mean age of study participants ranged from 61 to 63 years of age. The proportion of female patients ranged from 26 to 36 percent. All three studies reported the percentage of White study participants (range 92 to 95%) while only one study additionally reported the percentage of African-American (1%) and Asian (6%) study participants.54 All three studies were conducted internationally and included sites in the United States or Canada. All three studies were funded by industry.

In two of the three studies investigating clopidogrel, ticagrelor, and prasugrel, a mixed population of patients (unstable angina, NSTEMI, and STEMI) was evaluated.54,55 Combined UA/NSTEMI subgroup data for the primary composite endpoint were available for the TRITON-TIMI 38 study;55 these percentages were manually calculated for the PLATO study54 from the individually reported UA and NSTEMI subgroup data. Given the heterogeneity of treatment comparisons, the small number of studies, and differences in treatment duration, no meta-analysis was performed to summarize the effect of these treatments. The full results across all outcomes are reported in Table G-3 in Appendix G.

##### Effect on Composite Ischemic Endpoints at 30 Days and After 1 Year

All three RCTs54-56 reported a composite outcome of cardiovascular mortality, nonfatal myocardial infarction, or nonfatal stroke at 30 days. There were mixed results in the two studies (one good quality, one fair) of 19,608 patients comparing ticagrelor (4.3%;56 4.8%^54^) and clopidogrel (3.8%;56 5.4%^54^) at 30 days. When subgroups of only UA/NSTEMI patients in one study were evaluated for the occurrence of cardiovascular mortality, nonfatal myocardial infarction, or nonfatal stroke after 1 year, the lower rates of major adverse cardiovascular events (MACE) were statistically significant in patients treated with ticagrelor (10.6%) when compared with clopidogrel (12.6%),54 The SOE for the composite endpoint was rated insufficient at 30 days due to inconsistent and imprecise results and moderate at 1 year due to precise and statistically significant results.

One good-quality study of 13,608 patients55 showed statistically significantly lower rates of MACE in patients randomized to prasugrel (5.7%) when compared with clopidogrel (7.4%) at 30 days. In the UA/NSTEMI subgroup, the occurrence of this composite outcome at 15 months was statistically significant with prasugrel (9.9%) when compared with clopidogrel (12.1%) (HR 0.81; 95% CI, 0.73 to 0.90; p<0.001).55 At 15 months, they found a statistically significant reduction in the group receiving prasugrel (HR 0.81; 95% CI, 0.73 to 0.89) for the composite outcome of cardiovascular mortality, nonfatal MI, or revascularization. The SOE was rated moderate for the composite endpoints at 30 days, 12 months, and 15 months based on one large, good-quality RCT with a significant finding.

##### Effect on All-Cause Mortality at 30 Days and After 1 Year

One fair-quality RCT of 984 patients comparing ticagrelor with clopidogrel56 reported all-cause mortality results at 30 days and found no difference between clopidogrel (0.6%) and ticagrelor (1.9%), p=0.18. The SOE was rated insufficient for all-cause mortality at 30 days based on one small, fair-quality RCT.

One good-quality RCT of 18,624 patients, the lower incidence of all-cause death after 1 year was statistically significant in patients treated with ticagrelor (4.5%) when compared with clopidogrel (5.9%) (HR 0.78; 95% CI, 0.69 to 0.89, p<0.001).54 The SOE was rated moderate for a benefit of ticagrelor compared with clopidogrel for all-cause mortality after 1 year.

One good-quality RCT of 13,608 patients showed a statistically nonsignificant reduction in all-cause deaths in patients treated with prasugrel (3.0%) when compared with clopidogrel (3.2%) (HR 0.95; 95% CI, 0.78 to 1.16, p=0.64).55 The SOE was rated low for a reduction in all-cause mortality after 1 year for prasugrel compared with clopidogrel.

##### Effect on Cardiovascular Mortality at 30 Days and After 1 Year

One fair-quality RCT of 984 patients comparing ticagrelor with clopidogrel56 reported cardiovascular mortality results at 30 days and found no difference between clopidogrel (0.6%) and ticagrelor (1.9%), p=0.18. In one good-quality RCT, there was a lower incidence of cardiovascular deaths after 1 year that was statistically significant in 18,624 patients treated with ticagrelor (4.0%) when compared with clopidogrel (5.1%) (HR 0.79; 95% CI, 0.69 to 0.91, p=0.001).54 The SOE was rated insufficient for any difference in cardiovascular mortality at 30 days and was rated moderate for a reduction in cardiovascular mortality at 1 year for patients on ticagrelor compared with clopidogrel.

One good-quality RCT of 13,608 patients showed a statistically nonsignificant reduction in cardiovascular mortality in patients treated with prasugrel (2.1%) when compared with clopidogrel (2.4%) (HR 0.89; 95% CI, 0.70 to 1.12, p=0.31.^55^ The overall SOE was rated low for cardiovascular mortality after 1 year based on one good-quality RCT with imprecise results.

##### Effect on Nonfatal MI at 30 Days and After 1 Year

One fair-quality RCT of 984 patients comparing ticagrelor with clopidogrel56 reported nonfatal MI results at 30 days and found no difference between clopidogrel (3.5%) and ticagrelor (2.2%), p=0.34. The lower incidence of nonfatal MI after 1 year was statistically significant in 18,624 patients treated with ticagrelor (5.8%) when compared with clopidogrel (6.9%) (HR 0.84; 95% CI, 0.75 to 0.95), p=0.005.^54^ The SOE was rated insufficient for any difference in nonfatal MI at 30 days and moderate SOE for a benefit of clopidogrel in reducing nonfatal MI at 1 year based on a large, good-quality RCT.

One good-quality RCT of 13,608 patients showed a lower incidence of nonfatal MI at 1 year prasugrel (7.3%) when compared with clopidogrel (9.5%) (HR 0.76; 95% CI, 0.67 to 0.85, p<0.001).55 The SOE was rated moderate for nonfatal MI after 1 year based on one large, good-quality RCT.

##### Effect on Nonfatal Stroke at 30 Days and After 1 Year

One fair-quality RCT of 984 patients comparing ticagrelor with clopidogrel56 reported nonfatal stroke results at 30 days and found no difference between clopidogrel (0.3%) and ticagrelor (0.6%), p=0.57. At 1 year, the incidence of nonfatal stroke was similar in 18,624 patients treated with ticagrelor (1.5%) when compared with patients treated with clopidogrel (1.3%) (HR 1.17; 95% CI, 0.91 to 1.52, p=0.22).54 The SOE was rated insufficient for nonfatal stroke at 30 days and 1 year based on imprecise estimates due to sparse numbers of stroke events.

The incidence of nonfatal stroke after 1 year was similar in all patients (13,608 patients, not limited to UA/NSTEMI patients) treated with prasugrel (1.0%) and clopidogrel (1.0%) (HR 1.02; 95% CI, 0.71 to 1.45, p=0.93).55 The SOE was rated insufficient for nonfatal stroke at 1 year based on imprecise estimates likely due to inadequate total number of stroke events to detect a difference between the treatments.

##### Effect on Revascularization at 30 days and After 6 Months

None of the studies reported revascularization event rates at 30 days. One study comparing prasugrel to clopidogrel in 13,608 patients55 reported revascularization events after 6 months and found a statistically significant reduction in the group receiving prasugrel (HR 0.66; 95% CI, 0.54 to 0.81). The SOE was rated insufficient for revascularization at 30 days for no available data and rated moderate for revascularization after 6 months based on one good-quality RCT with a direct and precise estimate.

##### Effect on Major and Minor Bleeding at 30 Days and After 1 Year

One fair-quality RCT of 984 patients comparing ticagrelor with clopidogrel56 reported major bleeding results at 30 days and found no difference between clopidogrel (6.9%) and ticagrelor (7.1%), p=0.91. The same study found no difference in minor bleeding: clopidogrel (1.3%) and ticagrelor (2.7%), p=0.18. After 1 year, the incidence of TIMI major bleeding was similar in all patients (not limited to UA/NSTEMI patients) treated with ticagrelor (7.9%) and clopidogrel (7.7%) (HR 1.03; 95% CI, 0.93 to 1.15, p=0.57).54 The SOE was rated insufficient for major and minor bleeding at 30 days and low at 1 year.

In the RCT of 13,608 patients treated with prasugrel (2.4%) had a higher rate of TIMI major bleeding when compared with clopidogrel (1.8%) (HR 1.32; 95% CI, 1.03 to1.68, p=0.03).55 The SOE was rated moderate for major bleeding after 1 year based on one good-quality RCT.

##### Effect on Stent Thrombosis After 1 Year

One RCT of 18,624 patients showed a lower incidence of definite or probable stent thrombosis after 1 year in patients treated with ticagrelor (2.2%) when compared with clopidogrel (2.9%) (HR 0.75; 95% CI, 0.59 to 0.95, p=0.02).54 The SOE was rated moderate for stent thrombosis after 1 year based on one large, good-quality RCT.

One RCT of 13,608 patients showed a lower incidence of definite or probable stent thrombosis after 1 year in patients treated with prasugrel (1.1%) when compared with clopidogrel (2.4%) (HR 0.48; 95% CI, 0.36 to 0.64, p<0.001).55 The SOE was rated moderate for stent thrombosis after 1 year based on one large, good-quality RCT.

##### Findings by Subgroup (KQ 1c)

Two RCTs (good quality) of 32,232 patients reported variations in treatment effectiveness by subgroup.54,55 Subgroups analyzed were age, sex, race, diabetes mellitus, chronic kidney disease, troponin positivity, TIMI risk score, weight, prior TIA or stroke, prior coronary revascularization, the performance of PCI after randomization, type of coronary stent, geographic location, and high risk of bleeding. Other patient and demographic characteristics were not clearly described. Table H-1 in Appendix H presents the results data for these subgroups.

###### Age

In 8322 patients under age 65 enrolled in the TRITON-TIMI 38 study, there was a statistically significant reduction in the incidence of composite ischemic events favoring prasugrel (8.1%) when compared with clopidogrel (10.6%). In 3477 patients between ages 65 and 74, there was a statistically nonsignificant reduction in the incidence of composite ischemic events favoring prasugrel (10.7%) when compared with clopidogrel (12.3%). In 1809 patients over age 75, there was no difference in the incidence of composite ischemic events between prasugrel (17.2%) and clopidogrel (18.3%).55

In 10,643 patients under age 65 enrolled in the PLATO study, there was a statistically significant reduction in the incidence of composite ischemic events favoring ticagrelor (7.2%) when compared with clopidogrel (8.5%). A similar benefit was observed in 7979 patients over age 65 in PLATO (ticagrelor 13.2%; clopidogrel 16.0%). When the results were analyzed using an older age cohort, a similar benefit was observed in 15744 patients under age 75 (ticagrelor 8.6%; clopidogrel 10.4%). In 2878 patients over age 75, there was no significant difference in the incidence of composite ischemic events between ticagrelor (16.8%) and clopidogrel (18.3%). There were no significant differences in major bleeding events based on age.54

###### Sex

In 10,085 male patients in TRITON-TIMI 38, there was a statistically significant reduction in the incidence of composite ischemic events favoring prasugrel (9.5%) when compared with clopidogrel (11.9%). In 3523 female patients, a trend toward reduction in the incidence of composite ischemic events did not reach statistical significance favoring prasugrel (11.0%) when compared with clopidogrel (12.6%).55

In 13,336 male patients in PLATO, there was a statistically significant reduction in the incidence of composite ischemic events favoring ticagrelor (9.2%) when compared with clopidogrel (11.1%). In 5288 female patients, a similar, statistically significant reduction in the incidence of composite ischemic events was observed favoring ticagrelor (11.2%) when compared with clopidogrel (13.2%). There were no statistically significant differences in major bleeding events based on sex.54

###### Race

There was no subgroup analysis of race in TRITON-TIMI 38. In 17,077 Caucasian patients in PLATO, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (9.5%) when compared with clopidogrel (11.2%). There were statistically nonsignificant differences in favor of ticagrelor in 229 Black patients (ticagrelor 13.0%; clopidogrel 19.6%), 1096 Asian patients (ticagrelor 12.5%; clopidogrel 14.8%), and 221 “other” patients (ticagrelor 14.4%; clopidogrel 21.4%). There were no statistically significant differences in major bleeding events based on race.54

###### Diabetes Mellitus

In 3146 patients with diabetes in TRITON-TIMI 38, there was a statistically significant reduction in the composite incidence of cardiovascular death/nonfatal MI, or nonfatal stroke favoring prasugrel (12.2%) when compared with clopidogrel (17.0%), p<0.001. This effect was mostly driven by a significant reduction in nonfatal MI in diabetic patients (prasugrel 8.2%; clopidogrel 13.2%). There was also a statistically significant reduction in probable or definite stent thrombosis favoring prasugrel (2.0%) over clopidogrel (3.6%) in diabetic patients. There was no significant difference in major bleeding (not related to CABG) in diabetics treated with prasugrel (2.5%) or clopidogrel (2.6%).55

In 4662 patients with diabetes mellitus in PLATO, there was a statistically nonsignificant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (14.1%) when compared with clopidogrel (16.2%). There were no statistically significant differences in major bleeding events based on the presence of diabetes mellitus.54

###### Chronic Kidney Disease

In 1490 patients with chronic kidney disease (defined as CrCl<60 ml/min) in TRITON-TIMI 38, there was a statistically nonsignificant reduction in the composite incidence of cardiovascular death, nonfatal MI, or nonfatal stroke favoring prasugrel (15.1%) when compared with clopidogrel (17.5%).55

In 3237 patients with chronic kidney disease (defined as CrCl60 ml/min) in PLATO, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (17.3%) when compared with clopidogrel (22.0%).54

###### Troponin Positivity

There was no subgroup analysis of troponin positivity or negativity in TRITON-TIMI 38.^55^ In 15,089 patients who presented with a positive first troponin I in PLATO, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (10.3%) when compared with clopidogrel (12.3%). In those patients who presented with a negative first troponin I, there was no difference in the incidence of the primary composite ischemic endpoint in patients treated with ticagrelor (7.0%) or clopidogrel (7.0%). There was no difference in major bleeding based on troponin positivity or negativity.54

###### TIMI Risk Score

There was no subgroup analysis of TIMI risk score in TRITON-TIMI 38.^55^ In 730 patients who had a low TIMI risk score in PLATO, there was no difference in the incidence of the primary composite ischemic endpoint between ticagrelor (4.2%) when compared with clopidogrel (4.1%). In 5488 patients who had an intermediate TIMI risk score, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (8.2%) when compared with clopidogrel (10.9%). In 4849 patients who had a high TIMI risk score, there was a statistically nonsignificant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (14.4%) when compared with clopidogrel (15.6%). There was no difference in major bleeding based on TIMI risk score.54

###### Weight

In 664 patients with low body weight (defined as weight <60 kg) in TRITON-TIMI 38, there was a statistically nonsignificant reduction in the composite incidence of cardiovascular death, nonfatal MI, or nonfatal stroke favoring clopidogrel (6.5%) when compared with prasugrel (10.1%).55

In 1312 patients with low body weight (defined as weight <60 kg) in PLATO, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (13.1%) when compared with clopidogrel (17.3%). However there was a lower incidence of major bleeding in patients treated with ticagrelor (12.6%) versus clopidogrel (15.2%) in patients with body weight less than 60 kg was not statistically significant.54

###### Prior Transient Ischemic Attack or Stroke

In 518 patients with a prior history of TIA or stroke in TRITON-TIMI 38, there was a statistically nonsignificant reduction in the composite incidence of cardiovascular death, nonfatal MI, or nonfatal stroke favoring clopidogrel (14.4%) when compared with prasugrel (19.1%). There was a statistically nonsignificant reduction in major bleeding not related to CABG favoring clopidogrel (2.9%) when compared with prasugrel (5.0%).55

In 1152 patients with a prior history of TIA or stroke in PLATO, there was a statistically nonsignificant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (19.0%) when compared with clopidogrel (20.8%). There was no difference in major bleeding based on a prior history of TIA or stroke.54

###### Prior Coronary Revascularization

There was no subgroup analysis of prior coronary revascularization in TRITON-TIMI 38.^55^ In 2492 patients with a prior history of PCI in PLATO, there was no difference in the incidence of the primary composite ischemic endpoint between ticagrelor (14.1%) and clopidogrel (14.6%). In 16,312 patients without a prior history of PCI in PLATO, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (9.1%) when compared with clopidogrel (11.2%). In 1106 patients with a prior history of CABG in PLATO, there was a statistically nonsignificant difference in the incidence of the primary composite ischemic endpoint between ticagrelor (19.5%) and clopidogrel (21.7%). In 17,518 patients without a prior history of CABG in PLATO, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (9.2%) when compared with clopidogrel (11.1%). There was no difference in major bleeding based on prior history of coronary revascularization with either PCI or CABG.54

###### PCI After Randomization

All patients in TRITON-TIMI 38 underwent PCI, thus no subgroup analysis was performed.55 There was no subgroup analysis of patients who underwent PCI after randomization in PLATO.54

###### Type of Coronary Stent

In 6461 patients who underwent bare metal stent implantation in TRITON-TIMI 38, there was a statistically significant reduction in the composite incidence of cardiovascular death, nonfatal MI, or nonfatal stroke favoring prasugrel (10.0%) when compared with clopidogrel (12.2%). A similar, statistically significant difference in composite ischemic events was observed in 6383 patients who underwent drug-eluting stent implantation (prasugrel=9.4%; clopidogrel=11.6%).55 There was no subgroup analysis of coronary stenting in PLATO.54

###### Geographic Region

There was no subgroup analysis of geographic region in TRITON-TIMI 38.^55^ In 13,859 patients enrolled in Europe/Middle East/Africa in PLATO, there was a statistically significant reduction in the incidence of the primary composite ischemic endpoint between ticagrelor (8.8%) when compared with clopidogrel (11.0%). In 1237 patients enrolled from Central/South America, there was a statistically nonsignificant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (15.2%) when compared with clopidogrel (17.9%). In 1714 patients enrolled from Asia/Australia, there was a statistically nonsignificant reduction in the incidence of the primary composite ischemic endpoint favoring ticagrelor (11.4%) when compared with clopidogrel (14.8%). In 1814 patients enrolled from North America, there was a statistically nonsignificant reduction in the incidence of the primary composite ischemic endpoint favoring clopidogrel (9.6%) when compared with ticagrelor (11.9%). There was no difference in major bleeding based on geographic region.54

###### High Risk of Bleeding

In a subgroup analysis of patients with a high risk of bleeding (i.e., age >75 years, body weight <60 kg, or history of stroke or TIA), there was a statistically nonsignificant increase in non-CABG-related TIMI major bleeding favoring clopidogrel (3.3%) when compared with prasugrel (4.3%).55 This subgroup was not reported in studies of ticagrelor versus clopidogrel.

##### Summary of Results for Clopidogrel Versus Ticagrelor or Prasugrel

The studies comparing clopidogrel with ticagrelor or prasugrel (one study of prasugrel and one of ticagrelor) reported a lower incidence of the composite outcome of cardiovascular mortality, nonfatal MI, or nonfatal stroke at 30 days. When this same composite endpoint was measured after 1 year, both ticagrelor and prasugrel had lower event rates than clopidogrel. Prasugrel reduced the composite endpoint of cardiovascular mortality, nonfatal MI, or revascularization at 15 months compared with clopidogrel. There was insufficient evidence for the following individual outcomes at 30 days: all-cause mortality, cardiovascular mortality, nonfatal MI, nonfatal stroke, major bleeding, and minor bleeding. There was also insufficient evidence for nonfatal stroke after 1 year. However, after 1 year, all-cause mortality and cardiovascular mortality had statistically significant decreases in event rates in patients treated with ticagrelor, but the difference in event rates between prasugrel and clopidogrel was not statistically significant. For nonfatal MI after 1 year, there was a statistically significant difference in event rates favoring both ticagrelor and prasugrel when compared with clopidogrel. None of the studies reported revascularization event rates at 30 days; after 6 months, one study found a statistically significant reduction favoring prasugrel. After 1 year, there was no statistically significant difference in major bleeding event rates between ticagrelor and clopidogrel; however, prasugrel was associated with higher major bleeding event rates than clopidogrel. For stent thrombosis, there was a statistically significant difference in event rates favoring ticagrelor and prasugrel when compared with clopidogrel.

Subgroup findings from two studies included age, sex, race, diabetes mellitus, chronic kidney disease, troponin positivity, TIMI risk score, weight, prior TIA or stroke, prior coronary revascularization, the performance of PCI after randomization, type of coronary stent, geographic location, and high risk of bleeding. Both studies showed similar reductions in ischemic outcomes on patients receiving the newer agent (prasugrel or ticagrelor) compared with clopidogrel across all subgroups; most subgroups' differences were not statistically significant, except among subgroups where the sample size was sufficiently large to detect a difference. Detailed SOE ratings are shown in Table 7.

Table 7 Detailed strength of evidence for UA/NSTEMI patients treated with clopidogrel versus ticagrelor or prasugrel

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of Cardiovascular Mortality, Nonfatal MI, or Nonfatal Stroke at 30 Days
Clopidogrel vs. Ticagrelor 2 (19,608) | 2 RCTs/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | Insufficient SOE Compared with clopidogrel (3.8% and 5.4%), ticagrelor had mixed results (4.3% and 4.8%)
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (7.4%), prasugrel (5.7%) was associated with lower composite endpoint Favors prasugrel
Composite of Cardiovascular Mortality, Nonfatal MI, or Nonfatal Stroke After 1 Year
Clopidogrel vs. Ticagrelor 1 (18,624) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (12.6%), ticagrelor (10.6%) was associated with lower composite endpoint Favors ticagrelor
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.81 (0.73 to 0.90) Compared with clopidogrel (12.1%), prasugrel (9.9%) was associated with lower composite endpoint at 15 months Favors prasugrel
Composite of Cardiovascular Mortality, Nonfatal MI, or Revascularization at 15 Months
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.81 (0.73 to 0.89) Favors prasugrel
All-Cause Mortality at 30 Days
Clopidogrel vs. Ticagrelor 1 (984) | RCT/Fair quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 0.6% Ticagrelor 1.9% p=0.18
All-Cause Mortality After 1 Year
Clopidogrel vs. Ticagrelor 1 (18,624) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (5.9%), ticagrelor (4.5%) was associated with fewer deaths Favors ticagrelor
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Imprecise | Low SOE Compared with clopidogrel (3.2%), prasugrel (3.0%) was associated with fewer deaths Favors prasugrel
Cardiovascular Mortality at 30 Days
Clopidogrel vs. Ticagrelor 1 (984) | RCT/Fair quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 0.6% Ticagrelor: 1.9% p=0.18
Cardiovascular Mortality After 1 Year
Clopidogrel vs. Ticagrelor 1 (18,624) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (5.1%), ticagrelor (4.0%) was associated with fewer cardiovascular deaths Favors ticagrelor
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Imprecise | Low SOE Compared with clopidogrel (2.4%), prasugrel (2.1%) was associated with fewer cardiovascular deaths Favors prasugrel
Nonfatal MI at 30 Days
Clopidogrel vs. Ticagrelor 1 (984) | RCT/Fair quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 3.5% Ticagrelor: 2.2% p=0.34
Nonfatal MI After 1 Year
Clopidogrel vs. Ticagrelor 1 (18,624) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (6.9%), ticagrelor (5.8%) was associated with fewer MIs Favors ticagrelor
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (9.5%), prasugrel (7.3%) was associated with fewer MIs Favors prasugrel
Nonfatal Stroke at 30 days
Clopidogrel vs. Ticagrelor 1 (984) | RCT/Fair quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 0.3% Ticagrelor: 0.6% p=0.57
Nonfatal Stroke After 1 Year
Clopidogrel vs. Ticagrelor 1 (18,624) | RCT/Good quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 1.3% Ticagrelor: 1.5%
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 1.0% Prasugrel: 1.0%
Revascularization at 30 Days
Both comparisons 0 | NA | NA | NA | NA | Insufficient SOE NA
Revascularization After 6 Months
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.66 (0.54 to 0.81) Favors prasugrel
Major Bleeding at 30 Days
Clopidogrel vs. Ticagrelor 1 (984) | RCT/fair quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 6.9% Ticagrelor: 7.1%
Major Bleeding After 1 Year
Clopidogrel vs. Ticagrelor 1 (18,624) | RCT/Good quality | NA | Direct | Imprecise | Low SOE Compared with clopidogrel (7.7%), ticagrelor (7.9%) had similar event rates No difference
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (1.8%), prasugrel (2.4%) was associated with higher event rates Favors clopidogrel
Minor Bleeding at 30 Days
Clopidogrel vs. Ticagrelor 1 (984) | RCT/Fair quality | NA | Direct | Imprecise | Insufficient SOE Clopidogrel: 1.3% Ticagrelor: 2.7% p=0.18
Stent Thrombosis After 1 Year
Clopidogrel vs. Ticagrelor 1 (18,624) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (2.9%), ticagrelor (2.2%) was associated with lower event rates Favors ticagrelor
Clopidogrel vs. Prasugrel 1 (13,608) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Compared with clopidogrel (2.4%), prasugrel (1.1%) was associated with lower event rates Favors prasugrel

CI = confidence interval; HR = hazard ratio; MI = myocardial infarction; NA = not applicable; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

#### 4 Bivalirudin Versus Heparin-Based Strategy Without and With Planned GPI (KQ 1b)

Thirteen studies (eight RCTs, five observational) compared bivalirudin with a heparin-based strategy in 30,486 UA/NSTEMI patients undergoing an invasive approach.57-64,100,101,107-109 Outcomes that were assessed in this comparison included composite ischemic endpoints, all-cause mortality, nonfatal MI, revascularization, stent thrombosis, major bleeding, and minor bleeding. These results are reported in Table G-4 in Appendix G.

- Three RCTs compared bivalirudin with unfractionated heparin (UFH) or enoxaparin without planned GPI and included a total of 5822 patients.57-59 One additional RCT compared bivalirudin with UFH or enoxaparin without planned GPI60 and met inclusion criteria but was not included in our synthesis due to a low use of invasive strategy and because the sponsor terminated the study with 3 percent of patients enrolled. However because the study was designed to answer the question of interest we included it in our listing of studies.60
- Four RCTs compared bivalirudin with UFH or enoxaparin with planned GPI and included a total of 17,748 patients.61-64 One RCT64 reported outcomes in patients randomized to bivalirudin versus UFH plus GPI, but because followup was limited to 48 hours, these results were not included in the meta-analysis. The results, however, were similar to other studies in this comparison; total mortality and nonfatal MI were slightly higher in bivalirudin-treated patients when compared with UFH plus GPI, but major bleeding and minor bleeding were lower.
- Five observational studies (all fair quality) evaluated the use of bivalirudin in patients undergoing PCI for varying indications. Two studies evaluated patients with ACS only, but there was not clarity on the use of an early invasive strategy, and both studies had differential utilization of GPI.100,101 In both studies, the rate of ischemic complications was similar in the bivalirudin and heparin-treated groups. The other three studies included an unselected patient population undergoing PCI and there was differential use of GPI, thus limiting the estimation of effect of the treatment comparisons in UA/NSTEMI patients.107-109 In each of these studies, the rate of bleeding and ischemic complications was lower in bivalirudin-treated patients when compared with heparin or heparin + GPI treated patients. Because of patient population heterogeneity and differential use of GPI, none of these observational studies were included in the meta-analysis.

Of the six RCTs included in the meta-analyses,57-59,61-63 five (83%) were rated good quality and one (17%) fair. Sample sizes for individual studies ranged from 401 to 13,819 patients. Study duration ranged from 48 hours to 1 year, with each RCT reporting 30 day outcomes.

The mean age of study participants ranged from 61 to 70 years of age. The proportion of female patients ranged from 23 to 30 percent. One study (17%) reported the racial and ethnic demographics of study participants. One study (17%) was conducted entirely within the United States or Canada, with the other conducted internationally. Funding source was reported in all six studies, with five studies (83%) funded by an industry source.

Across all outcomes, we present the results of the bivalirudin versus heparin-based strategy for the “without planned GPI” studies separately from the “with planned GPI” studies since the event rates for ischemic and bleeding outcomes may differ across combinations of anticoagulant and antiplatelets administered.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, Revascularization, or Major Bleeding at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

Only one RCT (good quality) reported the composite endpoint of all-cause mortality, nonfatal MI, revascularization, or major bleeding at 30 days in 4571 patients randomized to a bivalirudin versus heparin-based strategy without planned GPI.58 In this study, there was a similar incidence of the composite endpoint for patients treated with bivalirudin (8.4%) and heparin without planned GPI (8.7%), relative risk (RR) 0.94 (95% CI, 0.77 to 1.15). The SOE was rated insufficient for this composite outcome based on one good-quality RCT that was underpowered to answer the question (i.e., study was powered to detect 27.5% risk reduction with bivalirudin for this primary endpoint; a larger sample size would be required to detect smaller differences).

###### Bivalirudin Versus UFH With Planned GPI

A random-effects meta-analysis of three RCTs61-63 (all good quality) including 12,287 UA/NSTEMI patients reporting the composite outcome of all-cause mortality, nonfatal MI, revascularization, or major bleeding at 30 days found that the odds ratio was 0.87 (95% CI, 0.78 to 0.97) favoring bivalirudin compared with a heparin-based strategy and planned GPI (Figure 13). There was no evidence of heterogeneity, with a Q-value of 0.51 for 2 degrees of freedom, p=0.78. The SOE was rated high for this composite outcome based on consistent results of a direct outcome and a narrow confidence interval.

Figure 13 Meta-analysis of bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor on all-cause mortality, nonfatal myocardial infarction, revascularization, or major bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 0.87 (95% CI, 0.78 to 0.97), favoring bivalirudin.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, or Revascularization at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

Two RCTs57,58 (one good quality, one fair) including 5420 UA/NSTEMI patients reported the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days. The study by Kastrati reported an odds ratio of 1.19 (95% CI, 0.92 to 1.54) with no statistically significant difference between treatment groups. The study by Parodi reported an odds ratio of 0.42 (95% CI, 0.21 to 0.84) with statistically significant reduction of composite events in the bivalirudin group, p=0.02. The differential use of clopidogrel loading, the discretionary use of bailout GPI at the time of PCI, and the inclusion of a different proportion of ACS and stable angina patients likely contributed to the inconsistent results. The SOE was rated insufficient for this composite outcome based on one good- and one fair-quality RCT with inconsistent results of a direct outcome and imprecise results.

###### Bivalirudin Versus UFH With Planned GPI

A random-effects meta-analysis of three RCTs61-63 (all good quality) including 12,287 UA/NSTEMI patients reporting the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days found that the odds ratio was 1.07 (95% CI, 0.95 to 1.22) showing noninferiority of a heparin-based strategy with planned GPI compared with bivalirudin (Figure 14). There was no evidence of heterogeneity, with a Q-value of 0.05 for 2 degrees of freedom, p=0.98. The SOE was rated high for this composite outcome based on three good-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 14 Meta-analysis of bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor on all-cause mortality, nonfatal myocardial infarction, or revascularization at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.07 (95% CI, 0.95 to 1.22), showing noninferiority of a heparin-based strategy with planned glycoprotein inhibitor compared with bivalirudin.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, or Revascularization at 1 Year

###### Bivalirudin Versus UFH Without Planned GPI

Two RCTs57,58 (one good quality, one fair) including 5420 UA/NSTEMI patients reported the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 1 year. The good-quality study by Kastrati reported an odds ratio of 0.97 (95% CI, 0.83 to 1.13) with no statistically significant difference between treatment groups. The fair-quality study by Parodi reported an odds ratio of 0.58 (95% CI, 0.37 to 0.92) with a statistically significant reduction in composite events in the bivalirudin group, p=0.02. The differential use of clopidogrel loading, the discretionary use of bailout GPI at the time of PCI, and the inclusion of a different proportion of ACS and stable angina patients likely contributed to the inconsistent findings. The SOE was rated insufficient for this composite outcome based on one good- and one fair-quality RCT with inconsistent and imprecise results of a direct outcome.

###### Bivalirudin Versus UFH With Planned GPI

Two RCTs62,63 (both good quality) including 10,566 UA/NSTEMI patients reported the composite outcome of all-cause mortality, nonfatal MI, or revascularization between 6 months and 1 year. The Rajagopal study found an OR of 1.11 (95% CI, 0.74 to 1.63), and the Stone study found an odds ratio of 1.08 (95% CI, 0.92 to 1.25). While both ORs favored GPI with UFH, the findings were not statistically significant and did not support a difference. The SOE of no difference was rated low for this composite outcome based on two good-quality RCTs with consistent results of a direct outcome and imprecise estimates with confidence intervals that cross 1.

##### Effect on All-Cause Mortality at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

A random-effects meta-analysis of three RCTs57-59 (two good quality, one fair) including 5822 UA/NSTEMI patients reporting all-cause mortality at 30 days found that the odds ratio was 0.46 (95% CI, 0.12 to 1.81) favoring bivalirudin compared with a heparin-based strategy without planned GPI (Figure 15). There was no evidence of heterogeneity, with a Q-value of 2.39 for 2 degrees of freedom, p=0.30. The SOE was rated insufficient based on two good- and one fair-quality RCTs with inconsistent results of a direct outcome and a wide confidence interval.

Figure 15 Meta-analysis of bivalirudin versus heparin-based strategy without planned glycoprotein inhibitor on all-cause mortality at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 0.46 (95% CI, 0.12 to 1.81).

###### Bivalirudin Versus UFH With Planned GPI

A random-effects meta-analysis of three RCTs61-63 (all good quality) including 12,287 UA/NSTEMI patients reporting all-cause mortality at 30 days found that the odds ratio was 1.21 (95% CI, 0.89 to 1.65) for bivalirudin compared with a heparin-based strategy and planned GPI (Figure 16). There was evidence of no heterogeneity, with a Q-value of 0.08 for 2 degrees of freedom, p=0.96. The SOE was rated insufficient based on three good-quality RCTs with consistent results of a direct outcome and a wide confidence interval.

Figure 16 Meta-analysis of bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor on all-cause mortality at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.21 (95% CI, 0.89 to 1.65).

##### Effect on All-Cause Mortality After 6 Months

###### Bivalirudin Versus UFH Without Planned GPI

Only two studies57,58 (one good quality, one fair) reported the incidence of all-cause mortality after 6 months in 5420 patients treated with bivalirudin versus heparin-based strategy. In one study of 850 patients, fewer patients treated with bivalirudin (1.2%) died compared with patients treated with a heparin-based strategy (2.4%) at 1 year, p=0.193.^57^ In the other study of 4570 patients, there was a slightly higher rate of death in patients treated with bivalirudin (1.9%) versus heparin-based strategy (1.7%) at 6 months, p=0.667.^58^ The SOE was rated insufficient based on one good- and one fair-quality RCTs with inconsistent results of a direct outcome.

###### Bivalirudin Versus UFH With Planned GPI

Only two studies62,63 (both good quality) reported the incidence of all-cause mortality after 6 months in 10,566 patients treated with bivalirudin versus heparin plus GPI. In one study of 1351 patients, death rates were similar between patients treated with bivalirudin (0.9%) and those treated with heparin plus GPI (1.3%) at 6 months, p=0.46.^63^ In the other study of 9215 patients, there was a similar rate of death in patients treated with bivalirudin (3.8%) versus heparin plus GPI (3.8%) at 1 year.62 The SOE was rated insufficient based on two good-quality RCTs with consistent results of a direct outcome.

##### Effect on Nonfatal MI at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

A random-effects meta-analysis of three RCTs57-59 (two good quality, one fair) including 5822 UA/NSTEMI patients reporting nonfatal MI at 30 days found that the odds ratio was 1.00 (95% CI, 0.64 to 1.55) for bivalirudin compared with a heparin-based strategy without planned GPI (Figure 17). There was some evidence of heterogeneity, with a Q-value of 3.93 for 2 degrees of freedom, p=0.14. The I^2^ value was 49.15. The differential use of clopidogrel loading, the discretionary use of bailout GPI at the time of PCI, and the inclusion of a different proportion of ACS and stable angina patients likely contributed to the statistical heterogeneity. The SOE was rated insufficient based on two good- and one fair-quality RCTs with inconsistent results of a direct outcome and a wide confidence interval.

Figure 17 Meta-analysis of bivalirudin versus heparin-based strategy without planned glycoprotein inhibitor on nonfatal myocardial infarction at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.00 (95% CI, 0.64 to 1.55).

###### Bivalirudin Versus UFH With Planned GPI

A random-effects meta-analysis of three RCTs61-63 (all good quality) including 12,287 UA/NSTEMI patients reporting nonfatal MI at 30 days found that the odds ratio was 1.06 (95% CI, 0.92 to 1.23) for bivalirudin compared with a heparin-based strategy and planned GPI (Figure 18). There was no evidence of heterogeneity, with a Q-value of 0.78 for 2 degrees of freedom, p=0.70. The SOE was rated moderate for no difference based on three good-quality RCTs with consistent results of a direct outcome and confidence interval that crosses 1.

Figure 18 Meta-analysis of bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor on nonfatal myocardial infarction at 30 days

CI = confidence interval; GPI = glycoprotein inhibitor; UFH = unfractionated heparin

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.06 (95% CI, 0.92 to 1.23), showing no difference.

##### Effect on Nonfatal MI After 6 Months

###### Bivalirudin Versus UFH Without Planned GPI

Only two studies57,58 (one good quality, one fair) reported the incidence of nonfatal MI after 6 months in 5420 patients treated with bivalirudin versus a heparin-based strategy. In one study of 850 patients, although there were fewer MI events in patients treated with bivalirudin (3.3%) compared with patients treated with a heparin-based strategy (5.7%) at 6 months, the finding was not statistically significant, p=0.095.^57^ In the other study of 4570 patients, there was a higher rate of MI in patients treated with bivalirudin (6.0%) versus a heparin-based strategy (5.3%) at 6 months which was also not statistically significant, p=0.320.^58^ The SOE was rated insufficient based on one good- and one fair-quality RCTs with inconsistent results of a direct outcome.

###### Bivalirudin Versus UFH With Planned GPI

Two studies62,63 (both good quality) reported the incidence of nonfatal MI after 6 months in 10,566 patients treated with bivalirudin versus a heparin-based strategy plus GPI strategy. In both studies, there was a higher rate of nonfatal MI in patients treated with bivalirudin (7.8%;62 8.1%^63^) versus heparin plus GPI (6.9%;62 7.6%^63^) at 6 months and 1 year (p=NS for both studies). The SOE was rated moderate for a benefit of heparin based on two good-quality RCTs with consistent results of a direct outcome.

##### Effect on Revascularization at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

A random-effects meta-analysis of three RCTs57-59 (two good quality, one fair) including 5822 UA/NSTEMI patients reporting revascularization at 30 days found that the odds ratio was 1.10 (95% CI, 0.60 to 2.04) for bivalirudin compared with a heparin-based strategy without planned GPI (Figure 19). There was no evidence of heterogeneity, with a Q-value of 0.721 for 2 degrees of freedom, p=0.697. The differential use of clopidogrel loading, the discretionary use of bailout GPI at the time of PCI, and the inclusion of a different proportion of ACS and stable angina patients likely contributed to the inconsistent results. The SOE was rated insufficient based on two good- and one fair-quality RCTs with inconsistent results of a direct outcome and a wide confidence interval.

Figure 19 Meta-analysis of bivalirudin versus heparin-based strategy without planned glycoprotein inhibitor on revascularization at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.10 (95% CI, 0.60 to 2.04).

###### Bivalirudin Versus UFH With Planned GPI

A random-effects meta-analysis of three RCTs61-63 (all good quality) including 12,287 UA/NSTEMI patients reporting revascularization at 30 days found that the odds ratio was 1.11 (95% CI, 0.86 to 1.42) demonstrating a trend favoring bivalirudin compared with a heparin-based strategy and planned GPI (Figure 20). There was no evidence of heterogeneity, with a Q-value of 1.12 for 2 degrees of freedom, p=0.57. The SOE was rated low for a benefit of bivalirudin based on three good-quality RCTs with consistent results of a direct outcome and a wide confidence interval that crosses 1.

Figure 20 Meta-analysis of bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor on revascularization at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.11 (95% CI, 0.86 to 1.42), demonstrating a trend favoring bivalirudin.

##### Effect on Revascularization After 6 Months

###### Bivalirudin Versus UFH Without Planned GPI

Only two studies57,58 (one good quality, one fair) reported the incidence of revascularization after 6 months in 5420 patients treated with bivalirudin versus heparin-based strategy without planned GPI. In both studies, there was a lower rate of revascularization in patients treated with bivalirudin (4.1%^57^ 11.2%^58^) versus heparin-based strategy (5.7%;57 12.5%^58^) at 6 months and 1 year (p=NS for both studies). The SOE was rated insufficient based on inconclusive and imprecise findings.

###### Bivalirudin Versus UFH With Planned GPI

Only two studies62,63 (both good quality) reported the incidence of revascularization after 6 months in 10,566 patients treated with bivalirudin versus heparin plus GPI. In both studies, there was a higher rate of revascularization in patients treated with bivalirudin (8.7%;62 11.7%^63^) versus heparin plus GPI (8.4% in both studies) at 6 months and 1 year (p=0.49 and 0.04, respectively). The SOE was rated low that favors heparin after 6 months with planned GPI based on two good-quality RCTs with consistent results of a direct outcome.

##### Effect on Major Bleeding at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

A random-effects meta-analysis of three RCTs57-59 (two good quality, one fair) including 5822 UA/NSTEMI patients reporting major bleeding at 30 days found that the odds ratio was 0.63 (95% CI, 0.47 to 0.85) favoring bivalirudin compared with a heparin-based strategy without planned GPI (Figure 21). There was no evidence of heterogeneity, with a Q-value of 1.51 for 2 degrees of freedom, p=0.47. The SOE was rated high based on two good- and one fair-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 21 Meta-analysis of bivalirudin versus heparin-based strategy without planned glycoprotein inhibitor on major bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 0.63 (95% CI, 0.47 to 0.85), favoring bivalirudin.

###### Bivalirudin Versus UFH With Planned GPI

A random-effects meta-analysis of three RCTs61-63 (all good quality) including 12,287 UA/NSTEMI patients reporting major bleeding at 30 days found that the odds ratio was 0.52 (95% CI, 0.43 to 0.63) favoring bivalirudin compared with a heparin-based strategy without planned GPI (Figure 22). There was no evidence of heterogeneity, with a Q-value of 0.20 for 2 degrees of freedom, p=0.91. The SOE was rated high based on three good-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 22 Meta-analysis of bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor use on major bleeding at 30 days

Bival = bivalirudin; CI = confidence interval; GPI = glycoprotein inhibitor; Hep = heparin

This figure displays a forest plot of a random-effects meta-analysis of three studies that show an odds ratio of 0.52 (95% CI, 0.43 to 0.63), favoring bivalirudin.

##### Effect on Minor Bleeding at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

A random-effects meta-analysis of three RCTs57-59 (two good quality, one fair) including 5822 UA/NSTEMI patients reporting minor bleeding at 30 days found that the odds ratio was 0.64 (95% CI, 0.43 to 0.95) favoring bivalirudin compared with a heparin-based strategy without planned GPI (Figure 23). There was no evidence of heterogeneity, with a Q-value of 1.86 for 2 degrees of freedom, p=0.395. The differential use of clopidogrel loading, the discretionary use of bailout GPI at the time of PCI, and the inclusion of a different proportion of ACS and stable angina patients likely contributed to the inconsistent results. The SOE was rated low based on two good- and one fair-quality RCTs with inconsistent results of a direct outcome and a wide confidence interval.

Figure 23 Meta-analysis of bivalirudin versus heparin-based strategy without planned glycoprotein inhibitor on minor bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 0.64 (95% CI, 0.43 to 0.95), favoring bivalirudin.

###### Bivalirudin Versus UFH With Planned GPI

A random-effects meta-analysis of three RCTs61-63 (all good quality) including 12,287 UA/NSTEMI patients reporting minor bleeding at 30 days found that the odds ratio was 0.49 (95% CI, 0.42 to 0.59) favoring bivalirudin compared with heparin-based strategy with planned GPI (Figure 24). There was no evidence of heterogeneity, with a Q-value of 3.16 for 2 degrees of freedom, p=0.21. The SOE was rated high based on three good-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 24 Meta-analysis of bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor on minor bleeding at 30 days

Bival = bivalirudin; CI = confidence interval; GPI = glycoprotein inhibitor; Hep = heparin

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 0.49 (95% CI, 0.42 to 0.59), favoring bivalirudin.

##### Effect on Stent Thrombosis at 30 Days

###### Bivalirudin Versus UFH Without Planned GPI

Of the three RCTs57-59 (two good quality, one fair) including 5822 UA/NSTEMI patients that reported stent thrombosis at 30 days, there was a higher incidence of stent thrombosis in patients treated with bivalirudin (event rate was 0.5% in all three studies) when compared with patients treated with a heparin-based strategy without planned GPI (range 0 to 0.4%) which was not statistically significant. A random effects meta-analysis of three RCTs (two good quality, one fair) including 5822 UA/NSTEMI patients reporting stent thrombosis at 30 days found that the odds ratio was 1.42 (95% CI, 0.64 to 3.15) comparing bivalirudin with a heparin-based strategy without planned GPI (Figure 25). There was no evidence of heterogeneity with a Q-value of 0.50 for 2 degrees of freedom, p=0.78. The SOE was rated insufficient based on an imprecise estimate and a low total number of events.

Figure 25 Meta-analysis of bivalirudin versus heparin-based strategy without planned glycoprotein inhibitor on stent thrombosis at 30 days

CI = confidence interval

This figure displays a forest plot of a random effects meta-analysis of three studies that shows an odds ratio of 1.42 (95% CI, 0.64 to 3.15).

###### Bivalirudin Versus UFH With Planned GPI

Of the two RCTs62,63 (both good quality) including 10,936 UA/NSTEMI patients that reported stent thrombosis at 30 days, there was a higher incidence in event rates between those treated with bivalirudin (0.7%;62 1.0%^63^) when compared with those treated with a heparin-based strategy plus GPI (0.6 %;62 0.8%^63^) which was not statistically significant. The SOE was rated insufficient based on studies not sufficiently powered to detect a difference.

##### Findings by Subgroup (KQ 1c)

Three studies (good quality) of 15,494 patients reported variations in treatment effectiveness by subgroup.58,61,62 The main report from an additional study reported subgroups, but because data were abstracted from the subgroup report of UA/NSTEMI patients, this was not included in the findings by subgroup.63 Subgroups analyzed were age, sex, diabetes mellitus, chronic kidney disease, serum biomarker positivity, TIMI risk score, weight, and the performance of PCI or CABG after randomization. Prespecified subgroup analysis of intended clopidogrel pretreatment is covered in a separate section of this report. Other patient and demographic characteristics were not clearly described. Table H-1- in Appendix H presents the results data for these subgroups.

###### Age

In 4570 patients in the ISAR-REACT 3 study, there was no significant difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding in patients less than or greater than 67.6 years of age (prespecified subgroup).58

In 5051 patients under 65 years of age and in 4164 patients over 65 years of age in ACUITY, there was no statistically significant difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 1 year between bivalirudin and heparin-based strategy with planned GPI use.62

In 1721 patients in ISAR-REACT 4, there was no statistically significant difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding in patients less than or greater than 68.3 years of age (prespecified subgroup).61

###### Sex

In 3495 male patients in ISAR-REACT 3, there was no difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 1 year between bivalirudin (7.3%) and heparin-based strategy without planned GPI use (7.4%). In 1075 female patients, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 1 year favoring bivalirudin (11.4%) when compared with heparin-based strategy without planned GPI use (13.2%).58

In 6444 male patients in ACUITY, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 1 year favoring heparin-based strategy with planned GPI use (16.2%) when compared with bivalirudin (17.1%). In 2771 female patients, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 1 year favoring bivalirudin (13.7%) when compared with heparin-based strategy with planned GPI use (14.3%).62

In 399 male patients in ISAR-REACT 4, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding favoring treatment with bivalirudin (12.6%) when compared with heparin-based strategy plus planned GPI use (15.5%). In 1332 female patients, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding favoring treatment with heparin-based strategy plus planned GPI use (9.5%) when compared with bivalirudin (10.6%).61 Even though the findings in men and women favor opposite treatments, the test for an interaction was not significant (p=0.27).

###### Diabetes Mellitus

In 1254 patients with diabetes mellitus in ISAR-REACT 3, there was no difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days between bivalirudin (10.0%) and heparin-based strategy without planned GPI use (9.7%).58

In 2585 patients with diabetes mellitus in ACUITY, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 1 year favoring heparin-based strategy with planned GPI use (17.9%) when compared with bivalirudin (19.5%).62

In 500 patients with diabetes mellitus in ISAR-REACT 4, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days favoring treatment with bivalirudin (9.9%) when compared with heparin-based strategy plus planned GPI use (10.5%).61

###### Chronic Kidney Disease

In 2598 patients with chronic kidney disease (defined as serum creatinine > 0.9) in ISAR-REACT 3, there was no difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days between bivalirudin (8.4%) and heparin-based strategy without planned GPI use (8.3%).58

In 1643 patients with chronic kidney disease (defined as CrCl<60 ml/min) in ACUITY, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days favoring bivalirudin (16.1%) when compared with heparin-based strategy with planned GPI use (16.9%). There was a statistically significant reduction in the incidence of major bleeding at 30 days favoring bivalirudin (6.2%) when compared with heparin-based strategy with planned GPI use (9.8%).62

In 860 patients with glomerular filtration rate less than 83 ml/min (prespecified subgroup) in ISAR-REACT 4, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days favoring treatment with heparin-based strategy plus planned GPI use (10.7%) when compared with bivalirudin (12.1%).61

###### Serum Biomarker Positivity

There was no subgroup analysis of serum biomarkers in ISAR-REACT 3.^58^ In 5073 patients with abnormal CK MB or troponin in ACUITY, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days favoring bivalirudin (16.1%) when compared with heparin-based strategy with planned GPI use (16.9%). There was a statistically significant reduction in the incidence of major bleeding at 30 days favoring bivalirudin (3.8%) when compared with heparin-based strategy with planned GPI use (6.4%) in patients with abnormal CK MB or troponin. The same finding was observed in patients without abnormal CK MB or troponin.62

In 849 patients with troponin T level greater than 0.12 mcg/l (prespecified subgroup) in ISAR-REACT 4, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days favoring treatment with heparin-based strategy plus planned GPI use (13.2%) when compared with bivalirudin (15.5%).61

###### TIMI Risk Score

There was no subgroup analysis of TIMI risk score in ISAR-REACT 3^58^ or ISAR-REACT 4.^61^ In 1291 patients with a low TIMI risk score in ACUITY, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days favoring bivalirudin (4.2%) when compared with heparin-based strategy with planned GPI use (5.8%). In 4407 patients with an intermediate TIMI risk score, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days favoring heparin-based strategy with planned GPI use (6.1%) when compared with bivalirudin (7.4%). In 2449 patients with a high TIMI risk score, there was no difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days between bivalirudin (11.0%) and heparin-based strategy with planned GPI use (10.6%).62

###### Weight

There was no subgroup analysis of weight or body-mass index in ISAR-REACT 3,^58^ or ACUITY.62 In ISAR-REACT 4, there was no significant difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days in patients with a body-mass index greater than or less than 27.3 (prespecified subgroup).61

###### PCI or CABG After Randomization

There was no subgroup analysis of PCI or CABG in ISAR-REACT 3^58^ or ISAR-REACT 4.^61^ In 5180 patients treated with PCI as initial treatment strategy in ACUITY, there was no difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days between bivalirudin (8.8%) and heparin-based strategy with planned GPI use (8.2%). In 1040 patients treated with CABG as initial treatment strategy in ACUITY, there was a statistically nonsignificant difference in the incidence of death, nonfatal MI, urgent target vessel revascularization or major bleeding at 30 days between bivalirudin (16.1%) and heparin-based strategy with planned GPI use (15.1%).62

##### Summary of Results for Bivalirudin Versus Heparin-Based Strategy

In our analysis of studies comparing bivalirudin versus heparin-based strategy with or without planned GPI use, there were no statistically significant differences in the incidence of the composite endpoints of mortality, nonfatal MI, or revascularization at 30 days, and the data were rated insufficient after 1 year without GPI use, and rated low after 1 year with GPI use. When major bleeding was added to this composite outcome (all-cause mortality, nonfatal MI, revascularization, or major bleeding), a statistically significant net clinical difference favoring bivalirudin was observed in the comparison of bivalirudin versus heparin-based strategy plus planned GPI, but there was insufficient SOE for the group without planned GPI. For the individual outcomes of all-cause mortality at 30 days and after 6 months, there was insufficient evidence with or without planned GPI use. For nonfatal MI and revascularization, there was insufficient SOE for the group without planned GPI use. There was no difference in nonfatal MI in patients treated with bivalirudin versus heparin-based strategy at 30 days in the planned GPI group; however, the incidence of nonfatal MI at 6 months in this group was significantly higher in bivalirudin-treated patients when compared with patients treated with heparin-based strategy with planned GPI. For revascularization in the planned GPI group, at 30 days there were higher rates of revascularization in heparin-treated patients (favoring bivalirudin), but revascularization after 6 months was statistically significantly higher in bivalirudin-treated patients when compared with patients treated with heparin-based strategy. For bleeding outcomes, the lower incidence in major and minor bleeding at 30 days was statistically significant favoring bivalirudin when compared with heparin-based strategy with or without GPI use. There was insufficient evidence for stent thrombosis at 30 days with or without GPI use.

Subgroups analyzed included age, sex, diabetes mellitus, chronic kidney disease, serum biomarker positivity, TIMI risk score, weight, and the performance of PCI or CABG after randomization. A majority of the subgroup analyses of the primary composite outcome showed no difference between bivalirudin and a heparin-based strategy, or a statistically nonsignificant reduction that favored bivalirudin. Detailed SOE ratings are shown in Tables 8 and 9. Odds ratios less than 1 favor bivalirudin-treated patients; odds ratios greater than 1 favor a heparin-based strategy.

Table 8 Detailed strength of evidence for UA/NSTEMI patients treated with bivalirudin versus heparin-based strategy without planned glycoprotein inhibitor use

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, Revascularization, or Major Bleeding at 30 Days | | | | | Insufficient SOE
1 (4571) | RCT/Good quality | NA | Direct | Imprecise | Bivalirudin 8.4% vs. heparin 8.7%
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 30 Days | | | | | Insufficient SOE
2 (5420) | 2 RCTs/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | 1 study found no difference, OR 1.19 (0.92 to 1.54); 1 study found statistically significant lowering in the bivalirudin group, OR 0.42 (0.21 to 0.84)
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 1 Year | | | | | Insufficient SOE
2 (5420) | 2 RCTs/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | 1 study found no difference, OR 0.97 (0.83 to 1.13); 1 study found statistically significant lowering in the bivalirudin group, OR 0.58 (0.37 to 0.92)
All-Cause Mortality at 30 Days | | | | | Insufficient SOE
3 (5822) | 3 RCTs/2 good quality, 1 fair | Inconsistent | Direct | Imprecise | OR 0.46 (0.12 to 1.81)
All-cause Mortality After 6 Months | | | | | Insufficient SOE
2 (5420) | 2 RCTs/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | Disparate results in 2 RCTs: bivalirudin 1.2% vs. heparin 2.4%; bivalirudin 1.9% vs. heparin 1.7%
Nonfatal MI at 30 days | | | | | Insufficient SOE
3 (5822) | 3 RCTs/2 good quality, 1 fair | Inconsistent | Direct | Imprecise | OR 1.00 (0.64 to 1.55)
Nonfatal MI After 6 Months | | | | | Insufficient SOE
2 (5420) | 2 RCTs/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | Disparate results in 2 RCTs; bivalirudin 3.3% vs. heparin 5.7%; bivalirudin 6.0% vs. heparin 5.3%
Revascularization at 30 Days | | | | | Insufficient SOE
3 (5822) | 3 RCTs/2 good quality, 1 fair | Inconsistent | Direct | Imprecise | OR 1.10 (0.60 to 2.04)
Revascularization After 6 Months | | | | | Insufficient SOE
2 (5420) | 2 RCTs/1 good quality, 1 fair | Consistent | Direct | Imprecise | Lower rate of revascularization in bivalirudin-treated patients (4.1% and 11.2%) vs. heparin-treated (5.7% and 12.5%)
Major Bleeding at 30 Days | | | | | High SOE
3 (5822) | 3 RCTs/2 good quality, 1 fair | Consistent | Direct | Precise | OR 0.63 (0.47 to 0.85) Favors bivalirudin
Minor Bleeding at 30 Days | | | | | Low SOE
3 (5822) | 3 RCTs/2 good quality, 1 fair | Inconsistent | Direct | Imprecise | OR 0.64 (0.43 to 0.95) Favors bivalirudin
Stent Thrombosis at 30 Days | | | | | Insufficient SOE
3 (5822) | 3 RCTs/2 good quality, 1 fair | Consistent | Direct | Imprecise | OR 1.42 (0.64 to 3.15)

CI = confidence interval; GPI = glycoprotein inhibitor; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

Table 9 Detailed strength of evidence for UA/NSTEMI patients treated with bivalirudin versus heparin-based strategy with planned glycoprotein inhibitor use

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, Revascularization, or Major Bleeding at 30 Days | | | | | High SOE
3 (12,287) | 3 RCTs/All good quality | Consistent | Direct | Precise | OR 0.87 (0.78 to 0.97) Favors bivalirudin
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 30 Days | | | | | High SOE
3 (12,287) | 3 RCTs/All good quality | Consistent | Direct | Precise | OR 1.07 (0.95 to 1.22) No difference
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 1 Year | | | | | Low SOE
2 (10,566) | 2 RCTs/Both good quality | Consistent | Direct | Imprecise | Both RCTs found no difference between treatments, OR 1.11 (0.74 to 1.63); and OR 1.08 (0.92 to 1.25) No difference
All-Cause Mortality at 30 Days | | | | | Insufficient SOE
3 (12,287) | 3 RCTs/All good quality | Consistent | Direct | Imprecise | OR 1.21 (0.89 to 1.65)
All-Cause Mortality After 6 Months | | | | | Insufficient SOE
2 (10,566) | 2 RCTs/Both good quality | Consistent | Direct | Imprecise | Similar event rate in 1 RCT (3.8% bivalirudin, 3.8% GPI), slightly lower event rate in other RCT (0.9% bivalirudin,1.3% GPI, p=0.46)
Nonfatal MI at 30 Days | | | | | Moderate SOE
3 (12,287) | 3 RCTs/All good quality | Consistent | Direct | Precise | OR 1.06 (0.92 to 1.23) No difference
Nonfatal MI After 6 Months | | | | | Moderate SOE
2 (10,566) | 2 RCTs/Both good quality | Consistent | Direct | Precise | Higher event rate in bivalirudin (7.8% and 8.1%) vs. heparin (6.9% and 7.6%) Favors heparin
Revascularization at 30 Days | | | | | Low SOE
3 (12,287) | 3 RCTs/All good quality | Consistent | Direct | Imprecise | OR 1.11 (0.86 to 1.42) Favors bivalirudin
Revascularization After 6 Months | | | | | Low SOE
2 (10,566) | 2 RCTs/Both good quality | Consistent | Direct | Imprecise | Higher event rate with bivalirudin (8.7% and 11.7%) vs. heparin (8.4% in both studies) Favors heparin
Major Bleeding at 30 Days | | | | | High SOE
3 (12,287) | 3 RCTs/All good quality | Consistent | Direct | Precise | OR 0.52 (0.43 to 0.63) Favors bivalirudin
Minor Bleeding at 30 Days | | | | | High SOE
3 (12,287) | 3 RCTs/All good quality | Consistent | Direct | Precise | OR 0.49 (0.42 to 0.59) Favors bivalirudin
Stent thrombosis at 30 Days | | | | | Insufficient SOE
2 (10,936) | 2 RCTs/Both good quality | Consistent | Direct | Imprecise | Similar event rates between treatment arms in both studies (bivalirudin 0.7% to 1.0%; heparin 0.6% to 0.8%)

CI = confidence interval; GPI = glycoprotein inhibitor; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

#### 5 Enoxaparin Versus Unfractionated Heparin Versus Fondaparinux (Percutaneous Coronary Intervention Cohort) (KQ 1b)

Thirteen studies (10 RCTs, 3 observational) compared the use of enoxaparin, UFH, and fondaparinux in 41,201 UA/NSTEMI patients undergoing an invasive strategy.65-74,102-104 Three RCTs compared enoxaparin with UFH prior to PCI and included a total of 14,760 patients.65-67 One RCT (20,078 patients) compared enoxaparin with fondaparinux,68 and one RCT (350 patients) compared fondaparinux with UFH.69

Eight studies contained important comparative effectiveness results of anticoagulant treatment in UA/NSTEMI patients even though they were not included in the meta-analysis for this comparison as their populations, comparisons, or outcomes of interest were too heterogeneous. However, because these studies were designed to answer the question of interest, they met our inclusion criteria, and we included them in our listing of studies and explored their findings qualitatively. Findings were as follows:

- Three RCTs compared enoxaparin with UFH at the time of PCI;70-72 however, the study populations had a low percentage of UA/NSTEMI patients, and it was unclear whether these patients underwent an early invasive approach. These three studies were therefore not included in the quantitative analysis. The Bertel study70 showed lower major cardiovascular events and bleeding events in ACS patients who received enoxaparin, but was stopped prematurely due to slow patient enrollment and a lower than expected event rate. The Chen study71 showed no differences in bleeding or ischemic event rates between enoxaparin and UFH, but 29 percent of the study population underwent PCI for UA/NSTEMI. The Bhatt study72 showed no difference in major cardiovascular events at 48 hours and 30 days, plus similar rates of bleeding and vascular site complications in both treatment groups.
- One RCT compared the use of enoxaparin with UFH in UA/NSTEMI patients; however, in those patients that underwent coronary angiography and PCI, open-label UFH was used instead of the study drug, and so this study was not included in our quantitative analysis.73 This study demonstrated that enoxaparin reduced the composite of death and serious cardiac ischemic events at 43 days compared with UFH (OR 0.85; 95% CI 0.72 to 1.00; p=0.048).
- One additional RCT compared the use of different doses of UFH at the time of PCI in patients who underwent an early invasive strategy and were initially treated with fondaparinux; as a result, we could not include it in our quantitative analysis.74 This study demonstrated that low-dose UFH did not reduce major peri-PCI bleeding or vascular site complications compared with standard-dose UFH.
- Multiple observational studies were screened and abstracted. With the exception of three studies, most were excluded due to lack of clarity about an early invasive management strategy or heterogeneity in the study population. Of the three included studies, one102 evaluated the use of enoxaparin and UFH in an unselected PCI population at the time of PCI, where the use of GPI varied from 44 to 96 percent. In this study, there was no difference in outcomes between patients treated with UFH and enoxaparin. The remaining two observational studies103,104 evaluated outcomes and comparisons of interest with greater detail and clarity and are discussed below.

Of the five analyzed RCTs, four were rated good quality,65-68 and one was rated fair.69 The two observational studies103,104 were both rated fair quality. Sample sizes for included individual studies ranged from 350 to 20,078 patients. Study duration ranged from 48 hours to 30 days, with three RCTs reporting 30 day outcomes and both observational studies reporting in hospital outcomes only.

The mean age of study participants ranged from 61 to 68 years of age. The proportion of female patients ranged from 23 to 38 percent. Two studies (29%) reported the racial and ethnic demographics of study participants. All five RCTs and both observational studies were international, multi-center studies, including sites in the United States and Canada. All five RCTs and the two observational studies were industry-sponsored.

The majority of these studies were performed prior to the time when an early invasive strategy was widely implemented. Most of the RCTs in this comparison allowed treatment by early invasive or initial conservative strategies, and subgroup analyses were reported in these studies. In the RCTs that reported subgroup analyses of patients treated with an early invasive strategy, only the patients in the subgroup undergoing early invasive treatment were used for analytic purposes,66,68 and this limited the number of outcome measures that were reported (specifically composite ischemic endpoints and bleeding endpoints). No individual ischemic endpoints were reported for the subgroup of invasively treated patients; therefore, only descriptions of composite outcome measures and major bleeding were included in this report. These results are also reported in Table G-5 in Appendix G.

##### Effect on Composite Ischemic Endpoints Prior to 7 Days and at 30 Days

Three good-quality RCTs65,67,68 (two studies evaluating enoxaparin versus UFH, one study evaluating enoxaparin versus fondaparinux) reported a composite ischemic endpoint at 30 days. One good-quality RCT66 comparing enoxaparin with UFH reported a composite endpoint at 7 days, and one fair-quality RCT69 comparing fondaparinux with UFH reported a composite endpoint at 48 hours. Of the three studies reporting a 30-day outcome, each reported separate composite outcome measures that prohibited incorporation of these studies into a meta-analysis.

In three good-quality RCTs, the use of enoxaparin was associated with a similar incidence of composite ischemic endpoints prior to 30 days when compared with UFH: all-cause mortality, nonfatal MI, or recurrent ischemia at 7 days (enoxaparin 8.8% vs. UFH 8.5% (HR 0.89; 95% CI, 0.75 to 1.05);66 all-cause mortality or nonfatal MI at 30 days (enoxaparin 14.0% vs. UFH 14.5%);65 and all-cause mortality, nonfatal MI, or revascularization at 30 days (enoxaparin 14.0% vs. UFH 16.1%).67 In the two observational studies (both fair quality) of enoxaparin versus unfractionated heparin, Brieger et al.104 reported a lower incidence of death during hospitalization in patients treated with enoxaparin when compared with unfractionated heparin. Singh et al.103 reported similar composite ischemic endpoints in enoxaparin-treated and unfractionated heparin-treated patients (7.4% in each group).

There were also similar rates of the composite outcome (all-cause mortality, nonfatal MI, or revascularization) at 30 days in patients treated with enoxaparin (7.4%) when compared with fondaparinux (7.4%).68 In the single, small RCT (fair quality) of fondaparinux versus UFH, there was a statistically nonsignificant reduction in the composite outcome of all-cause mortality, nonfatal MI, revascularization, or thrombotic GPI bailout in patients treated with fondaparinux (4.2%) when compared with UFH (6.0%) at 48 hours.69

Overall, the SOE was rated low for similar incidence in the composite ischemic endpoint at 7 days between enoxaparin and UFH based on one RCT (A to Z study),66 which was adequately powered for a noninferiority hypothesis. In the A to Z study, enoxaparin was to be considered noninferior to UFH if the upper one-sided 95% confidence boundary for the enoxaparin effect relative to UFH was less than 1.14. The SOE was rated insufficient between fondaparinux and UFH based on a fair-quality study assessing the composite outcome at 48 hours. The SOE was rated low for similar incidence of the composite ischemic endpoint at 30 days for enoxaparin versus UFH (based on two good-quality RCTs) and for enoxaparin versus fondaparinux (based on one good-quality RCT), all with consistent results of a direct outcome.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal MI, or Revascularization at 6 Months

One RCT68 (good quality) of 20,078 patients in this comparison group evaluated the effect of treatment on the composite endpoint of all-cause mortality, nonfatal MI, or revascularization at 6 months. In this study, there was a similar incidence of composite ischemic outcomes in patients treated with enoxaparin (10.2%) and fondaparinux (10.1%). The SOE was rated low for similar composite ischemic outcomes at 6 months between treatments based on a single, very large RCT that was adequately powered for a noninferiority hypothesis (i.e., noninferiority margin or delta of 1.185).

##### Effect on Major Bleeding at 30 Days

Two RCTs (both good quality, 30,105 patients)65,68 and two observational studies (both fair quality, 29,017 patients)103,104 evaluated the effect of treatment with enoxaparin, UFH, or fondaparinux on major bleeding. In one RCT, there was a significantly higher incidence of major bleeding in patients treated with enoxaparin when compared with fondaparinux at 30 days and at 6 months (5.0% vs. 3.1% at 30 days, 5.8% vs. 4.3% at 6 months, both p<0.001).68 In the other RCT, there was a significantly higher incidence of in-hospital major bleeding in patients treated with enoxaparin (9.1%) when compared with UFH (7.6%), p=0.008.^65^

In the observational studies, there was a statistically significant difference in major bleeding favoring enoxaparin (1.8%) versus UFH (2.7%), p<0.001,^104^ but no statistically significant difference in non–CABG-related transfusions (enoxaparin 6.7%; UFH 7.0%) between treatments.103 The SOE for major bleeding at 30 days was rated moderate for the RCT of enoxaparin versus UFH and for the RCT of enoxaparin versus fondaparinux. The SOE from the two fair-quality observational studies of enoxaparin versus UFH was rated low due to imprecise results and high risk of bias.

##### Findings by Subgroup (KQ 1c)

Three good-quality RCTs65,66,68 (two studies evaluating enoxaparin vs. UFH, one study evaluating enoxaparin vs. fondaparinux) reported variations in treatment effectiveness by subgroup. Subgroups analyzed included age, sex, diabetes mellitus, chronic kidney disease, presence of smoking, prior coronary revascularization, serum biomarker positivity, TIMI risk score, and geographic location. Prespecified subgroup analysis of clopidogrel pretreatment is covered in a separate section of this report. Other patient and demographic characteristics were not clearly described. Table H-1 in Appendix H presents the results data for these subgroups.

###### Age

In 2540 patients over 75 years of age in SYNERGY, there was no significant difference in the incidence of death or MI at 30 days between unfractionated heparin and enoxaparin. There was a higher and statistically significant incidence in TIMI major bleeding in elderly patients treated with enoxaparin when compared with unfractionated heparin.65

In 1599 patients over 65 years of age in A to Z, there was no significant difference in the incidence of death, nonfatal MI, or refractory ischemia at 7 days between enoxaparin (11.3%) and unfractionated heparin (12.4%).66

In 12261 patients over 65 years of age in OASIS-5, there was no significant difference in the incidence of death, nonfatal MI, or refractory ischemia between fondaparinux (6.6%) and enoxaparin (6.8%). There was a lower incidence of major bleeding in patients over 65 years of age treated with fondaparinux (2.7%) versus enoxaparin (5.5%) which was statistically significant.68

###### Sex

In 6595 male patients in SYNERGY, there was a statistically nonsignificant reduction in the incidence of death or MI at 30 days favoring enoxaparin (14.2%) when compared with unfractionated heparin (15.4%). In 3379 female patients, there was a statistically nonsignificant reduction in the incidence of death or MI at 30 days favoring unfractionated heparin (12.9%) when compared with enoxaparin (13.5%).65

In 2826 male patients in A to Z, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring enoxaparin (8.3%) and unfractionated heparin (9.5%). In 1141 female patients in A to Z, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring enoxaparin (8.6%) and unfractionated heparin (9.3%).66

In 12379 male patients in OASIS-5, there was no significant difference in the incidence of death, nonfatal MI, or refractory ischemia between fondaparinux (6.0%) and enoxaparin (5.8%). In 7699 female patients, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia favoring enoxaparin (5.3%) when compared with fondaparinux (5.7%). There was a lower incidence of major bleeding in men (fondaparinux 2.0%; enoxaparin 3.3%) and women (fondaparinux 2.5%; enoxaparin 5.5%) which was statistically significant.68

###### Diabetes Mellitus

In 2924 patients with diabetes mellitus in SYNERGY, there was no significant difference in the incidence of death or MI at 30 days between unfractionated heparin (15.7%) and enoxaparin (15.6%).65 In 751 patients with diabetes mellitus in A to Z, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring enoxaparin (8.4%) when compared with unfractionated heparin (10.7%).66 There was no subgroup analysis presented in patients with diabetes mellitus from OASIS-5.^68^

###### Chronic Kidney Disease

No subgroup analysis data on kidney function or chronic kidney disease was presented in SYNERGY or A to Z.65,66 In the OASIS-5 trial, an exclusion criterion for the trial was a serum creatinine greater than 3 mg/dL and the authors reported a subgroup analysis of serum creatinine less than or above the median for the population. In 11,124 patients with a serum creatinine at or above the median in this trial, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 9 days favoring fondaparinux (5.9%) versus enoxaparin (6.4%) and a statistically significant reduction in the incidence of major bleed at 9 days favoring fondaparinux (2.4%) versus enoxaparin (4.7%).68

###### Presence of Smoking

In 1403 patients from the SYNERGY trial who were current smokers at the time of randomization, there was a statistically significant reduction in the incidence of composite ischemic events (death or MI) at 30 days favoring enoxaparin (12.3%) when compared with unfractionated heparin (15.9%), p=0.009. Composite ischemic event rates were similar and nonsignificant in the nonsmokers and prior smokers.65

###### Prior Coronary Revascularization

In 2008 patients with prior PCI in SYNERGY, there was no significant difference in the incidence of death or MI at 30 days between unfractionated heparin (14.1%) and enoxaparin (13.9%). In 1658 patients with prior CABG, there was a lower incidence of death or MI at 30 days favoring enoxaparin (13.2%) when compared with unfractionated heparin (15.8%) which was not statistically significant.65 There was no subgroup analysis of prior coronary revascularization (including PCI or CABG) in A to Z or OASIS-5.^66,68^

###### Serum Biomarker Positivity

In 8174 patients with elevated cardiac biomarkers in SYNERGY, there was a statistically nonsignificant reduction in the incidence of death or MI at 30 days favoring enoxaparin (14.2%) when compared with unfractionated heparin (14.9%).65 In 2127 patients with an elevated troponin in A to Z, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring enoxaparin (8.3%) when compared with unfractionated heparin (9.5%).66 There was no subgroup analysis presented in patients with abnormal serum cardiac biomarkers from OASIS-5.^68^

###### TIMI Risk Score

No subgroup analysis data on TIMI risk score was presented in SYNERGY.65 In 1598 patients with a low TIMI risk score in A to Z, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring unfractionated heparin (5.7%) when compared with enoxaparin (6.4%). In 1833 patients with an intermediate TIMI risk score, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring enoxaparin (8.1%) when compared with unfractionated heparin (10.2%). In 536 patients with a high TIMI risk score, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring enoxaparin (15.1%) when compared with unfractionated heparin (17.9%).66 There was no subgroup analysis of TIMI risk score from OASIS-5.^68^

###### Geographic Region

In 481 patients enrolled from North America in SYNERGY, there was a statistically nonsignificant reduction in the incidence of death or MI at 30 days favoring enoxaparin (27.3%) when compared with unfractionated heparin (29.7%).65 In 798 patients enrolled from the United States in A to Z, there was a statistically nonsignificant reduction in the incidence of death, nonfatal MI, or refractory ischemia at 7 days favoring enoxaparin (6.7%) when compared with unfractionated heparin (7.7%).66 There was no subgroup analysis of geographic region presented in OASIS-5.^68^

##### Summary of Results for Enoxaparin Versus Unfractionated Heparin Versus Fondaparinux (PCI Cohort)

In our analysis of studies comparing enoxaparin, UFH, or fondaparinux, we used subgroups of UA/NSTEMI patients who underwent early invasive treatment. This limited the available outcomes to a composite ischemic outcome prior to 7 days, at 30 days, and after 6 months, and the incidence of major bleeding at 30 days. There were no significant differences in the incidence of the composite ischemic endpoints prior to 7 days between enoxaparin and heparin, or at 30 days between enoxaparin, UFH, or fondaparinux. At 6 months, there was no difference in the composite ischemic endpoint between enoxaparin and fondaparinux. For bleeding outcomes, there was a lower and statistically significant incidence in major bleeding at 30 days favoring fondaparinux when compared with enoxaparin; the rates of major bleeding in the enoxaparin versus UFH studies were inconsistent.

Subgroup analyses from three studies included age, sex, diabetes mellitus, chronic kidney disease, presence of smoking, prior coronary revascularization, serum biomarker positivity, TIMI risk score, and geographic location. Most showed nonsignificant reductions in composite outcomes in the enoxaparin and fondaparinux groups; there was a significant reduction in major bleeding in older persons treated with either enoxaparin or fondaparinux compared with UFH which are consistent with the total population findings. Detailed SOE ratings are shown in Table 10.

Table 10 Detailed strength of evidence for UA/NSTEMI patients treated with enoxaparin versus unfractionated heparin versus fondaparinux (percutaneous coronary intervention cohort)

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite Ischemic Endpoints Prior to 7 Days
Enoxaparin vs. UFH 1 (3987) | RCT/Good quality | NA | Direct | Precise | Low SOE HR 0.89 (0.75 to 1.05) No difference (adequately powered for noninferiority hypothesis)
Fondaparinux vs. UFH 1 (350) | RCT/Fair quality | NA | Direct | Imprecise | Insufficient SOE 4.2% vs. 6.0%
Composite Ischemic Endpoints at 30 Days
Enoxaparin vs. UFH 2 (10,773) | 2 RCTs/Both good quality | Consistent | Direct | Precise | Low SOE 14% vs. 14.5% and 14% vs. 16.1% No difference
Enoxaparin vs. fondaparinux 1 (20,078) | RCT/Good quality | NA | Direct | Precise | Low SOE 7.4% vs. 7.4% No difference
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 6 Months
Enoxaparin vs. fondaparinux 1 (20,078) | RCT/Good quality | NA | Direct | Precise | Low SOE Enoxaparin: 10.2% Fondaparinux: 10.1% No difference (adequately powered for a noninferiority hypothesis)
Major Bleeding at 30 Days
Enoxaparin vs. UFH 1 (10,027) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Lower events with UFH (7.6%) vs. enoxaparin (9.1%) Favors UFH
Enoxaparin vs. UFH 2 (29,017) | 2 observational/Both fair quality | Consistent | Direct | Imprecise | Low SOE Lower events with enoxaparin (2.7% UFH vs. 1.8% enoxaparin; 7% UFH vs. 6.7% enoxaparin) Favors enoxaparin
Enoxaparin vs. fondaparinux 1 (20,078) | RCT/Good quality | NA | Direct | Precise | Moderate SOE Lower events with fondaparinux (3.1%) vs. enoxaparin (5.0%); p<0.001 Favors fondaparinux

CI = confidence interval; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction; UFH = unfractionated heparin

#### 6 Upstream or Deferred Clopidogrel for Patients Undergoing Percutaneous Coronary Intervention for UA/NSTEMI in Studies With a Defined Anticoagulant or Intravenous Antiplatelet Strategy

A total of four studies—two RCTs75,76 (both fair quality; 735 patients) and two observational studies105,106 (both fair quality; 5590 patients)—directly compared a pretreatment (upstream) clopidogrel strategy with a deferred clopidogrel treatment strategy in a patient population receiving PCI (Tables G-6, G-7, and G-8 in Appendix G). However, the study populations were a mixture of non-ACS and ACS patients, and the use of anticoagulant (bivalirudin or UFH) and intravenous antiplatelet (upstream or deferred GPI) was not defined. In one RCT,75 the incidence of composite ischemic endpoints at 30 days was similar between strategies in all patients undergoing PCI (pretreatment 10.3% vs. in-laboratory treatment 8.8%, p=0.72) and in the subgroup of ACS patients undergoing PCI (pretreatment 10% vs. in-lab treatment 16%, p=0.36). In the other RCT,76 the incidence of composite ischemic endpoints was similar between the group of patients who were treated with clopidogrel at the time of PCI (12.6%) and those who underwent clopidogrel pretreatment followed by a delay in PCI (15.6%). In one observational study,105 patients with stable angina or UA/NSTEMI who were pretreated with clopidogrel had fewer composite ischemic endpoints when compared with patients who were not pretreated with clopidogrel (deferred strategy). In the other observational study106 of an unselected PCI cohort, patients who were pretreated with clopidogrel 6 to 24 hours prior to PCI had a 42 percent reduction in the occurrence of all-cause mortality, nonfatal MI, or revascularization at 30 days compared with patients who were not pretreated with clopidogrel.

While these data suggest that clopidogrel pretreatment is associated with improved outcomes, there are limited studies in general and in UA/NSTEMI patients. We therefore designed two types of analyses of available RCTs to determine the effect of two randomized treatment comparisons; namely, bivalirudin versus heparin-based strategy and upstream versus deferred GPI use, both in patients pretreated with clopidogrel (upstream) and patients treated with clopidogrel at the time of PCI (deferred). Therefore, the remainder of this analysis presents results for the following approaches:

- Clopidogrel upstream strategy (10 RCTs):
  a. Studies of patients pretreated with clopidogrel prior to PCI with random assignment to bivalirudin versus a heparin-based strategy (KQ 1b)
  b. Studies of patients pretreated with clopidogrel prior to PCI with random assignment to upstream versus deferred GPI use (KQ 1a)
- Clopidogrel deferred strategy (6 RCTs):
  a. Studies of patients treated with clopidogrel at the time of PCI with random assignment to bivalirudin versus heparin-based strategy (KQ 1b)
  b. Studies of patients treated with clopidogrel at the time of PCI with random assignment to upstream versus deferred GPI use (KQ 1a)

##### Clopidogrel Upstream Strategy

Ten RCTs compared different antithrombotic strategies in UA/NSTEMI patients pretreated with clopidogrel while undergoing an invasive strategy.23,36,38,39,43,44,58,59,62,63 Four of these studies involved patients who were pretreated with clopidogrel and underwent random assignment to bivalirudin versus a heparin-based strategy.58,59,62,63 Six of these studies involved patients who were pretreated with clopidogrel and underwent random assignment to upstream versus deferred use of GPI.23,36,38,39,43,44 While the decision to treat the patient with clopidogrel was not randomly assigned, the included studies may offer insight into the effect of these medications when used in combination for the treatment of UA/NSTEMI. To reduce potential treatment interactions, we excluded multiple studies of provisional (i.e., without planned) GPI use and other treatment options (i.e., enoxaparin, UFH).

Of the ten RCTs included in the meta-analysis, six studies (60%) were rated good quality, three (30%) fair, and one (10%) poor. Sample sizes for individual studies ranged from 100 to 13,819 patients. All studies reported 30 day outcomes.

The mean age of study participants ranged from 61 to 70 years of age. The proportion of female patients ranged from 23 to 54 percent. One study (10%) reported the racial and ethnic demographics of study participants. Five studies (50%) were conducted within the United States or Canada, with the rest international. Funding source was reported in seven studies (70%) as an industry source.

###### Bivalirudin Versus Heparin-Based Strategy in Patients Pretreated With Clopidogrel (KQ 1b)

###### Effect on Composite Ischemic Endpoints at 30 Days

Two good-quality RCTs62,63 including 7104 UA/NSTEMI patients treated with clopidogrel prior to PCI reported the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days. The study by Rajagopal had fewer composite ischemic events in the heparin-treated group (OR 1.11; 95% CI, 0.75 to 1.64), as did the study by Stone (OR 1.25; 95% CI, 0.99 to 1.56), but neither were statistically significant. The SOE was rated low for no difference based on two good-quality RCTs with consistent results of direct outcome and a wide confidence interval that crossed 1.

###### Effect on Composite Ischemic Endpoints at 1 Year

We identified one good-quality RCT58 of 4570 patients that reported the effect of treatment on all-cause mortality, nonfatal MI, or revascularization at 1 year. This study showed that in patients who were pretreated with clopidogrel, those patients randomly assigned to bivalirudin (21.5%) had a statistically nonsignificant difference in the incidence of composite ischemic endpoints when compared with a heparin-based strategy (20.1%). The SOE was rated insufficient based on subgroup findings from only one moderate-sized good-quality RCT that was underpowered to detect a difference for this subgroup.

###### Effect on All-Cause Mortality at 1 Year

One good-quality RCT62 of 5126 patients reported the effect of bivalirudin versus heparin on all-cause mortality at 1 year in patients pretreated with clopidogrel. Patients treated with bivalirudin had a similar incidence of all-cause mortality compared with those treated with a heparin-based strategy (16.0% vs. 16.3%, p=NS). The SOE was rated insufficient based on subgroup findings from only one moderate-sized good-quality RCT that was underpowered to detect a difference for this subgroup.

###### Effect on Major Bleeding at 30 Days

A random-effects meta-analysis of three RCTs58,59,63 (two good quality, one fair) including 6322 UA/NSTEMI patients pretreated with clopidogrel prior to PCI reporting major bleeding at 30 days found that the odds ratio was 0.64 (95% CI, 0.49 to 0.85) favoring bivalirudin compared with a heparin-based strategy (Figure 26). There was no evidence of heterogeneity, with a Q-value of 0.17 for 2 degrees of freedom, p=0.92. The SOE was rated moderate based on two good- and one fair-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 26 Meta-analysis of patients pretreated with clopidogrel randomly assigned to bivalirudin versus heparin-based strategy on major bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 0.64 (95% CI, 0.49 to 0.85), favoring bivalirudin.

###### Upstream Versus Deferred GPI Use in Patients Pretreated With Clopidogrel (KQ 1a)

###### Effect on Composite Ischemic Endpoints Prior to 30 Days

Only one good-quality RCT43 including 6895 UA/NSTEMI patients reported a composite endpoint of all-cause mortality, nonfatal MI, revascularization, or thrombotic GPI bailout at 96 hours in patients pretreated with clopidogrel prior to PCI who were randomly assigned to upstream versus deferred GPI use. This study showed that there was a small, statistically nonsignificant difference in composite endpoint in those patients treated with upstream GPI (8.7%) versus deferred GPI (9.4%). The SOE for this composite endpoint was rated insufficient based on only one good-quality RCT.

One poor-quality RCT39 that included 300 UA/NSTEMI patients reported a composite endpoint of all-cause mortality, nonfatal MI, or rehospitalization at 30 days in patients pretreated with clopidogrel prior to PCI who were randomly assigned to upstream versus deferred GPI use. In this study, patients treated with upstream GPI (9.0%) had a statistically nonsignificant lower incidence of the composite endpoint when compared with patients treated with deferred GPI (10.0%). The SOE for this composite endpoint was rated insufficient based on only one small, poor-quality RCT.

Two randomized studies (one good quality, one fair)36,38 that included 638 UA/NSTEMI patients reported a composite endpoint of all-cause mortality, nonfatal MI, or ischemia/revascularization at 30 days in patients pretreated with clopidogrel prior to PCI who were randomly assigned to upstream versus deferred GPI use. Patients treated with upstream GPI had a reduction in the incidence of the composite outcome when compared with deferred GPI (Durand, fair quality, 16% vs. 17%; Bhattacharya, good quality, 16% vs. 26%; combined average 15.7% vs. 20.3%). This effect was mainly driven by refractory ischemia in the good-quality study.38 The SOE was rated low based on one good-and one fair-quality RCT with consistent and imprecise results of a direct outcome.

###### Effect on All-Cause Mortality at 30 Days

A random-effects meta-analysis of five RCTs36,38,39,43,44 (two good quality, two fair, one poor) including 8168 UA/NSTEMI patients reporting all-cause mortality at 30 days in patients pretreated with clopidogrel prior to PCI randomly assigned to upstream versus deferred GPI found that the odds ratio was 0.56 (95% CI, 0.30 to 1.05) demonstrating a benefit of upstream GPI (Figure 27). There was no evidence of heterogeneity, with a Q-value of 6.76 for 4 degrees of freedom, p=0.15. The SOE was rated low based on two good-, two fair-, and one poor-quality RCTs with consistent results of a direct outcome and a wide confidence interval that crosses 1.

Figure 27 Meta-analysis of patients pretreated with clopidogrel randomly assigned to upstream versus deferred glycoprotein inhibitor use on all-cause mortality at 30 days

CI = confidence interval; GPI = glycoprotein inhibitor

This figure displays a forest plot of a random-effects meta-analysis of five studies that shows an odds ratio of 0.56 (95% CI, 0.30 to 1.05), demonstrating a benefit of upstream glycoprotein inhibitor.

###### Effect on Major Bleeding at 30 Days

A random-effects meta-analysis of five RCTs23,36,39,43,44 (two good quality, two fair, one poor) including 7416 UA/NSTEMI patients reporting major bleeding at 30 days in patients pretreated with clopidogrel prior to PCI randomly assigned to upstream versus deferred GPI found that the odds ratio was 1.49 (95% CI, 1.10 to 2.01), favoring deferred GPI, p=0.01 (Figure 28). There was no evidence of heterogeneity, with a Q-value of 0.44 for 4 degrees of freedom, p=0.98. The SOE was rated moderate based on consistent results of a direct outcome and a wide confidence interval.

Figure 28 Meta-analysis of patients pretreated with clopidogrel randomly assigned to upstream versus deferred glycoprotein inhibitor use on major bleeding at 30 days

CI = confidence interval; GPI = glycoprotein inhibitor

This figure displays a forest plot of a random-effects meta-analysis of five studies that shows an odds ratio of 1.49 (95% CI, 1.10 to 2.01), favoring deferred glycoprotein inhibitor.

##### Clopidogrel Deferred Strategy

Six RCTs (three good quality, two fair, one poor) compared different antithrombotic strategies in 14,429 UA/NSTEMI patients treated with clopidogrel at the time of PCI while undergoing an invasive strategy.41-43,57,61,110 Two of these studies (one good quality, one fair) involved patients who were treated with clopidogrel at the time of PCI (not pretreated with clopidogrel) and underwent random assignment to bivalirudin versus a heparin-based strategy.57,61 Four of these studies (two good quality, one fair, one poor) involved patients who were treated with clopidogrel at the time of PCI (not pretreated with clopidogrel) and underwent random assignment to upstream versus deferred use of GPI.41-43,110.

Of the six RCTs, three studies (50%) were rated good quality, two (33%) fair, and one (16%) poor. Sample sizes for individual studies ranged from 160 to 9378 patients. All studies reported 30 day outcomes.

The mean age of study participants ranged from 60 to 69 years of age. The proportion of female patients ranged from 23 to 32 percent. None of the studies reported the racial and ethnic demographics of study participants. Three studies (50%) were conducted within the United States or Canada, with the rest international. Funding source was reported in four studies (66%), with all four of the studies being funded by industry source.

###### Bivalirudin Versus Heparin-Based Strategy in Patients Treated With Clopidogrel at the Time of PCI (KQ 1b)

###### Effect on All-Cause Mortality, Nonfatal Myocardial Infarction, or Revascularization at 30 Days

Two RCTs57,61 (one good quality, one fair) including 2571 UA/NSTEMI patients treated with clopidogrel at the time of PCI reported the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days. The Parodi study (fair) showed a significant reduction in composite events in the group that received bivalirudin (OR 0.42; 95% CI, 0.21 to 0.84, p=0.02). The Kastrati study (good) showed no statistical difference between the groups (OR 1.05; 95% CI, 0.80 to 1.40). The SOE was rated insufficient based on one good- and one fair-quality RCT with inconsistent results of a direct outcome and a wide confidence interval.

###### Effect on Major Bleeding at 30 Days

Two RCTs57,61 (one good quality, one fair) including 2571 UA/NSTEMI patients treated with clopidogrel at the time of PCI reported major bleeding at 30 days. The Parodi study (fair) showed no statistical difference between the groups (OR 0.32; 95% CI, 0.10 to 1.01) and the Kastrati study (good) showed a statistically significant reduction favoring bivalirudin (OR 0.53; 95% CI, 0.31 to 0.91, p=0.02). The SOE was rated low based on one good- and one fair-quality RCT with consistent results of a direct outcome and a wide confidence interval.

###### Upstream Versus Deferred GPI Use in Patients Treated With Clopidogrel at the Time of PCI (KQ 1a)

###### Effect on All-Cause Mortality, Nonfatal Myocardial Infarction, Revascularization, or Thrombotic GPI Bailout at 96 Hours

Only one RCT (good quality)43 including 2271 UA/NSTEMI patients reported a composite endpoint of all-cause mortality, nonfatal MI, revascularization, thrombotic GPI bailout at 96 hours in patients treated with clopidogrel at the time of PCI randomly assigned to upstream versus deferred GPI use. This study showed that there was a small but not statistically significant difference in composite endpoint in those patients treated with upstream GPI (10.3%) versus deferred GPI (11.2%). The SOE was rated insufficient based on a subgroup analysis from one good-quality RCT.

###### Effect on All-Cause Mortality at 30 Days

A random-effects meta-analysis of four RCTs41-43,110 (two good quality, one fair, one poor) including 11,858 UA/NSTEMI patients reported all-cause mortality at 30 days in patients treated with clopidogrel at the time of PCI randomly assigned to upstream versus deferred GPI found that the odds ratio was 0.97 (95% CI, 0.80 to 1.18) demonstrating no difference (Figure 29). There was no evidence of heterogeneity, with a Q-value of 1.20 for 3 degrees of freedom, p=0.75. The low event rate (one death in upstream GPI group; no deaths in deferred GPI group) in one fair-quality study41 contributed to the inconsistent results. The exclusion of the poor-quality study42 did not impact our findings. The SOE of no difference was rated as low based on two good-, one fair-, and one poor-quality RCTs with inconsistent results of a direct outcome.

Figure 29 Meta-analysis of patients treated with clopidogrel at time of percutaneous coronary intervention randomly assigned to upstream versus deferred glycoprotein inhibitor use on all-cause mortality at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of four studies that shows an odds ratio of 0.97 (95% CI, 0.80 to 1.18), demonstrating no difference.

###### Effect on Major Bleeding at 30 Days

A random-effects meta-analysis of three RCTs42,43,110 (two good quality, one fair) including 11,698 UA/NSTEMI patients reported major bleeding at 30 days in patients treated with clopidogrel at the time of PCI randomly assigned to upstream versus deferred GPI found that the odds ratio was 1.27 (95% CI, 1.08 to 1.50), favoring deferred GPI (Figure 30). There was no evidence of heterogeneity, with a Q-value of 0.79 for 2 degrees of freedom, p=0.68. The SOE was rated high based on two good- and one fair-quality RCTs with consistent results of a direct outcome and a narrow confidence interval.

Figure 30 Meta-analysis of patients treated with clopidogrel at the time of percutaneous coronary intervention randomly assigned to upstream versus deferred glycoprotein inhibitor use on major bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.27 (95% CI, 1.08 to 1.50), favoring deferred glycoprotein inhibitor.

##### Findings by Subgroup (KQ 1c)

Since the findings from this comparison were derived from a subgroup of patients who were pretreated with clopidogrel or treated with clopidogrel prior to PCI, further attempts at subgroup analysis could not be performed.

##### Summary of Results for Upstream or Deferred Clopidogrel Strategy

In randomized comparisons of patients treated with (1) bivalirudin versus heparin-based strategy and (2) upstream versus deferred GPI use, the nonrandomized effectiveness and safety of clopidogrel pretreatment and deferred clopidogrel treatment was assessed. In these analyses, patients pretreated with clopidogrel and randomized to a heparin-based strategy had no differences in composite ischemic outcomes compared with patients randomized to bivalirudin, but the evidence was insufficient. However, the occurrence of major bleeding was significantly lower in bivalirudin-treated patients when compared with heparin-treated patients. There were no significant differences in the occurrence of composite ischemic endpoints at 1 year or all-cause mortality at 1 year between bivalirudin and heparin groups, based on insufficient SOE. Patients pretreated with clopidogrel and randomized to upstream GPI use had a trend toward fewer composite ischemic outcomes at 30 days and fewer deaths at 30 days when compared with patients randomized to deferred GPI use. There was insufficient SOE for the composite outcome at 96 hours, and for the composite of all-cause mortality, nonfatal MI, or rehospitalization at 30 days. The occurrence of major bleeding at 30 days was significantly higher in patients pretreated with clopidogrel who were randomized to upstream GPI when compared with deferred GPI use.

In patients treated with deferred clopidogrel strategy, there were conflicting results for composite ischemic events at 30 days in patients randomized to bivalirudin when compared with heparin-based strategy, therefore the SOE was insufficient. There was low SOE for the effect on major bleeding at 30 days in those patients treated with deferred clopidogrel and randomized to bivalirudin, with one good-quality study showing a reduction in major bleeding favoring bivalirudin. In studies of patients treated with deferred clopidogrel and randomized to upstream GPI, there was insufficient SOE for composite ischemic outcomes at 30 days, and low SOE for no difference in all-cause mortality at 30 days. The occurrence of major bleeding at 30 days was significantly higher in patients treated with deferred clopidogrel who were randomized to upstream GPI when compared with deferred GPI use. Detailed SOE ratings are shown in Tables 11–14. Odds ratios less than 1 favor bivalirudin or upstream GPI; odds ratios greater than 1 favor a heparin-based strategy or deferred GPI use.

Table 11 Detailed strength of evidence for bivalirudin versus heparin-based strategy in patients pretreated with clopidogrel

Number of Studies (Patients) | Domains | | | | Strength of Evidence and Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence and Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 30 Days | | | | | Low SOE
2 (7104) | 2 RCTs/Both good quality | Consistent | Direct | Imprecise | Both studies showed no statistically significant difference in composite event rates ranging from OR 1.11 to 1.25 No difference
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 1 Year | | | | | Insufficient SOE
1 (4570) | RCT/Good quality | NA | Direct | Imprecise | Bivalirudin: 21.5% Heparin: 20.1%
All-Cause Mortality at 1 Year | | | | | Insufficient SOE
1 (5126) | RCT/Good quality | NA | Direct | Imprecise | Bivalirudin: 16.0% Heparin: 16.3%
Major Bleeding at 30 Days | | | | | Moderate SOE
3 (6322) | 3 RCTs/2 good quality, 1 fair | Consistent | Direct | Precise | OR 0.64 (0.49 to 0.85) Favors bivalirudin

CI = confidence interval; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

Table 12 Detailed strength of evidence for upstream versus deferred GPI use in patients pretreated with clopidogrel

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, Revascularization, or Thrombotic GPI Bailout at 96 Hours | | | | | Insufficient SOE
1 (6895) | RCT/Good quality | NA | Direct | Imprecise | Upstream GPI: 8.7% Deferred GPI: 9.4%
Composite of All-Cause Mortality, Nonfatal MI, or Rehospitalization at 30 Days | | | | | Insufficient SOE
1 (300) | RCT/Poor quality | NA | Direct | Imprecise | Upstream GPI: 9% Deferred GPI: 10%
Composite of All-Cause Mortality, Nonfatal MI, or Ischemia/Revascularization at 30 Days | | | | | Low SOE
2 (638) | 2 RCTs/1 good quality, 1 fair | Consistent | Direct | Imprecise | Upstream GPI: 15.7% Deferred GPI: 20.3% Favors upstream GPI
All-Cause Mortality at 30 Days | | | | | Low SOE
5 (8168) | 5 RCTs/2 good quality, 2 fair, 1 poor | Consistent | Direct | Imprecise | OR 0.56 (0.30 to 1.05) favors upstream GPI
Major Bleeding at 30 Days | | | | | Moderate SOE
5 (7416) | 5 RCTs/2 good quality, 2 fair, 1 poor | Consistent | Direct | Imprecise | OR 1.49 (1.10 to 2.01) Favors deferred GPI

CI = confidence interval; GPI = glycoprotein inhibitor; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

Table 13 Detailed strength of evidence for bivalirudin versus heparin-based strategy in patients treated with clopidogrel at the time of PCI

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 30 Days | | | | | Insufficient SOE
2 (2571) | 2 RCTs/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | 1 RCT (fair) showed a significant reduction favoring bivalirudin, OR 0.42 (0.21 to 0.84, p=0.02), the other RCT (good) showed no difference, OR 1.05 (0.80 to 1.40)
Major Bleeding at 30 Days | | | | | Low SOE
2 (2571) | 2 RCTs/1 good quality, 1 fair | Consistent | Direct | Imprecise | One RCT (fair) showed no statistical difference between the groups, OR 0.32 (0.10 to 1.01); the other RCT (good) showed a statistically significant reduction favoring bivalirudin, OR 0.53 (0.31 to 0.91, p=0.02); Favors bivalirudin

CI = confidence interval; MI = myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

Table 14 Detailed strength of evidence for upstream versus deferred GPI use in patients treated with clopidogrel at the time of PCI

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, Revascularization, or Thrombotic Bailout With GPI at 96 Hours | | | | | Insufficient SOE
1 (2271) | RCT/Good quality | NA | Direct | Imprecise | Upstream GPI: 10.3% Deferred GPI: 11.2%
All-Cause Mortality at 30 Days | | | | | Low SOE
4 (11,858) | 4 RCTs/2 good quality, 1 fair, 1 poor | Inconsistent | Direct | Imprecise | OR 0.97 (0.80 to 1.18) No difference
Major Bleeding at 30 Days | | | | | High SOE
3 (11,698) | 3 RCTs/2 good quality, 1 fair | Consistent | Direct | Precise | OR 1.27 (1.08 to 1.50) Favors deferred GPI

CI = confidence interval; GPI = glycoprotein inhibitor; MI = myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

## Key Question 2 Initial Conservative Approach for UA/NSTEMI

KQ 2: In patients undergoing an initial conservative approach for treating UA/NSTEMI:

a. What are the comparative effectiveness (dose and timing) and comparative safety of different anticoagulants for improving cardiovascular outcomes?
b. What are the comparative effectiveness (dose and timing) and comparative safety of different antiplatelet agents for improving cardiovascular outcomes?
c. Based on demographic and other characteristics, are there subgroups of patients for whom the effectiveness and safety differ?

### Key Points

- Compared with UFH, enoxaparin treatment showed a significant reduction in composite ischemic events (high SOE) and nonfatal MI (moderate SOE) at around 30 days. There was no difference in all-cause mortality at 30 days (low SOE), but there was insufficient evidence to reach a conclusion on the comparative treatment effect on major bleeding at 30 days.
- Based on an indirect comparison of fondaparinux and UFH, there was a significant reduction in composite ischemic events (low SOE) and major bleeding (low SOE) at around 30 days favoring fondaparinux, but there was insufficient evidence to reach a conclusion on the comparative treatment effect on nonfatal MI or all-cause mortality.
- Observational studies within subgroups showed that the use of enoxaparin was associated with lower rates of ischemic events in obese patients, those with renal impairment, and those with ST depression on electrocardiography.
- Adding a GPI to UFH reduced the rate of mortality at 30 days (high SOE) and reduced composite ischemic events and nonfatal MI (moderate SOE).
- There was insufficient evidence for the effect of GPIs on revascularization although fewer events were seen in patients receiving GPIs in two small trials.
- While the use of GPIs reduces the rates of the adverse events mentioned above, the tradeoff is an increase in minor bleeding rates (high SOE). There was insufficient evidence on the effect of GPIs on major bleeding.
- Ticagrelor reduced the rates of composite ischemic and all-cause mortality events; however, it also increased rates of major bleeding and the combination of major or minor bleeding events (moderate SOE) compared with clopidogrel at up to 30 months. There was no difference in revascularization at 12 months for this comparison (moderate SOE).
- Prasugrel showed similar rates of composite ischemic events, all-cause mortality, and nonfatal MI compared with clopidogrel (moderate SOE) at up to 30 months. There was insufficient evidence to support findings concerning stroke or major bleeding events for this comparison; however, there was low SOE that the combination of major or minor bleeding events up to 30 months was lower in the clopidogrel group.

### Description of Included Studies

We identified 33 unique studies that evaluated the comparative effectiveness of antiplatelet medications and anticoagulant medications in 225,891 patients with UA/NSTEMI treated with an initial conservative approach or a mixed population for whom the approach (conservative or invasive) was not presented separately.38,40,62,65-73,103,104,111-129 Of these studies, 24 were RCTs (14 good quality, 9 fair, 1 poor) and 9 were observational (4 good quality, 4 fair, 1 poor) (Table E-2 in Appendix E). 28 studies were multicenter,62,65-69,71-73,103,104,111-116,118-120,122-129 four studies were single-center,38,70,117,121 and in one study the number of sites was unclear or not reported.40 Twenty-one studies included sites in the U.S. or Canada,62,65-69,72,73,103,104,114,116,118-120,122-125,128,^129^18 included sites in Europe,62,65,66,68-70,73,104,112,116,117,119,122,123,125,126,128,129 11 included sites in Asia,38,40,66,68,71,111,113,115,121,128,129 and in 1 study the site location was unclear or not reported.127 A total of 18 studies used industry funding,62,65-69,71,73,103,104,114,118,122-125,128,129 and in 15 studies the funding source was either not reported or unclear.38,40,70,72,111-113,115-117,119-121,126,127 The study characteristics table for KQ 2 (Table F-2 in Appendix F) contains details about the study design, proportion of UA/NSTEMI patients, antiplatelet/anticoagulant comparisons, outcomes measured, and study quality for studies included in the analysis of an initial conservative approach.

In the next section, we present the following three comparisons that were assessed in the included studies in KQ 2:

1. UFH versus enoxaparin or fondaparinux (full UA/NSTEMI cohort; KQ 2a)
  - 21 studies (12 RCTs, 9 observational; 161,506 total patients)
    a. Enoxaparin versus UFH (10 RCTs, 4 observational; 24,567 patients)
    b. Enoxaparin versus fondaparinux (1 RCT; 20,078 patients)
    c. Fondaparinux versus UFH (1 RCT; 350 patients)
    d. UFH versus low molecular weight heparin (either enoxaparin or fondaparinux; 4 observational; 56,152 patients)
    e. Enoxaparin (normal dose) versus low- or high-dose enoxaparin (1 observational; 10,687 patients)
2. GPI plus UFH versus UFH alone (KQ 2b)
  - 10 studies (10 RCTs; 38,518 total patients)
3. Clopidogrel versus ticagrelor or prasugrel (initial conservative cohort; KQ 2b)
  - 2 studies (2 RCTs; 12,459 total patients)

The subgroup findings (KQ 2c) are presented after each comparison.

### Detailed Synthesis

#### 1 Unfractionated Heparin Versus Enoxaparin or Fondaparinux (Full UA/NSTEMI Cohort; KQ 2a)

Twenty-one studies (12 RCTs, 9 observational) evaluated the use of UFH versus enoxaparin or fondaparinux in 161,506 patients with UA/NSTEMI.65-73,103,104,111-114,116,118,119,121,125,127 The majority of these studies were performed prior to the time (pre-2005) when an early invasive strategy was widely implemented, and employed an initial conservative strategy followed by percutaneous revascularization. An initial conservative strategy was particularly common during the study period for centers outside the United States. Proportions of patients proceeding to revascularization ranged from 29 percent67 to 63 percent.68

Six RCTs compared enoxaparin with UFH as an initial management strategy prior to PCI and included a total of 18,554 patients.65-67,119,121,125 One RCT (20,078 patients) compared enoxaparin with fondaparinux68 and one RCT (350 patients) compared fondaparinux with UFH.69 Three studies compared enoxaparin with UFH at the time of PCI.70-72 The study populations reflected a mixture of UA/NSTEMI and elective PCI patients, and the timing of PCI relative to presentation with ACS was not specified. One study compared the use of enoxaparin with UFH in UA/NSTEMI patients.73 Patients who underwent PCI uniformly received open-label UFH by protocol for the intervention, but all patients received double-blind, subcutaneous injections until hospital discharge or Day 8, whichever came first.

Sample sizes for the RCTs ranged from 93 to 20,078 patients. Study duration ranged from 48 hours to 6 months. The mean age of study participants ranged from 56 to 68 years of age. The proportion of female patients ranged from 23 to 38 percent. Two studies65,66 reported the racial and ethnic demographics of study participants and also contained a predominately Caucasian population (85% and 86%). The RCTs included 9 multicenter and 3 single-center studies, representing an international patient population including North America, Europe, and Asia. Eight of the 12 RCTs were industry-sponsored. The full results across all outcomes are reported in Table G-9 in Appendix G.

Nine observational studies met our inclusion criteria but were excluded from meta-analysis due to heterogeneity in the study population or risk for selection bias in the setting of nonrandomized treatment selection.103,104,111-114,116,118,127 A description of the observational studies follows our analysis of the RCTs; these are included in this section to compare their findings with the RCTs and to report subgroup findings that were not addressed in the RCTs. The Goodman 2006 article130 considered in this group is a prospective observational study on subgroups from the ESSENCE trial,125 which has been analyzed with the rest of the RCTs in this section. Sample sizes for these observational studies ranged from 2397 to 37,320 patients. The mean age of study participants ranged from 62 to 70 years. The proportion of female patients ranged from 30 to 48 percent. Three studies114,116,118 reported the racial and ethnic demographics of study participants and had a predominately Caucasian population (ranging from 82% to 85%). The observational studies were all multicenter trials representing an international population including North America, South America, Europe, and Asia, with the exception of one study where this was unreported.127 Four of the nine studies were industry sponsored and will be discussed qualitatively below.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, Revascularization, or Recurrent Ischemia at Around 30 Days

Six studies66,67,72,73,121,125 (all RCTs; 4 good quality, 2 fair) evaluated the effect of low molecular weight heparin and UFH on a composite endpoint of total mortality, nonfatal MI, or recurrent ischemia/revascularization in a total of 12,124 UA/NSTEMI patients. These endpoints were reported for short-term outcomes ranging from 7 days (Blazing et al.66) to 43 days (Antman et al.73), with the majority of studies reporting the composite outcome at 30 days (4 studies). Because the bulk of recurrent ischemic events in ACS occur soon after PCI, we assumed that relative estimates of effect would be comparable within this range of time points. This assumption holds for all analyses in this section.

A random-effects meta-analysis of the 6 studies comparing the effect of treatment strategies incorporating enoxaparin versus UFH found an estimated odds ratio of 0.84 (95% CI, 0.76 to 0.93) (Figure 31). There was no evidence of heterogeneity, with a Q-value of 5.38 for 5 degrees of freedom, p=0.37. The study by Malhotra et al. was a small, single-center, fair-quality study.121 The I^2^ value was 7.08. Accommodating for between-study variance, the relative estimates of effect on the composite endpoint were generally consistent among studies, suggesting a significant overall reduction in the ischemic composite endpoint in the setting of an enoxaparin-based treatment strategy. The SOE was rated high for this composite endpoint based on multiple head-to-head RCTs with a consistent evidence base, precise estimates of the overall effect, and moderate scores for risk of bias due to the clinical heterogeneity among studies.

Figure 31 Meta-analysis of enoxaparin versus unfractionated heparin on composite outcome of all-cause mortality, nonfatal myocardial infarction, revascularization, or recurrent ischemia at around 30 days

CI = confidence interval; UFH = unfractionated heparin

This figure displays a forest plot of a random-effects meta-analysis of six studies that shows an odds ratio of 0.84 (95% CI, 0.76 to 0.93), favoring enoxaparin.

The effect of fondaparinux versus UFH on the composite short-term endpoint was estimated using methods described by Hasselblad and Kong.131 We created an indirect comparison of fondaparinux versus UFH by combining the above estimate of enoxaparin versus UFH with the results for fondaparinux versus enoxaparin in the study by Yusuf et al.68 (20,078 patients). The uncertainty around the estimate is the sum of the variances of the meta-analysis and the results from Yusuf et al.68 The result is an estimated odds ratio of 0.78 (95% CI, 0.67 to 0.90), favoring fondaparinux. The SOE was rated low for this composite endpoint based on an indirect comparison with only a single trial contributing information on fondaparinux versus enoxaparin.

##### Effect on Composite Ischemic Endpoint at 6 Months

Only one good-quality RCT of 20,078 patients in this comparison group evaluated the effect of treatment on the composite ischemic outcome at 6 months.68 In this study, which was adequately powered for a noninferiority hypothesis (difference of 1.185 between groups), there was a similar incidence of composite ischemic outcomes in patients treated with enoxaparin (10.2%) and fondaparinux (10.1%). The SOE was rated low for the composite ischemic outcome at 6 months based on a single large RCT.

##### Effect on All-Cause Mortality at Around 30 Days

Eight studies65-67,72,73,119,121,125 (all RCTs, 5 good quality, 3 fair) reported the effect of low molecular weight heparin and UFH on total mortality in a total of 23,015 UA/NSTEMI patients. Two studies72,121 had no deaths and so were not included in the analysis.

A random-effects meta-analysis of the 6 studies comparing the effect of treatment strategies incorporating enoxaparin versus UFH on total mortality found an estimated odds ratio of 0.98 (95% CI, 0.84 to 1.14) (Figure 32). There was no evidence of heterogeneity, with a Q-value of 4.11 for 5 degrees of freedom, p=0.53. The I^2^ value was 0.00. Accommodating for between-study variance, the relative estimates of effect on the composite endpoint were generally consistent among studies, and the overall estimate does not detect a mortality difference in the setting of an enoxaparin-based treatment strategy. The SOE was rated low for no difference in all-cause mortality based on multiple head-to-head RCTs with a consistent evidence base, imprecise estimates of the overall effect, and moderate scores for risk of bias due to the clinical heterogeneity among studies. Note that failure to detect a difference does not imply that a difference does not exist. This analysis was not designed to test for equivalence between enoxaparin and UFH.

Figure 32 Meta-analysis of enoxaparin versus unfractionated heparin on all-cause mortality at around 30 days

CI = confidence interval; UFH = unfractionated heparin

This figure displays a forest plot of a random-effects meta-analysis of six studies that shows an odds ratio of 0.98 (95% CI, 0.84 to 1.14), showing no difference

We created an indirect comparison of fondaparinux versus UFH by combining the above estimate of enoxaparin versus UFH with the results for fondaparinux versus enoxaparin in Yusuf et al.68 (20,078 patients). The result is an estimated odds ratio of 0.93 (95% CI, 0.71 to 1.20), showing no difference between treatments. The SOE was rated insufficient for all-cause mortality based on an indirect comparison with only one trial contributing information on fondaparinux versus enoxaparin and imprecise results.

##### Effect on Nonfatal Myocardial Infarction at Around 30 Days

Nine studies65-67,70,72,73,119,121,125 (all RCTs; 5 good quality, 4 fair) reported the effect of low molecular weight heparin and UFH on nonfatal (re)infarction in a total of 22,970 UA/NSTEMI patients. A random-effects meta-analysis of the 9 studies comparing the effect of treatment strategies incorporating enoxaparin versus UFH on nonfatal (re)infarction found an odds ratio of 0.85 (95% CI, 0.76 to 0.95) (Figure 33).There was no evidence of heterogeneity, with a Q-value of 8.49 for 8 degrees of freedom, p=0.39. The I^2^ value was 5.75. Accommodating for between-study variance, the relative estimates of effect on the composite endpoint were generally consistent among studies, suggesting a significant overall reduction in myocardial (re)infarction in the setting of an enoxaparin-based treatment strategy. The SOE was rated moderate for nonfatal MI based on multiple head-to-head RCTs with a consistent evidence base, imprecise estimates of the overall effect, and moderate scores for risk of bias due to the clinical heterogeneity among studies.

Figure 33 Meta-analysis of enoxaparin versus unfractionated heparin on nonfatal myocardial infarction at around 30 days

CI = confidence interval; UFH = unfractionated heparin

This figure displays a forest plot of a random-effects meta-analysis of nine studies that shows an odds ratio of 0.85 (95% CI, 0.76 to 0.95), favoring enoxaparin.

We created an indirect comparison of fondaparinux versus UFH by combining the above estimate of enoxaparin versus UFH with the results for fondaparinux versus enoxaparin in Yusuf et al.68 (20,078 patients). The result is an estimated odds ratio of 0.85 (95% CI, 0.69 to 1.04) suggesting a benefit of fondaparinux, but the CI crosses 1, making the finding imprecise. The SOE was rated insufficient for nonfatal MI based on an indirect comparison with only one trial contributing information on fondaparinux versus enoxaparin.

##### Effect on Major Bleeding at Around 30 Days

Eight studies65-67,72,73,119,121,125 (all RCTs; 5 good quality, 3 fair) reported the effect of low molecular weight heparin and UFH on major bleeding in a total of 22,901 UA/NSTEMI patients. The study by Malhotra et al.121 had no events and so was not included in the analysis.

A random-effects meta-analysis of the seven studies comparing the effect of treatment strategies incorporating enoxaparin versus UFH found an odds ratio of 1.11 (95% CI, 0.81 to 1.51) (Figure 34). There was evidence of heterogeneity, with a Q-value of 14.87 for 6 degrees of freedom, p=0.02. The I^2^ value was 59.66. The heterogeneity likely represents the between-study differences in PCI utilization and dosing. For instance, the Cohen 2002 study119 was a double-blind, small-sized RCT with 30 percent of patients undergoing PCI. In contrast, the study by Blazing et al.66 was an open-label, large-sized RCT with 60 percent of patients undergoing PCI. Removal of that study reduced the heterogeneity to a Q-value of 10.18 (p=-0.07), but the summary estimate was essentially unchanged, 1.03 (95% CI, 0.78 to 1.35). Accommodating between-study variance, the overall estimate does not detect a difference in major bleeding rates in the setting of an enoxaparin-based treatment strategy. The SOE was rated insufficient for major bleeding based on multiple head-to-head RCTs with an inconsistent evidence base, imprecise estimates of the overall effect, and moderate scores for risk of bias due to the clinical heterogeneity among studies.

Figure 34 Meta-analysis of enoxaparin versus unfractionated heparin on major bleeding at around 30 days

CI = confidence interval; UFH = unfractionated heparin

This figure displays a forest plot of a random-effects meta-analysis of seven studies that shows an odds ratio of 1.11 (95% CI, 0.81 to 1.51).

We created an indirect comparison of fondaparinux versus UFH by combining the above estimate of enoxaparin versus UFH with the Yusuf et al.68 (20,078 patients). The result is an estimated odds ratio of 0.69 (95% CI, 0.49 to 0.97), favoring fondaparinux. The SOE was rated low for major bleeding based on an indirect comparison with only one trial contributing information on fondaparinux versus enoxaparin.

##### Findings in Observational Studies

As stated earlier, we identified nine observational studies (in addition to the Goodman 2006 prospective observational subgroup cohort of the ESSENCE trial), but none were meta-analyzed due to heterogeneity in the study population or risk for selection bias in the setting of nonrandomized treatment selection.103,104,111-114,116,118,127,130 Of these observational studies, only one112 included information on fondaparinux. We describe below the findings of these observational studies and how the findings relate to the RCT evidence base.

###### Prescribed Use Over Time

Six studies described use and overall trends from 1999 through 2007.^103,104,112,113,116,118^ The Thai registry113 described use in 17 centers in Thailand from 2002-2005 among 3,963 patients with NSTEMI or UA. Many more patients were treated with enoxaparin (84%) than with UFH (16%) overall. The U.S.-based CRUSADE Registry of 11,358 patients103 demonstrated a greater use of UFH (60.6%) than enoxaparin (39.4%) among invasively managed patients also treated with GPI. The GRACE Registry of 17,659 patients116 noted that 37.9 percent of patients received enoxaparin in first 24 hours with continued use; 17.0 percent received UFH in the first 24 hours with continued use; 12.7 percent received neither, and 31.7 percent had cross-over from enoxaparin to UFH or vice versa. Over time intervals from 1999 to 2005 there was an increased use of enoxaparin alone, and more crossovers, with less UFH alone. There was a greater use of enoxaparin outside of the United States. Patients treated with enoxaparin were less likely to undergo PCI in the first 24 hours, and those undergoing PCI were more likely to be treated with UFH or to be in the crossover group.

Another GRACE article104 evaluated heparin use in relation to GPI and invasive care. Enoxaparin was used in 51 percent, UFH in 32 percent, and 17 percent received both UFH and enoxaparin at some time. Patients given UFH had more comorbidity than those given enoxaparin or both. A multicenter registry of 2874 patients in France112 found that between 2006 and 2007, the use of fondaparinux increased considerably (5% to 25%) Patients given UFH were older, with more comorbidities and fewer guideline-associated treatments. Finally, the NRMI (National Registry of Myocardial Infarctions) study118 described use of heparins among 37,320 patients treated with GPI from 1998 to 2000. Only seven percent were treated with enoxaparin, and 93 percent were treated with UFH. Thus the older study (NRMI registry) showed low use of enoxaparin in the late 1990s, with more recent studies published in 2007 and 2010 showing increasing use of enoxaparin and fondaparinux.

###### Effect on Cardiovascular Events

Seven observational studies reported the effect on mortality, myocardial infarction, and/or recurrent ischemia. In the Thai registry113 the UFH group had more cardiac deaths than the enoxaparin group (9.3% vs. 5.2%, p<0.0001). Within the U.S.-based CRUSADE Registry103 the point estimate of risk of in-hospital death or reinfarction was lower in patients treated with enoxaparin (OR 0.81, 95% CI, 0.67 to 0.99) than with UFH. There were particular benefits in this study to enoxaparin among those who did not undergo revascularization. The GRACE Registry116 found that the adjusted ORs for death were not significant but favored enoxaparin over either UFH or crossover compared with no heparin. Also, the composite of death, MI, and recurrent ischemia were all higher in the treated groups compared with those not treated with any heparin, suggesting selection biases despite adjustment. Another GRACE article104 evaluated heparin use in relation to GPI and invasive care. Overall adjusted comparison demonstrated that enoxaparin was associated with lower mortality (OR 0.76; 95% CI, 0.63 to 0.91). Among subgroups by treatment, this was particularly true for those who did not receive GPI or PCI or who had PCI without GPI. There were no differences in enoxaparin or UFH in the subgroup receiving both GPI and PCI. The multicenter registry in France112 found that fondaparinux was associated with lower adjusted mortality than UFH and similar adjusted mortality to enoxaparin. Again, patients given UFH in the French registry were older, with more comorbidities and fewer guideline-associated treatments. The KAMIR (Korean Acute MI registry) study111 assessed the use of enoxaparin with low-dose UFH compared with usual-dose UFH alone in 2397 patients undergoing PCI with a drug-eluting stent. This study found that the enoxaparin group had similar incidences of cardiac death, total death, and total MACE at 8 months compared with the UFH group. However, there were significantly lower rates of recurrent myocardial infarction in the enoxaparin group (0.3%) compared with the UFH group (1.0, p=0.024). Finally, the NRMI study118 found no differences recurrent MI or death in those treated with enoxaparin compared with UFH. Similar to the RCT meta-analyses, most studies show a benefit of enoxaparin in reducing composite ischemic events, while the effect of enoxaparin on individual endpoints was inconsistent across studies.

###### Effect on Major Bleeding

Seven observational studies reported the findings on major bleeding. In the Thai registry,113 major bleeding was 6.3 percent in the enoxaparin group and 3.7 percent in the UFH group (p-value not reported). The U.S.-based CRUSADE Registry103 showed similar bleeding risks between the enoxaparin and UFH groups. In the GRACE Registry,116 the adjusted ORs for bleeding were not different in enoxaparin, UFH, or crossover groups compared with no heparin. Another GRACE article104 evaluated heparin use in relation to GPI, invasive care, and major bleeding (OR 0.78; 95% CI, 0.64 to 0.95). There was a slight trend to increase major bleeding with enoxaparin after adjustment. In patients who had crossover, UFH was superior in those with GPI and no PCI. A multicenter registry in France112 reported rates of in-hospital bleeding of 2.1 percent in the enoxaparin group, 5.0 percent in the UFH group, and 3.3 percent in the fondaparinux group; thus bleeding rates were similar in the enoxaparin and fondaparinux groups but significantly higher in the UFH group. The KAMIR study111 did not find any significant differences in in-hospital major or minor bleeding rates. Finally, the NRMI study118 noted no differences in major bleeding rates in those treated with enoxaparin compared with UFH. Overall, the major bleeding rates varied across observational studies with some showing no differences between enoxaparin and UFH, while other showed higher rates with either agent. Regional differences in the selection of anticoagulants to use based on clinical presentation and comorbidities may be responsible for the heterogeneity. The meta-analysis of randomized trials above failed to show a significant difference in major bleeding rates.

###### Effect on Other Outcomes

One observational study, the Thai registry,113 reported a longer length of hospital stay in the UFH group (56.9%, p<0.0001) compared with the enoxaparin group (44.7%). Two RCTs reported length of hospital stay. The ACUTE II study found similar duration of hospitalization in the UFH (208 ± 180 hours) and enoxaparin groups (209 ± 149 hours, p=0.20).119 The ESCAPEU study found a significantly lower duration of hospitalization in the enoxaparin group (156 ± 14 hours) compared with the UFH group (166 ± 19 hours, p=0.01).121

##### Findings by Subgroup (KQ 2c)

The subgroup findings for the RCTs of low molecular weight heparin and UFH are described in the KQ 1 section, so to avoid redundancy the following section focuses on the observational studies. Three other observational studies evaluated enoxaparin in relation to key subgroups; namely, patient factors related to excess dosage, obesity, renal impairment, and ECG changes.114,127,130 Among a CRUSADE Registry population who received enoxaparin,114 18.7 percent received an excess dose, and 29.2 percent received lower than recommended dose. Those receiving excess doses were more likely to be older, smaller, and female based upon the need to adjust for both weight and renal function. Lower than recommended dose was associated with a trend to higher mortality, and an excess dose was associated with more major bleeding and death compared with recommended doses. In an analysis from the clinical trial data in ESSENCE and TIMI 11B,127 enoxaparin was associated with lower rates of death, nonfatal MI, or unplanned revascularization among obese patients and those with renal impairment. There was a slight increased risk of bleeding with enoxaparin in those with renal impairment. Finally, a subgroup from the ESSENCE trial130 found that enoxaparin was particularly beneficial over UFH among patients with ECG changes, specifically ST-depression. This identified a higher risk subgroup, more likely to benefit from the use of enoxaparin. Table H-2 in Appendix H presents the results data for these subgroups.

##### Summary of Results for Enoxaparin Versus Unfractionated Heparin Versus Fondaparinux (Full UA/NSTEMI Cohort)

In our analysis of studies comparing enoxaparin, UFH, and fondaparinux, we present the findings of UA/NSTEMI patients who received primarily initial conservative treatment. There was a significant reduction in composite ischemic events and nonfatal MI at around 30 days with enoxaparin compared with UFH, but insufficient SOE for the outcomes of all-cause mortality and major bleeding for that time period. An indirect comparison of fondaparinux and UFH found a significant reduction in composite ischemic events and a nonsignificant reduction in major bleeding events favoring fondaparinux. Evidence was insufficient for the outcomes of nonfatal MI and all-cause mortality at around 30 days in this comparison. Results from observational studies show that use of low molecular weight heparin is increasing over time in the conservatively managed population and confirmed RCT findings that enoxaparin is associated with fewer ischemic events, although the results for bleeding events were mixed. Fondaparinux was associated with lower adjusted mortality than UFH and similar adjusted mortality to enoxaparin. In an RCT, fondaparinux significantly lowered mortality at 30 days and 180 days and major bleeding at 9 days compared with enoxaparin. Subgroups analyzed were dosage, obesity, renal impairment, and ECG changes. Excess dosage was associated with more major bleeding and death and was more likely to be received by older, smaller, and female patients. Use of enoxaparin was associated with lower rates of ischemic events in obese patients, those with renal impairment, and those with ST depression on ECG. Detailed SOE ratings are shown in Table 15. Odds ratios less than 1 favor enoxaparin or fondaparinux; odds ratios greater than 1 favor UFH.

Table 15 Detailed strength of evidence for UA/NSTEMI patients treated with unfractionated heparin versus enoxaparin or fondaparinux (full UA/NSTEMI cohort)

Number of Studies (Patients)^a^ | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients)^a^ | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, Revascularization, or Recurrent Ischemia at around 30 days
Enoxaparin vs. UFH 6 (12,124) | 6 RCTs/4 good quality, 2 fair | Consistent | Direct | Precise | High SOE OR 0.84 (0.76 to 0.93) Favors enoxaparin
Fondaparinux vs. UFH 1 (20,078) | RCT/Good quality | NA | Indirect | Precise | Low SOE OR 0.78 (0.67 to 0.90) Favors fondaparinux
Composite Ischemic Endpoint at 6 Months
Enoxaparin vs. fondaparinux 1 (20,078) | RCT/Good quality | NA | Direct | Precise | Low SOE No significant difference between fondaparinux and enoxaparin (10.1% vs. 10.2%)
All-Cause Mortality at Around 30 Days
Enoxaparin vs. UFH 8 (23,015) | 8 RCTs/5 good quality, 3 fair | Consistent | Direct | Imprecise | Low SOE OR 0.98 (0.84 to 1.14) No difference
Fondaparinux vs. UFH 1 (20,078) | RCT/Good quality | NA | Indirect | Imprecise | Insufficient SOE OR 0.93 (0.71 to 1.20)
Nonfatal MI at Around 30 Days
Enoxaparin vs. UFH 9 (22,970) | 9 RCTs/5 good quality, 4 fair | Consistent | Direct | Imprecise | Moderate SOE OR 0.85 (0.76 to 0.95) Favors enoxaparin
Fondaparinux vs. UFH 1 (20,078) | RCT/Good quality | NA | Indirect | Imprecise | Insufficient SOE OR 0.85 (0.69 to 1.04)
Major bleeding at Around 30 Days
Enoxaparin vs. UFH 8 (22,901) | 8 RCTs/5 good quality, 3 fair | Inconsistent | Direct | Imprecise | Insufficient SOE OR 1.11 (0.81 to 1.51)
Fondaparinux vs. UFH 1 (20,078) | RCT/Good quality | NA | Indirect | Precise | Low SOE OR 0.69 (0.49 to 0.97) Favors fondaparinux

CI = confidence interval; ECG = electrocardiogram; MI = myocardial infarction; NA = not applicable; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction; UFH = unfractionated heparin

a Populations for the indirect fondaparinux comparisons included the 20,078 patients from the Yusuf study.

#### 2 GPI Plus Unfractionated Heparin Versus Unfractionated Heparin Alone (KQ 2b)

Ten RCTs (7 good quality, 3 fair) evaluated GPIs versus UFH in 38,518 patients with UA/NSTEMI.38,40,62,115,117,120,122-124,126 The majority of these studies were performed prior to the time when an early invasive strategy was widely implemented, and employed an initial conservative strategy followed by percutaneous revascularization after 18 to 72 hours. Some of the studies had a mixture of treatment approaches and reported subgroup findings for the medically managed population. Subjects in older studies (pre-2000) were enrolled on the basis of high-risk MI features, while newer studies followed the standard definition for conservative strategy and are likely lower risk patients.

Proportions of patients proceeding to revascularization ranged from 0 percent38,115,117 to 100 percent.126 Sample sizes for the RCTs ranged from 60 to 13,819 patients. Study duration ranged from 30 days to 1 year. The mean age of study participants ranged from 53 to 65 years of age. The proportion of female patients ranged from 25 to 54 percent. Three studies122-124 reported the racial and ethnic demographics of study participants. The RCTs included eight multicenter and two single-center studies, representing an international patient population including North America, Europe, and Asia. Six of the studies were industry-sponsored. GPIs assessed included: abciximab (two studies120,126), eptifibatide (two studies40,122), tirofiban (five studies38,115,117,123,124), and any of the three GPIs with either UFH or enoxaparin (1 study62). The full results across all outcomes are reported in Table G-10 in Appendix G.

##### Effect on Composite Ischemic Endpoints up to 30 Days

All 10 RCTs (7 good quality, 3 fair; 38,518 patients) reported composite endpoints at 30 days.38,40,62,115,117,120,122-124,126 The results are described qualitatively since the specific components of the composite endpoints differed among the studies; pooling all the studies into an quantitative analysis was not possible due to the heterogeneity of the composite endpoint definition, and pooling only the studies that had similar composite endpoints would have reduced the number of studies available for analysis.

In the PURSUIT study,122 rates of the composite outcome (death or nonfatal MI) were significantly lower in the eptifibatide group compared with heparin (14.2% vs. 15.7%, p=0.04). Likewise, Momtahen et al.40 found that the composite of total mortality, nonfatal MI, or revascularization was significantly lower in the eptifibatide group (0%) compared with heparin (16%, p<0.01).

In the PRISM study,123 the primary composite endpoint (death, MI, refractory ischemia, or UA readmission) was lower in the tirofiban group compared with heparin (RR 0.67; 95% CI, 0.48 to 0.92, p=0.01). The secondary composite endpoint of death or MI showed a nonsignificant reduction in event rates in the tirofiban group (RR 0.80; 95% CI, 0.61 to 1.05). In an analysis of the medically managed (no PCI) subgroup (tirofiban, n=992 and UFH n=1007), the primary composite outcome also showed a lower risk of events in the tirofiban group, for both the primary composite endpoint (RR 0.84; 95% CI, 0.65 to 1.10) and the secondary composite endpoint (RR 0.58; 95% CI, 0.38 to 0.87).

In the PRISM-PLUS study,124 the primary composite endpoint (death, MI, or refractory ischemia) was lower in the tirofiban group compared with tirofiban plus heparin (RR 0.78 (95% CI, 0.63 to 0.98, p=0.03). The secondary composite endpoint of death or MI was also significant and favored the tirofiban group (RR 0.70 CI, 0.51 to 0.96, p=0.03). An analysis of the medically managed (no PCI) subgroup showed a nonsignificant reduction in the primary composite endpoint (RR 0.87; 95% CI, 0.60 to 1.25) and secondary composite endpoint (RR 0.75; 95% CI, 0.46 to 1.23).

The Bhattacharya study38 reported significant reduction in the composite endpoint of fatal/nonfatal MI, refractory ischemia or death with tirofiban with enoxaparin (19%) compared with enoxaparin (34%, p=0.01) at 30 days.

In the Okmen study,117 the in-hospital rate of composite events (total mortality, nonfatal MI, revascularization, or refractory angina) was significantly lower in the tirofiban group (26% vs. 54%, p=0.01) In the ACUITY TIMING study,110 the medical therapy subgroup also had fewer composite events (death, MI, or revascularization) in patients who received upstream GPI (2.4%) compared with deferred GPI (3.3%) (HR 1.39; 95% CI, 0.91 to 2.12). The medical therapy subgroup of the ACUITY trial showed a nonsignificant reduction in the same composite event at 30 days favoring UFH plus GPI over bivalirudin (RR 1.24; 95% CI, 0.83 to 1.85).

In the RCT by Song et al.,115 the frequency of the composite endpoint (total mortality, nonfatal MI, or refractory ischemia) in the tirofiban plus UFH arm was lower than UFH alone (13,9% vs. 29.3%, p=0.01).

The GUSTO-IV study reported no significant differences between abciximab and heparin in acute coronary syndrome patients who do not undergo early coronary revascularization (angiography was discouraged within 60 hours of randomization).120 The odds ratio of the primary composite endpoint of total mortality or nonfatal MI was 1.00 in the 24-hour infusion group (95% CI, 0.83 to 1.24) and 1.10 in the 48-hour infusion group (95% CI, 0.94 to 1.39) compared with heparin.

Finally, the study by van den Brand et al.126 showed lower rates of major events (total mortality, nonfatal MI, or recurrent ischemia) in the group receiving abciximab (1 out of 30) compared with heparin (7 out of 30), p=0.03.

Overall, the studies of eptifibatide and tirofiban showed a risk reduction in composite events compared with UFH alone, ranging from 0.58 to 0.84; one large trial of abciximab (GUSTO-IV ACS study)120 showed no difference in events, but a small trial126 showed lower rates of major events with abciximab versus heparin. The SOE was rated moderate for composite ischemic events up to 30 days based on multiple RCTs with consistent results of a direct outcome and imprecise estimates of the overall effect.

##### Effect on Mortality up to 30 Days

Nine RCTs (6 good quality, 3 fair) reported mortality rates in 24,699 UA/NSTEMI patients at 30 days.38,40,115,117,120,122-124,126 In the PURSUIT study122 the mortality rate was similar in the eptifibatide and heparin groups (3.5% vs. 3.7%). In the PRISM study123 the mortality rate was significantly lower in the tirofiban group (RR 0.62; 95% CI, 0.41 to 0.93, p=0.02). In the PRISM-PLUS study,124 the mortality rate was nonsignificantly lower in the tirofiban plus heparin group (RR 0.79; 95% CI, 0.48 to 1.30). The GUSTO-IV trial120 showed no differences in mortality at 30 days for both the abciximab 24-hour infusion group (OR 0.90; 95% CI, 0.64 to 1.50) and the 48-hour infusion group (OR 1.1; 95% CI, 0.83 to 1.43) compared with heparin.

Fewer deaths were also seen in the smaller trials of GPIs compared with UFH. The Bhattacharya study38 reported number of combined deaths due to unknown causes and fatal MI events (tirofiban 6%, heparin 14%) at 30 days. Momtahen et al.40 reported no deaths in the eptifibatide group (n=98) and two deaths in the heparin group (n=98). Note that no in-hospital deaths occurred in the Okmen study117 for both the tirofiban group (n=41) and the no tirofiban group (n=42); therefore, that study does not appear in the meta-analysis. Song et al.115 reported one death in the tirofiban group (n=101) and three deaths in the heparin group (n=99). Similarly, van den Brand126 reported no deaths in the abciximab group (n=30) and one death in the heparin group (n=30).

A random-effects meta-analysis of 8 studies38,40,115,120,122-124,126 in 24,616 patients reporting mortality rates at 30 days found that the odds ratio was 0.80 (95% CI, 0.67 to 0.96), favoring GPI use (Figure 35). There was no evidence of heterogeneity, with a Q-value of 8.18 and 7 degrees of freedom, p=0.32. The I^2^ value was 14.41.

Figure 35 Meta-analysis of glycoprotein inhibitor versus unfractionated heparin on mortality up to 30 days

CI = confidence interval; GPI = glycoprotein inhibitor

This figure displays a forest plot of a random-effects meta-analysis of eight studies that shows an odds ratio of 0.80 (95% CI, 0.67 to 0.96), favoring glycoprotein inhibitor use.

A fixed-effects model had minimal changes to the summary estimate, with an odds ratio of 0.83 (95% CI, 0.71 to 0.96). In an effort to explain the between-study variation, we performed a sensitivity analysis based on features we suspected might account for the variation and that had suitable distributions among the studies. The results of the subgroup sensitivity analyses are shown in Table 16 (forest plot appears in Appendix I).

Table 16 Sensitivity analysis of glycoprotein inhibitor versus unfractionated heparin on mortality up to 30 days

Study Characteristic | Number of Studies (Patients)^a^ | Summary Estimate (95% CI)
Trial Size
Small (<1000 patients) | 4 (761) | OR 0.36 (0.17 to 0.76)
Large (≥1000 patients) | 4 (23,855) | OR 0.86 (0.74 to 1.00)
Antiplatelet Use
Aspirin monotherapy | 6 (24,119) | OR 0.85 (0.73 to 0.99)
Dual antiplatelet therapy | 2 (497) | OR 0.37 (0.16 to 0.83)

CI = confidence interval

a Subgroup summary estimates with fewer than three studies should be interpreted with caution.

Studies with larger or smaller sample sizes favored GPI plus UFH, although the summary estimate for the smaller trials was more favorable toward GPI use than the larger trials. Also, the use of aspirin monotherapy and dual antiplatelet therapy favored GPI plus UFH with studies including dual antiplatelet therapy more favorable toward GPI use than the trials using aspirin monotherapy. The similarities between the fixed-effects and random-effects models support the conclusion that there is no statistical heterogeneity. Overall, the rates of mortality at 30 days were higher in the heparin group from these eight RCTs with consistent results of a direct outcome with precise results, thus leading us to conclude that the SOE was high.

##### Effect on Nonfatal MI up to 30 Days

Nine RCTs (6 good quality, 3 fair) with a total of 24,699 patients reported nonfatal MI event rates either in-hospital or at 30 days.38,40,115,117,120,122-124,126 In the PURSUIT study122 the rates nonfatal MI were nonsignificantly lower in the eptifibatide group compared with heparin (12.6% vs. 13.5%). In the PRISM study123 tirofiban had similar rates of nonfatal MI compared with heparin (RR 0.95; 95% CI, 0.58 to 1.34). In the PRISM-PLUS study,124 the rate of MI events was lower in the tirofiban plus heparin group (RR 0.70; 95% CI, 0.40 to 1.00). The GUSTO-IV trial120 showed no differences in mortality at 30 days for both the abciximab 24-hour infusion group (OR 1.1; 95% CI, 0.87 to 1.41) and the 48-hour infusion group (OR 1.2; 95% CI, 0.91 to 1.46) compared with heparin.

The smaller RCTs also reported lower nonfatal MI events in the GPI group compared with heparin. The Bhattacharya study38 reported six nonfatal MI events in the tirofiban group and 22 MIs in the heparin group up to 30 days. Momtahen et al.40 reported no MIs in the eptifibatide group (n=98) and five MIs in the heparin group (n=98). In the Okmen study117 one MI occurred in the tirofiban and eight MIs occurred in the no tirofiban group. Song et al.115 reported three MIs in the tirofiban group and seven deaths in the heparin group. Similarly, van den brand126 reported one MI in the abciximab group (n=30) and three MIs in the heparin group (n=30).

A random-effects meta-analysis of the 9 studies in 24,699 patients reporting nonfatal MI rates at 30 days found that the odds ratio was 0.79 (95% CI, 0.61 to 1.02), favoring GPI use (Figure 36). There was evidence of moderate heterogeneity, with a Q-value of 20.14 for 8 degrees of freedom, p=0.01. The I^2^ value was 60.27.

Figure 36 Meta-analysis of glycoprotein inhibitor versus unfractionated heparin on nonfatal myocardial infarction up to 30 days

CI = confidence interval; GPI = glycoprotein inhibitor

This figure displays a forest plot of a random-effects meta-analysis of nine studies that shows an odds ratio of 0.79 (95% CI, 0.61 to 1.02), favoring glycoprotein inhibitor use.

A fixed-effects model had minimal changes to the summary estimate, with an odds ratio of 0.91 (95% CI, 0.83 to 1.00). Again, we performed a sensitivity analysis based on subgroups, and the results are shown in Table 17 (forest plot appears in Appendix I).

Table 17 Sensitivity analysis of glycoprotein inhibitor versus unfractionated heparin on nonfatal myocardial infarction up to 30 days

Study Characteristic | Number of Studies (Patients)^a^ | Summary Estimate (95% CI)
Trial size
Small (<1000 patients) | 5 (844) | OR 0.26 (0.13 to 0.52)
Large (≥1000 patients) | 4 (23,855) | OR 0.94 (0.81 to 1.08)
Antiplatelet use
Aspirin monotherapy | 7 (24,202) | OR 0.89 (0.74 to 1.08)
Dual antiplatelet therapy | 2 (497) | OR 0.20 (0.05 to 0.89)

CI = confidence interval

a Subgroup summary estimates with fewer than three studies should be interpreted with caution.

Studies with smaller sample sizes favored GPI plus UFH, but the larger studies showed no significant difference. The summary estimate for the smaller studies was less precise than for the larger studies. Note that study quality was also highly correlated with study size, with three fair studies also being smaller in size. The use of dual antiplatelet therapy also favored GPI plus UFH, but the use of aspirin monotherapy showed no statistical difference, especially in the larger studies. Thus, the moderate heterogeneity seen in the full meta-analysis can be due to trial size and antiplatelet use. The similarities between the fixed and random effects model support the conclusion that there is no statistical heterogeneity. Overall, the rates of nonfatal MI at 30 days were higher in the heparin group from these nine RCTs with inconsistent results between smaller and larger trials of a direct outcome with precise results, thus leading us to conclude that the evidence is moderate.

##### Effect on Recurrent Ischemia up to 30 Days

Six RCTs (4 good quality, 2 fair) with a total of 5755 UA/NSTEMI patients reported recurrent or refractory ischemia either in-hospital or at 30 days.38,115,117,123,124,126 In the PRISM study,123 the rates of refractory ischemia were similar in the tirofiban and heparin groups, RR 0.98 (95% CI, 0.79 to 1.09). The PRISM-PLUS study124 found a slight increase in refractory ischemia events in the heparin group compared with tirofiban plus heparin, (95% CI, 0.57 to 1.01; p=0.05).The Okmen study117 reported an in-hospital recurrent angina rate of 27% in the tirofiban group and 50% in the heparin group. The Bhattacharya study38 reported a refractory ischemia rate at 30 days of 25 percent in the tirofiban group and 24 percent in the heparin group. The Song study115 saw a refractory ischemia rate at 30 days of 12 percent in the tirofiban group and 22 percent in the heparin group. In the Van den Brand study126 there was no recurrent ischemia at 30 days in the abciximab group and 23 percent rate in the heparin group.

A random-effects meta-analysis of these 6 studies in 5755 patients reporting recurrent ischemia rates at 30 days found that the odds ratio for GPI use was 0.81 (95% CI, 0.56 to 1.18) (Figure 37). There was evidence of extreme heterogeneity, with a Q-value of 15.26 for 5 degrees of freedom, p=0.009. The I^2^ value was 67.23.

Figure 37 Meta-analysis of glycoprotein inhibitor versus unfractionated heparin on recurrent ischemia at 30 days

CI = confidence interval; GPI = glycoprotein inhibitor

This figure displays a forest plot of a random-effects meta-analysis of six studies that shows an odds ratio of 0.81 (95% CI, 0.56 to 1.18).

A fixed-effects model had minimal changes to the summary estimate, with an odds ratio of 0.98 (95% CI, 0.83 to 1.16). Similar to the other outcomes, we performed the subgroup sensitivity analyses and the results are shown in Table 18 (forest plot appears in Appendix I).

Table 18 Sensitivity analysis of glycoprotein inhibitor versus unfractionated heparin on recurrent ischemia up to 30 days

Study Characteristic | Number of Studies (Patients)^a^ | Summary Estimate (95% CI)
Trial Size
Small (<1000 patients) | 4 (648) | OR 0.51 (0.26 to 1.02)
Large (≥1000 patients) | 2 (5107) | OR 1.11 (0.84 to 1.47)
Antiplatelet Use
Aspirin monotherapy | 5 (5454) | OR 0.97 (0.83 to 1.17)
Dual antiplatelet therapy | 1 (301) | OR 0.93 (0.55 to 1.58)

CI = confidence interval

a Subgroup summary estimates with fewer than three studies should be interpreted with caution.

Studies with smaller sample sizes favored GPI plus UFH, while larger studies did not. Note that the quality of the studies was highly correlated with study size, and that the use of dual antiplatelet therapy was highly correlated with publication year. We did not, however, find evidence of publication bias. The use of aspirin monotherapy showed no statistical difference between the two treatment strategies. Thus the heterogeneity is due to the size of the trial but not to the type of antiplatelet used. Again, the similarity between the fixed and random effects summary estimates shows that there is no statistical heterogeneity. Overall, the rates of recurrent ischemia/angina were lower in the GPI group from these six RCTs with inconsistent results of a direct outcome with wide confidence interval, thus leading us to conclude that the SOE was insufficient.

##### Effect on Revascularization up to 30 Days

Two fair-quality RCTs40,117 with a total of 279 UA/NSTEMI patients reported the revascularization rates at up to 30 days. The Okmen study117 found low numbers of in-hospital revascularization events (1 event in the tirofiban group and none in the heparin group). The Momtahen study40 found a revascularization rate of zero in the epitfibatide group and 4 percent (4 out of 98) in the heparin group at 30 days. Given the low number of events in both studies, the evidence for the effectiveness on revascularization is inconclusive and insufficient.

##### Effect on Major Bleeding up to 30 Days

Seven RCTs (5 good quality, 2 fair) with a total of 37,593 UA/NSTEMI patients reported major bleeding events either in-hospital or at 30 days.40,62,117,120,122-124 In the PURSUIT study122 the rate of TIMI-criteria major bleeding was higher in the eptifibatide group (10.6%) compared with heparin (9.1%). In the PRISM study,123 the rates of major bleeding were similar in the tirofiban and heparin groups (both 0.4%). In the PRISM-PLUS study,124 the rates of major bleeding were similar in the heparin and tirofiban plus heparin group, both by study definition (3.0% vs. 4.0%) and TIMI criteria (0.8% and 1.4%). The Okmen study117 reported zero in-hospital major bleeding events in both the tirofiban and heparin groups. The GUSTO-IV study120 reported in-hospital major bleeds of 0.6 percent with abciximab 24-hour infusion, 1.0 percent with abciximab 48-hour infusion, and 0.3 percent in the heparin group. The Momtahen study40 found no major bleeding events at 30 days in either the eptifibatide or heparin groups. In the ACUITY study62 subgroup that received medical therapy the rates of major bleeding at 30 days were 2.5 percent in the group receiving bivalirudin alone and 4.4 percent in the group receiving GPI with UFH (RR 0.57; 95% CI, 0.38 to 0.84) favoring bivalirudin. In the ACUITY TIMING110 subgroup that received medical therapy, the rates of major bleeding at 30 days were 2.6 percent in the deferred GPI group and 3.7 percent in the upstream GPI group (HR 0.70; 95% CI, 0.47 to 1.05), favoring deferred GPI. Thus major bleeding rates appear higher from longer infusion of GPI, lower in patients receiving bivalirudin alone and higher in patients who received upstream GPI.

A random-effects meta-analysis of 4 good-quality studies in 23,855 patients reporting major bleeding rates at 30 days found that the odds ratio was 1.13 (95% CI, 0.80 to 1.59), favoring heparin alone (Figure 38). There was no evidence of heterogeneity, with a Q-value of 4.927 for 3 degrees of freedom, p=0.18. The I^2^ value was 39.11. A fixed-effects model gave a summary odds ratio of 1.17 (95% CI, 1.02 to 1.33), which is similar to the random-effects model (therefore, no statistical heterogeneity). All studies were large RCTs that used aspirin monotherapy, and so a sensitivity analysis by these factors was not performed. The evidence for the effect of GPIs on major bleeding in the conservatively managed group is insufficient, with most trials reporting similar rates of major bleeding between the GPI and heparin groups. Since the studies by Okmen and Momtahen had no events in either group, they were not included in this meta-analysis. Also, the ACUITY study compared bivalirudin to GPI, and the ACUITY TIMING subgroup study compared deferred and upstream GPI use, so those studies were not included in this meta-analysis.

Figure 38 Meta-analysis of glycoprotein inhibitor versus unfractionated heparin on major bleeding up to 30 days

CI = confidence interval; GPI = glycoprotein inhibitor

This figure displays a forest plot of a random-effects meta-analysis of four studies that show an odds ratio of 1.13 (95% CI 0.80 to 1.59).

##### Effect on Minor Bleeding up to 30 Days

Five RCTs40,117,120,122,123 (three good quality, two fair) with a total of 22,259 UA/NSTEMI patients reported minor bleeding events up to 30 days. In the PURSUIT study122 the minor bleeding rate was higher in the eptifibatide group compared with heparin (12.9% vs. 7.4%). In the PRISM study123 the rates of minor bleeding were similar in the tirofiban and heparin groups (2.0% and 1.9% respectively). The GUSTO-IV study120 reported in-hospital minor bleeds of 3percent with abciximab 24-hour infusion, 4 percent with abciximab 48-hour infusion, and 2 percent in the heparin group. The Okmen study117 reported an in-hospital minor bleeding rate of 5% in both the tirofiban and heparin groups. The Momtahen study40 found a minor bleeding rate of 7% in the epitfibatide group and 0% in the heparin group at 30 days. Thus, minor bleeding is common with administration of GPI.

A random-effects meta-analysis of 5 studies in 22,259 patients reporting minor bleeding rates at 30 days found that the odds ratio was 1.62 (95% CI, 1.20 to 2.19), favoring heparin alone (Figure 39). There was no evidence of heterogeneity, with a Q-value of 7.14 for 4 degrees of freedom, p=0.13. The I^2^ value was 43.94.

Figure 39 Meta-analysis of glycoprotein inhibitor versus unfractionated heparin on minor bleeding up to 30 days

CI = confidence interval; GPI = glycoprotein inhibitor

This figure displays a forest plot of a random-effects meta-analysis of five studies that shows an odds ratio of 1.62 (95% CI, 1.20 to 2.19), favoring heparin alone.

A fixed-effects model had minimal changes to the summary estimate, with an odds ratio of 1.78 (95% CI, 1.56 to 2.02). Similar to the other outcomes, we performed a subgroup sensitivity analysis and the results are shown in Table 19 (forest plot appears in Appendix I).

Table 19 Sensitivity analysis of glycoprotein inhibitor versus unfractionated heparin on minor bleeding up to 30 days

Study Characteristic | Number of Studies (Patients)^a^ | Summary Estimate (95% CI)
Trial Size
Small (<1000 patients) | 2 (279) | OR 3.33 (0.23 to 48.23)
Large (≥ 1000 patients) | 3 (21,980) | OR 1.61 (1.20 to 2.15)
Antiplatelet Use
Aspirin monotherapy | 4 (22,063) | OR 1.62 (1.25 to 2.09)
Dual antiplatelet therapy | 1 (196) | OR 16.15 (0.91 to 286.74)

CI = confidence interval

a Subgroup summary estimates with fewer than three studies should be interpreted with caution.

Studies with larger or smaller sample sizes both favored heparin. The use of aspirin monotherapy also favored heparin. Thus, there was no clinical heterogeneity. Again, the similarity between the fixed and random effects summary estimates shows that there is no statistical heterogeneity. Given the consistent results in five RCTs with a narrow CI, the SOE was rated high for the effect of GPIs on minor bleeding, with fewer minor bleeds in the heparin group.

##### Findings by Subgroup (KQ 2c)

Four good-quality RCTs (PURSUIT, PRISM, PRISM PLUS, and GUSTO)120,122-124 with 23,855 UA/NSTEMI patients evaluated the effectiveness of GPIs in relation to key subgroups, namely patient factors related to diabetes (4 studies), sex (4 studies), age (4 studies), geographic location (2 studies), smoking status (2 studies) and weight (1 study). Table H-2 in Appendix H presents the results data for these subgroups. Of note, the ACUITY and ACUITY-TIMING study results reported above were from the subgroup of patients who received medical management; therefore, further subgroup analyses on the medically-managed population were not reported.

###### Diabetes

Four studies assessed the study primary composite endpoint in patients with or without diabetes. The PURSUIT study122 found a higher reduction in composite ischemic events in patients without diabetes receiving eptifibatide; there was also a reduction in events in diabetic patients and favoring eptifibatide but the results were nonsignificant. The PRISM study123 reported that patients with diabetes benefitted more than patients without diabetes from tirofiban treatment from the reduction in composite ischemic events. The PRISM-PLUS study124 reported a statistically significant benefit of tirofiban plus heparin compared with heparin alone in patients without diabetes. There was also a reduction in composite events in diabetic patients receiving tirofiban and heparin but the finding was not statistically significant. The GUSTO-IV study120 found no statistically significant difference between abciximab and heparin in patients with and without diabetes, although the event rates were lower in patients receiving abciximab.

###### Sex

Four studies assessed the study primary composite endpoint in men and women. The PURSUIT study122 found a reduction in composite ischemic events in men who received eptifibatide; however women in the heparin group had fewer events, OR 1.10 (95% CI, 0.91 to 1.34). The PRISM study123 reported a reduction in composite ischemic events in both men and women treated with tirofiban. The PRISM-PLUS study124 reported a statistically significant benefit of tirofiban plus heparin compared with heparin alone in male and female patients. The GUSTO-IV study120 found no significant difference between abciximab and heparin in men and women who received a 24-hour infusion of the drug; however, women receiving a 48-hour infusion fared worse with abciximab (10.1% vs. heparin 7.2%).

###### Age

Four studies assessed the study primary composite endpoint in different age subgroups. The PURSUIT study122 found statistically fewer events in patients <65 years of age favoring eptifibatide. Patients age 65 or older also benefitted from eptifibatide but the findings were nonsignificant. The PRISM study123 reported a reduction in composite ischemic events across all age groups (<65, 65-74, >75 and >65 years of age) in those treated with tirofiban, with the results being statistically significant in patients older than 65 years of age. The PRISM-PLUS study124 reported a statistically significant benefit of tirofiban plus heparin compared with heparin alone in patients under age 65 and 65 years of age or over. The GUSTO-IV study120 found no significant difference between abciximab and heparin in patients under age 65 or 65 years of age or over.

###### Geographic Location

Two studies assessed the study primary composite endpoint in different geographic regions. The PURSUIT study122 found a greater reduction in composite event rates from patients treated in North America with eptifibatide; there were also fewer composite events in patients from Western Europe, Eastern Europe, and Latin America, but the smaller sample sizes made the finding nonsignificant. The PRISM study123 reported a reduction in composite events in patients from the US and other countries treated with tirofiban.

###### Smoking Status

Two studies assessed the study primary composite endpoint based on smoking status. The PRISM study123 reported a statistically significant reduction in composite ischemic events in patients who received tirofiban and who never smoked; there was also a reduction in events in former and current smokers, but the findings were nonsignificant in both groups. The PRISM-PLUS study124 reported a benefit of tirofiban plus heparin compared with heparin alone in smokers and nonsmokers; however the finding in smokers was statistically nonsignificant.

###### Weight

The GUSTO-IV study120 analyzed the effect of abciximab on the composite endpoint of death or MI based on weight subgroups and found no significant difference between abciximab and heparin in patients under 75 kg, between 75 and 90 kg, or over 90 kg.

##### Summary of Results for Glycoprotein Inhibitor Plus Unfractionated Heparin Versus Unfractionated Heparin Alone

In our analysis of studies comparing GPIs with UFH, we present the findings of UA/NSTEMI patients who received primarily initial conservative treatment. Adding GPIs to UFH reduced the rate of mortality, composite ischemic events, and nonfatal MI, especially in trials of eptifibatide and tirofiban, and increased the rate of minor bleeding at 30 days. The addition of abciximab to UFH did not significantly reduce ischemic events compared with UFH alone. There was insufficient evidence for the effect of GPIs on recurrent ischemia, major bleeding, and revascularization, although fewer revascularization events were seen in patients receiving GPIs in two small trials. A sensitivity analysis subgrouping the studies by trial size (small, <1,000 patients; large, ≥1,000 patients) and antiplatelet use (aspirin monotherapy vs. dual antiplatelet therapy) showed that these two factors helped to explain the heterogeneity, if present, in the meta-analyses performed. For the mortality, nonfatal MI, and recurrent ischemia endpoints at 30 days, the smaller sized studies had summary estimates that were more favorable for GPI plus UFH. For the mortality and nonfatal MI endpoints at 30 days, the use of DAPT had summary estimates that were more favorable for GPI plus UFH.

Subgroups analyzed were diabetes, sex, age, geographic location, smoking status, and weight. Almost all subgroups experienced a reduction in composite ischemic events from adding GPI therapy to heparin (UFH or low molecular weight heparin). While some subgroups may have had a greater magnitude of benefit, there did not appear to be a significant interaction between the assigned treatment and demographic or clinical variables. Notable exceptions included the PURSUIT trial, where women in the heparin group had fewer ischemic events than the eptifibatide group (statistically nonsignificant), and the GUSTO IV study where women treated with a 48-hour infusion of abciximab had higher event rates. Detailed SOE ratings are shown in Table 20. Odds ratios less than 1 favor GPI plus UFH; odds ratios greater than 1 favor UFH alone.

Table 20 Detailed strength of evidence for UA/NSTEMI patients treated with glycoprotein inhibitor plus unfractionated heparin versus unfractionated heparin alone

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI) Odds ratios less than 1 favor GPI plus UFH; odds ratios greater than 1 favor UFH alone
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI) Odds ratios less than 1 favor GPI plus UFH; odds ratios greater than 1 favor UFH alone
Composite Ischemic Endpoints up to 30 Days | | | | | Moderate SOE
10 (38,518) | 10 RCTs/7 good quality, 3 fair | Consistent | Direct | Imprecise | Studies of eptifibatide and tirofiban showed a consistent reduction in composite events compared with UFH alone (RRs 0.58 to 0.84, favoring eptifibatide or tirofiban); one large trial of abciximab showed no difference in events (24 hr, OR 1.00, CI 0.83 to 1.24; 48 hr, OR 1.10, CI 0.94 to 1.39), while a small trial showed a reduction in major events with abciximab (1 out of 30) versus UFH alone (7 out of 30). Favors GPI plus UFH
Mortality up to 30 Days | | | | | High SOE
9 (24,699) | 9 RCTs/6 good quality, 3 fair | Consistent | Direct | Precise | OR 0.80 (0.67 to 0.96) Favors GPI plus UFH
Nonfatal MI up to 30 Days | | | | | Moderate SOE
9 (24,699) | 9 RCTs/6 good quality,3 fair | Inconsistent | Direct | Precise | OR 0.79 (0.61 to 1.02) Favors GPI plus UFH
Recurrent Ischemia up to 30 Days | | | | | Insufficient SOE
6 (5755) | 6 RCTs/4 good quality, 2 fair | Inconsistent | Direct | Imprecise | OR 0.81 (0.56 to 1.18)
Revascularization up to 30 Days | | | | | Insufficient SOE
2 (279) | 2 RCTs/Both fair quality | Consistent | Direct | Imprecise | Low number of events reported in both RCTs, with fewer in GPI plus UFH group
Major Bleeding up to 30 Days | | | | | Insufficient SOE
7 (37,953) | 7 RCTs/5 good quality. 2 fair | Consistent | Direct | Imprecise | OR 1.13 (0.80 to 1.59)
Minor Bleeding up to 30 Days | | | | | High SOE
5 (22,259) | 5 RCTs/3 good quality, 2 fair | Consistent | Direct | Precise | OR 1.62 (1.20 to 2.19) Favors heparin alone

CI = confidence interval; GPI = glycoprotein inhibitor; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction; UFH = unfractionated heparin

#### 3 Clopidogrel Versus Ticagrelor or Prasugrel (KQ 2b)

Two good-quality RCTs evaluated the use of clopidogrel versus ticagrelor or prasugrel in 12,459 patients with UA/NSTEMI.128,129 These trials were in patients undergoing an initial conservative strategy. Proportions of patients proceeding to revascularization ranged from 7.9 percent128 to 24 percent.129

One RCT (PLATO trial) compared ticagrelor with clopidogrel and included a total of 5216 conservatively managed patients.129 The other RCT (7243 patients; TRILOGY ACS trial) compared prasugrel with clopidogrel.128 The PLATO study included 8.7% STEMI patients, with the majority comprised of either NSTEMI (56%) or UA patients (35%). The TRILOGY study population consisted of only UA/NSTEMI patients and the primary analysis was based on the 7243 patients under the age of 75 therefore the results of this primary analysis population are reported in this section.

Study duration ranged from 12 to 30 months. The median age of study participants ranged from 65 to 66 years of age. The proportion of female patients ranged from 36 to 39 percent. Neither study reported the racial and ethnic demographics of study. The RCTs were both multi-center, representing an international patient population including North America, Europe, and Asia. Both RCTs were industry-sponsored. The full results across all outcomes are reported in Table G-11 in Appendix G.

##### Effect on Composite Ischemic Endpoints up to 30 Months

The PLATO RCT (good quality, 5216 patients)129 found lower rates of cardiovascular death, MI, or cerebrovascular accident (primary endpoint) in the ticagrelor group (12.0%) compared with the clopidogrel group (14.3%) at 12 months, HR 0.85 (95% CI, 0.73 to 1.00), p=0.04. The TRILOGY ACS RCT (good quality, 7243 patients)128 found similar rates of cardiovascular death, MI, or stroke (primary endpoint) in the prasugrel group (13.9%) and clopidogrel groups (16.0%) at a median followup of 17 months (or 30 months total followup), HR (95% CI, 0.79 to 1.05), p=0.21. Compared with clopidogrel, the evidence for a benefit of ticagrelor but similar effectiveness of prasugrel on composite outcomes is moderate (both studies meet OIS, optimum information size, criteria).

##### Effect on Mortality up to 30 Months

The PLATO RCT (good quality, 5216 patients)129 found lower rates of mortality in the ticagrelor group (6.1%) compared with the clopidogrel group (8.2%) at 12 months, HR 0.75 (95% CI, 0.61 to 0.93), p=0.01. The TRILOGY ACS RCT (good quality, 7243 patients)128 found similar mortality rates in the prasugrel (7.8%) and clopidogrel (8.1%) at 30 months, HR 0.96 (95% CI, 0.79 to 1.16), p=0.63. Compared with clopidogrel, the evidence for a benefit of ticagrelor but similar effectiveness of prasugrel on mortality is moderate (both studies meet OIS criteria).

##### Effect on Nonfatal MI up to 30 Months

The PLATO RCT (good quality, 5216 patients)129 found similar rates of nonfatal MI in the ticagrelor group (7.2%) compared with the clopidogrel group (7.8%) at 12 months, HR 0.94 (95% CI, 0.77 to 1.15), p=0.56. The TRILOGY ACS RCT (good quality, 7243 patients)128 found similar nonfatal MI rates in the prasugrel (8.3%) and clopidogrel (10.5%) at 30 months, HR 0.89 (95% CI, 0.74 to 1.07), p=0.21. The evidence for the effectiveness on nonfatal MI is moderate for ticagrelor and for prasugrel (both studies meet OIS criteria).

##### Effect on Stroke up to 30 Months

The PLATO RCT (good quality, 5216 patients)129 found similar rates of stroke in the ticagrelor group (2.1%) compared with the clopidogrel group (1.7%) at 12 months, HR 1.35 (95% CI, 0.89 to 2.07), p=0.16. The TRILOGY ACS RCT (good quality, 7243 patients)128 found similar stroke rates in the prasugrel (2.2%) and clopidogrel (1.5%) at 30 months, HR 0.67 (95% CI, 0.42 to 1.06), p=0.08. The evidence for the effectiveness on nonfatal MI is insufficient for ticagrelor and for prasugrel (neither study meets OIS criteria).

##### Effect on Revascularization up to 12 Months

The PLATO RCT (good quality, 5216 patients)129 found similar rates of PCI (28.4% ticagrelor, 29.7% clopidogrel) and CABG (11.0% ticagrelor, 10.4% clopidogrel) between the groups at 12 months. The evidence for the effectiveness on revascularization is moderate for ticagrelor (meets OIS criteria).

##### Effect on Major Bleeding up to 30 Months

The PLATO RCT (good quality, 5216 patients 129 found numerically higher rates of major bleeding with ticagrelor (11.9%) compared with clopidogrel (10.3%) at 12 months, HR 1.17 (95% CI, 0.98 to 1.39, p=0.08. The TRILOGY ACS RCT (good quality, 7243 patients)128 found similar TIMI criteria major bleeding rates in the prasugrel (2.1%) and clopidogrel (1.5%) groups at 30 months, HR 1.31 (95% CI, 0.81 to 2.11), p=0.27. The evidence for the effectiveness on major bleeding is moderate for ticagrelor (meets OIS) and insufficient for prasugrel (does not meet OIS).

##### Effect on Major or Minor Bleeding up to 30 Months

The PLATO RCT (good quality, 5216 patients)129 found higher major or minor bleeding rates in the ticagrelor group (16.4%) compared with clopidogrel (14.4%) at 12 months, HR 1.17 (95% CI, 1.01 to 1.36), p=0.04. The TRILOGY ACS RCT (good quality, 7243 patients)128 found higher TIMI criteria major or minor bleeding rates in the prasugrel (3.3%) and clopidogrel (2.1%) groups at 30 months, HR 1.54 (95% CI, 1.06 to 2.23), p=0.02. The evidence for the effectiveness on major or minor bleeding is moderate for ticagrelor (meets OIS) and low for prasugrel.

##### Findings by Subgroup (KQ 2c)

One good-quality RCT128 with a total of 7243 UA/NSTEMI patients under the age of 75 years evaluated the effectiveness of antiplatelet therapy on the primary composite endpoint (CV death, MI, or stroke) and TIMI criteria major bleeding events in relation to key subgroups, namely patient factors related to diabetes (yes or no), sex (female or male), age (<65 yr or ≥ 65 yr) , geographic location (multiple international regions), smoking status (current or not current), aspirin dose at randomization (<100 mg/d or ≥100 mg/d), PPI at randomization, previous history of MI, PCI, CABG, or PAD, creatinine clearance, GRACE risk score, clopidogrel use, and weight(<60 kg or ≥ 60 yr). Table H-2 in Appendix H presents the results data for these subgroups. The rates of the primary composite endpoint did not differ significantly among most of the prespecified subgroups, however there was a treatment interaction favoring prasugrel among 3 subgroups: current/recent smokers (HR 0.54; 95% CI, 0.39 to 0.74, p<0.001), those undergoing angiography prior to randomization (HR 0.77; 95% CI, 0.61 to 0.98, p=0.08), and those taking PPIs at randomization (HR 0.70; 95% CI, 0.53 to 0.92, p=0.02). For the TIMI criteria major bleeding endpoint, the only subgroup with a significant treatment interaction favoring those receiving clopidogrel with a reduced dose of aspirin (HR 4.56; 95% CI, 1.31 to 15.89, p=0.02). Note that the subgroup findings for the PLATO population54,129 were reported for the overall (invasive and noninvasive) population, and are described in KQ 1 (comparison 3) of this report.

##### Summary of Results for Clopidogrel Versus Ticagrelor or Prasugrel

In our analysis of studies comparing clopidogrel versus ticagrelor or prasugrel, we present the findings of UA/NSTEMI patients who received initial conservative treatment. Ticagrelor reduced the rates of composite ischemic and all-cause mortality events; however, ticagrelor also increased rates of major bleeding, and the combination of major or minor bleeding events. In contrast, prasugrel and clopidogrel had similar rates of composite ischemic and most individual clinical outcomes, except that there was a higher rate of TIMI criteria combined major or minor bleeding event rate in the prasugrel group at 30 months. Multiple subgroups were analyzed in the TRILOGY ACS study and found a treatment interaction favoring prasugrel among current/recent, those undergoing angiography prior to randomization, and those taking PPIs at randomization on the primary composite endpoint. For the TIMI criteria major bleeding endpoint, the only subgroup with a significant treatment interaction favored those receiving clopidogrel with a reduced dose of aspirin. Detailed SOE ratings are shown in Table 21.

Table 21 Detailed strength of evidence for UA/NSTEMI patients treated with clopidogrel versus ticagrelor or prasugrel

Number of Studies (Patients) | Domains | | | | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Strength of Evidence Magnitude of Effect Effect Estimate (95% CI)
Composite ischemic Endpoints up to 30 Months
Ticagrelor vs. clopidogrel 1 (5216) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.85 (0.73 to 1.00) Favors ticagrelor
Prasugrel vs. clopidogrel 1 (7243) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.91 (0.79 to 1.05) No difference
Mortality up to 30 Months
Ticagrelor vs. clopidogrel 1 (5216) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.75 (0.61 to 0.93) Favors ticagrelor
Prasugrel vs. clopidogrel 1 (7243) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.96 (0.79 to 1.16) No difference
Nonfatal MI up to 30 Months
Ticagrelor vs. clopidogrel 1 (5216) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.94 (0.77 to 1.15) No difference
Prasugrel vs. clopidogrel 1 (7243) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 0.89 (0.74 to 1.07) No difference
Stroke up to 30 Months
Ticagrelor vs. clopidogrel 1 (5216) | RCT/Good quality | NA | Direct | Imprecise | Insufficient SOE HR 1.35 (0.89 to 2.07) Insufficient evidence due to imprecision
Prasugrel vs. clopidogrel 1 (7243) | RCT/Good quality | NA | Direct | Imprecise | Insufficient SOE HR 0.67 (0.42 to 1.06) Insufficient evidence due to imprecision
Revascularization up to 12 Months
Ticagrelor vs. clopidogrel 1 (5216) | RCT/Good quality | NA | Direct | Unknown | Moderate SOE No difference
Major Bleeding up to 30 Months
Ticagrelor vs. clopidogrel 1 (5216) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 1.17 (0.98 to 1.39) Favors clopidogrel
Prasugrel vs. clopidogrel 1 (7243) | RCT/Good quality | NA | Direct | Imprecise | Insufficient SOE HR 1.31 (0.81 to 2.11) Insufficient evidence due to imprecision
Major or Minor Bleeding up to 30 Months
Ticagrelor vs. clopidogrel 1 (5216) | RCT/Good quality | NA | Direct | Precise | Moderate SOE HR 1.17 (1.01 to 1.36) Favors clopidogrel
Prasugrel vs. clopidogrel 1 (7243) | RCT/Good quality | NA | Direct | Imprecise | Low SOE HR 1.54 (1.06 to 2.23) Favors clopidogrel

CI = confidence interval; GPI = glycoprotein inhibitor; HR = hazard ratio; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction; UFH = unfractionated heparin

## Key Question 3 Postdischarge Treatment for UA/NSTEMI

KQ 3: In patients treated for UA/NSTEMI after hospitalization (postdischarge):

a. What are the comparative effectiveness (dose and duration) and comparative safety of the available oral antiplatelet agents given in combination with aspirin? Do the effectiveness and safety vary based on the dose of aspirin used?
b. What are the comparative effectiveness and comparative safety of proton pump inhibitors (PPIs) for reducing bleeding events in patients receiving dual antiplatelet therapy after UA/NSTEMI? Do the effectiveness and safety vary by oral antiplatelet therapy and PPI?
c. In patients with an indication for long-term anticoagulant therapy, what are the comparative effectiveness and comparative safety of adding an oral anticoagulant to aspirin and another antiplatelet agent for improving cardiovascular outcomes?
d. Based on demographic and other characteristics, are there subgroups of patients for whom the effectiveness and safety differ?

### Key Points

#### Low-Dose Versus High-Dose Aspirin (KQ 3a)

- In the postdischarge setting, high-dose aspirin was associated with fewer nonfatal MIs and more major bleeding events than low-dose aspirin at 6 months (low SOE for both outcomes). Evidence for all other outcomes was insufficient.

#### Single Antiplatelet Versus Dual Antiplatelet Therapy (KQ 3a)

- DAPT reduced the rates of composite ischemic outcomes and nonfatal MI compared with single antiplatelet therapy from in-hospital up to 1 year (high SOE).
- DAPT reduced all-cause mortality to 1 year compared with single antiplatelet therapy from in-hospital up to 1 year (moderate SOE).

#### Short-Term Versus Long-Term Dual Antiplatelet Therapy (KQ 3a)

- There was insufficient evidence for comparing short-term with long-term DAPT for composite ischemic events, all-cause mortality, cardiovascular mortality, nonfatal MI, stroke, revascularization, stent thrombosis, major bleeding, and minor bleeding. The findings were inconclusive because of heterogeneity of DAPT duration, timing of the endpoint measurement, and imprecision.

#### Antiplatelet Therapy With a PPI Versus Antiplatelet Alone (KQ 3b)

- In RCTs that evaluated the specific PPI omeprazole versus placebo and in observational studies assessing the use of diverse PPIs given in combination with DAPT, use of PPIs reduced rates of upper gastrointestinal bleeding (moderate SOE). However, use of PPIs was associated with higher rates of composite ischemic outcomes (death or MI) at 1 year (moderate SOE). There was low SOE that use of PPIs was associated with higher event rates for the following outcomes: composite ischemic events at 1 year, all-cause mortality at 6 years, nonfatal MI at 1 year, stroke at 1 year, revascularization at 1 year, stent thrombosis at 1 year, major bleeding at 1 year, or rehospitalization at 3 months. No difference between groups was seen for all-cause mortality at 1 year (moderate SOE) or revascularization at 6 months (low SOE)
- In observational studies assessing use of PPIs with aspirin monotherapy, there was a higher rate of nonfatal MI events and no difference in stroke events at 1 year in the group receiving any type of PPI (low SOE). These results are based on adjusted hazard ratios to reduce confounding due to patient and clinical characteristics; however, residual confounding cannot be excluded.
- There was insufficient evidence that the type of PPI affected any of the clinical outcomes (composite or individual) from subgroup analyses of observational studies.

#### Dual Antiplatelet Versus Triple Therapy (KQ 3c)

- DAPT reduced rates of nonfatal MI and major bleeding at 1 to 5 years, and triple therapy (dual antiplatelet plus anticoagulant) reduced rates of stroke at 6 months (low SOE). The findings for all other clinical endpoints were rated insufficient SOE due to inconsistency, imprecision of results, or both.

### Description of Included Studies

We identified 71 unique studies that evaluated the comparative effectiveness of antiplatelet medications and anticoagulant medications in 693,025 patients with UA/NSTEMI continuing treatment after hospitalization.14,132-200 Of these studies, 12 were RCTs (8 good quality, 2 fair, 2 poor) and 58 were observational (36 good quality, 16 fair, 6 poor). (Table E-3 in Appendix E details the quality ratings.)

Fifty-three studies were multicenter,14,133-139,143,145,146,148-151,154-161,163,165,166,168,170,173-177,179,180,182-189,191,192,194-200 15 were single-center,140,142,147,152,153,162,164,167,169,171,172,178,181,190,193 and in three studies the number of sites was unclear or not reported.132,141,144 Twenty-five studies included sites in the United States or Canada,133,135,142,145,150,161-163,166,167,169,171-174,176,179,183,185,190-192,194,197,199 31 in Europe,132,134,137,138,143,146-149,152-154,156-158,164,168,175,176,178,180,184-186,188,191,192,194,196-198 13 in Asia,136,139-141,144,155,159,160,176,177,182,195,197 6 in other locations,170,181,187,189,193,201 and in 3 studies the site location was unclear or not reported.14,151,165

A total of 11 studies were funded by industry,14,135,151,156,176,179,185,191,194,197,199 7 were funded by government-only sources,133,159,163,166,173,183,190 15 were funded by nongovernment/nonindustry sources,134,135,137,139-141,143,148,149,152-154,169,186,198 3 had a mix of government and private foundation funding,174,188,196 1 had a mix of government and industry funding,136 and in 33 studies the funding source was either not reported or unclear.132,138,142,144-147,150,155,157,158,160-162,164,165,167,168,170-172,175,177,178,180-182,184,187,189,192,193,195 Table F-3 in Appendix F details the study characteristics, including study design, proportion of UA/NSTEMI patients, antiplatelet/anticoagulant comparison, concomitant therapy, outcomes measured, and study quality.

In the next section, we present the following five comparisons that were assessed in the included studies for KQ 3:

1. Low-dose versus high-dose aspirin (KQ 3a)
  - 6 studies (all observational; 60,904 total patients)
2. Single antiplatelet versus dual antiplatelet therapy (KQ 3a)
  - 7 studies (1 RCT, 6 observational; 173,035 total patients)
3. Short-term versus long-term dual antiplatelet therapy (clopidogrel) (KQ 3a)
  - 11 studies (5 RCTs, 6 observational; 52,121 total patients)
4. Antiplatelet therapy with a PPI versus antiplatelet alone (KQ 3b)
  - 35 studies (4 RCTs, 30 observational; 340,559 total patients)
    a. Dual antiplatelet with and without a PPI
    b. Aspirin monotherapy with and without a PPI
5. Dual antiplatelet therapy alone versus dual antiplatelet plus oral anticoagulant (i.e., triple therapy) (KQ 3c)
  - 14 studies (all observational; 97,067 total patients)

The subgroup findings (KQ 3d) are presented after each comparison.

### Detailed Synthesis

#### 1 Low-Dose Versus High-Dose Aspirin (KQ 3a)

Six observational studies compared low-dose with high-dose aspirin in the postdischarge treatment of UA/NSTEMI patients.142,172,176,192,201,202 One study each compared:

- 81 mg versus 161 to 325 mg aspirin (Harjai et al. study; clopidogrel use was 53% in each group; fair quality; 2,820 patients)142
- 81 mg versus 325 mg aspirin (So et al. study; clopidogrel use 99% in each group; fair quality; 1,840 patients)172
- <162 mg versus ≥162 mg aspirin (Aronow et al. study; ticlopidine/clopidogrel use not permitted except for after revascularization for 30 days or less; good quality; 4,589 patients)176
- <150 mg versus ≥150 mg aspirin (Quinn et al. study; clopidogrel use not reported; good quality; 20,469 patients)192
- ≤100 mg versus 101–199 mg versus ≥200 mg (Peters et al. observational substudy of CURE; aspirin monotherapy or aspirin plus clopidogrel; good quality; 12,562 patients)202
- <300 mg versus ≥300 mg (Mahaffey et al. observational substudy of PLATO, aspirin plus clopidogrel and aspirin plus ticagrelor; good quality; 18,624 patients)201

Of the six observational studies, two (33%) were rated fair quality and four (67%) were good quality. Sample sizes for individual studies ranged from 1840 to 20,469 patients. Study duration ranged from 30 days to 12 months. The mean age of study participants ranged from 62 to 64 years. The proportion of female patients ranged from 27 to 38 percent. Three studies (50%) reported the racial and ethnic demographics of study participants. Two studies (33%) were conducted within the United States or Canada, with the rest international. Funding source was reported in four studies, and all were funded by industry.

These six studies assessed a composite endpoint of all-cause or cardiovascular mortality, nonfatal MI, or stroke in addition to individual endpoints of all-cause or cardiovascular mortality, nonfatal MI, stroke, and major bleeding. All studies, with the exception of the Mahaffey substudy, reported a revascularization endpoint. Table G-12 in Appendix G summarizes the results reported by each study. Because of the heterogeneity of aspirin dosage comparisons, dual antiplatelet use, patient populations, and measured composite outcomes, a quantitative analysis could not be performed. Therefore we discuss the results qualitatively by outcome.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, or Stroke at 6 Months and 1 Year

Only the Quinn study192 (good quality; 20,469 patients) reported the composite outcome of all-cause mortality, nonfatal MI, or stroke at 6 months and found that low-dose aspirin (<150 mg) had similar composite ischemic events compared with high-dose aspirin (≥150 mg) (HR 0.92; 95% CI, 0.79 to 1.07, p=0.28). Given the findings from one observational study with a confidence interval that crosses 1, the SOE was rated insufficient for this composite outcome at 6 months.

The CURE substudy202 (good quality; 12,562 patients) found that at 1 year, patients on aspirin monotherapy receiving a medium-dose aspirin (101–199 mg) had similar composite ischemic events compared with patients receiving a low-dose aspirin (≤100 mg) (9.8% vs. 10.5%; HR 1.0; 95% CI, 0.82 to 1.23). Patients receiving the highest dose (≥200 mg) experienced a higher rate of composite ischemic events compared with those receiving a low dose (13.6% vs. 10.5%; HR 1.3; 95% CI, 1.08 to 1.52). The rate of composite ischemic events was similar across aspirin doses among patients on DAPT (aspirin plus clopidogrel) (medium dose 9.5% vs. low dose 8.6%; HR 1.2; 95% CI, 0.98 to 1.48; high dose 9.8% vs. low dose 8.6%; HR 1.2; 95% CI, 0.95 to 1.40).

The PLATO substudy201 (good quality; 18,624 patients) found that at 1 year, patients on low-dose aspirin (<300mg) had a lower rate of composite ischemic events when treated with ticagrelor compared with patients treated with clopidogrel (HR 0.79; 95% CI, 0.71 to 0.88), while patients on high-dose aspirin (≥300 mg) had fewer events when treated with clopidogrel compared with those treated with ticagrelor (HR1.45; 95% CI, 1.01 to 2.09). The heterogeneity of the aspirin dosage comparisons between the CURE and PLATO substudies, plus the differences in the dual antiplatelet analysis (clopidogrel in CURE and ticagrelor vs. clopidogrel in PLATO), makes it difficult to combine these studies; thus the SOE was rated insufficient for this composite outcome at 1 year.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal Myocardial Infarction, or Revascularization at 1 Year

Three studies142,172,176 (1 good quality, 2 fair; 9249 patients) reported the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 12 months. In general, low-dose aspirin had similar composite event rates as high-dose aspirin. The study by Harjai et al.142 comparing 81 mg of aspirin with 162–325 mg found no significant difference in the composite of death or MI at 1 year (6.7% vs. 6.1%, respectively) or in the composite of death, MI, or stent thrombosis or target vessel revascularization (8.6% vs. 9.2%). Similarly, in the study by So et al.172 comparing 81 mg of aspirin with 325 mg, the risk of death or MI, and death, MI, or revascularization was not significantly different between the two treatment arms (adjusted OR 1.16; 95% CI, 0.73 to 1.85; and adjusted OR 1.08; 95% CI, 0.80 to 1.47). The third study, by Aronow et al.,176 included a mixed population of UA/NSTEMI, STEMI, and stable angina and showed no significant difference in the incidence of the composite endpoint of death, MI, or stroke (HR 0.96; 95% CI, 0.76 to 1.21) and death, MI, stroke, revascularization, or rehospitalization (HR 1.11; 95% CI, 0.97 to 1.28) between aspirin doses of <162 mg compared with ≥162 mg. Thus, composite outcomes at 6 months and 1 year were similar between low-dose and high-dose aspirin in studies that used aspirin monotherapy or dual antiplatelet therapy. While the findings are consistent between these three observational studies the imprecise estimates make the evidence insufficient to detect a difference in this composite outcome at 1 year.

##### Effect on All-Cause Mortality at 6 Months and 1 Year

The Quinn study192 (good quality; 20,469 patients) reported total mortality at 6 months and showed no effect of high-dose aspirin (≥150 mg) on mortality risk compared with lower dose (<150 mg) (HR 0.89; 95% CI, 0.72 to 1.10, p=0.30). Two studies172,176 (1 good quality, 1 fair; 6429 patients) reported 1-year mortality risk. In the So study,172 mortality risk was similar among patients discharged on low-dose aspirin (81 mg) compared with those discharged on a higher dose (325 mg) (adjusted OR 0.88; 95% CI, 0.51 to 1.55, p=0.664) in patients who also received clopidogrel. The Aronow study176 found that high-dose aspirin (≥162 mg) was associated with a significant reduction of all-cause mortality (HR 0.55; 95% CI, 0.37 to 0.83) compared with low-dose aspirin (<162 mg) in a population that received aspirin monotherapy. The SOE for assessing the comparative effectiveness between low- and high-dose aspirin was rated insufficient for all-cause mortality at 6 months and 1 year given the inconsistent and imprecise results.

##### Effect on Nonfatal MI at 6 Months and 1 Year

Two studies176,192 reported nonfatal MI, one at 6 months and the other at 1 year. While the study by Quinn et al.192 found a significant reduction of nonfatal MI events (HR 0.79; 95% CI, 0.64 to 0.98, p=0.03) among patients treated with high-dose of aspirin (≥150 mg vs. <150 mg) at 6 months, the study by Aronow et al.176 comparing similar doses of aspirin found no effect of high-dose versus low-dose (≥162 mg vs. <162 mg) in 1-year mortality (HR 0.98; 95% CI, 0.66 to 1.48). The Quinn study did not report clopidogrel use in the treatment groups, therefore we assume that their findings are based on aspirin monotherapy, while the Aronow study would only permit use of ticlopidine or clopidogrel for 30 days after PCI. The SOE for nonfatal MI at 6 months was rated low based on one large observational study that reported a statistically significant reduction; however, the evidence for nonfatal MI at 1 year was rated insufficient based on a moderate sized observational study with imprecise results.

##### Effect on Stroke at 6 Months and 1 Year

Two studies reported stroke events,176,192 one at 6 months and the other at 1 year. High-dose aspirin was associated with a trend toward higher risk of stroke both at 6 months in the Quinn study192 (≥150 mg vs. <150 mg; HR 1.59; 95% CI, 0.95 to 2.65) and at 1 year in the Aronow study176 (≥162 mg vs. <162 mg; HR 1.37; 95% CI, 0.94 to 2.00).The SOE for the comparative effectiveness of low- versus high-dose aspirin on stroke outcomes at 6 months and 1 year was rated insufficient based on imprecise results from observational studies.

##### Effect on Revascularization at 1 Year

Two studies reported revascularization at 1 year172,176 (1 good quality, 1 fair; 6429 patients). In the So study172 repeat revascularization was similar among patients discharged on low-dose aspirin (81 mg) compared with higher dose (325 mg) when both groups were also treated with clopidogrel (adjusted OR 1.05; 95% CI, 0.74 to 1.51, p=0.772). In the Aronow study176 patients treated with high-dose aspirin (≥162 mg) were more likely to undergo urgent revascularization (HR 1.34; 95% CI, 1.10 to 1.64). The inconsistent and imprecise findings for revascularization outcomes at 1 year resulted in a SOE rating of insufficient.

##### Effect on Major Bleeding at 1 Year

Three studies142,176,202 (2 good quality, 1 fair; 19,971 patients) reported major bleeding at 1 year. The fair-quality study by Harjai142 found a higher TIMI bleeding rate in the group taking low-dose aspirin (81 mg) compared with higher dose (162–325 mg) (3.8% vs. 1.6%); this was due to the higher baseline risk of the patients who received low-dose aspirin, and about half (53%) of the patients in each group had received clopidogrel. The Aronow study176 found a higher incidence of any bleeding among patients treated with high-dose aspirin monotherapy (≥162 mg vs. <162 mg; adjusted HR 1.32; 95% CI, 1.12 to 1.55).

Similarly, the CURE substudy found a higher risk of bleeding among patients receiving a medium-dose aspirin (101–199 mg) or a high-dose aspirin (≥200 mg) when compared with patients receiving a low-dose aspirin (≤ 100 mg), when patients received aspirin monotherapy (2.82% vs. 1.86%; OR 1.52; 95% CI, 1.00 to 2.31, and 3.67% vs. 1.86%; OR 1.7; 95% CI, 1.22 to 2.59, respectively). The CURE substudy also found a higher risk of bleeding on high-dose aspirin compared with low-dose aspirin among patients receiving dual antiplatelet therapy (4.89% vs. 2.97%; OR 1.63; 95% CI, 1.19 to 2.23). For patients receiving dual antiplatelet therapy, no differences in bleeding were found between the medium dose and the low dose (3.41% vs. 2.97%; OR 1.20; 95% CI, 0.84 to 1.73). Although the two good-quality studies both demonstrated a benefit of lower-dose aspirin in terms of major bleeding, the heterogeneity in aspirin dosage and the variable use of dual antiplatelet therapy across studies resulted in a SOE rating of low for an increase in major bleeding with high-dose aspirin outcomes at 1 year.

##### Findings by Subgroup (KQ 3d)

Three studies reported the treatment effectiveness of aspirin dosage by subgroup142,172,201 (Table H-3 in Appendix H). One fair-quality study by So et al.172 comparing aspirin doses in patients also receiving clopidogrel, reported variations in treatment effectiveness by subgroup This study compared the efficacy of low-dose aspirin (81 mg) with high-dose (325 mg) among diabetic patients, patients with multivessel disease, and by type of stent (drug-eluting stent [DES] vs. bare metal stent [BMS]). Patients with diabetes receiving low-dose aspirin had no advantage in terms of death or MI at 1 year (log OR=0) compared with high-dose aspirin. Patients with multivessel disease receiving low-dose aspirin were at higher risk of death or MI when compared with the high-dose aspirin group (p=0.07). Patients in the DES group receiving low-dose aspirin had a similar risk of death or MI (OR 1.12; 95% CI, 0.53 to 2.34) and of death, MI, or revascularization (OR 0.75; 95% CI, 0.46 to 1.25) compared with the high-dose aspirin group. Patients in the BMS group receiving low-dose aspirin were at similar risk of death or MI (OR 1.25; 95% CI, 0.67 to 2.33) and of death, MI, or revascularization (OR 1.38; 95% CI, 0.92 to 2.06) compared with the high-dose aspirin group.

The PLATO substudy reported variations in treatment effectiveness of aspirin dosage when combined with either ticagrelor or clopidogrel for patients located inside and outside the United States.201 When effect by location was evaluated, high-dose aspirin (>300 mg) was not associated with a significant effect on the primary composite endpoint in either U.S. patients (HR 1.62; 95% CI, 0.99 to 2.64) or non-U.S. patients (HR 1.23; 95% CI, 0.71 to 2.14). However, among patients receiving low-dose aspirin (≤300 mg), ticagrelor was associated with statistically significantly lower rates of the primary composite outcome when compared with clopidogrel (HR 0.78, 95% CI, 0.69 to 0.87) in non-U.S. patients versus U.S. patients (HR 0.73; 95% CI, 0.40 to 1.33).

The study by Harjai et al. reported variations in treatment effectiveness of aspirin dosage (81 mg vs. 162–325 mg) for patients with diabetes and those with a DES.142 Results between the low-dose and high-dose aspirin groups were similar, both for patients with diabetes and those with a DES for the outcomes of death, MI, stent thrombosis, revascularization (diabetes: 12.1% low-dose vs. 12.6% high-dose; DES: 6.3% low-dose vs. 6.7% high-dose), or stent thrombosis (diabetes: 2.2% low-dose vs. 2.6% high-dose; DES: 1.7% low-dose vs. 1.8% high-dose). However, the low-dose aspirin groups had a higher incidence of bleeding (diabetes: 6.6% low-dose vs. 2.1% high-dose; DES: 3.5% low-dose vs. 1.3% high-dose). In patients with diabetes, the low-dose aspirin group also had higher rates of death or MI (11.0% low-dose vs. 8.3% high-dose), but there was little difference in death or MI between groups in patients receiving a DES (4.6% low-dose vs. 5.3% high dose).

##### Summary of Results for Low-Dose Versus High-Dose Aspirin

In our analysis of low-dose versus high-dose aspirin, we found insufficient evidence for composite ischemic event rates and all-cause mortality at 6 months and 1 year. Nonfatal MI was lower from high-dose aspirin (≥150 mg vs. <150 mg) at 6 months in one study, but the evidence was insufficient from a second, smaller study at 1 year. Insufficient evidence was also found for stroke rates in these two studies at 6 months and 1 year. There were conflicting results on revascularization rates at 1 year, with one study showing no difference (81 mg vs. 325 mg) and another study showing higher rates of urgent revascularization in the high-dose (≥162 mg) group. The effect on major bleeding at 1 year was also inconsistent, with one fair-quality study reporting higher bleeding rates in the low-dose (81 mg) group and two good-quality studies reporting higher rates in the high-dose group (162 mg or ≥200 mg). Differences in consistency of the results may be that the Harjai142 and So172 studies were smaller, single-center studies that had higher rates of clopidogrel use (53% and 99% respectively) while the Aronow,176 Quinn,192 Peters,202 and Mahaffey201 studies were secondary analyses of larger RCTs (i.e., BRAVO, Gusto IIb, and PURSUIT, CURE, and PLATO)—one of which did not allow use of thienopyridines, one study did not report its use, one study reported results for aspirin monotherapy and dual antiplatelet therapy, and one study had only dual antiplatelet with two different thienopyridine medications In addition, the doses of aspirin compared differed among the six studies. Subgroup analyses included diabetes, multivessel disease, and type of stent from one study comparing low-dose aspirin (81 mg) with high-dose (325 mg) in addition to clopidogrel; geographic location from one study comparing low-dose aspirin (<300 mg) with high-dose (≥300 mg) in patients receiving either ticagrelor or clopidogrel; and diabetes and type of stent from one study comparing low-dose aspirin (81 mg) with high-dose aspirin (161–325 mg). Patients with multivessel disease had higher events rates on low-dose aspirin; however, patients with diabetes, drug-eluting stents, and bare metal stents had similar event rates on low-dose and high-dose aspirin as part of a dual antiplatelet treatment strategy. Patients on low-dose aspirin (<300 mg) and ticagrelor had lower events rates than those on low-dose aspirin and clopidogrel. Patients with diabetes and those with a DES receiving low-dose aspirin both had an increased incidence of bleeding, while patients with diabetes on low-dose aspirin also had an increased rate of death or MI. Detailed SOE ratings are shown in Table 22.

Table 22 Detailed strength of evidence for UA/NSTEMI patients treated with low-dose versus high-dose aspirin

Number of Studies (Patients) | Domains | | | | SOE and Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality, Nonfatal MI, or Stroke at 6 Months | | | | | Insufficient SOE
1 (20,469) | Observational/Good quality | NA | Direct | Precise | HR 0.92 (0.79 to 1.07) Insufficient evidence due to confidence interval that crosses 1
Composite of All-Cause Mortality, Nonfatal MI, or Stroke at 1 Year | | | | | Insufficient SOE
2 (31,186) | 2 observational/Both good quality | Inconsistent | Direct | Imprecise | Insufficient evidence due to inconsistency and imprecision. One study showed similar rates of composite events across 3 dosage categories for aspirin monotherapy and dual antiplatelet therapy; the other study showed lower event rates when combining low-dose aspirin with ticagrelor and high-dose aspirin with clopidogrel.
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 1 Year | | | | | Insufficient SOE
3 (9249) | 3 observational/1 good quality, 2 fair | Consistent | Direct | Imprecise | Insufficient evidence due to imprecision. Low-dose aspirin and high-dose aspirin had similar rates of ischemic events in all 3 studies.
All-Cause Mortality at 6 Months | | | | | Insufficient SOE
1 (20,469) | Observational/Good quality | NA | Direct | Imprecise | HR 0.89 (0.72 to 1.10) Insufficient evidence due to imprecision
All-Cause Mortality at 1 Year | | | | | Insufficient SOE
2 (6429) | 2 observational/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | Insufficient evidence due to inconsistency and imprecision. One study (aspirin/clopidogrel) showed no difference between doses, the other found that high-dose aspirin (monotherapy) reduced mortality.
Nonfatal MI at 6 Months | | | | | Low SOE
1 (20,469) | Observational/Good quality | NA | Direct | Precise | HR 0.79 (0.64 to 0.98) Favors high-dose aspirin
Nonfatal MI at 1 Year | | | | | Insufficient SOE
1 (4589) | Observational/Good quality | NA | Direct | Imprecise | HR 0.98 (0.66 to 1.48) Insufficient evidence due to imprecision.
Stroke at 6 Months | | | | | Insufficient SOE
1 (20,469) | Observational/Good quality | NA | Direct | Imprecise | HR 1.59 (0.95 to 2.65) Insufficient evidence due to imprecision.
Stroke at 1 Year | | | | | Insufficient SOE
1 (4589) | Observational/Good quality | NA | Direct | Imprecise | HR 1.37 (0.94 to 2.00) Insufficient evidence due to imprecision.
Revascularization at 1 Year | | | | | Insufficient SOE
2 (6429) | 2 observational/1 good quality, 1 fair | Inconsistent | Direct | Imprecise | Insufficient evidence due to inconsistency and imprecision. One study (aspirin/clopidogrel) showed no difference between doses, the other study (aspirin monotherapy) showed more events with high dose.
Major Bleeding at 1 Year | | | | | Low SOE
3 (19,971) | 3 observational/2 good quality, 1 fair | Inconsistent | Direct | Imprecise | 1 study had high bleeding rates in low-dose group; 2 studies had high bleeding rates in high-dose group. Favors low-dose aspirin

BMS = bare metal stent; CI = confidence interval; DES = drug-eluting stent; HR = hazard ratio; MI = myocardial infarction; NA = not applicable; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

#### 2 Single Antiplatelet Versus Dual Antiplatelet Therapy (KQ 3a)

Seven studies (one RCT, six observational) compared single antiplatelet with dual antiplatelet therapy in the postdischarge treatment of UA/NSTEMI patients.138,151,160,179,184,191,194 Of these studies, six compared aspirin monotherapy (single antiplatelet) with aspirin plus clopidogrel (dual antiplatelet), and one study contained three arms comparing aspirin monotherapy, clopidogrel monotherapy, and aspirin plus clopidogrel.160 The RCT was rated good quality, and of the six observational studies, two were rated good quality, three fair, and one poor. The RCT (CURE study194) allowed a dose of 75 mg to 325 mg daily. None of the observational studies reported the dose of aspirin used in the patient cohorts. Sample sizes for individual studies ranged from 1,331 to 44,426 patients. Study duration ranged from in-hospital to 12 months.

The mean age of study participants ranged from 64 to 70 years. The proportion of female patients ranged from 27 to 42 percent. None of the studies reported the racial or ethnic demographics of study participants. One study (14%)was conducted solely in the United States, two were conducted in Asia (29%), one was conducted in Europe (14%), and the other three were international (43%). Funding source was reported in five studies, with all five studies funded by industry. Table G-13 in Appendix G contains the results reported by each study.

##### Effect on Composite Ischemic Endpoints In-Hospital to 1 Year

One good-quality RCT and two observational studies (1 fair quality, 1 poor) including 106,749 patients comparing aspirin alone with aspirin plus clopidogrel reported composite outcomes. In the CURE RCT,194 the rate of cardiovascular mortality, nonfatal MI, or stroke and cardiovascular mortality, nonfatal MI, stroke, or refractory ischemia were both significantly lower among patients who were discharged on aspirin plus clopidogrel compared with those on aspirin alone (9.3% vs. 11.4%; RR 0.80; 95% CI, 0.72 to 0.90 and 16.5% vs. 18.8%; RR 0.86; 95% CI, 0.79 to 0.94) at the 9-month followup assessment. In one observational study (CRUSADE registry179), the rate of in-hospital total mortality and nonfatal MI was 5.4 percent for patients receiving aspirin plus clopidogrel and 7.6 percent for patients on aspirin alone (p <0.01). The other observational study (ACOS registry184) showed significantly lower rates of total mortality, nonfatal MI, or nonfatal stroke for patients receiving aspirin plus clopidogrel compared with aspirin alone (OR 0.69; 95% CI, 0.60 to 0.80) at 1-year followup. The consistent, precise, and statistically significant findings across studies favoring DAPT result in a high SOE rating.

##### Effect on Stroke In-Hospital to 1 Year

Four studies (1 good quality RCT and 3 observational, 2 fair quality, 1 poor) including 116,136 total patients reported stroke events within the first 9 months postdischarge. An observational study191 found a similar stroke rate at 6 months after discharge among patients discharged on aspirin alone and those on dual antiplatelet therapy (1.3% vs. 1.0%). In the CRUSADE registry,179 there was a significant reduction in in-hospital stroke in patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (0.7% vs. 1.0% , p<0.01). The ACOS registry184 showed similar rates of stroke for patients receiving aspirin plus clopidogrel compared with aspirin alone (1.88% and 1.98%, respectively) at 1-year followup.

The CURE RCT194 showed a nonsignificant reduction in stroke events at 9 months among patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (1.2% vs. 1.4%; RR 0.86; 95% CI, 0.63 to 1.18). The SOE was rated insufficient for stroke outcomes based on inconsistent and imprecise findings from these four studies.

##### Effect on Nonfatal MI In-Hospital to 1 Year

One good-quality RCT and two observational studies (1 fair quality, 1 poor) including 106,749 patients reported the effect of single versus DAPT on nonfatal MI. The CURE RCT194 showed a significant reduction in nonfatal MI events at 9 months among patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (5.2% vs.6.7%, RR 0.77; 95% CI, 0.67 to 0.89). In the CRUSADE registry,179 there was a significant reduction in postadmission (in-hospital) MI in patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (2.3% vs. 3.0%, p<0.01). The ACOS registry184 showed lower rates of nonfatal MI for patients receiving aspirin plus clopidogrel compared with aspirin alone (5.8% and 8.5%, respectively) at 1-year followup. The SOE was rated high for nonfatal MI outcomes based on consistent, statistically significant results favoring DAPT.

##### Effect on All-Cause Mortality In-Hospital to 1 Year

Five studies (1 good-quality RCT and 4 observational, 1 good quality, 2 fair, 1 poor) including 117,467 patients reported the effect of single versus dual antiplatelet therapy on mortality. One observational study191 reported higher mortality at 6 months among patients discharged on aspirin compared with those discharged on aspirin plus clopidogrel (5.8% vs. 4.45%). Another observational registry160 comparing single antiplatelet treatment (aspirin or clopidogrel) with dual antiplatelet treatment (aspirin plus clopidogrel) showed a significantly lower survival rate at 1 year among patients on single antiplatelet treatment (aspirin 53.9%, clopidogrel 51.9%, and aspirin plus clopidogrel 93.2%). No differences in survival rate were observed when duration of dual antiplatelet treatment was considered (0 to 3 months or 3 to 6 months or 6 to 9 months vs. 9 to 12 months). In the CRUSADE registry,179 there was a significant reduction in in-hospital mortality in patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (3.5% vs. 5.3%, p<0.01). The ACOS registry184 showed a significant reduction in mortality for patients receiving aspirin plus clopidogrel compared with aspirin alone (OR 0.66; 95% CI, 0.55 to 0.80) at 1-year followup. The CURE RCT194 showed a nonsignificant reduction in cardiovascular mortality at 9 months among patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (5.1% vs. 5.5%; RR 0.93; 95% CI, 0.79 to 1.08). The SOE was rated moderate based on consistent but imprecise findings that DAPT reduces all-cause mortality.

##### Effect on Major Bleeding In-Hospital to 9 Months

Two studies (1 good quality RCT, 1 fair observational) including 105,607 patients reported the effect of single versus dual antiplatelet therapy on major bleeding. In the CRUSADE registry,179 there was a significant reduction in in-hospital major bleeding in patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (16.0% vs. 20.6%, p<0.01). The CURE RCT194 showed a nonsignificant reduction in major bleeding at 9 months among patients treated with aspirin plus clopidogrel compared with those treated with aspirin alone (RR 0.93; 95% CI, 0.79 to 1.08). The SOE was rated low for major bleeding outcomes based on consistent and imprecise findings.

##### Findings by Subgroup (KQ 3d)

Four studies138,151,160,194 (one good-quality RCT; 1 good-, 1 fair-, and 1 poor-quality observational studies) reported variations in treatment effectiveness by subgroup. Subgroups analyzed were diabetes (1 study), sex (1), age (1), clinical presentation (1), heart failure (1), revascularization (1), chronic kidney disease (1), aspirin dosing (1), PCI (2), duration of treatment (1), and presence of smoking (1). Table H-3 in Appendix H presents the results data for these subgroups.

###### Diabetes

One RCT194 comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 9 months in the diabetic patients subgroup (n=2,840). Among this subgroup, the rate of the composite outcome was 14.2 percent in the aspirin plus clopidogrel arm and 16.7 percent in the aspirin-only arm.

###### Sex

One study assessed composite ischemic outcomes by sex. The CURE RCT194 comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 9 months by sex. Among men (n=7726), the rate of the composite outcome was 9.1 percent in the aspirin plus clopidogrel arm and 11.9 percent in the aspirin-only arm. Among women (n=4836), the rate of composite outcome was 9.5 percent in the aspirin plus clopidogrel arm and 10.7 percent in the aspirin-only arm.

###### Age

One RCT assessed composite ischemic outcomes by age. The CURE RCT194 comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 9 months by age subgroups (≤65 years vs. >65 years). Among those aged 65 years or less (n=6354), the rate of composite outcome was 5.4 percent in the aspirin plus clopidogrel arm and 7.6 percent in the aspirin-only arm. Among those aged over 65 years (n=6,208), the rate of the composite outcome was 13.3 percent in the aspirin plus clopidogrel arm and 15.3 percent in the aspirin-only arm.

###### Clinical Presentation

One RCT194 comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 9 months by clinical presentation (NSTEMI or UA). Among those with NSTEMI (n=3283), the rate of composite outcome was 11.3 percent in the aspirin plus clopidogrel arm and 13.7 percent in the aspirin-only arm. Among those with UA (n=9279), the rate of composite outcome was 8.6 percent in the aspirin plus clopidogrel arm and 10.6 percent in the aspirin-only arm.

###### Heart Failure

One observational study138 comparing aspirin alone with aspirin plus clopidogrel among patients with acute MI and concomitant heart failure not receiving PCI, found a nonsignificant decreased risk of death among heart failure patients treated with dual therapy compared with those receiving aspirin alone (28.1% vs. 32.2%; HR 0.86; 95% CI, 0.83 to 1.16). The effect of clopidogrel was not significant among the cohort without heart failure (9.4% vs. 9.7%; HR 0.98; 95% CI, 0.83 to 1.16).

###### Revascularization

One RCT194 comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 9 months by revascularization (PCI or CABG) after randomization. Among those receiving revascularization (n=4577), the rate of composite outcome was 11.5 percent in the aspirin plus clopidogrel arm and 13.9 percent in the aspirin-only arm. Among those not receiving revascularization (n=7985), the rate of composite outcome was 8.1 percent in the aspirin plus clopidogrel arm and 10 percent in the aspirin-only arm.

###### Chronic Kidney Disease

One RCT194 comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 9 months among patients with chronic kidney disease (CKD) (defined as creatinine clearance <64 mL/min). Among patients with CKD (n=4087), the rate of the composite outcome was 13.4 percent in the aspirin plus clopidogrel arm and 14.9 percent in the aspirin-only arm (RR 0.89; 95% CI, 0.76 to 1.05). The rate of cardiovascular mortality was 8.3 percent in the aspirin plus clopidogrel arm and 8.7 percent in the aspirin-only arm (RR 0.95; 95% CI, 0.77 to 1.17). The rate of all-cause mortality was 9.6 percent in the aspirin plus clopidogrel arm and 10.0 percent in the aspirin-only arm (RR 0.95; 95% CI, 0.78 to 1.16). The rate of major bleeding was 2.3 percent in the aspirin plus clopidogrel arm and 1.7 percent in the aspirin-only arm (RR 1.37; 95% CI, 0.89 to 2.12), and the rate of minor bleeding was 5.2 percent in the aspirin plus clopidogrel arm and 2.4 percent in the aspirin-only arm (RR 1.5; 95% CI, 1.21 to 1.86).

###### Aspirin Dosing

One RCT194 comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 9 months by aspirin dosing (≤100 mg/day vs. 101 to 199 mg/day). Among those receiving ≤100 mg/day (n=5,320), the rate of the composite outcome was lower in the aspirin plus clopidogrel arm than in the aspirin-only arm (RR 0.81; 95% CI, 0.68 to 0.97), although the rate of major bleed was nonsignificantly higher in the clopidogrel arm (3% vs. 1.9%). Among those receiving 100 to 199 mg/day of aspirin (n=3109), the rate of the composite outcome was not significantly lower in the aspirin plus clopidogrel arm compared with the aspirin arm (RR 0.97; 95% CI, 0.77 to 1.22), and again the rate of major bleed was slightly higher in the clopidogrel arm (3.4% vs. 2.8%).

###### PCI

Two studies (one RCT and one observational study) comparing aspirin alone with aspirin plus clopidogrel in postdischarge UA/NSTEMI patients reported findings by receipt of PCI. In the CURE RCT,194 those receiving PCI had a lower rate of the composite outcome of cardiovascular death, nonfatal MI, or stroke (RR 0.75; 95% CI, 0.56 to 1.00, p=0.047), but higher rates of minor bleeding (RR 1.68; 95% CI, 1.06 to 2.68, p=0.03), and similar rates of major bleeding (RR 1.12; 95% CI, 0.7 to 1.78, p=0.64). The observational study184 reported significantly lower mortality rates in patients who received PCI and were treated with aspirin plus clopidogrel compared with aspirin alone (OR 0.51; 95% CI, 0.33 to 0.77), whereas the group without PCI receiving aspirin plus clopidogrel had a nonsignificant reduction in total mortality compared with aspirin alone (OR 0.90; 95% CI, 0.73 to 1.11).

###### Duration of Treatment

One observational study160 comparing single antiplatelet treatment (aspirin or clopidogrel) with dual antiplatelet treatment (aspirin plus clopidogrel) showed a significantly lower survival rate at 1 year among patients on single antiplatelet treatment (aspirin 53.9%, clopidogrel 51.9%, and aspirin plus clopidogrel 93.2%). No significant differences in survival rate were observed when duration of dual antiplatelet treatment was considered: 0 to 3 months (96.5%), or 3 to 6 months (94.6%), or 6 to 9 months (100%) versus 9 to 12 months (100%).

###### Presence of Smoking

One observational study151 comparing early clopidogrel use to aspirin in an acute coronary syndrome population (30% UA, 34% NSTEMI, and 36% STEMI) evaluated the composite event rate in nonsmokers and current smokers. In both groups, early clopidogrel use was associated with a reduction in the composite endpoint of mortality and MI in-hospital and at 6 months (OR 0.77; 95% CI, 0.6 to 0.95); no interaction between smoking status and ischemic endpoints was found. In addition, current smokers with early clopidogrel use had lower rates of major bleeding (2%) compared with nonsmokers (3.1%).

##### Summary of Results for Single Antiplatelet Versus Dual Antiplatelet Therapy

Our analysis of single antiplatelet versus dual antiplatelet therapy addresses the question about the effectiveness of combinations of antiplatelet agents. The identified literature predominately reports the comparison of aspirin monotherapy (single antiplatelet) with aspirin plus clopidogrel therapy (dual antiplatelet). Use of newer antiplatelet agents (prasugrel, ticagrelor) with aspirin in comparison to clopidogrel plus aspirin was previously summarized under KQ 1; there we presented the findings from direct comparisons of different dual antiplatelet treatment strategies. In the analysis of single versus dual antiplatelet therapy, dual antiplatelet therapy reduces the rates of composite ischemic outcomes and nonfatal MI in UA/NSTEMI patients based on 3 studies (1 RCT and 2 observational registries). While five studies (1 RCT and 4 observational) showed a reduction in all-cause mortality in the dual antiplatelet therapy group, the wide CIs around the reported RRs in many of the studies made this finding less precise than the results on composite ischemic outcomes and nonfatal MI. Four out of five studies (2 RCTs and 3 observational studies) showed no significant difference in stroke rates between dual antiplatelet and single antiplatelet therapy; the evidence for this outcome was rated insufficient. The effect of dual antiplatelet therapy on major bleeding varied in three studies (two RCTs and one observational registry), and was also rated insufficient. Subgroup findings from four studies (two RCTs, two observational registries) assessed the effectiveness based on age, sex, clinical presentation, duration of treatment, receipt of PCI, receipt of any type of revascularization, or presence of diabetes, chronic kidney disease, heart failure, or smoking (one or two studies reported findings for each subgroup listed). Almost all of the studies showed similar rates of composite ischemic outcomes in the various subgroups, except for subgroup analyses of PCI and treatment duration. One study showed a significantly lower rate of composite ischemic outcomes, and another study showed a significantly lower rate of death in patients who received dual antiplatelet therapy and underwent PCI. One study showed a significantly lower survival rate at 1 year in the groups that received single antiplatelet therapy. The SOE for subgroup findings was rated insufficient given the small number of studies reporting results for each subgroup. Detailed SOE ratings are shown in Table 23.

Table 23 Detailed strength of evidence for UA/NSTEMI patients treated with single versus dual antiplatelet therapy

Number of Studies (Patients) | Domains | | | | SOE and Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
Composite Ischemic Endpoints In-Hospital to 1 Year | | | | | High SOE
3 (106,749) | 1 RCT/Good quality 2 observational/1 fair quality, 1 poor | Consistent | Direct | Precise | All studies showed significant lowering of composite events in dual antiplatelet arm, ranging from OR 0.69 to RR 0.86 Favors DAPT
Stroke In-Hospital to 1 Year | | | | | Insufficient SOE
4 (116,136) | 1 RCT/Good quality 3 observational/2 fair quality, 1 poor | Inconsistent | Direct | Imprecise | Insufficient evidence due to inconsistency and imprecision with 3 out of 4 studies showing no statistically significant difference in stroke rates
Nonfatal MI In-Hospital to 1 Year | | | | | High SOE
3 (106,749) | 1 RCT/Good quality 2 observational/1 fair quality, 1 poor | Consistent | Direct | Precise | 2.3% to 5.8% vs. 3.0% to 8.5% Favors DAPT
All-Cause Mortality In-Hospital to 1 Year | | | | | Moderate SOE
5 (117,467) | 1 RCTs/Good quality 4 observational/1 good quality, 2 fair, 1 poor | Consistent | Direct | Imprecise | OR/RR 0.66 to OR/RR 0.93 Favors DAPT
Major Bleeding In-Hospital to 9 Months | | | | | Low SOE
2 (105,607) | 1 RCT/Good quality 1 observational/Fair quality | Consistent | Direct | Imprecise | 2 studies showed a reduction in major bleed in DAPT group (1 statistically significant [16% vs. 21%], 1 not statistically significant) Favors DAPT

CI = confidence interval; DAPT = dual antiplatelet therapy; MI = myocardial infarction; NA = not applicable; RR = risk ratio; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

#### 3 Short-Term Versus Long-Term Dual Antiplatelet Therapy (KQ 3a)

Eleven studies (5 RCTs, 6 observational) compared short-term with long-term dual antiplatelet therapy (clopidogrel plus aspirin) in the postdischarge treatment of UA/NSTEMI patients.134,136,168-171,183,187,193,198,199 Of the RCTs, two studies compared 1 month versus 6 months of dual antiplatelet therapy (DAPT);187,193 one compared 1 month versus 12 months of DAPT;199 one compared 6 months versus 12 months of DAPT;136 and another compared 6 months versus 24 months.198

In the observational studies, one evaluated planned duration of DAPT use for less than 3 months versus 6 months versus 12 months;170 a second evaluated clopidogrel discontinuation by multivariable analysis at 6-month intervals;183 one assessed patients with stent thrombosis for independent predictors;171 one evaluated clopidogrel cessation by a competing risk approach;168 one compared dual antiplatelet therapy for more than 12 months with less than 12 months169 and one assessed the effect of clopidogrel discontinuation after 12 months of clopidogrel treatment.134

Of the RCTs, three (60%) were rated good quality and two (40%) fair. Of the observational studies, one (17%) was rated good quality, four (66%) fair, and one (17%) poor quality. Sample sizes for individual studies ranged from 278 to 29,268 patients. Study duration ranged from 30 days to 4 years.

The mean age of study participants ranged from 57 to 67 years. The proportion of female patients ranged from 2 to 43 percent. Two studies (18%) reported the racial and ethnic demographics of study participants. Three studies (27%) were conducted within the United States or Canada, one was conducted in Europe (9%), one was conducted in Asia (9%), and the rest were international. Funding source was reported in 6 studies (55%), with 1 study (9%) funded by an industry source, one by a private foundation (9%), and one by government (9%). Table G-14 in Appendix G summarizes the results reported by each study.

##### Effect on Composite Endpoint of All-Cause Mortality or Nonfatal MI Within 2 Years

Four studies (two RCTs,136,198 both good quality; two observational,134,183 both fair quality) including 34,179 patients reported the composite outcome of all-cause mortality or nonfatal MI. Both RCTs, one assessing DAPT for 6 months versus 24 months and the other evaluating DAPT for 6 months versus 12 months, showed no differences in the rate of the composite outcome at 2 years and 12 months respectively between the two treatment arms (9.6% vs. 8.9%; OR 1.07; 95% CI, 0.80 to 1.43, p=0.62; 2.4% vs.1.9%; HR 1.21; 95% CI, 0.60 to 2.47, p=0.58).

One retrospective observational study183, assessing the effect of clopidogrel discontinuation on the composite outcome at a median of 538 days, found that among patients who discontinue clopidogrel within the first 6 months after discharge, the rate of all-cause mortality and nonfatal MI was higher compared with those who continue clopidogrel treatment (HR 1.90; 95% CI, 1.39 to 2.59). The other observational study134 assessing the effect of clopidogrel discontinuation after 12 months of treatment subsequent to an MI, found a higher risk in the composite of cardiovascular death or MI during the first 90 days of discontinuation of clopidogrel compared with the next 90 days of discontinuation among those who were treated with PCI (IRR1.59; 95% CI, 1.11 to 2.30) but not among patients who were medically managed (IRR 1.07; 95% CI, 0.65 to 1.76). The SOE was rated insufficient for the composite outcome of all-cause mortality or nonfatal MI due to heterogeneity of DAPT duration, plus inconsistent and imprecise findings between the observational studies and randomized trials.

##### Effect on Composite Endpoint of All-Cause Mortality or Stroke at 2 Years

One good-quality RCT198 with 2013 patients evaluating DAPT for 6 months versus 24 months showed no differences in the rate of the composite outcome of all-cause mortality or stroke at 2 years between the two treatments arms (7.1% vs. 7.8%; OR 0.91; 95% CI, 0.66 to 1.26, p=0.57). The SOE was rated insufficient for the composite outcome of all-cause mortality or stroke based on one study with an imprecise estimate.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal MI, or Revascularization at 6 Months and 1 Year

Three studies (two RCTs,136,193 one good quality, one fair; and one fair-quality observational170) including 4701 patients reported the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 6 months and 1 year.

One RCT,193 comparing 1-month with 6-month treatment with DAPT, found that the rate of composite outcomes at 6 months was similar between the two treatment groups (12.9% vs. 13.8%). Likewise, the other RCT136 assessing 6-month versus 12-month DAPT treatment, found no difference in the composite outcome at 12 months (4.8% vs. 4.3%; HR 1.14; 95% CI, 0.70 to 1.86). In the observational study170 assessing DAPT use for <3 months versus 6 months versus >12 months, the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 1 year was reported based on type of stent (DES and BMS) used during PCI. The rate of composite outcome in both the DES-treated and BMS-treated patients at 1 year was similar across clopidogrel treatment groups (DES 11.2% vs. 16.0% vs. 14.3%, p=0.33; BMS 15.8% vs. 12.9% vs. 17.6%, p=0.26). The SOE was rated insufficient for this composite outcome based on the heterogeneity of the study durations assessed and imprecise estimates.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal MI, Stroke, or Revascularization at 1 Year

One good-quality RCT136 with 1443 patients assessing 6-month versus 12-month DAPT treatment found no difference in the composite endpoint at 1 year (8.0% vs. 8.5%, HR 0.94, 95% CI, 0.65 to 1.35). The SOE was rated insufficient for the composite outcome of all-cause mortality, nonfatal MI, stroke, or revascularization based on one study with an imprecise estimate.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal MI, or Stroke at 6 Months, 1 Year, and 2 Years

Three RCTs187,198,199 (two good quality, 1 fair) including 5133 patients reported the composite outcome of all-cause mortality, nonfatal MI, or stroke at 6 months, 1 year, and 2 years. One RCT187 comparing 1-month with 6-month treatment with DAPT found that the rate of the composite outcome at 6 months was significantly lower among patients treated with DAPT for 6 months compared with those treated for 30 days (1.7% vs. 5.0%; RR decrease 65%, p=0.010).

One RCT199 assessing DAPT treatment for 1 month versus 12 months found a significant reduction in the risk of the composite outcome at 12 months among patients treated with DAPT for 12 months (8.5% vs. 11.5%; RR 26.9; 95% CI, 3.9 to 44.4). The other RCT198 evaluating DAPT for 6 months versus 24 months showed no differences in the rate of the composite outcome at 2 years between the two treatments arms (10.0% vs. 10.1%; OR 0.98; 95% CI, 0.74 to 1.29, p=0.91). The SOE was rated insufficient for this composite outcome at each time point due to the heterogeneity of the study durations, timing of the outcome measurement (only one study available at each time point), and imprecise estimates.

##### Effect on All-Cause Mortality at 6 Months, 1 Year, and 2 Years

Seven studies134,136,170,183,187,193,198 (4 RCTs, 2 good quality, 2 fair; 3 observational, all fair quality) including 38,441 patients reported total mortality results. Two RCTs187,193 comparing 1-month with 6-month treatment with DAPT found that the rate of all-cause mortality at 6 months was lower among patients treated with DAPT for 6 months compared with those treated for 1-month. The difference in event rate was statistically different in only one study (0.87% vs. 2.6%, p=0.05^187^ and 0.7% vs. 1.4%^193^).

An RCT136 assessing DAPT for 6 months versus 12 months showed no difference in 1-year mortality between the two treatment arms (6.6% vs. 6.6%; HR 1.0; 95% CI, 0.72 to 1.40, p=0.98). Another RCT198 assessing DAPT for 6 months versus 24 months showed no difference in 2-year mortality between the two treatment arms (6.6% vs. 6.6%; OR 1.0; 95% CI, 0.72 to 1.40, p=0.98).

In one observational study170 evaluating DAPT use for less than 3 months versus 6 months versus more than 12 months, all-cause mortality at 1 year was reported based on type of stent used during PCI. In DES-treated patients, 1 year mortality was significantly lower in patients receiving DAPT for more than 12 months when compared with shorter duration of DAPT (2.8% vs. 5.3% vs. 5.3%, p=0.01), while in BMS-treated patients, 1 year mortality was similar among the three DAPT duration strategies (5.9% vs. 4.5% vs. 6.0%, 12 vs. 6 vs. 3 months, respectively). Although an observational study, this study highlights the different impact of DAPT among DES versus BMS patient populations.

A retrospective study183 assessing the effect of clopidogrel discontinuation on all-cause mortality at a median of 538 days found that among patients who discontinue clopidogrel within the first 6 months after discharge, the rate of all-cause mortality was higher compared with those who continue clopidogrel treatment (19.9% vs. 6.9%; adjusted HR 2.4; 95% CI, 1.61to 3.58). The other observational study,134 assessing the effect of clopidogrel discontinuation after 12 months of treatment subsequent to an MI, found a higher risk of cardiovascular death during the first 90 days of discontinuation of clopidogrel compared with the next 90 days of discontinuation among those who were treated with PCI (adjusted IRR 1.87; 95% CI, 1.11 to 3.15) but not among patients who were medically managed (adjusted IRR 0.77; 95% CI, 0.36 to 1.67). The SOE was rated insufficient for all-cause mortality based on the heterogeneity of DAPT duration, timing of endpoint measurement, and imprecision.

##### Effect on Cardiovascular Mortality at 6 Months, 1 Year, and 2 Years

Three RCTs136,187,198 (2 good quality, 1 fair) including 4460 patients reported cardiovascular mortality results, and one observational study134 (29,268 patients) reported all-cause mortality. One RCT187 comparing 1-month with 6-month treatment with DAPT found that the rate of cardiovascular mortality at 6 months was similar between the two treatment groups (1.7 vs. 0.87%, p=0.25). Another RCT136 assessing DAPT for 6 months versus 12 months found no difference in the rate of cardiovascular mortality between the two treatment arms (0.3% vs. 0.4%; HR 0.67; 95% CI, 0.11 to 3.99, p=0.66) at 1 year. Similarly, the third RCT198 comparing DAPT for 6 months and 24 months showed no difference in 2-year cardiovascular mortality between the two treatment arms (3.8% vs. 3.70%; OR 1.03; 95% CI, 0.66 to 1.61, p=0.89).

The fair-quality observational study with 29,268 patients134 that assessed the effect of clopidogrel discontinuation after 12 months of treatment subsequent to an MI found no significant difference in the risk of death between the first 90 days of discontinuation of clopidogrel compared with the next 90 days of discontinuation among both those who were treated with PCI (IRR 1.18; 95% CI, 0.73 to 1.91) and patients who were medically managed (IRR 1.56, 95% CI, 0.85 to 2.87). The SOE was rated insufficient for cardiovascular mortality based on imprecise and inconclusive findings from the three RCTs.

##### Effect on Nonfatal MI at 6 Months, 1 Year, and 2 Years

Six studies (four RCTs,136,187,193,198 two good quality, two fair; two fair-quality observational170,183) including 9173 patients reported nonfatal MI results. Two RCTs187,193 comparing 1-month and 6-month treatment with DAPT found that the rate of nonfatal MI at 6 months was similar between the two treatment groups (2.1% vs. 2.2%^193^ and 2.8% vs. 1.5%, p=0.18^187^).

An RCT136 evaluating DAPT for 6 months versus 12 months duration, found no difference in the rate of cardiovascular mortality between the two treatment arms (1.8% vs. 1.0%; HR 1.86; 95% CI, 0.74 to 4.67, p=0.19) at 1 year. In the fourth RCT198 comparing DAPT for 6 months with 24 months showed no difference in 2-year nonfatal MI rate between the two treatment arms (4.2% vs. 4.0%; OR 1.06; 95% CI, 0.69 to 1.63, p=0.80).

In one observational study170 assessing DAPT use for less than 3 months versus 6 months versus more than 12 months, nonfatal MI at 1 year was reported based on the type of stent used during PCI. The rate of composite outcome in both the DES-treated and BMS-treated patients at 1 year was similar across treatment groups (DES 3.3% vs. 7.7% vs. 6.4%, p=0.15; BMS 5.3% vs. 4.5% vs. 7.4%).

A retrospective observational study183 assessing the effect of clopidogrel discontinuation on all-cause mortality at a median of 538 days found that patients who discontinued clopidogrel within the first 6 months after discharge were at higher risk for subsequent acute MI if they received DES (HR 3.57; 95% CI, 1.13 to 11.3) than if they received BMS (HR 1.26; 95% CI, 0.58 to 2.74). The SOE was rated insufficient for nonfatal MI based on imprecise and inconclusive findings across studies.

##### Effect on Stroke at 6 Months, 1 Year, and 2 Years

Three RCTs136,187,198 (two good quality, 1 fair) including 4460 patients reported stroke results. One187 comparing 1-month with 6-month treatment with DAPT, found that the rate of stroke at 6 months was similar between the two treatment groups (0.21% vs. 0%, p=0.32). The study136 assessing DAPT for 6 months versus 12 months found a trend favoring 6 months but no statistically significant difference in the rate of cardiovascular mortality between the two treatment arms (0.4% vs. 0.7%; HR 0.60; 95% CI, 0.14 to 2.51, p=0.48) at 1 year. The third RCT198 assessing DAPT for 6 months versus 24 months again showed a trend towards a benefit of the 6 month duration but this was not statistically significant between the two treatment arms and had a wide confidence interval that crossed 1 (1.4% vs. 2.1%; OR 0.60; 95% CI, 0.29 to 1.23, p=0.17). The SOE was rated insufficient for stroke based on the differences in the treatment durations that were compared and imprecise findings from three RCTs.

##### Effect on Revascularization at 6 Months and 1 Year

Four studies (three RCTs,136,187,193 one good quality, two fair; and one fair-quality observational170) including 5705 patients reported target vessel revascularization results. Two studies187,193 comparing 1-month with 6-month treatment with DAPT found that the rate of target vessel revascularization (TVR) at 6 months was similar between the two treatment groups (5.6% vs. 3.98%, p=0.22 in one study187 and 11.4% vs.12.3% in the other193). The third RCT136 assessing DAPT for 6 months versus 12 months found no difference in the rate of TVR between the two treatment arms (3.1% vs. 3.2%; HR 1.00; 95% CI, 0.56 to 1.81, p=0.99) at 1 year.

In one observational study170 evaluating DAPT use for less than 3 months versus 6 months versus more than 1 year, TVR at 1 year was reported based on type of stent used during PCI. Both in DES-treated and BMS-treated patients, the rate of TVR at 1 year was similar across DAPT groups (DES 4.6% vs. 7.1% vs. 7.1%, p=0.51; BMS 7.2% vs. 7.0% vs. 7.9%). The SOE was rated insufficient for revascularization outcomes based on imprecise and inconclusive findings across the three RCTs.

##### Effect on Stent Thrombosis at 6 Months, 1 Year, and 2 Years

Six studies (three RCTs,136,193,198 two good quality, 1 fair; three observational,168,169,171 1 good quality, 1 fair, 1 poor) including 15,298 patients reported stent thrombosis results. One RCT193 comparing 1-month with 6-month treatment with DAPT found that the rate of subacute and late stent occlusion at 6 months was similar between the two treatment groups (3.6% vs. 2.2% and 2.2% vs. 1.6%). Another RCT136 assessing DAPT for 6 months versus 12 months found no difference in the rate of stent thrombosis between the two treatment arms (0.9% vs. 0.1%; HR 6.02; 95% CI, 0.72 to 49.96, p=0.10) at 1 year. The third RCT198 assessing DAPT for 6 months versus 24 months showed no difference in 2-year stent thrombosis between the two treatment arms (0.8% vs. 0.70%; OR 0.88; 95% CI, 0.32 to 2.42, p=0.80).

One observational study171 evaluated the temporal relation between clopidogrel cessation and stent thrombosis and found that clopidogrel cessation was an independent predictor of cumulative stent thrombosis at 1 month (OR 4.5; 95% CI, 2.0 to 10.4) and at 6 months (OR 2.4; 95% CI, 1.2 to 4.9) but not at 1 year (OR 1.7; 95% CI, 0.9 to 3.1). Another observational study168 assessing the change in risk of stent thrombosis over time based on DAPT found that the cumulative incidence of stent thrombosis was 12.36 percent among those who discontinued clopidogrel at 6 months and 0.58 percent among those still on clopidogrel treatment. One observational study169 evaluating DAPT for more than 12 months versus less than or equal to 12 months found no difference in the number of stent thromboses that occurred at 3 years between the two groups (14 vs. 7, log rank p=0.097).

The SOE was rated insufficient due to heterogeneity of DAPT duration and imprecision. The findings in observational studies were consistent that discontinuation of clopidogrel within 30 days or 6 months was associated with higher rates of stent thrombosis, and the findings from RCTs consistently showed that discontinuation of clopidogrel at 1 or more years showed no statistically significant differences in rates of stent thrombosis.

##### Effect on Major Bleeding at 1 and 2 Years

Three good-quality RCTs136,198,199 with 5572 patients reported major bleeding results. One199 assessing DAPT for 1 month versus 12 months found no significant increase in the risk of major bleeding among patients treated with DAPT at 1 year (6.7% vs. 8.8%, p= 0.7). The other198 evaluating DAPT for 6 months versus 24 months, showed a significantly lower rate of TIMI major bleeding at 2 years among patients treated with DAPT for 6 months (0.6% vs. 1.6%; OR 0.38; 95% CI, 0.15 to 0.97, p=0.041). The third RCT136, assessing DAPT for 6 months versus 12 months found no difference in the rate of major bleeding between the two treatment arms (0.3% vs. 0.6%; HR 0.50; 95% CI, 0.09 to 2.73, p=0.42) at 1 year. The SOE was rated insufficient for major bleeding outcomes based on the differences in the treatment durations that were compared and on inconsistent and imprecise results.

##### Effect on Minor Bleeding at 1 and 2 Years

Two good-quality RCTs198,199 with 4129 patients reported minor bleeding results. One199 assessing DAPT for 1 month versus 12 months found no difference in the rate of minor bleeding between the two treatment arms (5.6% vs. 5.3%, p= 0.84). Similarly, the other198 comparing DAPT for 6 months with 24 months found no difference in the rate of TIMI minor bleeding at 2 years between the two treatment arms (0.9% vs. 1.1%; OR 0.82; 95% CI, 0.34 to 1.94, p=0.66). The SOE was rated insufficient based on imprecise results.

##### Findings by Subgroup (KQ 3d)

Four studies136,169,183,198 (two good-quality RCTs; one good-quality, one fair observational) reported variations in treatment effectiveness by subgroup. Subgroups analyzed were diabetes (3 studies), age (2), sex (1), chronic kidney disease (1), and stent type (2). Table H-3 in Appendix H presents the results data for these subgroups.

###### Diabetes

Three studies136,169,198 reported a composite outcome in the diabetic subgroup. One RCT198 evaluating DAPT for 6 months versus 24 months showed no differences in the rate of composite outcomes (all-cause mortality, nonfatal MI, or stroke) at 2 years, both in the group of patients with diabetes (HR 0.85; 95% CI, 0.53 to 1.38) and without diabetes (OR 1.06; 95% CI, 0.76 to 1.50). The other RCT136 found a significantly higher rate of composite outcome (cardiovascular death, nonfatal MI, or target vessel revascularization) at 12 months in patients with diabetes receiving 6-month DAPT versus 12-month DAPT (9.1% vs. 3.0%; HR 3.16; 95% CI, 1.42 to 7.03, p=0.005). The rate of composite outcome (cardiovascular death, nonfatal MI, or target vessel revascularization) at 1 year in patients without diabetes was significantly lower among those receiving 6-month DAPT versus 12-month DAPT (2.3% vs. 5.1%; HR 0.44; 95% CI, 0.21 to 0.94, p=0.03). In the other study169 assessing DAPT for more than 12 months versus less than or equal 12 months, found no difference in the rate of the composite outcome (all-cause mortality or nonfatal MI) at 3 years between the two treatment groups among patients with diabetes (12% vs. 16%; HR 0.85; 95% CI, 0.51 to 1.43, p=0.55).

###### Age

Two RCTs reported a composite outcome by age subgroups (<65 vs. ≥65 years). One study198 assessing DAPT for 6 months versus 24 months reported no significant differences in the rate of composite outcomes (cardiovascular death, nonfatal MI, or stroke) at 2 years in either age group (<65 years, HR 0.57; 95% CI, 0.28 to 1.16; and ≥ 65 years, OR 1.12; 95% CI, 0.82 to 1.51). The other RCT136 evaluating DAPT for 6 months versus 12 months similarly found no difference in the rate of composite outcome (cardiovascular death, nonfatal MI, target vessel revascularization) at 1 year in either age group (<65 years, HR 1.61; 95% CI, 0.78 to 3.31; and ≥ 65 years, HR 0.83; 95% CI, 0.42 to 1.65).

###### Sex

One RCT198 assessing DAPT for 6 months versus 24 months, reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 2 years by sex. No significant differences in the rate of composite outcomes were observed in either group (women, HR 1.00; 95% CI, 0.60 to 1.68; and men, OR 1.09; 95% CI, 0.77 to 1.29).

###### Chronic Kidney Disease

One RCT198 assessing DAPT for 6 months versus 24 months, reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 2 years by renal function (creatinine clearance >60 mL/min vs. creatinine clearance ≤60 mL/min). No significant differences in the rate of composite outcomes were observed in either renal function group (creatinine clearance >60 mL/min, HR 0.90; 95% CI, 0.58 to 1.38; and creatinine clearance ≤60 mL/min, OR 1.14; 95% CI, 0.78 to 1.65).

###### Stent Type

One RCT198 evaluating DAPT for 6 months versus 24 months, reported a composite outcome (cardiovascular death, nonfatal MI, or stroke) at 2 years by stent type (BMS and DES). No significant differences in the rate of composite outcomes were observed in either stent type groups (BMS, HR 1.13; 95% CI, 0.68 to 1.86; and DES, 0.93; 95% CI, 0.67 to 1.30).

Two studies183,198 reported outcomes by stent type. One study183 assessing the effect of clopidogrel discontinuation on all-cause mortality at a median of 538 days, reported data by stent type (DES and BMS). The study found that among patients who discontinue clopidogrel within the first 6 months after discharge, the rate of all-cause mortality was higher compared with those who continue clopidogrel treatment, both in the BMS group (HR 2.65; 95% CI, 1.59 to 4.42) and DES group (HR 2.0; 95% CI, 1.06 to 3.75). Similarly, among patients who discontinue clopidogrel within the first 6 months after discharge, the rate of nonfatal MI was higher compared with those who continued clopidogrel treatment both in the BMS group (HR 1.26; 95% CI, 0.58 to 2.74) and the DES group (HR 3.57; 95% CI, 1.13 to 11.3).

##### Summary of Results for Short-Term Versus Long-Term Dual Antiplatelet Therapy

In our analysis of short-term versus long-term DAPT use, we aimed to address the question about the optimal duration of therapy by comparing short-term to long-term use of clopidogrel. The variations in the duration of therapy and the definitions of short-term and long-term treatment made meta-analysis impossible. Evidence was insufficient for the outcomes of composite ischemic events, all-cause mortality (7 studies), cardiovascular mortality (4 studies), nonfatal MI (6 studies), stroke (3 studies), and revascularization (4 studies). Rates of stent thrombosis (6 studies) were higher when DAPT was stopped within 30 days or 6 months, but the differences between therapies beyond 6 months were nonsignificant, thus the evidence was rated insufficient. Stent thrombosis rates may vary based on use of bare metal or drug-eluting stents. There was insufficient evidence that clopidogrel duration had an effect on major bleeding outcomes, with one RCT showing a significantly lower rate of major bleed with 6-month treatment compared with 24-month therapy, another RCT showing no significant increase in major bleed among patients treated for 28 days compared with 12 months, and a third RCT showing no difference in major bleeding among patients treated for 6 months compared with 12 months. There was also insufficient evidence that clopidogrel duration had an effect on minor bleeding rates, which were similar in the short- and long-term duration groups from the same RCTs. Four studies (two good-quality RCTs and two observational of good and fair quality) reported variations in treatment effectiveness by subgroup. Subgroups analyzed were diabetes (3 studies), age (2), sex (1), chronic kidney disease (1), and stent type (2). No differences in composite ischemic events were found among the different subgroup comparisons. The SOE was low based on the small number of studies that reported subgroup findings and the imprecise estimates of effect. Detailed SOE ratings are shown in Table 24.

Table 24 Detailed strength of evidence for UA/NSTEMI patients treated with short-term versus long-term dual antiplatelet therapy

Number of Studies (Patients) | Domains | | | | SOE and Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
Composite of All-Cause Mortality or Nonfatal MI Within 2 Years | | | | | Insufficient SOE
4 (34,179) | 2 RCTs/Both good quality 2 observational/Both fair quality | Inconsistent | Direct | Imprecise | 2 RCTs showed no difference between 6- and 12-month therapy and 6-and 24-month therapy; 1 observational study showed that discontinuation before 6 months increased events; 1 observational study showed increased events within first 3 months of stopping clopidogrel after 1 year of therapy
Composite of All-Cause Mortality or Stroke at 2 Years | | | | | Insufficient SOE
1 (2013) | RCT/Good quality | NA | Direct | Imprecise | No difference between 6-and 24-month therapy: OR 0.91; 95% CI, 0.66 to 1.26, p=0.57
Composite of All-Cause Mortality, Nonfatal MI, or Revascularization at 6 Months and 1 Year | | | | | Insufficient SOE
3 (4701) | 2 RCTs/1 good quality, 1 fair 1 observational/Fair quality | Consistent | Direct | Imprecise | Both RCTs (1 month vs. 6 months and 6 months vs. 12 months) found similar rates between short- and long-term therapy; the observational study (<3 months vs. 6 months vs. >12 months) showed similar rates across treatment groups in both DES-treated and BMS-treated populations
Composite of All-Cause Mortality, Nonfatal MI, Stroke, or Revascularization at 1 Year | | | | | Insufficient SOE
1 (1443) | RCT/Good quality | NA | Direct | Imprecise | No difference between 6- and 12-month therapy: HR 0.94, 95% CI, 0.65 to 1.35
Composite of All-Cause Mortality, Nonfatal MI, or Stroke at 6 Months, 1 Year, and 2 Years | | | | | Insufficient SOE
3 (5133) | 3 RCTs/2 good quality, 1 fair | Inconsistent | Direct | Imprecise | 2 studies found significant reductions in events from long-term DAPT at 6 months and 1 year; 1 study found no difference between 6- and 24-month therapy
All-Cause Mortality at 6 Months, 1 Year, and 2 Years | | | | | Insufficient SOE
7 (38,441) | 4 RCTs/2 good quality, 2 fair 3 observational/All fair quality | Inconsistent | Direct | Imprecise | 2 RCTs showed a reduction with longer therapy (1 month vs. 6 months) but 1 was statistically significant and the other was not; 1 RCT (6 months vs. 12 months) showed no difference; 1 observational study (<3 months vs. 6 months vs. <12 months) showed lower mortality in DES-treated patients receiving >12 months of therapy, but no difference in the BMS-treated patients; 1 observational study found a higher rate of mortality in those who discontinued clopidogrel within the first 6 months; 1 observational study fund a higher risk of death within the first 90 days of discontinuation after a 12-month treatment
Cardiovascular Mortality at 6 Months, 1 Year, and 2 Years | | | | | Insufficient SOE
4 (33,728) | 3 RCTs/2 good quality, 1 fair 1 observational/Fair quality | Consistent | Direct | Imprecise | All RCTs found similar rates between short-and long-term therapy (1 month vs. 6 months, 6 months vs. 12 months, and 6 months vs. 24 months); 1 observational study found no difference in CV mortality within the first 90 days of discontinuation after a 12-month treatment
Nonfatal MI at 6 Months, 1 Year, and 2 Years | | | | | Insufficient SOE
6 (9173) | 4 RCTs/2 good quality, 2 fair 2 observational/2 fair quality | Consistent | Direct | Imprecise | 5 studies (4 RCTs and 1 observational) showed similar rates of MI in short- and long-term therapy groups; 1 observational study showed statistically significant higher risk in DES patients who discontinue clopidogrel within first 6 months
Stroke at 6 Months, 1 Year, and 2 Years | | | | | Insufficient SOE
3 (4460) | 3 RCTs/2 good quality, 1 fair | Consistent | Direct | Imprecise | All RCTs (1 month vs. 6 months, 6 months vs. 12 months, and 6 months vs. 24 months) found similar rates between short-and long-term therapy, but heterogeneity of DAPT duration makes this inconclusive
Revascularization at 6 Months and 1 Year | | | | | Insufficient SOE
4 (5705) | 3 RCTs/1 good quality, 2 fair 1 observational/Fair quality | Consistent | Direct | Imprecise | Rates of revascularization were similar between short- and long-term therapy (1 month vs. 6 months and 6 months vs. 24 months)
Stent thrombosis at 6 Months, 1 Year, and 2 Years | | | | | Insufficient SOE
6 (15,298) | 3 RCTs/2 good quality, 1 fair 3 observational/1 good quality, 1 fair, 1 poor | Consistent | Direct | Imprecise | Rates of stent thrombosis were higher when clopidogrel was stopped within 30 days or 6 months in 2 observational studies; 4 studies (3 RCTs and 1 observational) showed no statistically significant difference in event rates at 1 or 2 years
Major Bleeding at 1 and 2 Years | | | | | Insufficient SOE
3 (5572) | 3 RCTs/All good quality | Inconsistent | Direct | Imprecise | 1 RCT (6 months vs. 24 months) showed a statistically significant lower rate of major bleeding with clopidogrel with 6-month treatment; the other 2 RCTs (1 months vs. 12 months and 6 months vs. 12 months) showed no statistically significant difference in rates with 1-year treatment
Minor Bleeding at 1 and 2 Years | | | | | Insufficient SOE
2 (4129) | 2 RCTs/Both good quality | Consistent | Direct | Imprecise | Both RCTs (1 month vs. 12 months and 6 months vs. 24 months) found no difference at 1 and 2 years

BMS = bare metal stent; CI = confidence interval; CV = cardiovascular; DES = drug-eluting stent; MI = myocardial infarction; NA = not applicable; NR = not reported; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

a Consistency cannot be determined because treatment durations were heterogeneous.

#### 4 Antiplatelet Treatments With and Without Use of PPI (KQ 3b)

Thirty-five studies (4 RCTs, 31 observational) evaluated antiplatelet treatments with PPI versus antiplatelets alone in the postdischarge treatment of 340,559 UA/NSTEMI patients.14,133,137,139-141,143-150,152-159,161-164,166,167,173,174,177,181,182,197,200 Three of these studies compared esomeprazole with placebo and were included in the analysis; one study compared esomeprazole with famotidine. All other studies evaluated treatment with a PPI (not otherwise specified) versus no PPI when given at hospital discharge in UA/NSTEMI patients.

Of the four RCTs, two (50%) were rated good quality and two (50%) poor. Of the 31 observational studies, 25 (80%) were rated good quality, 3 (10%) fair, and 3 (10%) poor. Sample sizes for individual studies ranged from 72 to 56,406 patients. Study duration ranged from 14 days to 6 years.

The mean age of study participants ranged from 58 to 77 years of age. The proportion of female patients ranged from 1 percent to 76 percent. Four studies (13%) reported the racial and ethnic demographics of study participants. Eleven studies (37%) were conducted within the United States or Canada, with the rest international. Funding source was reported in 19 studies (63%), with 4 studies (13%) funded by an industry source. Table G-15 in Appendix G contains the results reported by each study.

The PPI studies were grouped into the following two comparisons:

4a Dual antiplatelet therapy with and without PPI (4 RCTs of omeprazole; 1 observational study of omeprazole; 29 observational studies of any PPI)
4b Aspirin monotherapy (i.e., no clopidogrel) with and without PPI (two observational studies of any PPI)

##### 4a Dual Antiplatelet Therapy With and Without PPI

All 35 studies (4 RCTs, 31 observational) assessed the effect of antiplatelet treatments with PPI versus antiplatelets alone (no PPI) in the postdischarge treatment of UA/NSTEMI patients. Five of these, consisting of 4 RCTs14,140,144,177 (2 good quality, 2 poor) and one good-quality observational study164 in 5183 UA/NSTEMI patients, assessed the effect of omeprazole when added to dual antiplatelet treatment. One study was an RCT comparing omeprazole with famotidine for the prevention of gastrointestinal (GI) bleeding in patients with UA/NSTEMI.140 The other 30 observational studies assessed the effect of any type of PPI versus no PPI in the postdischarge treatment of UA/NSTEMI patients.

###### Effect on Composite Ischemic Endpoints at About 1 Year

Two good-quality RCTs and one good-quality observational study of omeprazole reported a composite outcome within about 1 year of enrollment (6 to 18 months). One RCT140 comparing omeprazole with famotidine reported a nonsignificant difference in the rate of composite outcomes (cardiovascular mortality, nonfatal MI, or stroke) at 4 months between the two treatment groups (4.3% vs. 3.4%, p=0.7788). One RCT14 comparing omeprazole with placebo reported a nonsignificant difference in the rate of composite outcomes (cardiovascular mortality, nonfatal MI, stroke, or revascularization) at 6 months between the two treatment arms (4.9% vs. 5.7%; HR 0.99; 95% CI, 0.68 to 1.44, p=0.96). Similarly, an observational study164 comparing omeprazole with placebo reported a nonsignificant difference in the rate of composite outcomes (cardiovascular mortality or nonfatal MI) at 12 months between the two treatment arms (10% vs. 9.7%; unadjusted HR 1.1; 95% CI, 0.6 to 1.8, p=0.89).

Twenty observational studies (18 good quality, 2 fair) reported the effect of any PPI on the composite endpoint of all-cause mortality, stroke, or MI at 6 to 18 months.139,143,145-150,153,154,156-159,163,166,167,173,197,200 Of these studies, 10 reported only standard adjusted results, 3 reported only propensity-adjusted results, and 7 reported both. We first did a meta-analysis that compared the two types of estimates. The overall estimate for the standard adjusted hazard ratios was 1.40 whereas the overall estimate for the propensity-adjusted hazard ratios was 1.34. The chi-square test for the difference was 0.111 for 1 degree of freedom, p=0.739. Next we did a meta-analysis using the propensity-adjusted hazard ratio (P) when it was available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of this analysis is shown in Figure 40.

Figure 40 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on composite endpoint at about 1 year

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of 20 studies that shows an odds ratio of 1.35 (95% CI, 1.18 to 1.54), favoring no proton pump inhibitor.

The random-effects combined estimate was 1.35 (95% CI, 1.18 to 1.54). The result was highly significant (p<0.001). The Q-value for the analysis was 196.64 for 19 degrees of freedom (p<0.001). The I^2^ was 90.34. Thus there was very significant heterogeneity. The SOE was rated low that favors no PPI for composite ischemic outcomes based on two RCTs and one observational study of omeprazole that failed to show a difference in events and the meta-analysis of 20 observational studies of nonspecific PPI that demonstrated significant heterogeneity, despite inconsistent and precise results.

###### Effect on Composite Endpoint of All-Cause Mortality or Myocardial Infarction at About 1 Year

Three good-quality observational studies with 60,389 patients reported the effect of any PPI on all-cause mortality or MI at about 1 year (6 to 18 months).150,166,197 Of these studies, one reported only standard adjusted results, and two reported both standard adjusted results and propensity-adjusted results. We first did a meta-analysis that compared the two types of estimates. The overall estimate for the standard adjusted hazard ratios was 1.23 whereas the overall estimate for the propensity-adjusted hazard ratios was 1.31. The chi-square test for the difference was 0.265 for 1 degree of freedom, p=0.607. Next we did a meta-analysis using the propensity-adjusted hazard ratio (P) when it was available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of this analysis is shown in Figure 41.

Figure 41 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on all-cause mortality or myocardial infarction at about 1 year

CI = confidence interval; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.27 (95% CI, 1.12 to 1.43), favoring no proton pump inhibitor.

The random-effects combined estimate was 1.27 (95% CI, 1.12 to 1.43). The result was highly significant (p<0.001). The Q-value for the analysis was 0.466 for 2 degrees of freedom (p=0.792). The I^2^ was 0.00. Thus there was no evidence of heterogeneity. The SOE was rated moderate that favors no PPI for composite ischemic outcomes based on consistent and precise results from three observational studies.

###### Effect on All-Cause Mortality Within First 3 Months

Three observational studies (all good quality; 8943 patients) reported the effect of any PPI versus no PPI on all-cause mortality within the first 3 months after hospital discharge for a UA/NSTEMI event. One study148 reported no difference in the rate of in-hospital all-cause mortality (3.0% vs. 4.0%, adjusted OR 1.04; 95% CI, 0.61 to 1.77). Another study157 reported significant increase in the risk of all-cause mortality at 30 days among patients treated with PPI (2.6% vs. 0.9%, adjusted HR 2.2; 95% CI, 1.1 to 4.3). A case-control study174 found no difference in the risk of all-cause mortality at 3 months among UA/NSTEMI patients treated with PPI versus those not treated with PPI (adjusted OR 0.82; 95% CI, 0.57 to 1.18). The SOE was rated insufficient for all-cause mortality within the first 3 months based on inconsistent and imprecise results.

###### Effect on All-Cause Mortality at About 1 Year

Three studies of omeprazole (2 RCT, 1 observational) reported all-cause or cardiovascular mortality within about 1 year of enrollment (6 to 18 months). One poor-quality RCT177 comparing omeprazole with placebo in 237 acute MI patients reported a significant difference in the rate of all-cause mortality at 14 days favoring omeprazole (3.5% versus placebo 10.6%, p=0.035). One good-quality RCT14 comparing omeprazole with placebo in a mixed population of 3,873 ACS and PCI patients reported a nonsignificant difference in the rate of all-cause mortality at 6 months between the two treatment arms (omeprazole 4%, placebo 5%). Similarly, a good-quality observational study164 comparing omeprazole with placebo in a mixed population of 558 stable angina and ACS patients reported a nonsignificant difference in the rate of cardiovascular mortality at 12 months between the two treatment arms (omeprazole 3.5% vs. placebo 3.2%; unadjusted HR 1.10; 95% CI, 0.44 to 2.84, p=0.84).

Seventeen observational studies (16 good quality, 1 fair) reported the effect of any PPI on all-cause mortality at 6 to 18 months.143,145-150,153,154,156,158,163,166,173,174,197,200 Of these studies, 11 reported only standard adjusted results, 2 reported only propensity-adjusted results, and 4 reported both. We first did a meta-analysis that compared the two types of estimates. The overall estimate for the standard adjusted hazard ratios was 1.18 whereas the overall estimate for the propensity-adjusted hazard ratios was 1.44. The chi-square test for the difference was 1.271 for 1 degree of freedom, p=0.258. Next we did a meta-analysis using the propensity-adjusted hazard ratio (P) when it was available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of this analysis is shown in Figure 42.

Figure 42 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on all-cause mortality at about 1 year

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of 17 studies that shows an odds ratio of 1.17 (95% CI, 0.92 to 1.48), showing no difference.

The random-effects combined estimate was 1.17 (95% CI, 0.92 to 1.48). The result was not significant (p=0.20). The Q-value for the analysis was 243.34 for 16 degrees of freedom (p<0.000). The I^2^ was 93.425. There was evidence of extreme heterogeneity. The SOE was rated moderate for no difference for all-cause mortality based on two RCTs and one observational study of omeprazole that showed no difference in events or favored omeprazole and the meta-analysis of observational studies of nonspecific PPI that demonstrated significant heterogeneity and nonsignificant findings.

###### Effect on All-Cause Mortality at 6 Years

Only one good-quality observational study of 23,200 patients150 reporting the effect of any PPI on all-cause mortality 6 years after hospital discharge for a UA/NSTEMI event, found an increase of all-cause mortality among patients treated with PPI (26.8% vs. 21.4%, adjusted HR 1.32; 95% CI, 1.00 to 1.73). The SOE was rated low that favors no PPI for all-cause mortality at 6 years based on one large observational study.

###### Effect on Cardiovascular Mortality at 1 Year

Three good-quality observational studies153,154,197 with 76,184 patients reported the effect of any PPI use on cardiovascular mortality at 1 year. Two studies assessing PPI versus no PPI in patients with UA/NSTEMI found a statistically significant increase in the risk of cardiovascular mortality at 1 year among patients treated with PPI (6.0% vs. 4.6%, adjusted HR 1.42; 95% CI, 1.14 to 1.76^197^ and adjusted HR 1.57; 95% CI, 1.36 to 1.82^154^). Another study153 assessing PPI versus no PPI in patients with UA/NSTEMI found no difference in the rate of cardiovascular mortality between the two treatment arms (1.2% vs. 1.9%, adjusted HR 0.56; 95% CI, 0.21 to 1.55). The SOE was rated insufficient for cardiovascular mortality at 1 year based on inconsistent and imprecise findings.

###### Effect on Nonfatal Myocardial Infarction Within First 3 Months

Three good-quality observational studies with 8943 patients reported the effect of PPIs on nonfatal MI within the first 3 months after hospital discharge for a UA/NSTEMI event. Two studies148,157 comparing PPI versus no PPI in patients with UA/NSTEMI, reported a nonsignificant difference in the rate of nonfatal MI in-hospital148 (2.0% vs. 1.4%, adjusted OR 1.15; 95% CI, 0.57 to 2.32) and at 30 days157 (3.0% vs. 2.0%, adjusted HR 1.3; 95% CI, 0.8 to 2.3). A case-control study174 found an increased risk of nonfatal MI events at 3 months among UA/NSTEMI patients treated with PPI versus those not treated with PPI (adjusted OR 1.27; 95% CI, 1.03 to 1.57). The SOE was rated insufficient for nonfatal MI within the first 3 months based on inconsistent and imprecise findings.

###### Effect on Nonfatal Myocardial Infarction at About 1 Year

Two studies (1 good-quality RCT, 1 good-quality observational) of omeprazole14,164 reported nonfatal MI, one at 6 months and one at 1 year. The RCT14 reporting the event at 6 months found a nonsignificant reduction of nonfatal MI events (1.2% vs. 1.5%; HR 0.92; 95% CI, 0.44 to 1.90, p=0.81) among patients treated with omeprazole. Similarly, the observational study164 found no effect of omeprazole versus placebo on nonfatal MI (6.5% vs. 6.5%; HR 1.0; 95% CI, 0.5 to 1.9).

Ten observational studies (8 good quality, 1 fair, 1 poor) reported the effect of any PPI on nonfatal MI at about 1 year (6 to 18 months).143,152,154,156-158,166,174,197,200 Of these studies, six reported only standard adjusted results, three reported both standard adjusted results and propensity adjusted-results, and one reported only propensity-adjusted results. We first did a meta-analysis that compared the two types of estimates. The overall estimate for the standard adjusted hazard ratios was 1.352 whereas the overall estimate for the propensity adjusted hazard ratios was 1.33. The chi-square test for the difference was 0.005 for 1 degree of freedom, p=0.941. Next we did a meta-analysis using the propensity-adjusted hazard ratio (P) when it was available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of this analysis is shown in Figure 43.

Figure 43 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on nonfatal myocardial infarction at about 1 year

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of 10 studies that shows an odds ratio of 1.33 (95% CI, 1.15 to 1.55), favoring no proton pump inhibitor.

The random-effects combined estimate was 1.33 (95% CI, 1.15 to 1.55). The result was highly significant (p<0.001).The Q-value for the analysis was 54.103 for 9 degrees of freedom (p<0.001). The I^2^ was 83.365. There was evidence of extreme heterogeneity. The SOE was rated low that favors no PPI for nonfatal MI at 1 year based on one RCT and one observational study of omeprazole that showed no difference in events or favored omeprazole and the meta-analysis of observational studies of nonspecific PPI that demonstrated significant heterogeneity, despite inconsistent and precise results.

###### Effect on Stroke at 30 Days and About 1 Year

Two RCTs (1 good quality, 1 poor) of omeprazole reported cerebrovascular events; one reported a transient ischemic attack (TIA) at 30 days,144 and the other reported stroke events at 6 months.14 Nonsignificant differences were found in the rate of TIA events in the poor-quality study144 and in the rate of stroke events in the good-quality RCT14 between patients treated with omeprazole versus those receiving placebo (TIA 2.3% vs. 1.0%; stroke 0.2% vs. 0.3%).

Five observational studies (4 good quality, 1 fair) reported the effect of any PPI on stroke at about 1 year (6 to 18 months).143,154,156,158,163 Of the five studies, four reported only standard adjusted results, and one reported both standard adjusted results and propensity-adjusted results. We did a meta-analysis using the propensity-adjusted hazard ratio (P) when it was available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of this analysis is shown in Figure 44.

Figure 44 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on stroke at about 1 year

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of five studies that shows an odds ratio of 1.49 (95% CI, 1.20 to 1.84), favoring no proton pump inhibitor.

The random-effects combined estimate was 1.49 (95% CI, 1.20 to 1.84). The result was highly significant (p<0.001). The Q-value for the analysis was 16.258 for 4 degrees of freedom (p=0.001). The I^2^ was 70.230. There was evidence of extreme heterogeneity. The SOE was rated low favoring no PPI for stroke at about 1 year based on two RCTs of omeprazole that showed no difference in events and the meta-analysis of observational studies of nonspecific PPI that demonstrated a benefit of no PPI but had significant heterogeneity, despite consistent and precise results.

###### Effect on Revascularization at 6 Months, 1 Year, and 4 Years

One good-quality RCT of omeprazole14 and one good-quality observational study of PPI versus no PPI166 with 22,326 patients reported revascularization results at 6 months. The RCT14 found a similar rate of revascularization among patients discharged on omeprazole compared with those discharged without omeprazole (4.0% vs. 4.6%). The observational study166 reporting the effect of PPIs on revascularization after hospital discharge for a UA/NSTEMI event, found no difference in the risk of revascularization at 6 months among patients treated with PPI compared with those not treated with PPI (adjusted HR 0.97; 95% CI, 0.79 to 1.21). The SOE was rated low for revascularization at 6 months based on imprecise findings.

One good-quality observational study of omeprazole reported repeat revascularization at 1 year164 in 588 UA/NSTEMI patients and found a similar rate of revascularization among patients discharged on omeprazole compared with those discharged without omeprazole (9.4% vs. 8.9%).

A random-effects meta-analysis of four observational studies of any PPI149,150,158,173 (all good quality), including 52,576 UA/NSTEMI patients reporting revascularization at 1 year reported standard adjusted results, and 1 study additionally reported propensity adjusted results.150 We first performed a meta-analysis where we preferentially used the propensity adjusted hazard ratio when available but used the standard adjusted hazard ratio when it was the only one available. The result of the analysis is shown in Figure 45.

Figure 45 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on revascularization at 1 year

CI = confidence interval; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of four studies that shows an odds ratio of 1.48 (95% CI, 1.21 to 1.82), favoring no proton pump inhibitor.

The fair-quality observational study167 of 315 UA/NSTEMI patients reporting the effect of PPI on revascularization (TVR) after hospital discharge for a UA/NSTEMI event found no difference in the risk of revascularization at 4 years among patients treated with PPI compared with those not treated with PPI (29.0% vs. 22%, adjusted HR 1.57; 95% CI, 0.80 to 3.03). The SOE was rated insufficient for revascularization at 4 years based on imprecise findings.

The random-effects combined estimate was 1.48 (95% CI, 1.21 to 1.82). The Q-value for the analysis was 11.092 for 3 degrees of freedom (p=0.011). The I^2^ was 72.955. There was evidence of heterogeneity which appeared to be due to the Banerjee study. As a sensitivity analysis, we performed a meta-analysis where we used only the adjusted hazard ratio from the Banerjee study. The random-effects combined estimate was 1.438 (95% CI, 1.215 to 1.703).The Q-value for the analysis was 13.347 for 3 degrees of freedom (p=0.004). The I^2^ was 77.523. There was evidence of heterogeneity that was due to the Ortolani study estimate.

The SOE was rated low that favors no PPI for revascularization at 1 year based on one observational study of omeprazole that showed no difference in events and the meta-analysis of four observational studies of nonspecific PPI that demonstrated significant heterogeneity.

###### Effect on Stent Thrombosis at 30 Days

Only one good-quality observational study157 of 3408 patients reporting the effect of PPI on stent thrombosis at 30 days after hospital discharge for a UA/NSTEMI event, found no significant difference in the rate of stent thrombosis between the two treatment arms (PPI 1.1% vs. 0.5%, adjusted HR 1.8; 95% CI, 0.7 to 4.7). The SOE was rated insufficient for stent thrombosis at 30 days based on imprecise findings.

###### Effect on Stent Thrombosis at About 1 Year

Two studies (1 good-quality RCT, 1 good-quality observational) of omeprazole reported stent thrombosis (definite, possible, probable) at 6 months14 and 1 year164 after hospital discharge for UA/NSTEMI. In the RCT, two cases of definite or probable stent thrombosis occurred in the placebo group and no cases occurred in the omeprazole group.14 A nonsignificant difference in the rate of stent thrombosis was found among patients discharged on omeprazole compared with those discharged without omeprazole (8.8% vs. 5.8%; HR 1.1; 95% CI, 0.7 to 1.8) at 1 year in the observational study.164

Six good-quality observational studies reported the effect of any PPI on stent thrombosis at about 1 year (6 to 18 months).145,146,153,157,197,200 Of these studies, four reported only standard adjusted results, and two reported only propensity-adjusted results. We first did a meta-analysis that compared the two types of estimates. The overall estimate for the standard adjusted hazard ratios was 1.35 whereas the overall estimate for the propensity-adjusted hazard ratios was 1.33. The chi-square test for the difference was 0.005 for 1 degree of freedom, p=0.941.Next we did a meta-analysis using the propensity-adjusted hazard ratio (P) when it was available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of the analysis is shown in Figure 46.

Figure 46 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on stent thrombosis at about 1 year

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of six studies that shows an odds ratio of 1.34 (95% CI, 1.17 to 1.55), favoring no proton pump inhibitor.

The random-effects combined estimate was 1.34 (95% CI, 1.17 to 1.55). The result was highly significant (p<0.001). The Q-value for the analysis was 14.845 for 5 degrees of freedom (p=0.011). The I^2^ was 66.318. There was evidence of heterogeneity. The SOE was rated low that favors no PPI for stent thrombosis at 1 year based on one RCT and one observational study of omeprazole that showed no difference in events and the meta-analysis of observational studies of nonspecific PPI that demonstrated heterogeneity, despite inconsistent and precise results.

###### Effect on Major Bleeding at 30 Days

Three good-quality observational studies with 7498 patients reported the effect of any PPI on major bleeding at 30 days.146,148,157 All three studies reported only standard adjusted (A) results. We did a meta-analysis of these studies as shown in Figure 47.

Figure 47 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on major bleeding at 30 days

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.73 (95% CI, 0.61 to 4.88).

The random-effects combined estimate was 1.73 (95% CI, 0.61 to 4.88). The result was not significant (p=0.302). The Q-value for the analysis was 7.252 for 2 degrees of freedom (p=0.027). The I^2^ was 72.422. There was evidence of heterogeneity. The SOE was rated insufficient for major bleeding at 30 days given the inconsistent and imprecise results.

###### Effect on Major Bleeding at About 1 Year

Four good-quality observational studies with 36,231 patients reported the effect of any PPI on major bleeding at about 1 year (6 to 18 months).145,146,197,200 Of these studies, three reported only standard adjusted results, and one reported only propensity-adjusted results. We first did a meta-analysis that compared the two types of estimates. The overall estimate for the standard adjusted hazard ratios was 1.27 whereas the overall estimate for the propensity-adjusted hazard ratios was 1.20. The chi-square test for the difference was 0.050 for 1 degree of freedom, p=0.823. Next we did a meta-analysis using the propensity-adjusted hazard ratio (P) when available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of the analysis is shown in Figure 48.

Figure 48 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on major bleeding at about 1 year

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of four studies that show an odds ratio of 1.26 (95% CI, 1.12 to 1.41), favoring no proton pump inhibitor.

The random-effects combined estimate was 1.26 (95% CI, 1.12 to 1.41). The result was highly significant (p <0.0001). The Q-value for the analysis was 5.933 for 3 degrees of freedom (p=0.115). The I^2^ was 49.435. There was some evidence of heterogeneity. The SOE was rated low that favors no PPI for major bleeding at about 1 year based on some heterogeneity with consistent results of a direct outcome and a narrow confidence interval.

###### Effect on Gastrointestinal Bleeding

Four RCTs (two good quality, 2 poor) of omeprazole reported gastrointestinal bleeding during the first year after hospital discharge.14,140,144,177 One RCT140 comparing omeprazole with famotidine reported a significantly lower incidence of overt upper GI bleeding at 4 months in the omeprazole group compared with the famotidine group (0.6% vs. 6.1%; HR 0.095; 95% CI, 0.005 to 0.504, p=0.0052). An RCT177 reported a significantly lower rate of upper GI bleeding at 14 days among patients treated with omeprazole compared with those not receiving omeprazole (5.3% vs. 14.6%, p=0.017). One RCT144 reported a nonsignificant difference in the rate of overt GI bleeding at 30 days between patients discharged on omeprazole compared with those discharged on placebo (0% vs. 2.0%). Another RCT14 reported a significantly lower rate of upper GI bleeding at 6 months among patients treated with omeprazole compared with those not receiving omeprazole (1.1% vs. 2.9%; HR 0.34; 95% CI, 0.18 to 0.63, p<0.001).

Four observational studies (three good quality, 1 poor) of any PPI reported GI bleeding with any PPI: two181,182 in-hospital, and two139,163 at long term in 23,555 patients. One study181 assessing the use of PPI versus no PPI, found no difference in the rate of in-hospital GI bleeding between the two treatment groups (0.7% vs. 0.6%, p=0.88). The other study182 found a significant increase in the rate of in-hospital GI bleeding among patients not receiving PPI compared with those treated with PPI (4.8% vs. 0.6%, p=0.001).

The two studies reporting GI events at longer followup found dissimilar results. One study139 found no differences in the risk of GI bleeding at 18 months between UA/NSTEMI patients treated with or without PPI (3.5% vs. 3.8%, HR 0.39; 95% CI, 0.04 to 3.26, p=0.38). The other study163 found a significant reduction in the risk of GI bleeding at 1 year among patients treated with PPI compared with those not treated with PPI (HR 0.50; 95% CI, 0.39 to 0.65).

Given the differences in the timing of followup in the RCTs (14 days, 30 days, 4 months, and 6 months) and the observational studies (in-hospital, 1 year, and 18 months), a meta-analysis was not performed, however the SOE was rated moderate that favors PPI for GI bleeding based on mostly consistent and precise findings from three of four randomized trials.

###### Effect on Minor Bleeding

One good-quality observational study146 of 1346 UA/NSTEMI patients evaluating the use of PPI versus no PPI found no differences in the rate of minor bleeding between the two treatments groups both in-hospital (3.5% vs. 3.1%) and at 1 year followup (5.3% vs. 5.4%). The SOE was rated insufficient for minor bleeding outcomes based on imprecise results.

###### Effect on Rehospitalization at 3 Months

One good-quality observational study159 of 5862 patients reporting the effect of PPI on rehospitalization after hospital discharge for a UA/NSTEMI event found a significant increase in the rate of rehospitalization at 3 months among patients treated with PPI compared with those not treated with PPI (24.6% vs. 10.1%, adjusted HR 1.32; 95% CI, 1.00 to 1.73). The SOE was rated low that favors no PPI for rehospitalization at 3 months based on significant results of an indirect outcome.

###### Effect on Rehospitalization at About 1 Year

Four good-quality observational studies with 16,925 patients reported the effect of a PPI on rehospitalization at about 1 year (6 to 18 months).141,149,153,161 Of these studies, two reported only standard adjusted results, one reported propensity-adjusted result, and one reported both. We first did a meta-analysis that compared the two types of estimates. The overall estimate for the standard adjusted hazard ratios was 1.89 whereas the overall estimate for the propensity-adjusted hazard ratios was 0.93. The chi-square test for the difference was 1.500 for 1 degree of freedom, p=0.221. Next we did a meta-analysis using the propensity-adjusted hazard ratio (P) when it was available and the standard adjusted hazard ratio (A) when the propensity-adjusted was not available. The result of this analysis is shown in Figure 49.

Figure 49 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on rehospitalization at about 1 year

A = standard adjusted hazard ratio; CI = confidence interval; P = propensity-adjusted hazard ratio; PPI = proton pump inhibitor

This figure displays a forest plot of a random-effects meta-analysis of four studies that shows an odds ratio of 1.70 (95% CI, 0.86 to 3.34).

The random-effects combined estimate was 1.70 (95% CI, 0.86 to 3.34). The result was not significant (p=0.126). The Q-value for the analysis was 14.240 for 3 degrees of freedom (p=0.003). The I^2^ was 78.932. There was evidence of heterogeneity. The SOE was rated insufficient for rehospitalization at about 1 year based on observational studies with inconsistent results of an indirect outcome and a wide confidence interval.

##### Summary of Results for Dual Antiplatelet Therapy With and Without PPI

In our analysis of DAPT with and without concomitant PPI therapy, we found that omeprazole was the most commonly studied PPI in both randomized trials and observational registries. These patient populations were treated with aspirin plus clopidogrel. Event rates were lower in patients who did not receive PPI medication for the various clinical outcomes: composite ischemic endpoints at 1 year, all-cause mortality at 6 years, nonfatal MI at 1 year, stroke at 1 year, revascularization at 1 year, or rehospitalization at 3 months, stent thrombosis at 1 year, and major bleeding at 1 year. There was no difference between groups for all-cause mortality at 1 year and revascularization at 6 months. As expected, GI bleeding was lower in patients treated with PPI medication. The findings were inconsistent (i.e., showing no differences between groups or showing increased event rates in the PPI group), and the evidence base was insufficient for all-cause mortality within the first 3 months, cardiovascular mortality at 1 year, nonfatal MI within the first 3 months, revascularization at 4 years, stent thrombosis at 30 days, major bleeding at 30 days, minor bleeding, and rehospitalization at 1 year.

The detailed SOE ratings are shown in Table 25. Odds ratios less than 1 favor PPI use; odds ratios greater than 1 favor no PPI use.

Table 25 Detailed strength of evidence for UA/NSTEMI patients treated with dual antiplatelet therapy with and without proton pump inhibitor

Number of Studies (Patients) | Domains | | | | SOE and Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
Composite Ischemic Endpoints at About 1 Year | | | | | Low SOE
23 (272,311) | 2 RCTs/Both good quality 21 observational/19 good quality, 2 fair | Inconsistent | Direct | Precise | RCTs of omeprazole showed no difference; however, meta-analysis of observational studies of any PPI showed adj HR 1.35 (1.18 to 1.54), which favors no PPI. The discrepancy between the RCTs and the observational studies makes it difficult to draw a firm conclusion about the effect.
Composite of All-Cause Mortality or MI at About 1 Year | | | | | Moderate SOE
3 (60,389) | 3 observational/All good quality | Consistent | Direct | Precise | Adj HR 1.27 (1.12 to 1.43) Favors no PPI
All-Cause Mortality Within First 3 Months | | | | | Insufficient SOE
3 (8943) | 3 observational/All good quality | Inconsistent | Direct | Imprecise | Two studies showed no differences in mortality rates; one study showed a statistically significant increase in mortality in PPI group Adj HR 2.2 (1.1 to 4.3)
All-Cause Mortality at About 1 Year | | | | | Moderate SOE
20 (264,172) | 2 RCTs/1 good quality, 1 poor 18 observational/17 good quality, 1 fair | Consistent | Direct | Precise | RCTs of omeprazole showed no difference or favored omeprazole, and the meta-analysis of observational studies of any PPI showed adj HR 1.17 (0.92 to 1.48) No difference
All-Cause Mortality at 6 Years | | | | | Low SOE
1 (23,200) | Observational/Good quality | NA | Direct | Precise | Adj HR 1.32 (1.00 to 1.73) Favors no PPI
Cardiovascular Mortality at 1 Year | | | | | Insufficient SOE
3 (76,184) | 3 observational/All good quality | Inconsistent | Direct | Imprecise | Two out of 3 studies showed statistically significant increase in CV mortality in PPI group
Nonfatal MI Within First 3 Months | | | | | Insufficient SOE
3 (8943) | 3 observational/All good quality | Inconsistent | Direct | Imprecise | Two studies showed no statistically significant difference in MI rates; one study showed statistically significant increase in MI events in PPI group
Nonfatal MI at About 1 Year | | | | | Low SOE
12 (225,687) | 1 RCT/Good quality 11 observational/9 good quality, 1 fair, 1 poor | Inconsistent | Direct | Precise | The RCT and observational study of omeprazole showed no difference; however, the meta-analysis of observational studies of any PPI showed adj HR 1.33 (1.15 to 1.55), which favors no PPI. The discrepancy between the omeprazole studies and the observational studies of any PPI makes it difficult to draw a firm conclusion about the effect.
Stroke at About 1 Year | | | | | Low SOE
7 (165,212) | 2 RCTs/1 good quality, 1 poor 5 observational/4 good quality, 1 fair | Consistent | Direct | Precise | RCTs of omeprazole showed no difference; however, the meta-analysis of observational studies of any PPI showed adj HR 1.49 (1.20 to 1.84), which favors no PPI. The discrepancy between the RCTs and the observational studies makes it difficult to draw a firm conclusion about the effect.
Revascularization at 6 Months | | | | | Low SOE
2 (22,326) | 1 RCT, 1 observational/Both good quality | Consistent | Direct | Imprecise | Both studies showed no difference in revascularization rates
Revascularization at 1 Year | | | | | Low SOE
5 (53,164) | 5 observational/All good quality | Inconsistent | Direct | Precise | Observational study of omeprazole showed no difference. Meta-analysis of observational studies of any PPI showed adj OR 1.48 (1.21 to 1.82), which favors no PPI
Revascularization at 4 Years | | | | | Insufficient SOE
1 (315) | Observational/Fair quality | NA | Direct | Imprecise | Insufficient evidence due to imprecision: no statistically significant difference in revascularization rate between groups
Stent Thrombosis at 30 Days | | | | | Insufficient SOE
1 (3408) | Observational/Good quality | NA | Direct | Imprecise | No statistically significant difference in stent thrombosis rate between groups
Stent Thrombosis at About 1 Year | | | | | Low SOE
8 (45,198) | 1 RCT/1 good quality 7 observational/All good quality | Inconsistent | Direct | Precise | The RCT and observational study of omeprazole showed no difference, however the meta-analysis of observational studies of any PPI showed adj HR 1.34 (1.17 to 1.55), which favors no PPI. The discrepancy between the RCT and the observational studies makes it difficult to draw a firm conclusion about the effect.
Major Bleeding at 30 Days | | | | | Insufficient SOE
3 (7498) | 3 observational/All good quality | Inconsistent | Direct | Imprecise | Adj HR 1.73 (0.61 to 4.88)
Major Bleeding at About 1 Year | | | | | Low SOE
4 (36,231) | 4 observational/All good quality | Consistent | Direct | Precise | Adj HR 1.26 (1.12 to 1.41) Favors no PPI
GI Bleeding | | | | | Moderate SOE
8 (28,032) | 4 RCTs/2 good quality, 2 poor 4 observational/3 good quality, 1 poor | Consistent | Direct | Precise | 3 out of 4 RCTs of omeprazole and 2 out of 4 observational studies of any PPI showed statistically significant lower rates of GI bleed in the PPI group Favors PPI
Minor Bleeding | | | | | Insufficient SOE
1 (1346) | Observational/Good quality | NA | Direct | Imprecise | No difference in minor bleed in-hospital or at 1 year
Rehospitalization at 3 Months | | | | | Low SOE
1 (5862) | Observational/Good quality | NA | Indirect | Precise | Significant increase in rehospitalization in PPI group at 3 months Adj HR 1.32 (1.00 to 1.73) Favors no PPI
Rehospitalization at About 1 Year | | | | | Insufficient SOE
4 (16,925) | 4 observational/All good quality | Inconsistent | Indirect | Imprecise | Adj HR 1.70 (0.86 to 3.34)

CI = confidence interval; CV = cardiovascular; GI = gastrointestinal; HR = hazard ratio; MI = myocardial infarction; NA = not applicable; OR = odds ratio; PPI = proton pump inhibitor; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

##### 4b Aspirin Monotherapy With and Without PPI

Two observational studies (both good quality)143,148 reported the results of 52,196 UA/NSTEMI patients who were given aspirin monotherapy (i.e., not prescribed clopidogrel) and then either treated or not treated with PPIs.

###### Effect on Composite Endpoint of Cardiovascular Death, Nonfatal MI, or Stroke at 1 Year

Both observational studies143,148 compared the effect of PPI versus no PPI on the composite of cardiovascular death, nonfatal MI, or stroke at 1 year. One study143 showed an increased risk among patients receiving PPI at hospital discharge (PPI 22.9% vs. no PPI 15.2%, propensity-score adj HR 1.61; 95% CI, 1.45 to 1.79). The other study148 showed no difference in the risk of the composite outcome at 1 year among patients receiving PPI at hospital discharge (PPI 42% vs. no PPI 38%; adj HR 1.00; 95% CI, 0.88 to 1.15). The SOE was rated insufficient for this composite endpoint at 1 year based on two observational studies reporting adjusted findings with inconsistent results of a direct outcome and precise results.

###### Effect on In-Hospital Outcomes

One good-quality observational study148 comparing PPI with no PPI among 2744 UA/NSTEMI patients receiving aspirin monotherapy reported the in-hospital rate of individual components of the composite outcomes and major bleeding. The study found no differences in the rate of in-hospital all-cause mortality (PPI 12.8% vs. no PPI.15.9%, adj OR 0.96; 95% CI, 0.49 to 1.88), nonfatal MI (3.4% vs. 2.9%, adj HR 1.50; 95% CI, 0.41 to 5.43), stroke (1.5% vs.1.8%, adj HR 0.75; 95% CI, 0.11 to 4.85), or major bleeding (3.8% vs. 2.5%, adj OR 1.30; 95% CI, 0.38 to 4.39). The SOE was rated insufficient for all four in-hospital outcomes (all-cause mortality, nonfatal MI, stroke, and major bleeding) based on one study with imprecise results.

###### Effect on All-Cause Mortality at 1 Year

Both observational studies143,148 compared the effect of PPI versus no PPI on all-cause mortality at 1 year. One study143 showed an increased risk among patients receiving PPI at hospital discharge (PPI 15.9% vs. no PPI 10.3%, adj HR 2.38; 95% CI, 2.12 to 2.67). The other study148 showed no difference in all-cause mortality at 1 year among patients receiving PPI at hospital discharge (PPI 38% vs. no PPI 34%; adj HR 0.99; 95% CI, 0.86 to 1.14). The SOE was rated insufficient for all-cause mortality at 1 year based on two observational studies reporting adjusted findings with inconsistent results of a direct outcome and precise results.

###### Effect on Nonfatal MI at 1 Year

One good-quality observational study143 with 49,452 patients comparing the effect of PPI versus no PPI on nonfatal MI at 1 year showed an increased risk among patients receiving PPI at hospital discharge (11.5% vs.7.1%, adj HR 1.33; 95% CI, 1.13 to 1.56). The SOE was rated low for nonfatal MI at 1 year based on one good-quality observational study reporting adjusted results.

###### Effect on Stroke at 1 Year

Both observational studies143,148 compared the effect of PPI versus no PPI on stroke at 1 year. One study143 showed no difference in the rate of stroke at 1 year (7.9% vs.7.7%, adj HR 1.20; 95% CI, 0.99 to 1.46). The other study148 showed no difference in stroke at 1 year among patients receiving PPI at hospital discharge (PPI 1.5 % vs. no PPI 1.8%; adj HR 0.75; 95% CI, 0.11 to 4.85). The SOE was rated low for stroke at 1 year based on two good-quality observational studies reporting adjusted findings with consistent but imprecise results of a direct outcome.

##### Summary of Results for Aspirin Monotherapy With and Without PPI

In our analysis of aspirin monotherapy with and without concomitant PPI therapy, we presented the findings from two good-quality observational studies that compared clinical outcomes between patients receiving different PPI medications with patients who did not receive a PPI. In contrast to the previous section, these patient populations were not prescribed dual antiplatelet therapy; therefore, this evaluation focuses on the addition of PPIs to aspirin monotherapy. There was insufficient evidence for the effect of PPIs on aspirin monotherapy for in-hospital outcomes; only one study of 2744 patients reported the rates of all-cause mortality, nonfatal MI, stroke, and major bleeding. That study found no significant differences between the PPI and no PPI groups. There were inconsistent results for composite ischemic events (cardiovascular mortality, nonfatal MI, or stroke) and lower all-cause mortality at 1 year of followup, with one study showing an increased risk of events in the PPI group and the other study showing no difference. One study reported rates of nonfatal MI at 1 year and showed an increased risk of MI events in the PPI group. Both studies showed no difference in stroke events at 1 year. Detailed SOE ratings are shown in Table 26. Odds ratios less than 1 favor PPI use; odds ratios greater than 1 favor no PPI use.

Table 26 Detailed strength of evidence for UA/NSTEMI patients treated with aspirin monotherapy with and without proton pump inhibitor

Number of Studies (Patients) | Domains | | | | SOE and Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
Composite of CV Death, Nonfatal MI, or Stroke at 1 Year | | | | | Insufficient SOE
2 (52,196) | 2 observational/Both good quality | Inconsistent | Direct | Precise | One study reported increased risk among PPI group Adj HR 1.61 (1.45 to 1.79), while the other study showed no difference Adj HR 1.00 (0.88 to 1.15)
All-cause Mortality (In-Hospital) | | | | | Insufficient SOE
1 (2744) | Observational/Good quality | NA | Direct | Imprecise | Adj OR 0.96 (0.49 to 1.88)
All-cause Mortality at 1 Year | | | | | Insufficient SOE
2 (52,196) | 2 observational/Both good quality | Inconsistent | Direct | Precise | One study reported increased risk among PPI group Adj HR 2.38 (2.12 to 2.67), while the other study showed no difference Adj HR 0.99 (0.86 to 1.14)
Nonfatal MI (In-Hospital) | | | | | Insufficient SOE
1 (2744) | Observational/Good quality | NA | Direct | Imprecise | Adj HR 1.50 (0.41 to 5.43)
Nonfatal MI at 1 Year | | | | | Low SOE
1 (49,452) | Observational/Good quality | NA | Direct | Precise | Adj HR 1.33 (1.13 to 1.56) Increased risk for PPI group
Stroke (In-Hospital) | | | | | Insufficient SOE
1 (2744) | Observational/Good quality | NA | Direct | Imprecise | Adj HR 0.75 (0.11 to 4.85)
Stroke at 1 Year | | | | | Low SOE
2 (52,196) | 2 observational/Both good quality | Consistent | Direct | Imprecise | Both studies showed no difference Adj HR 1.20 (0.99 to 1.46) and Adj HR 0.75 (0.11 to 4.85)
Major Bleeding ( In-Hospital) | | | | | Insufficient SOE
1 (2744) | Observational/Good quality | NA | Direct | Imprecise | Adj OR 1.30 (0.38 to 4.39)

CI = confidence interval; CV = cardiovascular; MI = myocardial infarction; NA = not applicable; OR = odds ratio; PPI = proton pump inhibitor; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

##### Findings by Subgroup Across All PPI/No PPI Comparisons (Omeprazole, Dual Antiplatelet Therapy, and Aspirin Monotherapy) (KQ 3d)

Thirteen studies (11 good quality, 1 fair, 1 poor) reported variations in treatment effectiveness by subgroup. Subgroups analyzed were diabetes (2 studies), sex (1), age (2), the use or timing of PCI (1), chronic renal disease (1), type of PPI (9), timing of PPI (3), dose of PPI (1), and clopidogrel use (2).Table H-3 in Appendix H presents the results data for these subgroups.

###### Diabetes

Two good-quality observational studies146,154 assessing PPI versus no PPI in 57,752 UA/NSTEMI patients, reported outcomes among patients with diabetes. One study154 reported the rate of the composite outcome (cardiovascular death, nonfatal MI, or stroke) by clopidogrel use among patients with and without diabetes. The study found a significant increase in the risk of composite outcome at 1 year among patients treated with PPI and concomitant clopidogrel, both in patients with diabetes (HR 1.36; 95% CI, 1.10 to 1.70) and without diabetes (HR 1.28; 95% CI, 1.16 to 1.43). A significant increase in the risk of composite outcome at 1 year was also found among patients treated with PPI but no concomitant clopidogrel, both in patients with diabetes (HR 1.25; 95% CI, 1.06 to 1.45) and those without diabetes (HR 1.35; 95% CI, 1.26 to 1.44).

The other study146 assessing PPI versus no PPI in UA/NSTEMI patients, reported the rate of composite outcome (all-cause mortality, nonfatal MI, stroke, or rehospitalization) among patients with and without diabetes and found a nonsignificant increase in the risk of composite outcomes in both groups (diabetes OR 1.31; 95% CI, 0.38 to 4.53; without diabetes OR 1.72; 95% CI, 0.61 to 4.88).

###### Sex

Only one good-quality observational study154 assessing PPI versus no PPI in 56,406 UA/NSTEMI patients reported the rate of the composite outcome (cardiovascular death, nonfatal MI, or stroke) by clopidogrel use among male and female patients. The study found a significant increase in the risk of composite outcome at 1 year among patients treated with PPI and concomitant clopidogrel, both in women (HR 1.18; 95% CI, 1.00 to 1.37) and men (HR 1.38; 95% CI, 1.23 to 1.58). A significant increase in the risk of the composite outcome at 1 year was found also among patients treated with PPI but no concomitant clopidogrel, both women (HR 1.32; 95% CI, 1.21 to 1.44) and men (HR 1.34; 95% CI, 1.23 to 1.46).

###### Age

Two good-quality observational studies146,154 assessing PPI versus no PPI in 57,752 UA/NSTEMI patients reported outcomes by age group. One study154 reported the rate of the composite outcome (cardiovascular death, nonfatal MI, or stroke) by clopidogrel use among patients of under age 70 and over age 70. This study found a significant increase in the risk of the composite outcome at 1 year among patients treated with PPI and concomitant clopidogrel both age groups (≤70 years HR 1.37; 95% CI, 1.19 to 1.62 and >70 years HR 1.30; 95% CI, 1.18 to 1.43). A significant increase in the risk of composite outcome at 1 year was found among patients treated with PPI but no concomitant clopidogrel in the older patients group (> 70 years HR 1.33; 95% CI, 1.24 to 1.43) but not the younger group (≤70 years HR 1.19; 95% CI, 0.99 to 1.39).

The other study146 reporting the rate of a composite outcome (all-cause mortality, nonfatal MI, stroke, or rehospitalization) among patients by age group (≤75 vs. >75 years), found a nonsignificant increase in the risk of composite outcomes in both groups (≤75 years OR 1.46; 95% CI, 0.62 to 3.46 and >75 years OR 1.61; 95% CI, 0.35 to 7.37).

###### Chronic Kidney Disease

Only one good-quality observational study146 comparing PPI versus no PPI in 1346 UA/NSTEMI patients reported rate of composite outcome (all-cause mortality, nonfatal MI, stroke, or rehospitalization) among patients by renal function (CKD vs. no CKD). This study found a nonsignificant increase in the risk of composite outcomes in both groups (CKD OR 0.65; 95% CI, 0.18 to 2.36 and no CKD OR 2.48; 95% CI, 0.76 to 8.06).

###### Type of PPI

Nine observational studies137,146,148,154,156,163,166,173,200 (7 good quality, 1 fair, 1 poor) assessing PPI versus no PPI in 153,195 UA/NSTEMI patients reported outcomes by type of PPI. Table 27 summarizes the results reported by each study for each PPI. The studies by Charlot et al.154 and Schmidt et al.137 reported the rate of a composite outcome (Charlot: cardiovascular death, nonfatal MI, or stroke; Schmidt: cardiovascular death, nonfatal MI, stroke, stent thrombosis, or target lesion revascularization) by concomitant clopidogrel use and by type of PPI (pantoprazole, omeprazole, lansoprazole, esomeprazole). Both studies found significant increases in the risk of the composite outcome at 1 year among patients treated with PPI and concomitant clopidogrel for all types of PPI. Similarly both studies also found increases in the risk of the composite outcome at 1 year among patients treated with PPI but no concomitant clopidogrel for all types of PPI, with the results from the Charlot study being statistically significant. A Cox proportional hazards regression analysis in the Charlot study demonstrated no difference in risk associated with the type of PPI independent of clopidogrel treatment, and interaction effect calculations in the Schmidt study resulted in similar findings.

Table 27 Summary of findings by type of proton pump inhibitor prescribed

Study Details | Outcome(s) Effect Estimate (95% CI)
Study Details | Esomeprazole | Lansoprazole | Omeprazole | Pantoprazole | Rabeprazole
Charlot, 2010^154^ Total N: 56,406 Quality: Good | [underlined: CV death/MI/CVA 1 yr] With clopidogrel HR 1.29 (1.09 to1.48) Without clopidogrel HR 1.53 (1.39 to 1.71) | [underlined: CV death/MI/CVA 1 yr] With clopidogrel HR 1.47 (1.21 to 1.81) Without clopidogrel HR 1.45 (1.27 to 1.68) | [underlined: CV death/MI/CVA 1 yr] With clopidogrel HR 1.40 (1.10 to 1.78) Without clopidogrel HR 1.25 (1.09 to 1.41) | [underlined: CV death/MI/CVA 1 yr] With clopidogrel HR 1.42 (1.22 to 1.67) Without clopidogrel HR 1.5 (1.36 to 1.69) | NR
Ho, 2009^173^ Total N: 8790 Quality: Good | NR | NR | [underlined: Death/rehospitalization] Adj OR 1.24 (1.08 to 1.41) | NR | [underlined: Death/rehospitalization] Adj OR 2.83 (1.96 to 4.0)
O'Donoghue, 2009^200^ Total N: 4529 Quality: Good | [underlined: CV death/MI/CVA] Clopidogrel Adj HR 1.07 (0.75 to 1.52) Prasugrel Adj HR 0.86 (0.55 to 1.33) [underlined: MI] Clopidogrel Adj HR 1.18 (0.81 to 1.73) Prasugrel Adj HR 0.92 (0.57 to 1.48) | [underlined: CV death/MI/CVA] Clopidogrel Adj HR 1.00 (0.63 to 1.59) Prasugrel Adj HR 0.98 (0.61 to 1.57) [underlined: MI] Clopidogrel Adj HR 0.86 (0.51 to 1.46) Prasugrel Adj HR 1.08 (0.66 to 1.79) | [underlined: CV death/MI/CVA] Clopidogrel Adj HR 0.91 (0.72 to 1.15) Prasugrel Adj HR 1.04 (0.81 to 1.34) [underlined: MI] Clopidogrel Adj HR 0.95 (0.73 to 1.23) Prasugrel Adj HR 1.02 (0.76 to 1.36) | [underlined: CV death/MI/CVA] Clopidogrel Adj HR 0.94 (0.74 to 1.18) Prasugrel Adj HR 1.09 (0.86 to 1.39) [underlined: MI] Clopidogrel Adj HR 0.97 (0.75 to 1.24) Prasugrel Adj HR 1.09 (0.83 to 1.43) | Not analyzed since only 66 patients were given this at baseline
Rassen, 2009^166^ Total N: 18,565 Quality: Good | NR | NR | [underlined: Death/MI] HR 1.17 (0.68 to 2.01) | [underlined: Death/MI] HR 1.26 (0.93 to 1.71) | NR
Ray, 2010^163^ Total N: 20,596 Quality: Good | [underlined: CV death/MI/CVA] HR 0.71 (0.48 to 1.06 [underlined: GI bleeding] HR 0.43 (0.18 to 1.07) | [underlined: CV death/MI/CVA] HR 1.06 (0.77 to 1.45) [underlined: GI bleeding] HR 0.71 (0.43 to 1.18) | [underlined: CV death/MI/CVA] HR 0.79 (0.54 to 1.15) [underlined: GI bleeding] HR 0.43 (0.16 to 1.13) | [underlined: CV death/MI/CVA] HR 1.08 (0.88 to 1.32) [underlined: GI bleeding] HR 0.46 (0.33 to 0.63) | [underlined: CV death/MI/CVA] HR 0.54 (0.30 to 0.97) [underlined: GI bleeding] HR 0.25 (0.03 to 2.01)
Rossini, 2011^146^ Total N: 1346 Quality: Good | NR | MACE in-hospital: 2.2% MACE at 1 yr: 7.8% Major bleeding in-hospital: 1.3% Major bleeding at 1 yr: 3.3% Minor bleeding in-hospital: 2.9% Minor bleeding at 1 yr: 5.1% Total mortality at 1 yr: 2.1% Stent thrombosis at 1 yr: 2.1% | MACE in-hospital: 2.5% MACE at 1 yr: 4.2% Major bleeding in-hospital: 1.6% Major bleeding at 1 yr: 3.2% Minor bleeding in-hospital: 7.1% Minor bleeding at 1 yr: 9.6% Total mortality: 0.8% Stent thrombosis at 1 yr: 1.7% | MACE in-hospital: 4.1%; p=0.346 MACE at 1 yr: 8.1%; p=0.465 Major bleeding in-hospital: 1.1%; p=0.936 Major bleeding at 1 yr: 3.4%; p=0.996 Minor bleeding in-hospital: 1.1% p=0.009 Minor bleeding at 1 yr: 3.4% p=0.052 Total mortality: 3.1%; p=0.424 Stent thrombosis at 1 yr: 3.1%; p=0.671 | NR
Schmidt, 2012^137^ Total N: 13,001 Quality: Poor | [underlined: CV death/MI/stroke/stent thrombosis/revascularization] With clopidogrel HR 1.37 (1.04 to 1.79) Without clopidogrel HR 1.03 (0.74 to 1.44) | [underlined: CV death/MI/stroke/stent thrombosis/revascularization] With clopidogrel HR 1.28 (0.88 to 1.87) Without clopidogrel HR 1.17 (0.79 to 1.75) | [underlined: CV death/MI/stroke/stent thrombosis/revascularization] With clopidogrel HR 1.09 (0.69 to 1.72) Without clopidogrel HR 1.08 (0.71 to 1.66) | [underlined: CV death/MI/stroke/stent thrombosis/revascularization] With clopidogrel HR 1.55 (1.09 to 2.19) Without clopidogrel HR 1.05 (0.67 to 1.66) | NR
Simon, 2011^148^ FAST-MI Study Total N: 2744 Quality: Good | Death/MI/CVA in-hospital: Adj OR 0.77 (0.41 to 1.46) Death/MI/CVA at 1 yr: Adj OR 1.05 (0.62 to 1.77) Total mortality: Adj OR 0.72 (0.30 to 1.7) Nonfatal MI: Adj OR 1.20 (0.44 to 3.30) Stroke: Adj OR 0.54 (0.14 to 2.16) Bleeding: Adj OR 0.97 (0.33 to 2.86) | Death/MI/CVA in-hospital: Adj OR 0.59 (0.07 to 4.72) Death/MI/CVA at 1 yr: Adj OR 0.40 (0.05 to 2.95) Total mortality: Adj OR 1.30 (0.15 to 11.5) Nonfatal MI: 0 Stroke: 0 Bleeding: Adj OR 1.82 (0.22 to 15.3) | Death/MI/CVA in-hospital: Adj OR 0.92 (0.59 to 1.43) Death/MI/CVA at 1 yr: Adj OR 0.82 (0.54 to 1.24) Total mortality: Adj OR 1.16 (0.66 to 2.05) Nonfatal MI: Adj OR 1.18 (0.55 to 2.52) Stroke: Adj OR 0.14 (0.03 to 0.67) Bleeding: Adj OR 0.94 (0.44 to 1.98) | Death/MI/CVA in-hospital: Adj OR 1.31 (0.54 to 3.17) Death/MI/CVA at 1 yr: Adj OR 1.79 (0.95 to 3.37) Total mortality: Adj OR 1.00 (0.27 to 3.68) Nonfatal MI: Adj OR 1.22 (0.26 to 5.77) Stroke: Adj OR 1.78 (0.36 to 8.83) Bleeding: 0 | NR
Van Boxel, 2010^156^ Total N: 18,139 Quality: Fair | Death/MI/CVA: HR 1.83 (1.52 to 2.21) | NR | Death/MI/CVA:HR1.62 (1.38 to 1.91) | Death/MI/CVA: HR 1.83 (1.61 to 2.08) | Death/MI/CVA: HR 1.76 (1.07 to 2.88)

Adj = adjusted; CI = confidence interval; CV = cardiovascular; CVA = cardiovascular accident; GI = gastrointestinal; HR = hazard ratio; MACE = major adverse cardiovascular events; MI = myocardial infarction; N = number of patients; NR = not reported; OR = odds ratio; PPI = proton pump inhibitor

The study by Ho173 found a significant increase in the composite of all-cause mortality or rehospitalization both with omeprazole and with rabeprazole. A third study by Rassen166 found a nonsignificant increase in the composite of all-cause mortality or nonfatal MI with omeprazole as well as with pantoprazole.

The study by Ray163 found a nonsignificant difference in the composite of cardiovascular mortality, nonfatal MI, or stroke with omeprazole, pantoprazole, esomeprazole, and lansoprazole. Only the treatment with rabeprazole showed a significant reduction in the composite outcome (HR 0.54; 95% CI, 0.30 to 0.97). The same study evaluated the effect of different PPIs on the incidence of GI bleeding and found a nonsignificant reduction in GI bleeding with omeprazole, or esomeprazole, or lansoprazole, or rabeprazole. However, treatment with pantoprazole showed a significant reduction in the incidence of GI bleeding (HR 0.46; 95% CI, 0.33 to 0.63).

The study by Rossini146 found no differences in event rate for different outcomes by PPI type: in-hospital MACE and major bleeding. Only in-hospital minor bleeding was lower in the pantoprazole (1.1%) and lansoprazole group (2.9%, p=0.009) compared with omeprazole (7.1%). No differences in event rates by PPI were found for all outcomes at 1 year, all-cause mortality, stent thrombosis, major bleeding, and minor bleeding.

The study by Simon148 found no significant differences in the risk of different outcomes with each PPI studied. Patients treated with esomeprazole, lansoprazole, omeprazole, and pantoprazole were at similar risk of the composite outcome of death, MI, or stroke (in-hospital and at 1 year), and individual outcomes of total mortality nonfatal MI, stroke, or bleeding compared with those not receiving those PPIs.

The study by van Boxel156 found a significant increase in the composite outcome (all-cause mortality, nonfatal MI, or stroke) with omeprazole, pantoprazole, esomeprazole and rabeprazole.

The study by O'Donoghue200 found no significant differences in event rates by type of PPI (omeprazole, esomeprazole, pantoprazole, or lansoprazole) at 6 months for myocardial infarction, or the composite of cardiovascular death, myocardial infarction, or stroke for patients randomized to clopidogrel or prasugrel in the TRITON-TIMI 38 trial. Rabeprazole was not analyzed given the small number of patients (n=66) receiving it at baseline. In addition, they reported that use of an H2 receptor antagonist or PPI at baseline was not associated with risk of cardiovascular death, myocardial infarction, or stroke for patients randomly assigned to clopidogrel (adj HR 0.80; 95% CI 0.51 to 1.26) or prasugrel (adj HR 0.91; 95% CI 0.55 to 1.51).

###### Timing of PPI

Three observational studies152,158,174 (2 good quality, 1 poor quality) comparing PPI versus no PPI in 43,136 UA/NSTEMI patients reported outcomes by timing of PPI use. One study158 found a significant increase in the rate of major cardiovascular events at 1 year among patients with no prior PPI use (PPI vs. no PPI 27.8% vs. 17.9%, HR 1.57; 95% CI, 1.44 to 1.71) but not among patients who were on PPI already at hospital admission (PPI vs. no PPI 23.2% vs. 19.2%, HR 1.24; 95% CI, 0.98 to 1.71). Another study174 found no difference in the rate of nonfatal MI among patients with both prior use (HR 0.86; 95% CI, 0.63 to 1.19) and remote use (HR 0.81; 95% CI, 0.46 to 1.41). Another study152 comparing current PPI use with past PPI use found no difference in the rate of nonfatal MI among patients (OR 0.95; 95% CI, 0.38 to 2.41).

###### Dose of PPI

One good-quality observational study163 comparing PPI versus no PPI in 20,596 UA/NSTEMI patients, assessed the effect of a low-dose or high-dose PPIs on gastroduodenal bleeding and composite cardiovascular events. The study found that both low doses and high doses had similar rates of composite cardiovascular events (cardiovascular death, nonfatal MI, stroke) (low dose HR 1.0; 95% CI, 0.81 to 1.22 and high dose HR 0.94; 95% CI, 0.75 to 1.17). Low doses and high doses of PPI were both associated with a lower risk of gastroduodenal bleeding (low dose HR 0.48; 95% CI, 0.36 to 0.64 and high dose HR 0.53; 95% CI, 0.32 to 0.89).

#### 5 Dual Antiplatelet Versus Triple Therapy (KQ 3c)

Fourteen studies (all observational) compared dual antiplatelet therapy (DAPT), defined as aspirin with oral antiplatelet, with triple therapy, defined as dual antiplatelet therapy with an oral anticoagulant, in the postdischarge treatment of 97,067 total patients with UA/NSTEMI and a long-term indication for anticoagulation. The dual versus triple therapy comparisons studied included:

- Seven studies comparing DAPT (with aspirin and clopidogrel) with triple therapy (with oral anticoagulant, aspirin, and clopidogrel)135,175,180,186,189,195,196
- One study comparing warfarin with no warfarin among patients with atrial fibrillation-complicating a UA/NSTEMI event165
- One study comparing DAPT (aspirin plus clopidogrel) with two triple therapy arms—one consisting of oral anticoagulant, aspirin, and clopidogrel, and one consisting of LMWH, aspirin, and clopidogrel178
- One study comparing triple therapy (oral anticoagulant, aspirin, and clopidogrel) with warfarin plus aspirin or thienopyridine185
- Two studies comparing aspirin and/or thienopyridine versus oral anticoagulant with or without an antiplatelet agent132,188
- One study with five treatment arms comparing aspirin, warfarin, aspirin plus warfarin, aspirin plus a thienopyridine (DAPT), and aspirin plus warfarin plus a thienopyridine (triple therapy).190
- One study comparing monotherapy with aspirin, oral anticoagulant, or clopidogrel; aspirin plus oral anticoagulant; aspirin plus clopidogrel (DAPT); oral anticoagulant plus clopidogrel; and aspirin plus oral anticoagulant plus thienopyridine (triple therapy)203

Of the 14 observational studies, 10 (71%) were rated good quality, 3 (21%) were fair quality, and 1 (7%) was poor quality. Sample sizes for individual studies ranged from 102 to 27,972 patients. Study duration ranged from 30 days to 5 years. The mean age of study participants ranged from 61 to 80 years of age. The proportion of female patients ranged from 28 to 51 percent. Four studies (33%) reported the racial and/or ethnic demographics of study participants. Two studies (14%) were conducted within the United States or Canada, 7 studies (50%) were conducted in Europe, one was conducted in Asia (7%), one was conducted in Israel (7%), one was international (7%), and one study did not report the location (7%). Funding source was reported in seven studies (50%), with two studies (14%) funded by an industry source. Table G-16 in Appendix G contains the results reported by each study.

##### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal MI, Revascularization, or Stroke at 1 Year or More

Four observational studies (2 good quality, 1 fair, 1 poor) with 8,509 patients reported four different combinations of composite endpoints. Given the low number of studies for each combination, a quantitative analysis was not conducted.

Two studies comparing DAPT with triple therapy reported a composite of all-cause mortality, nonfatal MI, or revascularization at long-term followup. One study180 showed a significant increase in the composite outcomes at 5 years among patients treated with DAPT compared with triple therapy (38.7% vs.26.5%, HR 4.9; 95% CI, 2.17 to 11.1). The other study195 showed a nonsignificant difference in the rate of composite outcomes at 3 years between patients treated with DAPT and triple therapy (15.5% vs.11.9%, HR 0.94; 95% CI, 0.56 to 1.59).

One study comparing DAPT with triple therapy showed that patients discharged on DAPT were at higher risk for the composite outcome of all-cause mortality, nonfatal MI, or stroke at 1 year (32.5% vs. 25.6%).135 One study evaluating aspirin and/or thienopyridine versus oral anticoagulant with or without an antiplatelet agent among patients at risk for high bleeding (HAS-BLED ≥3) showed that patients on an oral anticoagulant had a lower rate of composite outcome (death, MI, or target vessel failure) (13.0% vs.26.4%, HR 0.48; 95%CI 0.29-0.77, p<0.01).132

One study reported a composite of all-cause mortality, nonfatal MI, or stroke at long-term followup.175 This study, comparing DAPT with triple therapy showed a nonsignificant difference in the rate of composite outcomes at 18 months between the two treatment arms (4.9% versus 5.8%, respectively, p=0.7).

One study180 comparing DAPT with triple therapy showed that patients discharged on DAPT were at higher risk of the composite outcome of stroke, major bleeding, death, nonfatal MI, or revascularization at 5 years (HR 4.33; 95% CI, 1.96 to 9.59). The SOE was rated insufficient for the various combinations of composite outcomes based on inconsistent and imprecise results.

##### Effect on Composite Endpoint of All-Cause Mortality or Nonfatal MI Within First Year

Four good-quality observational studies with 57,144 patients reported a composite endpoint of all-cause mortality or nonfatal MI during the first year of followup. One study,165 comparing the use of warfarin with no warfarin among patients with atrial fibrillation complicating a UA/NSTEMI event, showed a significant reduction of the composite of all-cause mortality or nonfatal MI at 6 months among patients treated with warfarin (adjusted OR 0.39; 95% CI, 0.15 to 0.98, p=0.04). Another study196 showed a higher incidence of the composite of all-cause mortality or nonfatal MI at 1 year among patients treated with warfarin (adjusted RR 1.20; 95% CI, 1.00 to 1.45).

A study186 comparing triple therapy with DAPT found a nonsignificant difference in the rate of composite outcomes (all-cause mortality, nonfatal MI, revascularization, or stent thrombosis) at 12 months between the two treatment arms (2.7% vs.1.3%, OR 2.1; 95% CI, 0.5 to 8.6, p=0.30). Another study203 comparing DAPT with triple therapy found no significant difference in the rate of all-cause mortality or nonfatal MI at 1 year (HR 1.17; 95% CI, 0.96 to 1.42). The SOE was rated insufficient for the composite outcome of all-cause mortality or nonfatal MI within the first year due to inconsistent and imprecise results.

##### Effect on All-Cause Mortality at 30 Days to 6 Months

Two good-quality observational studies with 7075 patients reported mortality at 30 days and 6 months. One study185 comparing triple therapy versus warfarin plus single antiplatelet found no difference in the rate of all-cause mortality at 6 months between the two groups (5.1% vs.6.5%, p=0.47). The other study188 comparing DAPT versus triple therapy found a significantly lower rate of all-cause mortality at 30 days among patients in the triple therapy group (4.1% vs.6.1%, p=0.002). The SOE was rated insufficient for all-cause mortality at 30 days to 6 months due to inconsistent results and unknown precision.

##### Effect on All-Cause Mortality at 1 to 5 Years

A random-effects meta-analysis of eight observational studies135,178,180,186,189,195,196,203 (4 good quality, 3 fair, 1 poor) including 41,192 UA/NSTEMI patients reporting all-cause mortality at 1 to 5 years found that the odds ratio for triple therapy compared with DAPT was 1.04 (95% CI, 0.59 to 1.83) (Figure 50). There was evidence of extreme heterogeneity, with a Q-value of 87.83 for 7 degrees of freedom, p<0.001, I^2^=92.03.

Figure 50 Meta-analysis of triple versus dual therapy on all-cause mortality at 1 to 5 years

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of seven studies that shows an odds ratio of 1.26 (95% CI, 0.75 to 2.10).

Two studies132,188 reported all-cause mortality but were not included in the analysis because they had different treatment comparison groups: aspirin and/or thienopyridine versus oral anticoagulant with or without an antiplatelet agent. The Stenestrand study188 found that the mortality rate at 1 year was significantly lower in patients in the oral anticoagulant arm (22.4% vs.31.4%, RR 0.73; 95% CI, 0.62 to 0.86, p=<0.001). The other study132 showed that among patients at high bleeding risk (HAS-BLED ≥ 3) those on an oral anticoagulant had a lower rate of death (9.3% versus 20.1%, HR 0.45, 95%CI0.26-0.78, p<0.01). The SOE was rated insufficient based on eight observational studies with inconsistent results of a direct outcome and a wide confidence interval.

##### Effect on Nonfatal MI at 6 Months

Only one good-quality observational study185 with 800 patients reported nonfatal MI at 6 months. This study comparing triple therapy versus warfarin plus single antiplatelet found no difference in the rate of nonfatal MI at 6 months between the two groups (3.3% vs.4.5%, p=0.49). The SOE was rated insufficient for nonfatal MI at 6 months based on findings from one small observational study.

##### Effect on Nonfatal MI at 1 to 5 Years

A random-effects meta-analysis of four observational studies178,180,186,195 (2 good quality, 1 fair, 1 poor) including 1425 UA/NSTEMI patients reporting nonfatal MI at 1 to 5 years found that the odds ratio for triple therapy compared with DAPT was 1.85 (95% CI, 1.13 to 3.02), favoring DAPT (Figure 51). There was no evidence of heterogeneity, with a Q-value of 2.68 for 3 degrees of freedom, p=0.44.

Figure 51 Meta-analysis of triple versus dual therapy on nonfatal myocardial infarction at 1 to 5 years

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of four studies that shows an odds ratio of 1.85 (95% CI, 1.13 to 3.02), favoring dual antiplatelet therapy.

The study comparing aspirin versus warfarin versus aspirin plus warfarin found that patients treated with warfarin plus aspirin were at a significantly lower risk of nonfatal MI at 4 years compared with those treated with aspirin alone (RR 0.56; 95% CI, 0.41 to 0.78, p<0.001) as well as those treated with warfarin compared with aspirin alone (RR 0.74; 95% CI, 0.55 to 0.98), p=0.03). The SOE was rated low based on four observational studies with consistent results of a direct outcome and a wide confidence interval.

##### Effect on Stroke at 6 Months

Only one good-quality observational study185 with 800 patients reported stroke at 6 months. This study comparing triple therapy versus warfarin plus single antiplatelet found a significantly lower rate of stroke at 6 months among patients treated with triple therapy (0.7% vs.3.4%, p=0.02). The SOE was rated low for stroke at 6 months based on significant findings from one small study.

##### Effect on Stroke at 1 to 5 Years

A random-effects meta-analysis of four observational studies178,186,195,203 (2 good quality, 1 fair, 1 poor) including 6,485 UA/NSTEMI patients reporting stroke at 1 to 5 years found that the odds ratio for triple therapy compared with DAPT was 1.01 (95% CI, 0.38 to 2.67) (Figure 52). There was evidence of heterogeneity, with a Q-value of 9.90 for 3 degrees of freedom, p=0.018.

Figure 52 Meta-analysis of triple versus dual therapy on stroke at 1 to 5 years

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.57 (95% CI, 0.72 to 3.43).

The study comparing aspirin versus warfarin versus aspirin plus warfarin found that patients treated with warfarin plus aspirin were at significantly lower risk of stroke at 4 years compared with those treated with aspirin alone (RR 0.52; 95% CI, 0.28 to 0.98, p<0.03) as were those treated with warfarin compared with aspirin alone (RR 0.52; 95% CI, 0.28 to 0.97, p=0.03). The SOE was rated insufficient on the basis of four observational studies with inconsistent results of a direct outcome and a wide confidence interval that crosses 1.

##### Effect on Revascularization up to 5 Years

Four observational studies180,185,186,195 (3 good quality, 1 poor) with 2066 patients reported revascularization between 6 months and 5 years of followup. One study185 comparing triple therapy versus warfarin plus single antiplatelet found no difference in the rate of repeat revascularization (unscheduled PCI) at 6 months between the two groups (10.6% vs.12.5%, p=0.50). Another study186 comparing triple therapy with DAPT found no difference in the rate of revascularization (TVR) at 1 year between the two treatment groups (11.0% vs.7.5%, OR 1.5; 95% CI, 0.8 to 2.9, p=0.21). A third study195 comparing triple therapy with DAPT found no significant difference in the rate of revascularization (TLR) at 3 years between the two treatment groups (4.3% vs.1.2%, p=0.13). The fourth study,180 again comparing DAPT with triple therapy found no difference in the rate of revascularization (TVR) between the two treatment groups (8.4% vs.7.1%, p=0.3). The SOE was rated insufficient for revascularization outcomes due to nonsignificant results from four observational studies.

##### Effect on Major Bleeding at 30 Days

A random-effects meta-analysis of five observational studies135,146,178,186,189 (2 good quality, 3 fair) including 12,339 UA/NSTEMI patients reporting major bleeding at 30 days found that the odds ratio for triple therapy compared with DAPT was 1.70 (95% CI, 0.88 to 3.30) (Figure 53). There was no evidence of heterogeneity, with a Q-value of 4.66 for 4 degrees of freedom, p=0.33. The SOE was rated insufficient for major bleeding at 30 days based on five observational studies with inconsistent results of a direct outcome and a wide confidence interval.

Figure 53 Meta-analysis of triple versus dual therapy on major bleeding at 30 days

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of five studies that shows an odds ratio of 1.70 (95% CI, 0.88 to 3.30).

##### Effect on Major Bleeding at 1 to 5 Years

A random-effects meta-analysis of seven observational studies135,146,174,180,186,196,203 (6 good quality, 1 fair) including 38,398 UA/NSTEMI patients reporting major bleeding at 1 to 5 years found that the odds ratio for triple therapy was 1.46 (95% CI, 1.07 to 2.00) (Figure 54). There was evidence of heterogeneity, with a Q-value of 16.04 for 6 degrees of freedom, p= 0.014. The I^2^ value was 62.59.

Figure 54 Meta-analysis of triple versus dual therapy on major bleeding at 1 to 5 years

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of six studies that shows an odds ratio of 1.57 (95% CI, 0.99 to 2.51).

Three observational studies132,178,190 reported major bleeding at long term followup but were not included in the analysis because of different treatment comparison groups and/or very low event rates. In one study178 comparing three treatment arms (clopidogrel plus aspirin; clopidogrel plus aspirin plus LMWH; and clopidogrel plus aspirin plus oral anticoagulant), only two severe bleeding events occurred—both in the clopidogrel plus aspirin arm. The other study190 comparing aspirin to warfarin to aspirin plus warfarin found a significantly increased risk of bleeding at 2 years among patients treated with warfarin compared with those treated with aspirin (OR 1.85; 95% CI, 1.54 to 2.22) and among those treated with warfarin and aspirin compared with aspirin alone (OR 1.84; 95% CI, 1.23 to 2.76). In the third study,132 which evaluated aspirin and/or thienopyridine versus oral anticoagulant with or without an antiplatelet agent among patients at high bleeding risk (HAS-BLED ≥ 3), major bleeding at 1 year was significantly increased in patients on an oral anticoagulant (11.8% versus 4.0%; HR 3.03, 95%CI 1.24-7.38; p=0.01). The SOE was rated low favoring DAPT for major bleeding outcomes at 1 to 5 years based on six observational studies with inconsistent results of a direct outcome and a precise estimate.

##### Effect on Minor Bleeding at 1 to 5 Years

A random-effects meta-analysis of three observational studies146,180,195 (2 good quality, 1 poor) including 890 UA/NSTEMI patients reporting minor bleeding at 1 to 5 years found that the odds ratio for triple therapy compared with DAPT was 1.33 (95% CI, 0.48 to 3.69) (Figure 55). There was some evidence of heterogeneity, with a Q-value of 4.22 for 2 degrees of freedom, p=0.12. The SOE was rated insufficient based on three observational studies with inconsistent results of a direct outcome and a wide confidence interval.

Figure 55 Meta-analysis of triple versus dual therapy on minor bleeding at 1 to 5 years

CI = confidence interval

This figure displays a forest plot of a random-effects meta-analysis of three studies that shows an odds ratio of 1.33 (95% CI, 0.48 to 3.69).

##### Effect on Major and Minor Bleeding

One good-quality observational study175 comparing DAPT with triple therapy found a nonsignificant increase in major and minor bleeding at 18 months followup among UA/NSTEMI patients treated with triple therapy after discharge (10.8% vs.4.9%, p=0.1). Another good-quality observational study190 compared aspirin, warfarin, aspirin plus warfarin, aspirin plus a thienopyridine (DAPT), and aspirin plus warfarin plus a thienopyridine (triple therapy). In the triple therapy group, only 1 of 141 had a bleeding event (or 1 bleeding event per 11.8 patient-years), and the authors were unable to calculate an odds ratio. In the DAPT group, there was an incidence rate per patient-year of 0.07 (95% CI, 0.04 to 0.10). Both studies failed to show a difference between DAPT and triple therapy in the combined endpoint of major and minor bleeding. The overall SOE was rated insufficient based on two observational studies with consistent results of a direct outcome and imprecise estimates.

##### Effect on Stent Thrombosis

Two observational studies reported stent thrombosis at 1 and 3 years. One good-quality study186 comparing triple therapy with DAPT found no difference in the rate of stent thrombosis at 1 year between the two treatment groups (4.1% vs.1.3%, OR 3.2; 95% CI, 0.8 to 12.1, p=0.09). One poor-quality observational study195 comparing triple therapy with DAPT found no significant difference in the rate of stent thrombosis at 3 years between the two treatment groups (1.4% vs.3.6%, p=0.206). The SOE was rated insufficient for stent thrombosis outcomes due to inconsistent and imprecise results.

##### Findings by Subgroup (KQ 3d)

One good-quality observational study188 reported variations in treatment effectiveness by subgroup. Subgroups analyzed were diabetes, sex, and age. Table H-3 in Appendix H presents the results data for these subgroups.

###### Diabetes

One study comparing dual antiplatelet therapy versus triple therapy reported all-cause mortality at 1 year188 and found no difference in the rate of all-cause mortality at 30 days between the two treatment groups among patients with diabetes (RR 0.85; 95% CI, 0.56 to 1.30). However a significantly lower rate of all-cause mortality at 30 days was found among nondiabetic patients in the triple therapy group compared with those treated with dual antiplatelet therapy (RR 0.64; 95% CI, 0.47 to 0.86).

###### Age

The same study reported all-cause mortality by age group (≤75 years vs. >75 years)188 and found a significantly lower rate of all-cause mortality at 30 days among patients receiving triple therapy in both age groups (≤75 RR 0.61; 95% CI, 0.40 to 0.93; >75 RR 0.71; 95% CI, 0.53 to 0.96).

###### Sex

This study also reported all-cause mortality by sex188 and found a significantly lower rate of all-cause mortality at 30 days among patients receiving triple therapy in men (RR 0.60; 95% CI, 0.43 to 0.82) but not in women (RR 0.93; 95% CI, 0.64 to 1.36).

##### Summary of Results for Dual Antiplatelet Versus Triple Therapy

In our analysis of DAPT versus triple therapy, we present the findings from studies comparing treatment groups that received two antiplatelet agents with groups that received long-term anticoagulation in addition to the two antiplatelet agents. Indications for long-term anticoagulation include atrial fibrillation, presence of a prosthetic valve, chronic deep venous thrombosis, or hypercoagulable states (e.g., protein C or S deficiency). We found 14 observational studies that examined the differences between adding anticoagulant therapy (i.e., warfarin) to various combinations of antiplatelet therapy. These studies had inconsistent and imprecise findings on the differences between dual and triple therapy on composite ischemic endpoints (all-cause mortality, nonfatal MI, or revascularization and all-cause mortality or nonfatal MI) at all time points—with some studies showing no difference and others showing increases or decreases in events in the triple therapy group. Dual therapy is better than triple therapy in reducing nonfatal MI and major bleeding at 1 year or longer. One observational study of 800 patients that evaluated the effect of dual versus triple therapy showed a significantly lower rate of stroke at 6 months in the triple therapy group, but the evidence from this study was insufficient for nonfatal MI at 6 months. Evidence for an effect of dual therapy versus triple therapy was also insufficient for the outcomes of all-cause mortality at 30 days to 6 months and 1 to 5 years, stroke at 1 to 5 years, revascularization up to 5 years, major bleeding at 30 days, minor bleeding at 1 to 5 years, major and minor bleeding at 1 to 5 years, and stent thrombosis. One observational study of 6,275 patients reported findings in subgroups of sex, age, and patients with diabetes. That study found lower rates of all-cause mortality in men, across all age groups, and in nondiabetic patients receiving triple therapy; SOE was low for the findings by subgroup since only one study was identified. Detailed SOE ratings are shown in Table 28.

Table 28 Detailed strength of evidence for UA/NSTEMI patients treated with dual antiplatelet versus triple therapy

Number of Studies (Patients) | Domains | | | | SOE and Magnitude of Effect Effect Estimate (95% CI)
Number of Studies (Patients) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | SOE and Magnitude of Effect Effect Estimate (95% CI)
Composite of all-cause mortality, nonfatal MI, revascularization, or stroke at 1 year or more | | | | | Insufficient SOE
4 (8509) | 4 observational/2 good quality, 1 fair, 1 poor | Inconsistent | Direct | Imprecise | 2 studies showed statistically nonsignificant differences; 2 studies showed statistically significant increases in events in DAPT group
Composite of all-cause mortality or nonfatal MI within first year | | | | | Insufficient SOE
4 (57,144) | 4 observational/All good quality | Inconsistent | Direct | Imprecise | 1 study showed a statistically significant increase, 1 a statistically significant decrease in the triple therapy group, and 2 studies showed statistically nonsignificant difference in events between DAPT and triple therapy.
All-cause mortality at 30 days to 6 months | | | | | Insufficient SOE
2 (7075) | 2 observational/Both good quality | Inconsistent | Direct | Unknown | One study found no difference, another found statistically significant lower deaths in in triple therapy group
All-cause mortality at 1 to 5 years | | | | | Insufficient SOE
8 (41,192) | 8 observational/4 good quality, 3 fair, 1 poor | Inconsistent | Direct | Imprecise | OR 1.03(0.59 to 1.83)
Nonfatal MI at 6 months | | | | | Insufficient SOE
1 (800) | Observational/Good quality | NA | Direct | Unknown | Triple therapy 3.3% Warfarin/aspirin 4.5% (p=0.49)
Nonfatal MI at 1 to 5 years | | | | | Low SOE
4 (1425) | 4 observational/2 good quality, 1 fair, 1 poor | Consistent | Direct | Imprecise | OR 1.85 (1.13 to 3.02) Favors DAPT
Stroke at 6 months | | | | | Low SOE
1 (800) | Observational/Good quality | NA | Direct | Unknown | Triple therapy 0.7% Warfarin/aspirin 3.4% (p=0.02) Favors triple therapy
Stroke at 1 to 5 years | | | | | Insufficient SOE
4 (6,485) | 4 observational/2 good quality, 1 fair, 1 poor | Inconsistent | Direct | Imprecise | OR 1.01 (0.38 to 2.67)
Revascularization up to 5 years | | | | | Insufficient SOE
4 (2066) | 4 observational/3 good quality, 1 poor | Consistent | Direct | Imprecise | No statistical difference between DAPT and triple therapy groups
Major bleeding at 30 days | | | | | Insufficient SOE
5 (12,339) | 5 observational/2 good quality, 3 fair | Inconsistent | Direct | Imprecise | OR 1.70 (0.88 to 3.30)
Major bleeding at 1 to 5 years | | | | | Low SOE
7 (38,398) | 7 observational/6 good quality, 1 fair | Inconsistent | Direct | Precise | OR 1.46 (1.07 to 2.00) Favors DAPT
Minor bleeding at 1 to 5 years | | | | | Insufficient SOE
3 (890) | 3 observational /2 good quality, 1 poor | Inconsistent | Direct | Imprecise | OR 1.33 (0.48 to 3.69)
Major and minor bleeding | | | | | Insufficient SOE
2 (21,545) | 2 observational/Both good quality | Consistent | Direct | Imprecise | Both studies failed to show a difference between DAPT and triple therapy in the combined endpoint of minor and major bleeding.
Stent thrombosis | | | | | Insufficient SOE
2 (840) | 2 observational/1 good quality, 1 poor | Inconsistent | Direct | Imprecise | No significant difference in rates (triple therapy 1.4% to 4.1%; dual antiplatelet 1.3%to 3.6%)

CI = confidence interval; CV = cardiovascular; DAPT = dual antiplatelet therapy; MI = myocardial infarction; NA = not applicable; OR = odds ratio; PPI = proton pump inhibitor; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction