# Methods

The methods for this Comparative Effectiveness Review follow those suggested in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the Methods Guide).16 The main sections in this chapter reflect the elements of the protocol established for the systematic review; certain methods map to the PRISMA checklist.17 All methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

During the topic refinement stage, we solicited input from Key Informants representing clinicians (cardiology, internal medicine, pharmacology, emergency medicine), patients, scientific experts, and Federal agencies to help define the KQs. The KQs were then posted for public comment in October 2011 for 4 weeks, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP), comprising clinical, content, and methodological experts, to provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. The Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Any potential conflicts of interest were balanced or mitigated. Neither Key Informants nor members of the TEP did analysis of any kind or contributed to the writing of the report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol, which was then refined based on their input, reviewed by AHRQ, and posted for public access at the AHRQ Effective Health Care Web site.18

## Literature Search Strategy

### Sources Searched

Our search strategy used the National Library of Medicine's medical subject headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. In consultation with our research librarians, we searched PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews (last search data for all three sources July 19, 2012). Our search strategy for PubMed is included in Appendix A; this strategy was adapted as necessary for use in the other databases. We date-limited our search to articles published since January 1995, corresponding to the period when contemporary studies on antiplatelet therapy, anticoagulant therapy, and combined therapies were published. The reference lists for identified pivotal articles were hand-searched and cross-referenced against our library, and additional manuscripts were retrieved. All citations were imported into an electronic database (EndNote^®^ X4; Thomson Reuters, Philadelphia, PA).

We also searched the gray literature of study registries and conference abstracts for relevant articles from completed studies. Gray literature databases included ClinicalTrials.gov (August 20, 2012); the World Health Organization (WHO) International Clinical Trials Registry Platform Search Portal (March 7, 2012); and ProQuest COS Conference Papers Index (February 15, 2012). Scientific information packets were requested from the manufacturers of medications and devices and reviewed for relevant articles from completed studies not previously identified in the literature searches.

Although this was not an exhaustive strategy, the search of ClinicalTrials.gov was also used as a mechanism to ascertain publication bias by identifying completed but unpublished studies. During peer and public review of the draft report, we updated all database searches and included any eligible studies identified either through that search or through suggestions from peer and public reviewers.

### Inclusion and Exclusion Criteria

The PICOTS criteria used to screen articles for inclusion/exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 2.

Table 2 Inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adult patients with UA or NSTEMI | - Studies with only a STEMI or stable angina population; - All patients are <18 years of age, or some patients are ≥18 years of age, but results are not reported for the adult population separately from the pediatric population
Interventions | - KQ 1: Early invasive strategy (before cardiac catheterization or during PCI); ○ Aspirin; ○ Intravenous glycoprotein IIb/IIIa inhibitors; ■ Abciximab; ■ Eptifibatide; ■ Tirofiban; ○ Oral antiplatelets; ■ Clopidogrel; ■ Prasugrel; ■ Ticagrelor; ○ Anticoagulants; ■ Bivalirudin; ■ Fondaparinux; ■ Enoxaparin; ■ Unfractionated heparin | - Study does not include any of the medications listed; - Medications are not administered as part of an early invasive strategy
Interventions | - KQ 2: Initial conservative strategy; ○ Aspirin; ○ Oral antiplatelets; ■ Clopidogrel; ■ Prasugrel; ■ Ticagrelor; ○ Anticoagulants; ■ Fondaparinux; ■ Enoxaparin; ■ Unfractionated heparin; ○ Intravenous glycoprotein IIb/IIIa inhibitors; ■ Abciximab; ■ Eptifibatide; ■ Tirofiban | - Study does not include any of the medications listed; - Medications are not administered as part of an initial conservative strategy
Interventions | - KQ 3: Postdischarge treatment; ○ Aspirin; ○ Oral antiplatelets; ■ Clopidogrel; ■ Prasugrel; ■ Ticagrelor; ○ Anticoagulants; ■ Warfarin; ■ Dabigatran; ■ Rivaroxaban; ■ Apixaban; ○ PPIs; ■ Pantoprazole; ■ Omeprazole; ■ Lansoprazole; ■ Rabeprazole; ■ Esomeprazole | Study does not include any of the medications listed; - Medications are not administered as part of postdischarge treatment
Comparators | - KQ 1a: Before catheterization, dose and timing of intravenous or oral antiplatelets with anticoagulants plus aspirin; - KQ 1b: During PCI, dose and timing of intravenous or oral antiplatelet with anticoagulants plus aspirin; - KQ 2a: Dose and timing of anticoagulants plus aspirin; - KQ 2b: Dose and timing of oral antiplatelets plus aspirin; - KQ 3a: Dose and duration of oral antiplatelets in combination with aspirin at different doses; - KQ 3b: PPIs versus no PPIs; - KQ 3c: Dual antiplatelet therapy (aspirin with oral antiplatelet) versus triple therapy (oral anticoagulant, aspirin, and oral antiplatelet) | Studies without an active comparator
Outcomes | - Intermediate outcomes; ○ Rehospitalization; ○ Length of hospital stay; ○ Resource utilization (e.g., emergency department visits); - Final outcomes; ○ All-cause death; ○ Cardiovascular-related death; ○ Nonfatal myocardial infarction; ○ Revascularization; ○ Stroke; e Quality of life | No intermediate or final outcomes of interest are reported
Outcomes (subgroups) | KQs 1–3: Individual characteristics including age, sex, weight, body mass index, diabetes, heart failure, previous stroke, renal insufficiency, type of stent, type of vascular access | None
Outcomes (safety) | KQs 1–3: Adverse effects of treatments such as adverse drug reactions (thrombocytopenia, allergic drug reaction), bleeding^a^, and stent thrombosis | None
Timing | Short-term (≤ 30 days), intermediate-term (31 days to 1 year), and long-term (> 1 year) | None
Setting | - Inpatient for early invasive and initial conservative therapies; - Outpatient for after hospitalization (postdischarge) therapies | None
Study design | - Randomized controlled trial, prospective or retrospective observational cohort study; - Original data (or related methodology paper of an included article) for interventions listed in KQs 1–3; - Relevant systematic review or meta-analysis (used for background only); All sample sizes | Not a clinical study (e.g., editorial, non–systematic review, letter to the editor, case series)
Publications | - English-language only; - Peer-reviewed article; Published from January 1, 1995, to present | Given the high volume of literature available in English-language publications (including the majority of known important studies), non-English articles were excluded

KQ = Key Question; NSTEMI = non-ST elevation myocardial infarction; PCI = percutaneous coronary intervention; PPI = proton pump inhibitor; STEMI = ST elevation myocardial infarction; UA = unstable angina

a Major and minor bleeding were defined by multiple validated criteria or by study protocol.

### Study Selection

Using the prespecified inclusion and exclusion criteria, titles and abstracts were examined independently by two reviewers for potential relevance to the KQs. Articles included by any reviewer underwent full-text screening. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to include or exclude the article for data abstraction. When the paired reviewers arrived at different decisions about whether to include or exclude an article, we reconciled the difference through a third-party arbitrator. Articles meeting our eligibility criteria were included for data abstraction. Relevant systematic review articles, meta-analyses, and methods articles were flagged for hand-searching and cross-referencing against the library of citations identified through electronic database searching.

## Data Extraction

The investigative team created data abstraction forms and evidence table templates for abstracting data for the KQs. Based on clinical and methodological expertise, two investigators were assigned to the research questions to abstract data from the eligible articles. One investigator abstracted the data, and the second overread the article and the accompanying abstraction to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer's opinion if consensus was not reached between the first two investigators. To aid in both reproducibility and standardization of data collection, investigators received data abstraction instructions directly on each form created specifically for this project with the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, Ontario, Canada). Data reported only in graphs were estimated quantitatively using Engauge Digitizer version 4.1 software (www.digitizer.sourceforge.net).

We designed the data abstraction forms for this project to collect data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate outcomes, health outcomes, and safety outcomes). The safety outcomes were framed to help identify adverse events, including adverse drug reactions and bleeding.

Data necessary for assessing quality and applicability, as described in the Methods Guide,16 were also abstracted. Before they were used, abstraction form templates were pilot tested with a sample of included articles to ensure that all relevant data elements were captured and that there were consistency and reproducibility between abstractors. Forms were revised as necessary before full abstraction of all included articles.

Appendix B lists the elements used in the data abstraction forms. Appendix C contains a bibliography of all articles/studies included in this review, organized alphabetically by author. Appendix D provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

## Quality Assessment of Individual Studies

We evaluated the quality of individual studies by using the approach described in the Methods Guide.16 To assess quality, we used the strategy of (1) classifying the study design, (2) applying predefined criteria for quality and critical appraisal, and (3) arriving at a summary judgment of the study's quality. To evaluate methodological quality, we applied criteria for each study type derived from the core elements described in the Methods Guide. For RCTs, criteria included adequacy of randomization and allocation concealment, the comparability of groups at baseline, blinding, the completeness of followup and differential loss to followup, whether incomplete data were addressed appropriately, the validity of outcome measures, and conflict of interest.

For nonrandomized clinical trials, such as those with an observational control group that was not randomized, we assessed the following study-specific issues that may affect the internal validity of our systematic review: potential for selection bias (i.e., degree of similarity between intervention and control patients); performance bias (i.e., differences in care provided to intervention and control patients not related to the study intervention); attribution and detection bias (i.e., whether outcomes were differentially detected between intervention and control groups); and magnitude of reported intervention effects.19

To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of good, fair, or poor based on their adherence to well-accepted standard methodologies and adequate reporting (Table 3).

Table 3 Definitions of overall quality ratings

Quality Rating | Description
Good | A study with the least bias; results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
Fair | A study that is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | A study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

Included meta-analyses were appraised according to criteria adapted from the PRISMA Statement.17 Rating was outcome-specific; thus, a given study may have been of different quality for two individual outcomes reported within that study. Study design also was considered when rating quality. RCTs were rated as good, fair, or poor. Observational studies were rated separately, also as good, fair, or poor.

## Data Synthesis

We summarized the primary literature by abstracting relevant continuous data (e.g., age) and categorical data (e.g., race, presence of coronary disease risk factors). Continuous variable outcomes reported by study authors included means, medians, standard deviations, interquartile ranges, ranges, and associated p-values. Dichotomous variable outcomes were summarized by proportions and associated p-values. We then determined the feasibility of completing a quantitative analysis (i.e., meta-analysis). Feasibility depended on the volume of relevant literature, conceptual homogeneity of the studies, and completeness of the reporting of results. We considered meta-analysis for comparisons in which at least three studies reported the same outcome. For the KQ 2 sensitivity analyses, we grouped studies by trial size (small, <1,000 patients; large, ≥1,000 patients) and by use (aspirin monotherapy vs. dual antiplatelet therapy) to help explain any heterogeneity, if present. Any subgroup summary estimate based on fewer than three studies is noted as such and should be interpreted with caution.

Meta-analyses were based on the nature of the outcome variable, but random-effects models were used for all outcomes because of the heterogeneity of the studies. Dichotomous outcome measures comparing two treatments were combined using odds ratios and a random-effects model as implemented in Comprehensive Meta-Analysis Version 2 (Biostat; Englewood, NJ). We tested for statistical heterogeneity between studies (Q and I^2^ statistics) while recognizing that the power to detect such heterogeneity may be limited. Potential heterogeneity between studies was reflected through the confidence intervals (CIs) of the summary statistics obtained from a random-effects approach. When substantial heterogeneity was present, we conducted sensitivity analyses to assess whether omitting the poor-quality studies would reduce the heterogeneity.

We present summary estimates, standard errors, and CIs in our data synthesis. When the summary estimate and CI were precise and crossed 1, we looked at the particular studies to determine the minimally important difference for noninferiority, or at the total number of events in both arms from the set of studies to see if it met criteria for optimal information size for the level of risk reduction.20 If the CI was within the minimally important difference or the number of events met the optimal information size, then we concluded equivalence; otherwise we concluded insufficient evidence.

## Strength of the Body of Evidence

We graded the strength of evidence (SOE) for each outcome assessed because a given study may be of different quality for two individual outcomes reported within that study. The SOE for each KQ and outcome was assessed using the approach described in the Methods Guide.16,21 In brief, the approach required assessment of four domains: risk of bias, consistency, directness, and precision (Table 4). Risk of bias ratings were based on the studies that were used in the meta-analysis (when performed) or on the findings from RCTs, which carry the lowest risk of bias, when meta-analysis was not performed. For some comparisons, especially those for KQ 3, the only available literature was from observational studies.

Table 4 Strength of evidence required domains

Domain | Rating | How Assessed
Risk of bias | Low Medium High | Assessed primarily through study design (RCT versus observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect” and the overall range of effect sizes
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Precision | Precise Imprecise Unknown | Based primarily on the size of the confidence intervals of effect estimates

RCT = randomized controlled trial

Additionally, when appropriate, the studies were evaluated for the presence of confounders that would diminish an observed effect, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating of high, moderate, or low SOE was assigned after discussion by two reviewers. In some cases, high, moderate or low ratings were impossible or imprudent to make (e.g., when no evidence was available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn), and therefore the evidence was rated insufficient. In these situations, a grade of insufficient was assigned. This four-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

## Applicability

We assessed applicability across our KQs using the method described in the Methods Guide.16,22 In brief, the PICOTS format was used as a way to organize information relevant to applicability. We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population (e.g., age, ethnicity, and sex) in comparison with the target population, version or characteristics of the intervention used in comparison with therapies currently in use (such as specific components of treatments considered to be supportive therapy), and clinical relevance and timing of the outcome measures. We used a checklist to guide our assessment and summarized issues of applicability qualitatively (Appendix E).

## Peer Review and Public Commentary

The peer review process is our principal external quality-monitoring device. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. Experts in cardiology, radiology, vascular surgery, general medicine, and nursing along with individuals representing stakeholder and user communities, were invited to provide external peer review of this draft report; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site from November 1 through November 29, 2012. We have addressed reviewer comments, revising the report as appropriate, and have documented our responses in a disposition of comments report available on the AHRQ Web site. A list of peer reviewers is given in the preface of this report.