# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- J. Dawn Abbott, M.D.
  Associate Professor of Medicine
  Brown University
  Providence, RI
- Nakela Cook, M.D., M.P.H.
  Medical Officer, Clinical Applications and Prevention Branch, Division of Cardiovascular Sciences
  National Heart, Lung and Blood Institute
  National Institutes of Health
  Bethesda, MD
- James A. de Lemos, M.D.
  Professor of Internal Medicine
  University of Texas Southwestern Medical Center
  Dallas, TX
- Elizabeth Delong, Ph.D., M.A.
  Chair, Department of Biostatistics and Bioinformatics
  Duke University
  Durham, NC
- Stephen M. Grant, M.D.
  Deputy Director, Division of Cardiovascular and Renal Products
  U.S. Food and Drug Administration
  Silver Spring, MD
- Neal S. Kleiman, M.D.
  Professor of Medicine
  Weill Cornell Medical College
  Houston, TX
- Charles V. Pollack, Jr., M.D.
  Chair, Department of Emergency Medicine, Pennsylvania Hospital
  University of Pennsylvania
  Philadelphia, PA
- Anupama K. Rao, M.D.
  Medical Officer, Division of Cardiovascular Sciences
  National Heart, Lung and Blood Institute
  Bethesda, MD