# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Jeffrey L. Anderson, M.D.
  Cardiologist
  Intermountain Heart Institute
  Murray, UT
- Patricia J. M. Best, M.D.
  Cardiovascular Diseases
  Mayo Clinic
  Rochester, MN
- Deepak L. Bhatt, M.D.
  Director, Integrated Interventional Cardiovascular Program
  Brigham and Women's Hospital
  Boston, MA
- Elizabeth Delong, Ph.D., M.A.
  Chair, Department of Biostatistics and Bioinformatics
  Duke University
  Durham, NC
- Deborah B. Diercks, M.D., M.Sc.
  Professor, Department of Emergency Medicine
  University of California, Davis
  Sacramento, CA
- James Douketis, M.D.
  Professor, Division of General Internal Medicine
  McMaster University
  Hamilton, Ontario, Canada
- Alice Mascette, M.D.
  Senior Clinical Science Advisor, Division of Cardiovascular Sciences
  National Heart, Lung and Blood Institute
  National Institutes of Health
  Bethesda, MD
- Zachary Stacy, Pharm.D.
  Assistant Professor of Pharmacy Practice
  St. Louis College of Pharmacy
  St. Louis, MO