# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Jeffrey L. Anderson, M.D.
  Cardiologist
  Intermountain Heart Institute
  Murray, UT
- Patricia J. M. Best, M.D.
  Cardiovascular Diseases
  Mayo Clinic
  Rochester, MN
- Deepak L. Bhatt, M.D.
  Director, Integrated Interventional Cardiovascular Program
  Brigham and Women's Hospital
  Boston, MA
- Donald Casey, Jr., M.D., M.B.A., M.P.H.
  Former Chief Medical Officer, Vice President of Quality
  Atlantic Health System
  Morristown, NJ
- Deborah B. Diercks, M.D., M.Sc.
  Professor, Department of Emergency Medicine
  University of California, Davis
  Sacramento, CA
- James Douketis, M.D.
  Professor, Division of General Internal Medicine
  McMaster University
  Hamilton, Ontario, Canada
- Neil C. Jensen, M.H.A., M.B.A.
  Director, Cardiology Networks
  United Healthcare
  Edina, MN
- Kathryn Kastan, L.C.S.W., M.A.Ed.
  Director, Duke Medicine's Women's Health and Advocacy Initiative
  Duke University Health System
  Durham, NC
- Alice Mascette, M.D.
  Senior Clinical Science Advisor, Division of Cardiovascular Sciences
  National Heart, Lung and Blood Institute
  National Institutes of Health
  Bethesda, MD
- Zachary Stacy, Pharm.D.
  Assistant Professor of Pharmacy Practice
  St. Louis College of Pharmacy
  St. Louis, MO
- Rita Weber
  Patient Advocate
  Duke University
  Durham, NC