# Acknowledgments

The authors thank Gillian D. Sanders, Ph.D., and Douglas McCrory, M.D., for assistance with evaluating the strength-of-evidence ratings, and Megan von Isenburg, M.S.L.S., for help with the literature search and retrieval.