# Discussion

## Key Findings and Strength of Evidence

In this Comparative Effectiveness Review, we reviewed 175 studies represented by 302 articles that directly compared antiplatelet and anticoagulant medications prescribed for the treatment of UA/NSTEMI. We included 87 unique studies with 354,511 patients treated with an early invasive approach or PCI-based strategy, 33 unique studies with 225,891 patients treated with an initial conservative strategy, and 71 unique studies with 693,539 patients continued on treatment after hospitalization (postdischarge). One of the main challenges in this report was that studies were not easily grouped into the early invasive, initial conservative, or postdischarge strategies.

Another challenge was grouping the studies to come up with valid comparisons of treatments. For some sections we describe the full number of studies that included a comparative study of the treatment of interest, but then describe the ones that were not included in the quantitative analysis due to study design, patient population, or variations in the concomitant antiplatelet or anticoagulation therapy that did not match the other studies. The findings from the studies that were not included in those sections were described qualitatively, and the results are available in the Appendix.

The current evidence base was greatest for the comparative safety and effectiveness of glycoprotein IIb/IIIa inhibitors (GPIs), UFH, enoxaparin, and dual antiplatelet therapy with clopidogrel. Numerous uncertainties remain about the use of newer antiplatelets (e.g., ticagrelor, prasugrel) and newer anticoagulants (e.g., fondaparinux, bivalirudin), as well as the related use of older and newer therapies on specific patient populations of interest.

We provide important information on the SOE that supports, or requires more evidence to support, current antiplatelet- and anticoagulant-prescribing practices as detailed below. This information will help to inform clinical decisionmaking by health care providers and patients and help to inform policymakers about which prescribing patterns have an adequate evidence-base and which findings are less robust. We also define important gaps in knowledge and identify areas in need of future research, which will help guide funding agencies in prioritizing these research areas.

### Key Question 1 Early Invasive Approach to UA/NSTEMI

Eighty-seven unique studies evaluated the comparative effectiveness of antiplatelet medications and anticoagulant medications in 354,511 patients with UA/NSTEMI treated with an early invasive approach or PCI-based strategy. Studies that assessed dosage, timing, and combinations of antiplatelet and anticoagulant therapies delivered at the time of PCI were analyzed, including (1) upstream versus deferred GPIs, (2) different loading doses of clopidogrel, (3) clopidogrel versus ticagrelor or prasugrel, (4) bivalirudin versus a heparin-based strategy (without and with planned GPI use), (5) enoxaparin versus UFH versus fondaparinux, and (6) upstream or deferred clopidogrel administration. A narrative of our findings for each comparison is included below, followed by a summary SOE table. The detailed SOE tables are located in the Results section after each comparison.

#### Upstream Versus Deferred GPI Administration

In our analysis of upstream versus deferred GPI administration, we found no statistically significant difference between upstream and deferred GPI therapy for the composite outcome of all-cause mortality, nonfatal MI, or revascularization at 30 days and 6 months. For the individual outcomes of all-cause mortality and nonfatal MI, there was no statistically significant difference between upstream and deferred GPI therapy at 30 days, but the results are less certain at 6 months since fewer trials reported results at this time point, although the ones that did report outcomes also showed no difference. For revascularization, there was a statistically significant difference favoring upstream GPI therapy at 30 days, but the results are less certain at 6 months due to a small number of trials that showed no difference in outcomes. For bleeding outcomes, there was a statistically significant difference favoring deferred GPI therapy in major bleeding events at 30 days but no statistically significant differences between therapies in minor bleeding events at 30 days. No studies reported the occurrence of stent thrombosis during study followup. In summary, upstream GPI reduced short-term revascularization at the cost of increased short-term major bleeding, and the final impact on clinical outcomes is likely somewhere in the middle, although the studies are too inconsistent or imprecise to determine whether the net benefit is truly zero or whether there is a small benefit from either therapy. Table 29 shows the summary SOE and effect estimates for these outcomes.

Table 29 Summary strength of evidence and effect estimates: upstream versus deferred glycoprotein inhibitors

Outcome and Timing | SOE^a^ and Effect Estimate^b^ (95% CI)
Composite of all-cause mortality, nonfatal MI, or revascularization at 30 days | SOE = Low (6 RCTs; 19,662 patients) OR 0.88 (0.77 to 1.01); no difference
Composite of all-cause mortality, nonfatal MI, or revascularization after 6 months | SOE = Insufficient (4 RCTs; 773 patients) Insufficient evidence due to imprecision: OR 0.77 (0.46 to 1.28)
All-cause mortality at 30 days | SOE=Insufficient (10 RCTs, 20,521 patients) Insufficient evidence due to inconsistency and imprecision, with a CI that crosses 1: OR 0.80 (0.57 to 1.11)
All-cause mortality at 6 months | SOE = Insufficient (3 RCTs; 673 patients) Insufficient evidence due to inconsistency and imprecision: 1 study reported no deaths in either arm; 1 study reported 1 death in the upstream GPI arm; 1 study reported similar rates (2.0% upstream GPI, 3.6% deferred GPI)
Nonfatal MI at 30 days | SOE = Insufficient (9 RCTs; 20,263 patients) Insufficient evidence due to inconsistency and imprecision: OR 0.84 (0.65 to 1.10)
Nonfatal MI at 6 months | SOE = Insufficient (3 RCTs; 673 patients) Insufficient evidence due to inconsistency and imprecision: 1 study reported 1 MI in the deferred GPI arm only; 2 other studies reported MI rates of 12% upstream vs. 15% deferred, and 10% upstream vs. 9% deferred
Revascularization at 30 days | SOE = High (6 RCTs; 19,454 patients) OR 0.77 (0.65 to 0.92); favors upstream GPI
Revascularization at 6 months | SOE = Insufficient (3 RCTs; 673 patients) Insufficient evidence due to inconsistency and imprecision: OR 0.69 (0.34 to 1.39)
Major bleeding at 30 days | SOE = High (9 RCTs; 20,242 patients) OR 1.24 (1.08 to 1.43); favors deferred GPI
Minor bleeding at 30 days | SOE = Insufficient (5 RCTs; 969 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.58 (0.95 to 2.64)
Stent thrombosis at 30 days | SOE = Insufficient (0 studies; 0 patients)

CI = confidence interval; GPI = glycoprotein IIb/IIIa inhibitor; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b ORs less than 1 favor upstream GPI; ORs greater than 1 favor deferred GPI.

Subgroups analyzed in two studies included age, sex, diabetes, chronic renal disease, troponin positivity, and TIMI risk score and most findings showed statistically nonsignificant reductions in ischemic outcomes from upstream GPI; the only statistically significant findings were a lower risk of major bleeding favoring treatment with deferred GPI use in patients over age 65, CrCl less than 60 ml/min, and elevated serum biomarkers (all findings from one RCT).

#### Clopidogrel Loading Dose of 300 mg Versus 600 mg

In our analysis of clopidogrel loading doses (300 mg vs. 600 mg), each of the six studies reported different composite ischemic outcomes, thus prohibiting a meta-analysis. One large RCT reported no differences by loading dose for the composite endpoint of cardiovascular mortality, nonfatal MI, or nonfatal stroke at 30 days. For the individual outcomes of all-cause mortality and cardiovascular mortality, there were no statistically significant differences between clopidogrel loading doses. For nonfatal MI, there was a statistically nonsignificant difference in event rate but a trend favoring clopidogrel 600 mg loading dose at 30 days. There was a statistically significant lower rate of stent thrombosis favoring a clopidogrel loading dose of 600 mg versus 300 mg. Insufficient evidence exists for the comparative effectiveness of clopidogrel loading doses on composite ischemic endpoints, cardiovascular mortality at 30 days, nonfatal MI at 6 months, nonfatal stroke, revascularization, major bleeding, and minor bleeding, with most of these outcomes reported in smaller trials with imprecise estimates. Table 30 shows the summary SOE and effect estimates for these outcomes.

Table 30 Summary strength of evidence and effect estimates: 300 mg versus 600 mg clopidogrel loading dose

Outcome and Timing | SOE^a^ and Effect Estimate (95% CI)
Composite of cardiovascular mortality, nonfatal MI, or nonfatal stroke at 30 days | SOE = Low (1 RCT; 25,086 patients) HR 0.94 (0.83 to 1.06) in this large good-quality RCT sufficiently powered to assess this composite endpoint; no difference
Composite of cardiovascular mortality, nonfatal MI, or revascularization at 30 days | SOE = Insufficient (1 RCT; 119 patients) Insufficient evidence due to imprecision: lower rate in 600 mg group (10.4% vs. 23.8%)
Composite of cardiovascular mortality, nonfatal MI, or recurrent ACS at 30 days | SOE = Insufficient (1 RCT; 387 patients) Insufficient evidence due to imprecision: lower rate in 600 mg group (4.8% vs. 12.3%)
Composite of all-cause mortality, nonfatal MI, revascularization, or rehospitalization at 30 days | SOE = Insufficient (1 RCT; 103 patients) Insufficient evidence due to imprecision: lower rate in 600 mg group (5.9% vs. 11.4%)
Composite of all-cause mortality, nonfatal MI, or revascularization at 30 days | SOE = Insufficient (1 RCT; 255 patients) Insufficient evidence due to imprecision: lower rate in 600 mg group (4.0% vs. 11.6%)
Composite of all-cause mortality, nonfatal MI, nonfatal stroke, or rehospitalization at 6 months | SOE = Insufficient (1 RCT; 256 patients) Insufficient evidence due to imprecision: no difference in event rates between groups (13.3% vs. 13.2%)
All-cause mortality at 30 days | SOE = Low (3 RCTs; 25,802 patients) 2 small studies reported no deaths in either group; largest study reported HR 0.93 (0.83 to 1.05); no difference
All-cause mortality at 6 months | SOE = Insufficient (1 RCT; 256 patients) Insufficient evidence due to sparse data: 3 deaths in 300 mg group; 1 death in 600 mg group
Cardiovascular mortality at 30 days | SOE = Low (3 RCTs; 25,497 patients) HR 0.95 (0.81 to 1.13) in the large good-quality RCT; no difference
Nonfatal MI at 30 days | SOE = Low (5 RCTs; 25,855 patients) OR 1.74 (0.99 to 3.05); favors 600 mg dose
Nonfatal MI at 6 months | SOE = Insufficient (1 RCT; 256 patients) Insufficient evidence due to imprecision: higher MI rate in 600 mg group (8.6% vs. 5.0%; p = 0.26)
Nonfatal stroke at 30 days | SOE = Insufficient (2 RCTs; 25,378 patients) Insufficient evidence due to imprecision: largest study reported HR 1.19 (0.84 to 1.68); smaller study reported 2 strokes in 300 mg group, 1 stroke in 600 mg group
Nonfatal stroke at 6 months | SOE = Insufficient (1 RCT; 256 patients) Insufficient evidence due to sparse data: only 1 stroke in overall cohort (600 mg group)
Revascularization at 30 days | SOE = Insufficient (3 RCTs; 477 patients) Insufficient evidence due to inconsistency and low overall event rate, ranging from 0 to 1.3% in 600 mg group and from 0 to 4.8% in 300 mg group
Revascularization at 6 months | SOE = Insufficient (1 RCT; 256 patients) Insufficient evidence due to imprecision: lower incidence in 600 mg group (2.3% vs. 3.3%; p = 0.64)
Major bleeding at 30 days | SOE = Insufficient (6 RCTs; 26,111 patients) Insufficient evidence due to inconsistency and imprecision: 3 studies reported no bleeding events; inconsistent findings from 3 other studies, with largest study reporting HR 1.09 (0.89 to 1.34)
Minor bleeding at 30 days | SOE = Insufficient (5 RCTs; 25,819 patients) Insufficient evidence due to inconsistency and imprecision: incidence ranged from 0.8% to 9.5% in 300 mg group and from 0.8% to 3.9% in 600 mg group
Stent thrombosis at 30 days | SOE = Low (1 RCT; 17,263 patients) HR 0.68 (0.55 to 0.85); favors 600 mg dose

ACS = acute coronary syndrome; CI = confidence interval; HR = hazard ratio; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

Subgroups analyzed in one study included age, sex, diabetes mellitus, GRACE risk score, the performance of PCI after randomization, and the presence of smoking. The analyses showed nonsignificant reductions in composite ischemic events favoring clopidogrel 600 mg for five subgroup categories, with statistically significant findings in patients who underwent PCI after randomization.

#### Clopidogrel Versus Ticagrelor or Prasugrel (PCI Cohort)

In our analysis of studies comparing clopidogrel, ticagrelor, or prasugrel, two studies reported a lower incidence of the composite outcome of cardiovascular mortality, nonfatal MI, or nonfatal stroke at 30 days in patients treated with prasugrel or ticagrelor. When this same composite endpoint was measured after 1 year, both ticagrelor and prasugrel had lower event rates than clopidogrel. Prasugrel reduced the composite endpoint of cardiovascular mortality, nonfatal MI, or revascularization at 15 months compared with clopidogrel. There was insufficient evidence for the following individual outcomes at 30 days: all-cause mortality, cardiovascular mortality, nonfatal MI, nonfatal stroke, major bleeding, and minor bleeding. There was also insufficient evidence for nonfatal stroke after 1 year. However after 1 year, all-cause mortality and cardiovascular mortality had statistically significant decreases in event rates in patients treated with ticagrelor; but, the difference in event rates between prasugrel and clopidogrel was not statistically significant. For nonfatal MI after 1 year, there was a statistically significant difference in event rates favoring both ticagrelor and prasugrel when compared with clopidogrel. None of the studies reported revascularization event rates at 30 days; after 6 months, one study found a statistically significant reduction favoring prasugrel. After 1 year, there was no statistically significant difference in major bleeding event rates between ticagrelor and clopidogrel; however, prasugrel was associated with higher major bleeding event rates than clopidogrel. For stent thrombosis, there was a statistically significant difference in event rates favoring ticagrelor and prasugrel when compared with clopidogrel. Table 31 shows the summary SOE and effect estimates for these outcomes.

Table 31 Summary strength of evidence and effect estimates: clopidogrel versus ticagrelor or prasugrel

Outcome and Timing | SOE^a^ and Effect Estimate (95% CI)
Composite of cardiovascular mortality, nonfatal MI, or nonfatal stroke at 30 days | Clopidogrel vs. ticagrelor: SOE = Insufficient (2 RCTs; 19,608 patients) Insufficient evidence due to inconsistency and imprecision: compared with clopidogrel (3.8% and 5.4%), ticagrelor had mixed results (4.3% and 4.8%)
Composite of cardiovascular mortality, nonfatal MI, or nonfatal stroke at 30 days | Clopidogrel vs. prasugrel: SOE = Moderate (1 RCT; 13,608 patients) Compared with clopidogrel (7.4%), prasugrel (5.7%) was associated with lower composite endpoint; favors prasugrel
Composite of cardiovascular mortality, nonfatal MI, or nonfatal stroke after 1 year | Clopidogrel vs. ticagrelor: SOE = Moderate (1 RCT; 18,624 patients) Compared with clopidogrel (12.6%), ticagrelor (10.6%) was associated with lower composite endpoint; favors ticagrelor Clopidogrel vs. prasugrel: SOE = Moderate (1 RCT; 13,608 patients) HR 0.81 (0.73 to 0.90) Compared with clopidogrel (12.1%), prasugrel (9.9%) was associated with lower composite endpoint at 15 months; favors prasugrel
Composite of cardiovascular mortality, nonfatal MI, or revascularization at 15 months | Clopidogrel vs. prasugrel: SOE = Moderate (1 RCT; 13,608 patients) HR 0.81 (0.73 to 0.87); favors prasugrel
All-cause mortality at 30 days | Clopidogrel vs. ticagrelor: SOE = Insufficient (1 RCT; 984 patients) Insufficient evidence due to imprecision: clopidogrel 0.6%, ticagrelor 1.9%; p = 0.18
All-cause mortality after 1 year | Clopidogrel vs. ticagrelor: SOE = Moderate (1 RCT; 18,624 patients) Compared with clopidogrel (5.9%), ticagrelor (4.5%) was associated with fewer deaths; favors ticagrelor Clopidogrel vs. prasugrel: SOE = Low (1 RCT; 13,608 patients) Compared with clopidogrel (3.2%), prasugrel (3.0%) was associated with fewer deaths; favors prasugrel
Cardiovascular mortality at 30 days | Clopidogrel vs. ticagrelor: SOE = Insufficient (1 RCT; 984 patients) Insufficient evidence due to imprecision: clopidogrel 0.6%, ticagrelor 1.9%; p = 0.18
Cardiovascular mortality after 1 year | Clopidogrel vs. ticagrelor: SOE = Moderate (1 RCT; 18,624 patients) Compared with clopidogrel (5.1%), ticagrelor (4.0%) was associated with fewer cardiovascular deaths; favors ticagrelor Clopidogrel vs. prasugrel: SOE = Low (1 RCT; 13,608 patients) Compared with clopidogrel (2.4%), prasugrel (2.1%) was associated with fewer cardiovascular deaths; favors prasugrel
Nonfatal MI at 30 days | Clopidogrel vs. ticagrelor: SOE = Insufficient (1 RCT; 984 patients) Insufficient evidence due to imprecision: clopidogrel 3.5%, ticagrelor 2.2%; p = 0.34
Nonfatal MI after 1 year | Clopidogrel vs. ticagrelor: SOE = Moderate (1 RCT; 18,624 patients) Compared with clopidogrel (6.9%), ticagrelor (5.8%) was associated with fewer MIs; favors ticagrelor Clopidogrel vs. prasugrel: SOE = Moderate (1 RCT; 13,608 patients) Compared with clopidogrel (9.5%), prasugrel (7.3%) was associated with fewer MIs; favors prasugrel
Nonfatal stroke at 30 days | Clopidogrel vs. ticagrelor: SOE = Insufficient (1 RCT; 984 patients) Insufficient evidence due to imprecision: clopidogrel 0.3%, ticagrelor 0.6%; p = 0.57
Nonfatal stroke after 1 year | Clopidogrel vs. ticagrelor: SOE = Insufficient (1 RCT; 18,624 patients) Insufficient evidence due to imprecision: clopidogrel 1.3%, ticagrelor 1.5% Clopidogrel vs. prasugrel: SOE = Insufficient (1 RCT; 13,608 patients) Insufficient evidence due to imprecision: clopidogrel 1.0%, prasugrel 1.0%
Revascularization at 30 days | Both comparisons: SOE = Insufficient (0 studies; 0 patients)
Revascularization after 6 months | Clopidogrel vs. prasugrel (1 RCT, 13,608 patients) SOE = Moderate HR 0.66 (0.54 to 0.81); favors prasugrel
Major bleeding at 30 days | Clopidogrel vs. ticagrelor: SOE = Insufficient (1 RCT; 984 patients) Insufficient evidence due to imprecision: clopidogrel 6.9%, ticagrelor 7.1%
Major bleeding after 1 year | Clopidogrel vs. ticagrelor: SOE = Low (1 RCT; 18,624 patients) Compared with clopidogrel (7.7%), ticagrelor (7.9%) had similar event rates; no difference Clopidogrel vs. prasugrel: SOE = Moderate (1 RCT; 13,608 patients) Compared with clopidogrel (1.8%), prasugrel (2.4%) was associated with higher event rates; favors clopidogrel
Minor bleeding at 30 days | Clopidogrel vs. ticagrelor: SOE = Insufficient (1 RCT; 984 patients) Insufficient evidence due to imprecision: clopidogrel 1.3%, ticagrelor 2.7%; p = 0.18
Stent thrombosis after 1 year | Clopidogrel vs. ticagrelor: SOE = Moderate (1 RCT; 18,624 patients) Compared with clopidogrel (2.9%), ticagrelor (2.2%) was associated with lower event rates; favors ticagrelor Clopidogrel vs. prasugrel: SOE = Moderate (1 RCT; 13,608 patients) Compared with clopidogrel (2.4%), prasugrel (1.1%) was associated with lower event rates; favors prasugrel

CI = confidence interval; HR = hazard ratio; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

Subgroup findings from two studies included age, sex, race, diabetes mellitus, chronic kidney disease, troponin positivity, TIMI risk score, weight, prior TIA or stroke, prior coronary revascularization, the performance of PCI after randomization, type of coronary stent, geographic location, and high risk of bleeding. Both studies showed similar reductions in ischemic outcomes on patients receiving the newer agent (prasugrel or ticagrelor) compared with clopidogrel across all subgroups; most subgroups' differences were not statistically significant, except among subgroups where the sample size was sufficiently large to detect a difference.

#### Bivalirudin Versus Heparin-Based Strategy

In our analysis of studies comparing bivalirudin versus heparin-based strategy with or without planned GPI use, there were no statistically significant differences in the incidence of the composite endpoints of mortality, nonfatal MI, or revascularization at 30 days, and the data were rated insufficient after 1 year without GPI use and rated low after 1 year with GPI use. When major bleeding was added to this composite outcome (all-cause mortality, nonfatal MI, revascularization, or major bleeding), a statistically significant net clinical difference favoring bivalirudin was observed in the comparison of bivalirudin versus heparin-based strategy plus planned GPI, but there was insufficient evidence for the group without planned GPI. For the individual outcomes of all-cause mortality at 30 days and after 6 months, there was insufficient evidence with or without planned GPI use. For nonfatal MI and revascularization, there was insufficient evidence for the group without planned GPI use. There was no difference in nonfatal MI in patients treated with bivalirudin versus heparin-based strategy at 30 days in the planned GPI group; however, the incidence of nonfatal MI at 6 months in this group was significantly higher in bivalirudin-treated patients when compared with patients treated with heparin-based strategy with planned GPI use although the SOE was rated insufficient for this outcome. For revascularization in the planned GPI group, at 30 days there were higher rates of revascularization in heparin-treated patients (favoring bivalirudin), but revascularization after 6 months was statistically significantly higher in bivalirudin-treated patients when compared with patients treated with heparin-based strategy. For bleeding outcomes, the lower incidence in major and minor bleeding at 30 days was statistically significant favoring bivalirudin when compared with heparin-based strategy with or without GPI use. There was insufficient evidence for stent thrombosis at 30 days with or without GPI use. Table 32 shows the summary SOE and effect estimates for these outcomes.

Table 32 Summary strength of evidence and effect estimates: bivalirudin versus heparin-based strategy without and with planned glycoprotein inhibitor use

Outcome and Timing | SOE^a^ and Effect Estimate^b^ (95% CI)
Bivalirudin vs. Heparin-Based Strategy Without Planned GPI Use
Composite of all-cause mortality, nonfatal MI, revascularization, or major bleeding at 30 days | SOE = Insufficient (1 RCT; 4,571 patients) Insufficient evidence due to imprecision: bivalirudin 8.4% vs. heparin 8.7%
Composite of all-cause mortality, nonfatal MI, or revascularization at 30 days | SOE = Insufficient (2 RCTs; 5,420 patients) Insufficient evidence due to inconsistency and imprecision: 1 study found no difference, OR 1.19 (0.92 to 1.54); 1 study found statistically significant lowering in the bivalirudin group, OR 0.42 (0.21 to 0.84)
Composite of all-cause mortality, nonfatal MI, or revascularization at 1 year | SOE = Insufficient (2 RCTs; 5,420 patients) Insufficient evidence due to inconsistency and imprecision: 1 study found no difference, OR 0.97 (0.83 to 1.13); 1 study found statistically significant lowering in the bivalirudin group, OR 0.58 (0.37 to 0.92)
All-cause mortality at 30 days | SOE = Insufficient (3 RCTs; 5,822 patients) Insufficient evidence due to inconsistency and imprecision: OR 0.46 (0.12 to 1.81)
All-cause mortality after 6 months | SOE = Insufficient (2 RCTs; 5,420 patients) Insufficient evidence due to inconsistency and imprecision: disparate results in 2 RCTs: bivalirudin 1.2% vs. heparin 2.4%; bivalirudin 1.9% vs. heparin 1.7%
Nonfatal MI at 30 days | SOE = Insufficient (3 RCTs; 5,822 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.00 (0.64 to 1.55)
Nonfatal MI after 6 months | SOE = Insufficient (2 RCTs; 5,420 patients) Insufficient evidence due to inconsistency and imprecision: disparate results in 2 RCTs: bivalirudin 3.3% vs. heparin 5.7%; bivalirudin 6.0% vs. heparin 5.3%
Revascularization at 30 days | SOE = Insufficient (3 RCTs; 5,822 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.10 (0.60 to 2.04)
Revascularization after 6 months | SOE = Insufficient (2 RCTs; 5,420 patients) Insufficient evidence due to imprecision: lower rate of revascularization in bivalirudin-treated patients (4.1% and 11.2%) vs. heparin-treated (5.7% and 12.5%)
Major bleeding at 30 days | SOE = High (3 RCTs; 5,822 patients) OR 0.63 (0.47 to 0.85); favors bivalirudin
Minor bleeding at 30 days | SOE = Low (3 RCTs; 5,822 patients) OR 0.64 (0.43 to 0.95); favors bivalirudin
Stent thrombosis at 30 days | SOE = Insufficient (3 RCTs; 5,822 patients) Insufficient evidence due to imprecision: OR 1.42 (0.64 to 3.15)
Bivalirudin vs. Heparin-Based Strategy With Planned GPI Use
Composite of all-cause mortality, nonfatal MI, revascularization, or major bleeding at 30 days | SOE = High (3 RCTs; 12,287 patients) OR 0.87 (0.78 to 0.97); favors bivalirudin
Composite of all-cause mortality, nonfatal MI, or revascularization at 30 days | SOE = High (3 RCTs; 12,287 patients) OR 1.07 (0.95 to 1.22); no difference
Composite of all-cause mortality, nonfatal MI, or revascularization at 1 year | SOE = Low (2 RCTs; 10,566 patients) Both RCTs found no difference between treatments: OR 1.11 (0.74 to 1.63) and OR 1.08 (0.92 to 1.25); no difference
All-cause mortality at 30 days | SOE = Insufficient (3 RCTs; 12,287 patients) Insufficient evidence due to imprecision: OR 1.21 (0.89 to 1.65)
All-cause mortality after 6 months | SOE = Insufficient (2 RCTs; 10,566 patients) Insufficient evidence due to imprecision: similar event rate in 1 RCT (3.8% bivalirudin, 3.8% GPI); slightly lower event rate in other RCT (0.9% bivalirudin,1.3% GPI; p = 0.46)
Nonfatal MI at 30 days | SOE = Moderate (3 RCTs; 12,287 patients) OR 1.06 (0.92 to 1.23); no difference
Nonfatal MI after 6 months | SOE = Moderate (2 RCTs; 10,566 patients) Higher event rate with bivalirudin (7.8% and 8.1%) vs. heparin (6.9% and 7.6%); favors heparin
Revascularization at 30 days | SOE = Low (3 RCTs; 12,287 patients) OR 1.11 (0.86 to 1.42); favors bivalirudin
Revascularization after 6 months | SOE = Low (2 RCTs; 10,566 patients) Higher event rate with bivalirudin (8.7% and 11.7%) vs. heparin (8.4% in both studies); favors heparin
Major bleeding at 30 days | SOE = High (3 RCTs; 12,287 patients) OR 0.52 (0.43 to 0.63); favors bivalirudin
Minor bleeding at 30 days | SOE = High (3 RCTs; 12,287 patients) OR 0.49 (0.42 to 0.59); favors bivalirudin
Stent thrombosis at 30 days | SOE = Insufficient (2 RCTs; 10,936 patients) Insufficient evidence due to imprecision: similar event rates between treatment arms in both studies (bivalirudin 0.7% to 1.0%; heparin 0.6% to 0.8%)

CI = confidence interval; GPI = glycoprotein IIb/IIIa inhibitor; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b ORs less than 1 favor bivalirudin; ORs greater than 1 favor heparin-based strategy.

Subgroups analyzed included age, sex, diabetes mellitus, chronic kidney disease, serum biomarker positivity, TIMI risk score, weight, and the performance of PCI or CABG after randomization. A majority of the subgroup analyses of the primary composite outcome showed no difference between bivalirudin and a heparin-based strategy, or a statistically nonsignificant reduction that favored bivalirudin.

#### Enoxaparin Versus Unfractionated Heparin Versus Fondaparinux (PCI Cohort)

In our analysis of studies comparing enoxaparin, UFH, and fondaparinux, we used subgroups of UA/NSTEMI patients who underwent early invasive treatment. This limited the available outcomes to a composite ischemic outcome prior to 7 days, at 30 days, and after 6 months, and the incidence of major bleeding at 30 days. There were no significant differences in the incidence of the composite ischemic endpoints prior to 7 days between enoxaparin and heparin, or at 30 days between enoxaparin, UFH, and fondaparinux. At 6 months, there was no difference in the composite ischemic endpoint between enoxaparin and fondaparinux. For bleeding outcomes, there was a lower and statistically significant incidence in major bleeding at 30 days favoring fondaparinux when compared with enoxaparin; the rates of major bleeding in the enoxaparin versus UFH studies were inconsistent. Table 33 shows the summary SOE and effect estimates for these outcomes.

Table 33 Summary strength of evidence and effect estimates: enoxaparin versus unfractionated heparin versus fondaparinux (percutaneous coronary intervention cohort)

Outcome and Timing | SOE^a^ and Effect Estimate (95% CI)
Composite ischemic endpoints prior to 7 days | Enoxaparin vs. UFH: SOE = Low (1 RCT; 3,987 patients) HR 0.89 (0.75 to 1.05); no difference (adequately powered for noninferiority hypothesis)
Composite ischemic endpoints prior to 7 days | Fondaparinux vs. UFH: SOE = Insufficient (1 RCT; 350 patients) Insufficient evidence due to imprecision: 4.2% vs. 6%
Composite ischemic endpoints at 30 days | Enoxaparin vs. UFH: SOE = Low (2 RCTs; 10,773 patients) 14% vs. 14.5% and 14% vs. 16.1%; no difference Enoxaparin vs. fondaparinux: SOE = Low (1 RCT; 20,078 patients) 7.4% vs. 7.4%; no difference
Composite of all-cause mortality, nonfatal MI, or revascularization at 6 months | Enoxaparin vs. fondaparinux: SOE = Low (1 RCT; 20,078 patients) Enoxaparin 10.2% and fondaparinux 10.1%; no difference (adequately powered for noninferiority hypothesis)
Major bleeding at 30 days | Enoxaparin vs. UFH: SOE = Moderate (1 RCT; 10,027 patients) Lower event rates with UFH (7.6%) vs. enoxaparin (9.1%); favors UFH Enoxaparin vs. UFH: SOE = Low (2 observational studies; 29,017 patients) Lower event rates with enoxaparin (2.7% UFH vs. 1.8% enoxaparin; 7% UFH vs. 6.7% enoxaparin); favors enoxaparin Enoxaparin vs. fondaparinux: SOE = Moderate (1 RCT; 20,078 patients) Lower event rates with fondaparinux (3.1%) vs. enoxaparin (5.0%); p <0.001; favors fondaparinux

CI = confidence interval; HR = hazard ratio; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence; UFH = unfractionated heparin

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

Subgroup analyses from three studies included age, sex, diabetes mellitus, chronic kidney disease, presence of smoking, prior coronary revascularization, serum biomarker positivity, TIMI risk score, and geographic location. Most showed nonsignificant reductions in composite outcomes in the enoxaparin and fondaparinux groups; there was a significant reduction in major bleeding in older persons treated with either enoxaparin or fondaparinux compared with UFH which are consistent with the total population findings.

#### Upstream or Deferred Clopidogrel for Patients Undergoing PCI for UA/NSTEMI in Studies With a Defined Anticoagulant or Intravenous Antiplatelet Strategy

In randomized comparisons of patients treated with (1) bivalirudin versus heparin-based strategy and (2) upstream versus deferred GPI use, the nonrandomized effectiveness and safety of clopidogrel pretreatment and deferred clopidogrel treatment was assessed. In these analyses, patients pretreated with clopidogrel and randomized to a heparin-based strategy had no differences in composite ischemic outcomes compared with patients randomized to bivalirudin, but the evidence was insufficient. However, the occurrence of major bleeding was significantly lower in bivalirudin-treated patients when compared with heparin-treated patients. There were no significant differences in the occurrence of composite ischemic endpoints at 1 year or all-cause mortality at 1 year between bivalirudin and heparin groups, based on insufficient SOE. Patients pretreated with clopidogrel and randomized to upstream GPI use had a trend toward fewer composite ischemic outcomes at 30 days and fewer deaths at 30 days when compared with patients randomized to deferred GPI use. There was insufficient SOE for the composite outcome at 96 hours, and the composite of all-cause mortality, nonfatal MI, or rehospitalization at 30 days. The occurrence of major bleeding at 30 days was significantly higher in patients pretreated with clopidogrel who were randomized to upstream GPI when compared with deferred GPI use.

In patients treated with deferred clopidogrel strategy, there were conflicting results for composite ischemic events at 30 days in patients randomized to bivalirudin when compared with heparin-based strategy, therefore the SOE was insufficient. There was low SOE for the effect on major bleeding at 30 days in those patients treated with deferred clopidogrel and randomized to bivalirudin, with one good-quality study showing a reduction in major bleeding favoring bivalirudin. In studies of patients treated with deferred clopidogrel and randomized to upstream GPI, there was insufficient SOE for composite ischemic outcomes at 30 days and low SOE for no difference in all-cause mortality at 30 days. The occurrence of major bleeding at 30 days was significantly higher in patients treated with deferred clopidogrel who were randomized to upstream GPI when compared with deferred GPI use. Detailed SOE ratings are shown in Tables 11–14. Odds ratios less than 1 favor bivalirudin or upstream GPI; odds ratios greater than 1 favor a heparin-based strategy or deferred GPI use. Table 34 shows the summary SOE and effect estimates for these outcomes.

Table 34 Summary strength of evidence and effect estimates: clopidogrel upstream (pretreatment) and deferred treatment strategies

Outcome and Timing | SOE^a^ and Effect Estimate^b^ (95% CI)
Upstream Clopidogrel: Bivalirudin vs. Heparin-Based Strategy
Composite of all-cause mortality, nonfatal MI, or revascularization at 30 days | SOE = Low (2 RCTs; 7,104 patients) Both studies showed no statistically significant difference in composite event rates ranging from OR 1.11 to 1.25; no difference
Composite of all-cause mortality, nonfatal MI, or revascularization at 1 year | SOE = Insufficient (1 RCT; 4,570 patients) Insufficient evidence due to imprecision: bivalirudin 21.5%, heparin 20.1%
All-cause mortality at 1 year | SOE = Insufficient (1 RCT; 5,126 patients) Insufficient evidence due to imprecision: bivalirudin 16.0%, heparin 16.3%
Major bleeding at 30 days | SOE = Moderate (3 RCTs; 6,322 patients) OR 0.65 (0.49 to 0.85); favors bivalirudin
Upstream Clopidogrel: Upstream vs. Deferred GPI Use
Composite of all-cause mortality, nonfatal MI, revascularization, or thrombotic bailout with GPI at 96 hours | SOE = Insufficient (1 RCT; 6,895 patients) Insufficient evidence due to imprecision: upstream GPI 8.7%, deferred GPI 9.4%
Composite of all-cause mortality, nonfatal MI, or rehospitalization at 30 days | SOE = Insufficient (1 RCT; 300 patients) Insufficient evidence due to imprecision: upstream GPI 9%, deferred GPI 10%
Composite of all-cause mortality, nonfatal MI, or ischemia/revascularization at 30 days | SOE = Low (2 RCTs; 638 patients) Upstream GPI 15.7%, deferred GPI 20.3%; favors upstream GPI
All-cause mortality at 30 days | SOE = Low (5 RCTs; 8,168 patients) OR 0.56 (0.30 to 1.05); favors upstream GPI
Major bleeding at 30 days | SOE = Moderate (5 RCTs; 7,416 patients) OR 1.49 (1.10 to 2.01); favors deferred GPI
Deferred Clopidogrel: Bivalirudin vs. Heparin-Based Strategy
Composite of all-cause mortality, nonfatal MI, or revascularization at 30 days | SOE = Insufficient (2 RCTs; 2,571 patients) Insufficient evidence due to inconsistency and imprecision: 1 RCT (fair) showed a significant reduction favoring bivalirudin, OR 0.42 (0.21 to 0.84; p = 0.02); the other RCT (good) showed no difference, OR 1.05 (0.80 to 1.40)
Major bleeding at 30 days | SOE = Low (2 RCTs; 2,571 patients) 1 RCT (fair) showed no statistical difference between the groups, OR 0.32 (0.10 to 1.01); the other RCT (good) showed a statistically significant reduction favoring bivalirudin, OR 0.53 (0.31 to 0.91, p = 0.02); favors bivalirudin
Deferred Clopidogrel: Upstream vs. Deferred GPI Use
Composite of all-cause mortality, nonfatal MI, revascularization, or thrombotic bailout with GPI at 96 hours | SOE = Insufficient (1 RCT; 2,271 patients) Insufficient evidence due to imprecision: upstream GPI 10.3%, deferred GPI 11.2%
All-cause mortality at 30 days | SOE = Low (4 RCTs; 11,858 patients) OR 0.97 (0.80 to 1.18); no difference
Major bleeding at 30 days | SOE = High (3 RCTs; 11,698 patients) OR 1.27 (1.08 to 1.50); favors deferred GPI

CI = confidence interval; GPI = glycoprotein IIb/IIIa inhibitor; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence; UFH = unfractionated heparin

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b ORs less than 1 favor bivalirudin or upstream GPI; ORs greater than 1 favor UFH or deferred GPI.

### Key Question 2 Initial Conservative Approach to UA/NSTEMI

Thirty-three studies evaluated the comparative effectiveness of antiplatelet medications and anticoagulant medications in 225,891 patients with UA/NSTEMI treated with an initial conservative approach or a mixed population for whom the approach (conservative or invasive) was not presented separately. Thus we present the findings of studies comparing (1) UFH versus enoxaparin or fondaparinux in the conservatively managed or total population (if results by treatment strategy are not presented) and (2) GPI plus UFH versus UFH alone in a patient population where coronary angiography was discouraged in the first 24 to 60 hours after study drug administration or in populations who did not receive PCI, and (3) clopidogrel versus ticagrelor or prasugrel. A narrative of our findings for each comparison is included below, followed by a summary SOE table. The detailed SOE tables are located in the Results section after each comparison.

#### Unfractionated Heparin Versus Enoxaparin or Fondaparinux

In our analysis of studies that evaluated the use of UFH versus enoxaparin or fondaparinux, we present the findings of UA/NSTEMI patients who received primarily initial conservative treatment. From the comparison of enoxaparin and UFH, there was a significant reduction in composite ischemic events and nonfatal MI at around 30 days with enoxaparin. There was insufficient evidence for the outcomes of all-cause mortality and major bleeding at around 30 days. From an indirect comparison of fondaparinux and UFH, there was a significant reduction in composite ischemic events and a nonsignificant reduction in major bleeding events favoring fondaparinux. Evidence was insufficient for the outcomes of nonfatal MI and all-cause mortality at around 30 days in this comparison. Results from observational studies show that use of low molecular weight heparin is increasing over time in the conservatively managed population. Use of low molecular weight heparin was associated with fewer ischemic events and similar or lower bleeding events compared with UFH. Fondaparinux was associated with lower adjusted mortality than UFH and similar adjusted mortality enoxaparin. In an RCT, fondaparinux significantly lowered mortality at 30 days and 180 days and major bleeding at 9 days compared with enoxaparin. Table 35 shows the summary SOE and effect estimates for these outcomes.

Table 35 Summary strength of evidence and effect estimates: unfractionated heparin versus enoxaparin or fondaparinux (full UA/NSTEMI cohort)

Outcome and Timing | SOE^a^ and Effect Estimate^b^ (95% CI)
Composite endpoint of all-cause mortality, nonfatal MI, revascularization, or recurrent ischemia at around 30 days | Enoxaparin vs. UFH: SOE = High (6 RCTs; 12,124 patients) OR 0.84 (0.76 to 0.93); favors enoxaparin Fondaparinux vs. UFH: SOE = Low (1 RCT; 20,078 patients) OR 0.78 (0.67 to 0.90); favors fondaparinux
Composite ischemic outcome at 6 months | Enoxaparin vs. fondaparinux: SOE = Low (1 RCT, 20,078 patients) 10.2% vs. 10.1% in large good-quality RCT adequately powered for a noninferiority hypothesis; no difference
All-cause mortality at around 30 days | Enoxaparin vs. UFH: SOE = Low (8 RCTs; 23,015 patients) OR 0.98 (0.84 to 1.14); no difference
All-cause mortality at around 30 days | Fondaparinux vs. UFH: SOE = Insufficient (1 RCT; 20,078 patients) Insufficient evidence due to imprecision and indirect comparison: OR 0.93 (0.71 to 1.20)
Nonfatal MI at around 30 days | Enoxaparin vs. UFH: SOE = Moderate (9 RCTs; 22,970 patients) OR 0.85 (0.76 to 0.95); favors enoxaparin
Nonfatal MI at around 30 days | Fondaparinux vs. UFH: SOE = Insufficient (1 RCT; 20,078 patients) Insufficient evidence due to imprecision and indirect comparison: OR 0.85 (0.69 to 1.04)
Major bleeding at around 30 days | Enoxaparin vs. UFH: SOE = Insufficient (8 RCTs; 22,901 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.11 (0.81 to 1.51)
Major bleeding at around 30 days | Fondaparinux vs. UFH: SOE = Low (1 RCT; 20,078 patients) OR 0.69 (0.49 to 0.97); favors fondaparinux

CI = confidence interval; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non–ST elevation myocardial infarction; UFH = unfractionated heparin

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b ORs less than 1 favor enoxaparin or fondaparinux; ORs greater than 1 favor UFH.

Subgroups analyzed were dosage, obesity, renal impairment, and ECG changes. Excess dosage was associated with more major bleeding and death and was more likely to be received by older, smaller, and female patients. Use of enoxaparin was associated with lower rates of ischemic events in obese patients, those with renal impairment, and those with ST depression on ECG.

#### GPI Plus Unfractionated Heparin Versus Unfractionated Heparin Alone

In our analysis of studies comparing GPIs with UFH, we present the findings of UA/NSTEMI patients who received primarily initial conservative treatment. Adding GPIs to UFH reduced the rate of mortality, composite ischemic events, and nonfatal MI, especially in trials of eptifibatide and tirofiban, and increased the rate of minor bleeding at 30 days. The addition of abciximab to UFH did not significantly reduce ischemic events compared with UFH alone. There was insufficient evidence for the effect of GPIs on recurrent ischemia, major bleeding, and revascularization, although fewer revascularization events were seen in patients receiving GPIs in two small trials. A sensitivity analysis subgrouping the studies by trial size (small, <1,000 patients; large, ≥1,000 patients) and antiplatelet use (aspirin monotherapy vs. dual antiplatelet therapy) showed that these two factors helped to explain the heterogeneity, if present, in the meta-analyses performed. For the mortality, nonfatal MI, and recurrent ischemia endpoints at 30 days, the smaller sized studies had summary estimates that were more favorable for GPI plus UFH. For the mortality and nonfatal MI endpoints at 30 days, the use of DAPT had summary estimates that were more favorable for GPI plus UFH. Table 36 shows the summary SOE and effect estimates for these outcomes.

Table 36 Summary strength of evidence and effect estimates: glycoprotein inhibitor plus unfractionated heparin versus unfractionated heparin alone

Outcome and Timing | SOE^a^ and Effect Estimate^b^ (95% CI)
Composite ischemic endpoints up to 30 days | SOE = Moderate (10 RCTs; 38,518 patients) Studies of eptifibatide and tirofiban showed a consistent reduction in composite events compared with UFH alone (RRs 0.58 to 0.84; favors eptifibatide or tirofiban); 1 large trial of abciximab showed no difference in events—24 hr OR 1.00 (CI 0.83 to 1.24); 48 hr OR 1.10 (CI 0.94 to 1.39); a small trial showed a reduction in major events with abciximab (1 out of 30) versus UFH alone (7 out of 30); favors GPI plus UFH
Mortality up to 30 days | SOE = High (9 RCTs; 24,699 patients) OR 0.80 (0.67 to 0.96); favors GPI plus UFH
Nonfatal MI up to 30 days | SOE = Moderate (9 RCTs; 24,699 patients) OR 0.79 (0.61 to 1.02); favors GPI plus UFH
Recurrent ischemia up to 30 days | SOE = Insufficient (6 RCTs; 5,755 patients) Insufficient evidence due to inconsistency and imprecision: OR 0.81 (0.56 to 1.18)
Revascularization up to 30 days | SOE = Insufficient (2 RCTs; 279 patients) Insufficient evidence due to imprecision; low number of events reported in both RCTs, with fewer in GPI plus UFH group
Major bleeding up to 30 days | SOE = Insufficient (4 RCTs; 18,855 patients) Insufficient evidence due to imprecision: OR 1.13 (0.80 to 1.59)
Minor bleeding up to 30 days | SOE = High (5 RCTs; 22,259 patients) OR 1.62 (1.20 to 2.19); favors heparin alone

CI = confidence interval; GPI = glycoprotein IIb/IIIa inhibitor; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; SOE = strength of evidence; UFH = unfractionated heparin

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b ORs less than 1 favor GPI plus UFH; ORs greater than 1 favor UFH alone.

Subgroups analyzed were diabetes, sex, age, geographic location, smoking status, and weight. Almost all subgroups experienced a reduction in composite ischemic events from adding GPI therapy to heparin (UFH or low molecular weight heparin). While some subgroups may have had a greater magnitude of benefit, there did not appear to be a significant interaction between the assigned treatment and demographic or clinical variables. Notable exceptions included the PURSUIT trial, where women in the heparin group had fewer ischemic events than the eptifibatide group (statistically nonsignificant), and the GUSTO IV study where women treated with a 48-hour infusion of abciximab had higher event rates.

#### Clopidogrel Versus Ticagrelor or Prasugrel (Initial Conservative Cohort)

In our analysis of studies comparing clopidogrel versus ticagrelor or prasugrel, we present the findings of UA/NSTEMI patients who received initial conservative treatment. Ticagrelor reduced the rates of composite ischemic and all-cause mortality events; however, ticagrelor also increased rates of major bleeding, and the combination of major or minor bleeding events. In contrast, prasugrel and clopidogrel had similar rates of composite ischemic and most individual clinical outcomes, except that there was a higher rate of TIMI criteria combined major or minor bleeding events in the prasugrel group at 30 months. Table 37 shows the summary SOE and effect estimates for these outcomes.

Table 37 Summary strength of evidence for UA/NSTEMI patients treated with clopidogrel versus ticagrelor or prasugrel

Outcome and Timing | SOE^a^ and Effect Estimate^b^ (95% CI)
Composite ischemic endpoints up to 30 months | Ticagrelor vs. clopidogrel: SOE = Moderate (1 RCT; 5,216 patients) HR 0.85 (0.73 to 1.00); favors ticagrelor Prasugrel vs. clopidogrel: SOE = Moderate (1 RCT; 7,243 patients) HR 0.91 (0.79 to 1.05); no difference
Mortality up to 30 months | Ticagrelor vs. clopidogrel: SOE = Moderate (1 RCT; 5,216 patients) HR 0.75 (0.61 to 0.93); favors ticagrelor Prasugrel vs. clopidogrel: SOE = Moderate (1 RCT; 7,243 patients) HR 0.96 (0.79 to 1.16); no difference
Nonfatal MI up to 30 months | Ticagrelor vs. clopidogrel: SOE = Moderate (1 RCT; 5,216 patients) HR 0.94 (0.77 to 1.15); no difference Prasugrel vs. clopidogrel: SOE = Moderate (1 RCT; 7,243 patients) HR 0.89 (0.74 to 1.07); no difference
Stroke up to 30 months | Ticagrelor vs. clopidogrel: SOE = Insufficient (1 RCT; 5,216 patients) Insufficient evidence due to imprecision: HR 1.35 (0.89 to 2.07) Prasugrel vs. clopidogrel: SOE = Insufficient (1 RCT; 7,243 patients) Insufficient evidence due to imprecision: HR 0.67 (0.42 to 1.06)
Revascularization up to 12 months | Ticagrelor vs. clopidogrel: SOE = Moderate (1 RCT; 5,216 patients) No difference
Major bleeding up to 30 months | Ticagrelor vs. clopidogrel: SOE = Moderate (1 RCT; 5,216 patients) HR 1.17 (0.98 to 1.39); favors clopidogrel
Major bleeding up to 30 months | Prasugrel vs. clopidogrel: SOE = Insufficient (1 RCT; 7,243 patients) Insufficient evidence due to imprecision: HR 1.31 (0.81 to 2.11)
Major or minor bleeding up to 30 months | Ticagrelor vs. clopidogrel: SOE = Moderate (1 RCT; 5,216 patients) HR 1.17 (1.01 to 1.36); favors clopidogrel Prasugrel vs. clopidogrel: SOE = Low (1 RCT; 7,243 patients) HR 1.54 (1.06 to 2.23); favors clopidogrel

CI = confidence interval; HR = hazard ratio; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence; UA/NSTEMI = unstable angina/non–ST elevation myocardial infarction

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b HRs less than 1 favor ticagrelor or prasugrel; HRs greater than 1 favor clopidogrel.

Multiple subgroups were analyzed in the TRILOGY ACS study, which found a treatment interaction favoring prasugrel among current/recent users, patients undergoing angiography prior to randomization, and those taking PPIs at randomization on the primary composite endpoint. For the TIMI criteria major bleeding endpoint, the only subgroup with a significant treatment interaction favored patients receiving clopidogrel with a reduced dose of aspirin.

### Key Question 3 Postdischarge Treatment for UA/NSTEMI

Seventy-one studies evaluated the comparative effectiveness of antiplatelet medications and anticoagulant medications in 693,025 patients with UA/NSTEMI continued on treatment after hospitalization (postdischarge). We present the findings of studies comparing (1) low-dose versus high-dose aspirin, (2) single antiplatelet versus dual antiplatelet therapy, (3) short-term versus long-term clopidogrel, (4) antiplatelet therapy with or without the addition of proton pump inhibitors (PPIs), (5) dual antiplatelet versus triple therapy in patients with an indication for long-term anticoagulation (e.g., atrial fibrillation, prosthetic valve). A narrative of our findings for each comparison is included below, followed by a summary SOE table. The detailed SOE tables are located in the Results section after each comparison.

#### Low-Dose Versus High-Dose Aspirin

In our analysis of low-dose versus high-dose aspirin, we found insufficient evidence for composite ischemic event rates and all-cause mortality at 6 months and 1 year. Nonfatal MI was lower from high-dose aspirin (≥150 mg vs. <150 mg) at 6 months in one study, but the evidence was insufficient from a second, smaller study at 1 year. Insufficient evidence was also found for stroke rates in these two studies at 6 months and 1 year. There were conflicting results on revascularization rates at 1 year, with one study showing no difference (81 mg vs. 325 mg) and another study showing higher rates of urgent revascularization in the high-dose (≥162 mg) group. The effect on major bleeding at 1 year was also inconsistent, with one fair-quality study reporting higher bleeding rates in the low-dose (81 mg) group and two good-quality studies reporting higher rates in the high-dose group (162 mg or ≥200 mg). Differences in consistency of the results may be that the Harjai142 and So172 studies were smaller, single-center studies that had higher rates of clopidogrel use (53% and 99% respectively) while the Aronow,176 Quinn,192 Peters,202 and Mahaffey201 studies were secondary analyses of larger RCTs (i.e., BRAVO, Gusto IIb, and PURSUIT, CURE, and PLATO)—one of which did not allow use of thienopyridines, one study did not report its use, one study reported results for aspirin monotherapy and dual antiplatelet therapy, and one study had only dual antiplatelet with two different thienopyridine medications In addition, the doses of aspirin compared differed among the six studies. Table 38 shows the summary SOE and effect estimates for these outcomes.

Table 38 Summary strength of evidence and effect estimates: low-dose versus high-dose aspirin

Outcome and Timing | SOE^a^ and Effect Estimate^b^ (95% CI)
Composite of all-cause mortality, nonfatal MI, or stroke at 6 months | SOE = Insufficient (1 observational study; 20,469 patients) Insufficient evidence due to CI that crosses 1: HR 0.92 (0.79 to 1.07)
Composite of all-cause mortality, nonfatal MI, or stroke at 1 year | SOE = Insufficient (2 observational studies; 31,186 patients) Insufficient evidence due to inconsistency and imprecision: 1 study showed similar rates of composite events across 3 dosage categories for aspirin monotherapy and DAPT; the other study showed lower event rates when combining low-dose aspirin with ticagrelor and high-dose aspirin with clopidogrel
Composite of all-cause mortality, nonfatal MI, or revascularization at 1 year | SOE = Insufficient (3 observational studies; 9,249 patients) Insufficient evidence due to imprecision: low-dose aspirin and high-dose aspirin had similar rates of ischemic events in all 3 studies
All-cause mortality at 6 months | SOE = Insufficient (1 observational study; 20,469 patients) Insufficient evidence due to imprecision: HR 0.89 (0.72 to 1.10)
All-cause mortality at 1 year | SOE = Insufficient (2 observational studies; 6,429 patients) Insufficient evidence due to inconsistency and imprecision: 1 study (aspirin/clopidogrel) showed no difference between doses; the other found that high-dose aspirin (monotherapy) reduced mortality
Nonfatal MI at 6 months | SOE = Low (1 observational study; 20,469 patients) HR 0.79 (0.64 to 0.98); favors high-dose aspirin
Nonfatal MI at 1 year | SOE = Insufficient (1 observational study; 4,589 patients) Insufficient evidence due to imprecision: HR 0.98 (0.66 to 1.48)
Stroke at 6 months | SOE = Insufficient (1 observational study; 20,469 patients) Insufficient evidence due to imprecision: HR 1.59 (0.95 to 2.65)
Stroke at 1 year | SOE = Insufficient (1 observational study; 4,589 patients) Insufficient evidence due to imprecision: HR 1.37 (0.94 to 2.00)
Revascularization at 1 year | SOE = Insufficient (2 observational studies; 6,429 patients) Insufficient evidence due to inconsistency and imprecision: 1 study (aspirin/clopidogrel) showed no difference between doses; the other study (aspirin monotherapy) showed more events with high dose
Major bleeding at 1 year | SOE = Low (3 observational studies; 19,971 patients) 1 study had high bleeding rates in low-dose group; 2 studies had high bleeding rates in high-dose group; favors low-dose aspirin

CI = confidence interval; DAPT = dual antiplatelet therapy; HR = hazard ratio; MI = myocardial infarction; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b HRs less than 1 favor high-dose aspirin; HRs greater than 1 favor low-dose aspirin.

Subgroup analyses included diabetes, multivessel disease, and type of stent from one study comparing low-dose aspirin (81 mg) with high-dose (325 mg) in addition to clopidogrel; geographic location from one study comparing low-dose aspirin (<300 mg) with high-dose (≥300 mg) in patients receiving either ticagrelor or clopidogrel; and diabetes and type of stent from one study comparing low-dose aspirin (81 mg) with high-dose aspirin (161–325 mg). Patients with multivessel disease had higher events rates on low-dose aspirin; however, patients with diabetes, drug-eluting stents, and bare metal stents had similar event rates on low-dose and high-dose aspirin as part of a dual antiplatelet treatment strategy. Patients on low-dose aspirin (<300 mg) and ticagrelor had lower events rates than those on low-dose aspirin and clopidogrel. Patients with diabetes and those with a DES receiving low-dose aspirin both had an increased incidence of bleeding, while patients with diabetes on low-dose aspirin also had an increased rate of death or MI.

#### Single Antiplatelet Versus Dual Antiplatelet Therapy

Our analysis of single antiplatelet versus dual antiplatelet therapy addresses the question about the effectiveness of combinations of antiplatelet agents. The identified literature predominately reports the comparison of aspirin monotherapy (single antiplatelet) with aspirin plus clopidogrel therapy (dual antiplatelet). Use of newer antiplatelet agents (prasugrel, ticagrelor) with aspirin in comparison to clopidogrel plus aspirin was previously summarized under KQ 1; there we presented the findings from direct comparisons of different dual antiplatelet treatment strategies. In the analysis of single versus dual antiplatelet therapy, dual antiplatelet therapy reduced the rates of composite ischemic outcomes and nonfatal MI in UA/NSTEMI patients based on 3 studies (1 RCT and 2 observational registries). While 5 studies (1 RCT and 4 observational) showed a reduction in all-cause mortality in the dual antiplatelet therapy group, the wide confidence intervals around the reported risk ratios in many of the studies made this finding less precise than the results on composite ischemic outcomes and nonfatal MI. Four out of five studies (2 RCTs and 3 observational studies) showed no significant difference in stroke rates between dual antiplatelet and single antiplatelet therapy; the evidence for this outcome was rated insufficient. The effect of dual antiplatelet therapy on major bleeding varied in three studies (two RCTs and one observational registry), and was also rated insufficient. Table 39 shows the SOE and effect estimates for these outcomes.

Table 39 Summary strength of evidence and effect estimates: single antiplatelet versus dual antiplatelet therapy

Outcome and Timing | SOE^a^ and Effect Estimate (95% CI)
Composite ischemic endpoints, in-hospital to 1 year | SOE = High (1 RCT, 2 observational studies; 106,749 patients) All studies showed statistically significant lowering of composite events in DAPT arm, ranging from RR 0.69 to OR 0.80; favors DAPT
Stroke, in-hospital to 1 year | SOE = Insufficient (1 RCT, 3 observational studies; 116,136 patients) Insufficient evidence due to inconsistency and imprecision: 3 out of 4 studies showed no statistically significant difference in stroke rates
Nonfatal MI, in-hospital to 1 year | SOE = High (1 RCT, 2 observational studies; 106,749 patients) All studies showed fewer recurrent MIs in DAPT group (2.3% to 5.8%) vs. aspirin alone (3.0% to 8.5%); favors DAPT
All-cause mortality, in-hospital to 1 year | SOE = Moderate (1 RCT, 4 observational studies; 117,467 patients) All studies showed fewer deaths in DAPT group, ranging from OR/RR 0.66 to OR/RR 0.93; favors DAPT
Major bleeding, in-hospital to 9 months | SOE = Low (1 RCT, 1 observational study; 105,607 patients) 2 studies showed a reduction in major bleeding in DAPT group (1 statistically significant [16% vs. 21%]; 1 not statistically significant); favors DAPT

CI = confidence interval; DAPT = dual antiplatelet therapy; MI = myocardial infarction; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

Subgroup findings from four studies (two RCTs, two observational registries) assessed the effectiveness based on age, sex, clinical presentation, duration of treatment, receipt of PCI, receipt of any type of revascularization, or presence of diabetes, chronic kidney disease, or smoking (one or two studies reported findings for each subgroup listed). Almost all of the studies showed similar rates of composite ischemic outcomes in the various subgroups, except for subgroup analyses of PCI and treatment duration. One study showed a significantly lower rate of composite ischemic outcomes, and another study showed a significantly lower rate of death in patients who received dual antiplatelet therapy and underwent PCI. One study showed a significantly lower survival rate at 1 year in the groups that received single antiplatelet therapy. Strength of evidence for subgroup findings was rated insufficient given the small number of studies reporting results for each subgroup.

#### Short-Term Versus Long-Term Dual Antiplatelet Therapy

In our analysis of short-term versus long-term DAPT use, we aimed to address the question about the optimal duration of therapy by comparing short-term to long-term use of clopidogrel. The variations in the duration of therapy and the definitions of short-term and long-term treatment made meta-analysis impossible. Our qualitative analysis showed that DAPT duration of either 6 months or 1 year reduced the rate of composite ischemic events (all-cause mortality, nonfatal MI, or stroke) compared with therapy less than 6 months in duration based on two RCTs; however, the findings from an RCT comparing 6-month and 24-month duration showed no differences in the rate of the same composite outcomes at 2 years. Similar results were found when assessing the effect of DAPT duration on all-cause mortality from the same set of RCTs. In addition, one observational study showed that patients receiving a drug-eluting stent benefited from longer dual antiplatelet therapy more than patients receiving a bare metal stent. Evidence was insufficient for the outcomes of composite ischemic events, all-cause mortality (7 studies), cardiovascular mortality (4 studies), nonfatal MI (6 studies), stroke (3 studies), and revascularization (4 studies). Rates of stent thrombosis (6 studies) were higher when DAPT was stopped within 30 days or 6 months, but the differences between therapies beyond 6 months were nonsignificant, thus the evidence was rated insufficient. Stent thrombosis rates may vary based on use of bare metal or drug-eluting stents. There was insufficient evidence that clopidogrel duration had an effect on major bleeding outcomes, with one RCT showing a significantly lower rate of major bleed with 6-month treatment compared with 24-month therapy, another RCT showing no significant increase in major bleed among patients treated for 28 days compared with 12 months, and a third RCT showing no difference in major bleeding among patients treated for 6 months compared with 12 months. There was also insufficient evidence that clopidogrel duration had an effect on minor bleeding rates, which were similar in the short- and long-term duration groups from the same RCTs. Table 40 shows summary SOE and effect estimates for these outcomes.

Table 40 Summary strength of evidence and effect estimates: short-term versus long-term dual antiplatelet therapy

Outcome and Timing | SOE^a^ and Effect Estimate (95% CI)
Composite of all-cause mortality or nonfatal MI within 2 years | SOE = Insufficient (2 RCTs, 2 observational studies; 34,179 patients) Insufficient evidence due to heterogeneity of DAPT duration, inconsistency, and imprecision: 2 RCTs showed no difference between 6- and 12-month therapy and 6- and 24-month therapy; 1 observational study showed that discontinuation before 6 months increased events; 1 observational study showed increased events within first 3 months of stopping clopidogrel after 1 year of therapy
Composite of all-cause mortality or stroke at 2 years | SOE = Insufficient (1 RCT; 2,013 patients) Insufficient evidence due to imprecision: no difference between 6- and 24-month therapy
Composite of all-cause mortality, nonfatal MI, or revascularization at 6 months and 1 year | SOE = Insufficient (2 RCTs, 1 observational study; 4,701 patients) Insufficient evidence due to heterogeneity of DAPT duration and imprecision: both RCTs (1 month vs. 6 months and 6 months vs. 12 months) found similar rates between short- and long-term therapy; the observational study (<3 months vs. 6 months vs. >12 months) showed similar rates across treatment groups in both DES-treated and BMS-treated populations
Composite of all-cause mortality, nonfatal MI, stroke, or revascularization at 1 year | SOE = Insufficient (1 RCT; 1,443 patients) Insufficient evidence due to imprecision: no difference between 6- and 12-month therapy
Composite of all-cause mortality, nonfatal MI, or stroke at 6 months, 1 year, and 2 years | SOE = Insufficient (3 RCTs; 5,133 patients) Insufficient evidence due to heterogeneity of DAPT duration, inconsistency, and imprecision: 2 studies found significant reductions in events from long-term DAPT at 6 months and 1 year; 1 study found no difference between 6- and 24-month therapy
All-cause mortality at 6 months, 1 year, and 2 years | SOE = Insufficient (4 RCTs, 3 observational studies; 38,441 patients) Insufficient evidence due to heterogeneity of DAPT duration, inconsistency, and imprecision: 2 RCTs showed a reduction with longer therapy (1 month vs. 6 months) but 1 was statistically significant and the other was not; 1 RCT (6 months vs. 12 months) showed no difference; 1 observational study (<3 months vs. 6 months vs. >12 months) showed lower mortality in DES-treated patients receiving >12 months of therapy but no difference in the BMS-treated patients; 1 observational study found a higher rate of mortality in those who discontinued clopidogrel within the first 6 months; 1 observational study found a higher risk of death within the first 90 days of discontinuation after a 12-month treatment
Cardiovascular mortality at 6 months, 1 year, and 2 years | SOE = Insufficient (3 RCTs, 1 observational study; 33,728 patients) Insufficient evidence due to heterogeneity of DAPT duration, timing of endpoint measurement, and imprecision: all RCTs found similar rates between short- and long-term therapy (1 month vs. 6 months, 6 months vs. 12 months, and 6 months vs. 24 months); 1 observational study found no difference in CV mortality within the first 90 days of discontinuation after a 12-month treatment
Nonfatal MI at 6 months, 1 year, and 2 years | SOE = Insufficient (4 RCTs, 2 observational studies; 9,173 patients) Insufficient evidence due to imprecision: 5 studies (4 RCTs and 1 observational) showed similar rates of MI in short- and long-term therapy groups; 1 observational study showed statistically significant higher risk in DES patients who discontinued clopidogrel within first 6 months
Stroke at 6 months, 1 year, and 2 years | SOE = Insufficient (3 RCTs; 4,460 patients) Insufficient evidence due to imprecision: all RCTs (1 month vs. 6 months, 6 months vs. 12 months, and 6 months vs. 24 months) found similar rates between short- and long-term therapy, but heterogeneity of DAPT duration makes this inconclusive
Revascularization at 6 months and 1 year | SOE = Insufficient (3 RCTs, 1 observational study; 5,705 patients) Insufficient evidence due to imprecision: rates of revascularization were similar between short- and long-term therapy (1 month vs. 6 months and 6 months vs. 24 months)
Stent thrombosis at 6 months, 1 year, and 2 years | SOE = Insufficient (3 RCTs, 3 observational studies; 15,298 patients) Insufficient evidence due to heterogeneity of DAPT duration and imprecision: rates of stent thrombosis were higher when clopidogrel was stopped within 30 days or 6 months in 2 observational studies; 4 studies (3 RCTs and 1 observational) showed no statistically significant difference in event rates at 1 or 2 years
Major bleeding at 1 year and 2 years | SOE = Insufficient (3 RCTs; 5,572 patients) Insufficient evidence due to inconsistency and imprecision: 1 RCT (6 months vs. 24 months) showed a statistically significant lower rate of major bleeding with clopidogrel with 6-month treatment; the other 2 RCTs (1 month vs. 12 months and 6 months vs. 12 months) showed no statistically significant difference in rates with 1-year treatment
Minor bleeding at 1 year and 2 years | SOE = Insufficient (2 RCTs; 4,129 patients) Insufficient evidence due to imprecision: both RCTs (1 month vs. 12 months and 6 months vs. 24 months) found no difference at 1 and 2 years

BMS = bare metal stent; CI = confidence interval; CV = cardiovascular; DAPT = dual antiplatelet therapy; DES = drug-eluting stent; MI = myocardial infarction; RCT = randomized controlled trial; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

Four studies (two good-quality RCTs and two observational of good and fair quality) reported variations in treatment effectiveness by subgroup. Subgroups analyzed were diabetes (3 studies), age (2), sex (1), chronic kidney disease (1), and stent type (2). No differences in composite ischemic events were found among the different subgroup comparisons. The SOE was low based on the small number of studies that reported subgroup findings and the imprecise estimates of effect.

#### Dual Antiplatelet Therapy With and Without PPI

In our analysis of antiplatelet treatment with and without concomitant PPI therapy, we found that omeprazole was the most commonly studied PPI in both randomized trials and observational registries. In our analysis of DAPT with and without concomitant PPI therapy, we found that omeprazole was the most commonly studied PPI in both randomized trials and observational registries. These patient populations were treated with aspirin plus clopidogrel. Event rates were lower in patients who did not receive PPI medication for the various clinical outcomes: composite ischemic endpoints at 1 year, all-cause mortality at 6 years, nonfatal MI at 1 year, stroke at 1 year, revascularization at 1 year, or rehospitalization at 3 months, stent thrombosis at 1 year, and major bleeding at 1 year. There was no difference between groups for all-cause mortality at1 year and revascularization at 6 months. As expected, GI bleeding was lower in patients treated with PPI medication. The findings were inconsistent (i.e., showing no differences between groups or showing increased event rates in the PPI group), and the evidence base was insufficient for all-cause mortality within the first 3 months, cardiovascular mortality at 1 year, nonfatal MI within the first 3 months, revascularization at 4 years, stent thrombosis at 30 days, major bleeding at 30 days, minor bleeding, and rehospitalization at 1 year. Table 41shows summary SOE and effect estimates for these outcomes.

Table 41 Summary strength of evidence and effect estimates: dual antiplatelet therapy with and without proton pump inhibitor

Outcome and Timing | SOE^a^ and Effect Estimate (95% CI)
Dual Antiplatelet Therapy With and Without PPI b
Composite ischemic endpoints at about 1 year | SOE = Low (2 RCTs, 21 observational studies; 272,311 patients) RCTs of omeprazole showed no difference; however, meta-analysis of observational studies of any PPI showed adj HR 1.35 (1.18 to 1.54), which favors no PPI. The discrepancy between the RCTs and the observational studies makes it difficult to draw a firm conclusion about the effect.
Composite of all-cause mortality or MI at about 1 year | SOE = Moderate (3 observational studies; 60,389 patients) Adj HR 1.27 (1.12 to 1.43); favors no PPI
All-cause mortality within first 3 months | SOE = Insufficient (3 observational studies; 8,943 patients) Insufficient evidence due to inconsistency and imprecision: 2 studies showed no differences in mortality rates; 1 study showed a statistically significant increase in mortality in PPI group, adj HR 2.2 (1.1 to 4.3)
All-cause mortality at about 1 year | SOE = Moderate (2 RCTs, 18 observational studies; 264,172 patients) RCTs of omeprazole showed no difference or favored omeprazole, and the meta-analysis of observational studies of any PPI showed adj HR 1.17 (0.92 to 1.48); no difference
All-cause mortality at 6 years | SOE = Low (1 observational study; 23,200 patients) Adj HR 1.32 (1.00 to 1.73); favors no PPI
Cardiovascular mortality at 1 year | SOE = Insufficient (3 observational studies; 76,184 patients) Insufficient evidence due to inconsistency and imprecision: 2 out of 3 studies showed statistically significant increase in CV mortality in PPI group
Nonfatal MI within first 3 months | SOE = Insufficient (3 observational studies; 8,943 patients) Insufficient evidence due to inconsistency and imprecision: 2 studies showed no statistically significant difference in MI rates; 1 study showed statistically significant increase in MI events in PPI group
Nonfatal MI at about 1 year | SOE = Low (1 RCT, 11 observational studies; 225,687 patients) The RCT and observational study of omeprazole showed no difference; however, the meta-analysis of observational studies of any PPI showed adj HR 1.33 (1.15 to 1.55), which favors no PPI. The discrepancy between the omeprazole studies and the observational studies of any PPI makes it difficult to draw a firm conclusion about the effect.
Stroke at about 1 year | SOE = Low (2 RCTs, 5 observational studies; 165,212 patients) RCTs of omeprazole showed no difference; however, the meta-analysis of observational studies of any PPI showed adj HR 1.49 (1.20 to 1.84), which favors no PPI. The discrepancy between the RCTs and the observational studies makes it difficult to draw a firm conclusion about the effect.
Revascularization at 6 months | SOE = Low (1 RCT, 1 observational study; 22,326 patients) Both studies showed no difference in revascularization rates; no difference
Revascularization at 1 year | SOE = Low (5 observational studies; 53,164 patients) Observational study of omeprazole showed no difference; meta-analysis of observational studies of any PPI showed adj OR 1.48 (1.21 to 1.82); favors no PPI
Revascularization at 4 years | SOE = Insufficient (1 observational study; 315 patients) Insufficient evidence due to imprecision; no statistically significant difference in revascularization rate between groups
Stent thrombosis at 30 days | SOE = Insufficient (1 observational study; 3,408 patients) Insufficient evidence due to imprecision: no statistically significant difference in stent thrombosis rate between groups
Stent thrombosis at about 1 year | SOE = Low (1 RCT, 7 observational studies; 45,198 patients) The RCT and observational study of omeprazole showed no difference; however, the meta-analysis of observational studies of any PPI showed adj HR 1.34 (1.17 to 1.55), which favors no PPI. The discrepancy between the RCT and the observational studies makes it difficult to draw a firm conclusion about the effect.
Major bleeding at 30 days | SOE = Insufficient (3 observational studies; 7,498 patients) Insufficient evidence due to inconsistency and imprecision: adj HR 1.73 (0.61 to 4.88)
Major bleeding at about 1 year | SOE = Low (4 observational studies; 36,231 patients) Adj HR 1.26 (1.12 to 1.41); favors no PPI
GI bleeding | SOE = Moderate (4 RCTS, 4 observational studies; 28,032 patients) 3 out of 4 RCTs of omeprazole and 2 out of 4 observational studies of any PPI showed statistically significant lower rates of GI bleed in the PPI group; favors PPI
Minor bleeding | SOE = Insufficient (1 observational study; 1,346 patients) Insufficient evidence due to imprecision: no difference in minor bleed in-hospital or at 1 year
Rehospitalization at 3 months | SOE = Low (1 observational study; 5,862 patients) Significant increase in rehospitalization in PPI group at 3 months; adj HR 1.32 (1.00 to 1.73); favors no PPI
Rehospitalization at about 1 year | SOE = Insufficient (4 observational studies; 16,925 patients) Insufficient due to inconsistency and imprecision: adj HR 1.70 (0.86 to 3.34)

adj = adjusted; CI = confidence interval; CV = cardiovascular; GI = gastrointestinal; HR = hazard ratio; MI = myocardial infarction; OR = odds ratio; PPI = proton pump inhibitor; RCT = randomized controlled trial; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b ORs less than 1 favor PPI use; ORs greater than 1 favor no PPI use.

#### Aspirin Monotherapy With and Without PPI

In our analysis of aspirin monotherapy with and without concomitant PPI therapy, we presented the findings from two good-quality observational studies that compared clinical outcomes between patients receiving different PPI medications with patients who did not receive a PPI (Table 42). In contrast to the previous section, these patient populations were not prescribed dual antiplatelet therapy; therefore, this evaluation focuses on the addition of PPIs to aspirin monotherapy. There was insufficient evidence for the effect of PPIs on aspirin monotherapy for in-hospital outcomes; only one study of 2744 patients reported the rates of all-cause mortality, nonfatal MI, stroke, and major bleeding. That study found no significant differences between the PPI and no PPI groups. There were inconsistent results for composite ischemic events (cardiovascular mortality, nonfatal MI, or stroke) and lower all-cause mortality at 1 year of followup, with one study showing an increased risk of events in the PPI group and the other study showing no difference. One study reported rates of nonfatal MI at 1 year and showed an increased risk of MI events in the PPI group. Both studies showed no difference in stroke events at 1 year.

Table 42 Summary strength of evidence and effect estimates: aspirin monotherapy with and without proton pump inhibitor

Aspirin Monotherapy With and Without PPI^b^
Composite of CV death, nonfatal MI, or stroke at 1 year | SOE = Insufficient (2 observational studies; 52,196 patients) Insufficient evidence due to inconsistency: 1 study reported increased risk among PPI group (adj HR 1.61 [1.45 to 1.79]), while the other study showed no difference (adj HR 1.00 [0.88 to 1.15])
All-cause mortality (in-hospital) | SOE = Insufficient (1 observational study; 2,744 patients) Insufficient evidence due to imprecision: adj OR 0.96 (0.49 to 1.88)
All-cause mortality at 1 year | SOE = Insufficient (2 observational studies; 52,196 patients) Insufficient evidence due to imprecision: 1 study reported increased risk among PPI group (adj HR 2.38 [2.12 to 2.67]), while the other study showed no difference (adj HR 0.99 [0.86 to 1.14])
Nonfatal MI (in-hospital) | SOE = Insufficient (1 observational study; 2,744 patients) Insufficient evidence due to imprecision: adj HR 1.50 (0.41 to 5.43)
Nonfatal MI at 1 year | SOE = Low (1 observational study; 49,452 patients) Adj HR 1.33 (1.13 to 1.56); favors no PPI
Stroke (in-hospital) | SOE = Insufficient (1 observational study; 2,744 patients) Insufficient evidence due to imprecision: adj HR 0.75 (0.11 to 4.85)
Stroke at 1 year | SOE = Low (2 observational studies; 52,196 patients) Both studies showed no difference, adj HR 1.20 (0.99 to 1.46) and adj HR 0.75 (0.11 to 4.85); no difference
Major bleeding (in-hospital) | SOE = Insufficient (1 observational study; 2,744 patients) Insufficient evidence due to imprecision: adj OR 1.30 (0.38 to 4.39)

adj = adjusted; CI = confidence interval; CV = cardiovascular; GI = gastrointestinal; HR = hazard ratio; MI = myocardial infarction; OR = odds ratio; PPI = proton pump inhibitor; RCT = randomized controlled trial; SOE = strength of evidence

a All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

b ORs less than 1 favor PPI use; ORs greater than 1 favor no PPI use.

#### Dual Antiplatelet Versus Triple Therapy

In our analysis of dual antiplatelet therapy versus triple therapy, we present the findings from studies that compared two antiplatelet agents to a treatment group that received long-term anticoagulation in addition to the two antiplatelet agents. Indications for long-term anticoagulation include atrial fibrillation, presence of a prosthetic valve, chronic deep venous thrombosis, or hypercoagulable states (e.g., protein C or S deficiency). We found 14 observational studies that examined the differences between adding anticoagulant therapy (i.e., warfarin) to various combinations of antiplatelet therapy. In these observational studies there were inconsistent and imprecise findings on the differences between dual and triple therapy on composite ischemic endpoints (all-cause mortality, nonfatal MI, or revascularization, and all-cause mortality or nonfatal MI) at all time points, with some studies showing no difference and others showing increases or decreases in events in the triple therapy group. Dual therapy is better than triple therapy in reducing nonfatal MI and major bleeding at 1 year or longer. One observational study of 800 patients on the effect of dual versus triple therapy showed a significantly lower rate of stroke at 6 months in the triple therapy group, but the evidence from this study was insufficient for nonfatal MI at 6 months. Evidence for an effect of dual therapy versus triple therapy was also insufficient for the outcomes of all-cause mortality at 30 days to 6 months and 1 to 5 years, stroke at 1 to 5 years, revascularization up to 5 years, major bleeding at 30 days, minor bleeding at 1 to 5 years, major and minor bleeding at 1 to 5 years, and stent thrombosis. Table 43 shows the summary SOE and effect estimates for these outcomes.

Table 43 Summary strength of evidence and effect estimates: dual antiplatelet versus triple therapy^a^

Outcome and Timing | SOE^b^ and Effect Estimate^c^ (95% CI)
Composite of all-cause mortality, nonfatal MI, revascularization, or stroke at 1 year or more | SOE = Insufficient (4 observational studies; 8,509 patients) Insufficient evidence due to inconsistency and imprecision: 2 studies showed statistically nonsignificant differences; 2 studies showed statistically significant increases in events in DAPT group
Composite of all-cause mortality or nonfatal MI within first year | SOE = Insufficient (4 observational studies; 57,144 patients) Insufficient evidence due to inconsistency and imprecision: 1 study showed a statistically significant increase, 1 statistically significant decrease in the triple therapy group, and 2 studies showed statistically nonsignificant difference in events between the DAPT and triple therapy.
All-cause mortality at 30 days to 6 months | SOE = Insufficient (2 observational studies; 7,075 patients) Insufficient evidence due to inconsistency and imprecision: 1 study found no difference, another found statistically significantly lower deaths in triple therapy group
All-cause mortality at 1 to 5 years | SOE = Insufficient (8 observational studies; 41,192 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.03 (0.59 to 1.83)
Nonfatal MI at 6 months | SOE = Insufficient (1 observational study; 800 patients) Insufficient evidence due to unknown precision: triple therapy 3.3%; warfarin/aspirin 4.5% (p = 0.49)
Nonfatal MI at 1 to 5 years | SOE = Low (4 observational studies; 1,425 patients) OR 1.85 (1.13 to 3.02); favors DAPT
Stroke at 6 months | SOE = Low (1 observational study; 800 patients) Triple therapy 0.7%; warfarin/aspirin 3.4% (p = 0.02); favors triple therapy
Stroke at 1 to 5 years | SOE = Insufficient (4 observational studies; 6,485 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.01 (0.59 to 2.67)
Revascularization up to 5 years | SOE = Insufficient (4 observational studies; 2,066 patients) Insufficient evidence due to imprecision: no statistical difference between DAPT and triple therapy groups
Major bleeding at 30 days | SOE = Insufficient (5 observational studies; 11,095 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.70 (0.88 to 3.30)
Major bleeding at 1 to 5 years | SOE = Low (7 observational studies; 38,398 patients) OR 1.46 (1.07 to 2.00); favors DAPT
Minor bleeding at 1 to 5 years | SOE = Insufficient (3 observational studies; 890 patients) Insufficient evidence due to inconsistency and imprecision: OR 1.33 (0.48 to 3.69)
Major and minor bleeding | SOE = Insufficient (2 observational studies; 21,545 patients) Insufficient evidence due to imprecision: both studies failed to show a difference between DAPT and triple therapy in the combined endpoint of major and minor bleeding
Stent thrombosis | SOE = Insufficient (2 observational studies; 840 patients) Insufficient evidence due to inconsistency and imprecision: no significant difference in rates (triple therapy 1.4% to 4.1%; dual antiplatelet 1.3% to 3.6%)

CI = confidence interval; DAPT = dual antiplatelet therapy; MI = myocardial infarction; OR = odds ratio; SOE = strength of evidence

a Triple therapy refers to aspirin plus antiplatelet plus anticoagulant.

b All SOE ratings of “Insufficient” (no evidence is available or available evidence is imprecise or too inconsistent to reach a conclusion) are shaded.

c ORs less than 1 favor triple therapy; ORs greater than 1 favor DAPT.

One observational study of 6275 patients reported findings in subgroups of sex, age, and patients with diabetes. That study found lower rates of all-cause mortality in men, across all age groups, and in nondiabetic patients receiving triple therapy; SOE was low for the findings by subgroup since only one study was identified.

### Findings in Relation to What Is Already Known

The American College of Cardiology/American Heart Association guidelines have been published and recently updated to guide clinicians in the treatment of patients with UA/NSTEMI.204 For each KQ, we discuss the findings of this report in relationship to current guidelines and previous systematic reviews or meta-analyses.

#### KQ 1

For KQ 1, which addresses the use of antiplatelet and anticoagulant therapy in UA/NSTEMI patients treated with an early invasive or PCI-based strategy, our findings are consistent with those of previously published guidelines and meta-analyses in many respects. Many large RCTs (including EARLY-ACS, CURRENT-OASIS 7, PLATO, and TRITON-TIMI 38) have impacted our comparisons, and these studies were incorporated into the recent American College of Cardiology Foundation/American Heart Association (ACCF/AHA) guidelines update. Our major findings mirror those of other meta-analyses in that upstream GPI use was not associated with a significant reduction in ischemic endpoints, the optimal loading dose of clopidogrel remains unclear, and prasugrel was associated with a significant reduction in ischemic endpoints compared with clopidogrel. One new finding from this report is that upstream GPI use was associated with lower rates of revascularization, but the tradeoff was a higher risk of major bleeding at 30 days.

Our review expands on what is known about one of the newer antiplatelets: ticagrelor. Based on two new RCTs, ticagrelor was associated with a significant reduction in ischemic endpoints when compared with clopidogrel at 1 year, but unlike the case with prasugrel, the incidence of major bleeding was not significantly higher in ticagrelor-treated patients.

There was a paucity of data on the optimal timing of oral antiplatelet agents as initial treatment for UA/NSTEMI, since the four previous studies (two RCTs, two observational studies) contained a mixture of non-ACS and ACS patients, and the use of anticoagulant (bivalirudin or UFH) and IV antiplatelet (upstream or deferred GPI) was not well defined. Thus, we analyzed the subgroup results of patients receiving either clopidogrel pretreatment or clopidogrel treatment at the time of PCI from randomized trials of (1) bivalirudin versus heparin-based strategy and (2) upstream GPI use versus deferred GPI use. These studies confirmed that in patients pretreated with clopidogrel, the use of bivalirudin at the time of PCI was associated with less major bleeding than a heparin-based strategy. In patients pretreated with clopidogrel, the use of deferred GPI was associated with higher rates of ischemic endpoints (all-cause mortality, nonfatal MI, ischemia, revascularization) and lower rates of major bleeding at 30 days than with the use of upstream GPI was. In patients treated with clopidogrel at the time of PCI there was less major bleeding at 30 days with the use of deferred GPI.

#### KQ 2

For KQ 2, which addresses antiplatelet and anticoagulant treatment in patients undergoing an initial conservative approach for treating UA/NSTEMI, our findings were concordant with the recently published ACCF/AHA guideline recommendations. A direct comparison of enoxaparin and UFH showed a significantly lower incidence of composite ischemic endpoint mostly driven by nonfatal MI reduction among patients receiving enoxaparin, with no difference in the rate of major bleeding. An indirect comparison of fondaparinux and UFH showed significant reductions in composite ischemic events and major bleeding favoring fondaparinux. These results, based mostly on RCTs and supported by observational studies, are consistent with guideline recommendations of initial anticoagulant treatment among UA/NSTEMI patients undergoing an initial conservative approach, in which all three anticoagulants are recommended but with indication of a preferable option for enoxaparin and fondaparinux.

Our findings on the effectiveness and safety of GPIs when administered with UFH compared with UFH alone have shown that the use of tirofiban or eptifibatide reduced the rate of composite ischemic events, mortality, nonfatal MI, and recurrent ischemia. The administration of abciximab with UFH did not significantly reduce ischemic events compared with UFH alone. Use of GPIs increased the rates of major and minor bleeding. Data gained from these studies are more challenging to extrapolate and implement in the context of actual clinical practice because the majority were performed before an early invasive strategy was widely implemented, and they employed an initial conservative strategy followed by percutaneous revascularization after 18 to 72 hours. Further, several GPI studies reported results from a combination of treatment approaches (both invasive and medically managed), and the proportion of patients receiving percutaneous revascularization ranged widely. Lastly, the treatment approach seems to vary by country, with greater use of conservative, medically managed approaches in countries with less access to cardiac catheterization laboratories than in more developed countries.

Current ACCF/AHA UA/NSTEMI guidelines recommend adding a GPI (tirofiban or eptifibatide) to patients who were initially treated conservatively but then require diagnostic angiography due to an increase or new onset of symptoms (class I recommendation, level of evidence A). These guidelines, including the recently published update,204 show no change in the recommendation of administering a GPI (tirofiban or eptifibatide) in addition to an anticoagulant or oral antiplatelet for patients for whom an initial conservative strategy is selected (class IIb, level of evidence B). At the same time, they recommend withholding a GPI if patients are clinically stable; if, after angiography, a percutaneous revascularization is deemed not necessary or if they do not undergo diagnostic angiography (class IIa, level of evidence C). Our analysis shows that newer, smaller studies and the use of DAPT in the conservatively managed population resulted in summary estimates that were more favorable for GPI plus UFH, which supports the class IIb ACCF/AHA recommendation for use of GPI with an anticoagulant or oral antiplatelet for patients treated with an initial conservative strategy.

#### KQ 3

For KQ 3, which addresses antiplatelet and anticoagulant treatment after hospital discharge in patients with UA/NSTEMI, our findings are mostly consistent with recently published guidelines. We found conflicting results on aspirin dosing due to different dosing comparisons and a paucity of studies. Comparison of single antiplatelet therapy versus DAPT supported current recommendations, with evidence of better outcomes among patients treated with dual antiplatelet therapy.

Effect of clopidogrel duration was assessed in nine studies; however, because of differences in the comparison of duration of treatment and outcomes that were assessed, a meta-analysis was not performed and only a qualitative assessment was possible. Significant differences in outcomes were observed when clopidogrel was discontinued early after discharge, and no differences in outcomes were observed when treatment comparisons were greater than 6 months. Only two studies looked at treatment effect based on stent type, and again the worst outcomes were observed among patients with either bare metal or drug-eluting stents who discontinued clopidogrel (either stopped taking it or were taken off it by their doctor) within the first 6 months. Guidelines recommend a treatment duration of 1 year if there is no increased risk of bleeding. Our findings support the recommendation not to treat beyond 1 year; however, there is uncertainty about whether discontinuation at an earlier time point (between 6 and 12 months) could be safely done since the data are not clear about when exactly the benefit fades.

In our analysis of the use of PPIs with dual antiplatelet therapies meta-analyses using adjusted or propensity-scored hazard ratios from observational studies, showed an association between PPI use (any type) and increased rates of composite ischemic endpoints, death, nonfatal MI, stroke, revascularization, stent thrombosis and major bleeding. We downgraded the SOE ratings since the findings from observational studies conflicted with the few randomized trials of omeprazole. We cannot exclude the possibility of residual confounding in the observational studies, despite the adjustment for comorbid illness and other clinical factors. A recent update of the ACCF/AHA guidelines has removed the recommendation to administer PPIs among patients with a history of gastrointestinal bleeding and instead suggests that health care providers reevaluate the need for starting or continuing PPI treatment in patients taking clopidogrel. Their statement does not prohibit the use of PPI agents in appropriate clinical settings; however, they describe the potential risks and benefits from use of PPI agents in combination with clopidogrel. Our findings support a cautious approach to PPI use with DAPT therapy in UA/NSTEMI patients.

Finally, we assessed the use of triple therapy (dual antiplatelet plus anticoagulation) and found low SOE that nonfatal MI and major bleeding rates were higher and stroke rates were lower with triple therapy than with DAPT. However, the findings for all other endpoints were rated insufficient due to either inconsistency or imprecision of results, or both—making it impossible to reach a firm conclusion. The current ACCF/AHA guidelines give a class I recommendation that warfarin in combination with aspirin or dual antiplatelet therapy is associated with an increased risk of bleeding and a class IIb recommendation that targeting oral anticoagulant therapy to a lower international normalized ratio (INR) (e.g., 2.0 to 2.5) is reasonable in patients managed with DAPT due to inconsistency and imprecision of existing data for this comparison.

## Applicability

Studies included in this review were primarily multicenter international studies that included the United States and Canada, so the applicability of our findings spans multiple geographic locations. While many studies were also conducted outside the United States, there are similarities in UA/NSTEMI treatments internationally and this should therefore not be seen as a limitation in treatment setting. However, two main factors limit our findings: population and intervention. First, in order to have adequate numbers of citations to address the safety and effectiveness of antiplatelet and anticoagulant therapies in UA/NSTEMI patients, we had to broaden our eligible patient population to include studies of either UA/NSTEMI or ACS (STEMI, NSTEMI, and UA). In addition, some antiplatelet and anticoagulant studies included ACS and stable angina populations. To improve the applicability of our findings to the UA/NSTEMI population, we excluded studies that focused exclusively on the STEMI or stable angina population.

Second, due to a change in terminology regarding treatment approach (i.e., early invasive strategy and initial conservative strategy), we had to make an assumption that trials that discouraged coronary angiography or PCI in the early phase of MI treatment could be labeled as a conservatively managed approach. Many of those types of studies are older (mid-1990s), or were conducted in non-U.S. settings. We did not find any limits to applicability regarding the comparisons or outcomes reported.

## Implications for Clinical and Policy Decisionmaking

More than one million patients in the United States are treated for UA/NSTEMI each year. Ischemic heart disease has remained a leading cause of death in the United States despite major advances in cardiovascular care over the past decade. Due to the prevalence, associated morbidity and mortality, cost, and multiple effective treatment options for UA/NSTEMI patients, this Comparative Effectiveness Review provides important information to guide both future research and clinical and policy decisionmaking.

Regarding the invasive treatment strategy in UA/NSTEMI patients, this review found that several therapies were effective at improving ischemic endpoints while minimizing bleeding endpoints. Two new antiplatelet medications (prasugrel and ticagrelor) were superior to clopidogrel in terms of reduction of ischemic endpoints, but the cost-effectiveness of these novel agents is not currently known because generic formulations of clopidogrel have recently become available in the United States. Additionally, due to the different pharmacokinetic and pharmacodynamic properties of these novel agents, their effectiveness may differ when studying the combination of strategies that were compared in this review (i.e., upstream GPI vs. deferred GPI, bivalirudin vs. heparin, timing of P2Y_12_ administration). Further study is needed to determine the effectiveness and safety of these newer agents in these specific contexts.

Regarding the conservative management approach, in our review of observational studies we found a growing use of low molecular weight heparin (i.e., enoxaparin) based on evidence of better effectiveness and similar bleeding rates compared with UFH. The effectiveness of fondaparinux in comparison with enoxaparin requires further study; however, our indirect analysis comparing fondaparinux with UFH provides preliminary evidence that fondaparinux also reduces composite ischemic events and does not increase the risk of bleeding. Our review shows that the administration of GPI in the conservatively managed population is beneficial; however, newer ACCF/AHA guideline recommendations suggest that GPIs should be administered only prior to PCI or for recurrent symptoms. The guideline recommendation is primarily based on findings in the invasively managed population (presented for KQ 1) and not specifically on the findings from the conservatively managed population.

For the postdischarge setting, the optimal aspirin dose to use with clopidogrel for dual antiplatelet therapy is uncertain; however, it is clear that DAPT is beneficial in reducing future ischemic events compared with single antiplatelet therapy and that treatment durations of 6 months to 1 year are better than shorter duration of therapy. Our findings support a cautious approach to PPI use with DAPT therapy in UA/NSTEMI patients given the higher number of ischemic events in patients who receive a PPI. Finally, our analysis of observational studies of DAPT and triple therapy in patients with a long-term indication for warfarin shows inconsistent and insufficient evidence for the impact on ischemic events; however, bleeding events are increased with triple therapy. Further study on aspirin dosing with DAPT, the role of newer antiplatelet agents (prasugrel, ticagrelor), and newer anticoagulants (dabigatran, rivaroxaban, and apixaban) for triple therapy are needed.

## Limitations of the Review Process

The current review was limited to English-language studies and focused on those that directly compared various antiplatelet and anticoagulation agents, either individually or in combination. Any studies that reported noncomparative findings, such as a study assessing the outcomes of patients treated with one antiplatelet or anticoagulant agent over time without a control or comparator group, were excluded. However, it is unlikely that these studies would have provided substantial additional information given the quality and SOE of the studies reviewed.

For most of the comparisons, a quantitative analysis of composite ischemic endpoints was challenging to conduct given the different composite endpoint definitions. In some comparisons, we pooled the studies for the most frequently reported composite, but this resulted in excluding relevant studies with a different composite endpoint definition. In some comparisons, the number of studies for each composite endpoint definition was too small to put into a meta-analysis model. Another option is to pool studies with composite endpoints that are essentially similar (e.g., 2 out of 3 of the components are the same, with the event rates of the third component reasonably similar to each other). For some studies, we treated total mortality and cardiovascular mortality as essentially similar, since the event rates of cardiovascular mortality usually dominate the event rates for total mortality.

Related to the variations in the composite ischemic endpoint definition outlined above, there was also heterogeneity in the individual endpoint definitions (e.g., MI, stroke, bleeding) and how these endpoints were reported within the published literature. We were not able to focus on the nuances in the endpoint definitions but instead relied on the study authors' definitions. This is another limitation of the review process, which can be resolved with further standardization of outcome definitions and reporting.

A final limitation of this review is the separation of the effectiveness and safety outcomes in our analyses. We did not conduct an analysis of the net benefit (i.e., assessing the effectiveness while accounting for the risk of these therapies). Very few studies reported the net benefit of their interventions. Further, a calculation of net benefit across studies may not be robust since often there was heterogeneity in the composite endpoint definition, and pooling in order to combine individual outcomes into a standard composite benefit may have overestimated the number of events if patients experienced more than one individual outcome. We also did not assess for consistency in endpoint definitions across studies, assuming that the differences between studies and any definition changes over time were minimal. Bleeding definitions were also variable across studies. In our analyses of bleeding definitions we used TIMI (thrombolysis in myocardial infarction) criteria when they were reported; otherwise we accepted the study definition of a major and minor bleed.

## Limitations of the Evidence Base

The main limitation was the change in terminology regarding treatment approach (i.e., early invasive strategy and initial conservative strategy) in the early 2000s. There is no MeSH search term for these types of treatment approaches; thus, it was difficult to group studies and patient populations into an early invasive treatment or initial conservative strategy. Some studies included both early invasive and early conservative treatment approaches and some studies did not report which treatment approach was used. Fortunately, newer publications are starting to report findings by treatment approach, so future evidence reviews will benefit from further specification. However, in clinical practice the treatment approach for a UA/NSTEMI patient may not always be determined before the pharmacologic therapy is selected. For this review, we tried to separate the early invasive and initial conservative studies into a PCI-based strategy and a medically managed strategy. This led to some overlap in the comparisons of enoxaparin, UFH, and fondaparinux in both the KQ 1 and KQ 2 sections of this report. Another limitation was the patient population enrolled in these antiplatelet and anticoagulant studies. While the focus of this review was the UA/NSTEMI population, we found a lower proportion of studies (about 35%) that solely enrolled UA/NSTEMI patients. Instead, the majority of studies (65%) contained a mixed population of ACS patients, including UA/NSTEMI and STEMI patients. Also, improvements in diagnostic testing have altered the definition and classification of MI and UA over time, thus leading to variations in these definitions across studies.

Important limitations of the literature across the KQs include: (1) few studies that assess long-term clinical outcomes for both ischemic and bleeding events, (2) few studies in specific patient subgroups of interest, and (3) few studies that looked at combinations of antiplatelet and anticoagulant treatments, specifically dosage, timing, and duration of these combinations.

## Research Gaps

Acute coronary syndromes, including UA/NSTEMI, are widely studied, as evidenced by our screening of over 20,000 abstracts to identify 290 articles (166 studies) of antiplatelet and anticoagulant agents. In our review, we found research gaps involving both established and newer therapies, particularly related to the comparative effectiveness of these treatments; issues related to dosage, timing, and type of administration (IV or oral), and combinations of therapy. We used the framework recommended by Robinson et al.205 to identify gaps in evidence and describe the reasons why these gaps exist. This approach considers PICOTS criteria to classify gaps as due to (1) insufficient or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information. Results are presented for each KQ.

Across all KQs, we found a gap in reporting of racial and ethnic demographics of study participants. Future studies should take care to report the comparative effectiveness and safety of antiplatelet and anticoagulant treatment regimens in racial and ethnic subpopulations as well as summary population effects.

### KQ 1

In KQ 1, the primary research gap was the lack of direct comparisons of IV and oral combination treatment strategies. While many studies investigated the use of one oral antiplatelet versus another oral antiplatelet, there were scant data on combinations of antiplatelet and anticoagulant medications used for UA/NSTEMI patients. In addition, there is a paucity of evidence surrounding the optimal timing and administration of these antiplatelet and anticoagulant medications when used in combination for patients with UA/NSTEMI. Our review highlights the need for future studies to compare novel antiplatelet agents (ticagrelor, prasugrel) in a head-to-head manner. In clinical practice, the use of bleeding-avoidance strategies has prompted many clinicians to avoid the use of GPI while using clopidogrel pretreatment and bivalirudin at the time of PCI. Validation of the use of these medications in combination when compared with the use of GPI is needed. Further, given the importance of reducing ischemic events and bleeding events, a gap was present, as no included studies measured the effect of specific strategies to reduce bleeding (i.e., radial artery access, vascular closure devices).

### KQ 2

In KQ 2, the primary research gap is reporting safety and effectiveness among the subgroup of conservatively managed patients within trials or observational studies of mixed treatment approaches. We found only a couple of studies presenting subgroup analysis by medically managed patients for both the low molecular weight heparin and GPI analyses—and often the data were not concordant. Future studies can address this either by stratification of the antiplatelet or anticoagulant therapy by treatment approach (invasive or conservative) or by reporting the subgroup findings for the conservatively managed population within a larger trial or observational study.

### KQ 3

In KQ 3, there were many research gaps. First, more studies assessing the optimal loading and maintenance dose of aspirin are needed since our review found heterogeneity in the definitions of low- and high-dose aspirin. In addition, the optimal dose of aspirin within a DAPT strategy requires further study, especially within subgroups of patients at risk for bleeding complications.

Second, more randomized trials are needed on clopidogrel duration up to and beyond 1 year of ongoing treatment. There were few RCTs on this subject, and the small number of observational studies showed no difference in clinical outcomes when assessing 6-month versus longer treatment durations. While published literature has shown that early discontinuation of dual antiplatelet therapy (within 3 months, 6 months, or 1 year) is associated with a poorer clinical outcome, the need for treatment beyond 1 year is still uncertain. Also, as stated above in the KQ 1 research gaps, the duration of new antiplatelet agents (prasugrel and ticagrelor) in combination with aspirin requires further study, as does the comparative effectiveness of use of these agents based on the type of stent used during PCI.

Third, observational studies have concluded that concomitant PPI treatment is related to worse clinical outcomes, while RCTs of one specific PPI (omeprazole) showed no effect. This suggests that the observational studies are confounded by comorbid conditions (i.e., selection bias). It is unclear whether genetic resistance to clopidogrel is a causal factor, or whether the negative interaction is drug or class specific, since those variables were not included in the studies we reviewed. Further research, preferably additional RCTs of specific PPIs compared with each other or prospective propensity score-matched cohort studies, is warranted on whether the detrimental effect of PPIs is due to comorbid conditions of the patient population, type of PPI, or genetic predisposition for reduced clopidogrel sensitivity.

The final research gap for KQ 3 is the limited and inconsistent data on long-term anticoagulant therapy. Further study on aspirin dosing with dual antiplatelet therapy, the role of newer antiplatelet agents (prasugrel, ticagrelor), and newer anticoagulants (dabigatran, rivaroxaban, and apixaban) for triple therapy are needed.

Across all KQs, we found a gap in reporting of racial and ethnic demographics of study participants. Thus, we had few studies that looked at the comparative effectiveness and safety of antiplatelet and anticoagulant treatment regimens in racial and ethnic subpopulations.

## Conclusions

- Overall, the administration of GPIs prior to PCI is associated with a reduction in revascularization rates but an increase in major bleeding events, regardless of whether clopidogrel is administered prior to or during the PCI.
- Prasugrel reduces rates of composite ischemic events (death, MI, or stroke) at 30 days and 1 year, but also results in an increase in major bleeding events at 1 year in comparison with clopidogrel. Ticagrelor reduces rates of composite ischemic events, but has similar rates of major bleeding at 1 year compared with clopidogrel.
- Bivalirudin is associated with a lower incidence of major bleeding events compared with heparin-based treatment, regardless of whether GPI administration was planned; bivalirudin also reduces rates of minor bleeding events compared with heparin with GPI use.
- Enoxaparin and fondaparinux are associated with a significant reduction in composite ischemic events when compared with UFH in a conservatively managed population.
- Dual antiplatelet therapy of 6 months to 1 year reduces the rates of composite ischemic outcomes and nonfatal MI; however, the optimal dose of aspirin in combination with clopidogrel is less certain.
- While PPIs have been associated with worse clinical outcomes compared with no PPI use in observational studies, the results from a small number of RCTs of omeprazole show no significant difference in clinical events compared with placebo. Therefore, PPIs should be used with caution in patients receiving clopidogrel with aspirin (DAPT).

Although we identified many citations, the number of studies for each comparison was relatively small, and the preponderance of observational studies in some of the comparisons made the findings less conclusive. To improve the findings of this report, more good-quality studies (both RCTs and observational) of antiplatelet and anticoagulant treatments are required. Uncertainty remains about the optimal dosing, timing, duration, and combinations of many of the options. This uncertainty is seen especially in subpopulations of interest (e.g., the elderly, patients with diabetes, women, obese patients, and those with comorbid illness).