# Unadjusted, Adjusted, and Propensity-Scored Results for Studies of Proton Pump Inhibitors

Table J-1 Unadjusted, adjusted, and propensity-scored results for PPI versus no PPI from Key Question 3

## Unadjusted Results From Studies of Proton Pump Inhibitors

### Effect on Composite Ischemic Endpoints Within 1 Year

Five observational studies (3 good quality, 1 fair, 1 poor; 29,403 patients) reported composite ischemic outcomes at 1 year.4,25-27,34 One study25 comparing the use of PPI versus no PPI found a nonsignificant difference in the rate of in-hospital composite outcomes (all-cause mortality, nonfatal MI, or stroke) between the two treatment arms (no PPI vs. PPI 0.6% vs. 2.5%; OR 3.29; 95% CI, 0.44-24.73, p=0.247). Another study26 assessed the use of PPI versus no PPI and found a significant increase in the rate of composite outcomes (all-cause mortality or stent thrombosis) at 30 days among patients discharged with PPI treatment versus no PPI (PPI vs. no PPI 3.3% vs. 1.2%; adjusted OR 2.0; 95% CI, 1.1 to 3.7, p=0.02). Another study34 evaluated the use of PPI versus no PPI found a significant increase in the rate of composite outcomes (all-cause mortality or rehospitalization for MI) at 3 months among patients discharged with PPI treatment versus without PPI (33.2% [PPI] vs.11.6% [no PPI]; adjusted HR 3.20; 95% CI, 2.56 to 4.01, p<0.0001). A study4 evaluating the use of PPI versus no PPI found a significant increase in the rate of composite outcomes (rehospitalization for MI, percutaneous coronary intervention, or intermediate coronary syndrome) among patients discharged with PPI treatment versus without PPI treatment (PPI vs. no PPI HR 1.44; 95% CI, 1.24 to 1.68). Another study27 evaluating the use of PPI versus no PPI, found a significantly higher rate of composite outcomes (cardiovascular mortality, MI, ischemic stroke, stent thrombosis, or target lesion revascularization) among patients concomitantly treated with clopidogrel (HR 1.40; 95% CI, 1.17 to 1.68) but not among those who did not receive clopidogrel ( HR 1.16; 95% CI, 0.95 to 1.43). The strength of evidence was rated moderate for composite ischemic outcomes based on consistent but imprecise results from five observational studies.

### Effect on Composite Endpoint of All-Cause Mortality, Nonfatal MI, or Stroke at 1 Year

A random-effects meta-analysis of 9 observational studies5,7,10,11,13,23,28,31,33 (8 good quality, 1 fair) in 124,888 UA/NSTEMI patients reporting a composite outcome of all-cause mortality, nonfatal MI, or stroke between 6 and 18 months found an odds ratio of 1.35 (95% CI, 1.05 to 1.73), favoring no PPI use (Figure J-1). There was evidence of extreme heterogeneity, with a Q-value of 248.9 for 8 degrees of freedom, p<0.001. The strength of evidence was rated moderate for this composite outcome at 1 year based on good-quality studies and inconsistent findings of a direct outcome with a narrow confidence interval.

Figure J-1 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on composite of all-cause mortality, nonfatal myocardial infarction, or stroke at 1 year

Abbreviations: CI=confidence interval; Clop=clopidogrel; PPI=proton pump inhibitor

This figure shows a forest plot of nine studies that shows an odds ratio of 1.35 (95% CI, 1.05 to 1.73), favoring no proton pump inhibitor use.

### Effect on Composite Endpoint of All-Cause Mortality or Nonfatal MI at 6 to 18 Months

A random-effects meta-analysis of three good-quality observational studies10,13,22 in 22,094 UA/NSTEMI patients reporting all-cause mortality or nonfatal MI between 6 and 18 months found an odds ratio of 1.40 (95% CI, 1.24 to 1.59), favoring no PPI use (Figure J-2). There was no evidence of heterogeneity, with a Q-value of 1.80 for 2 degrees of freedom, p=0.41. Despite having good-quality studies and consistent findings of a direct outcome with a narrow confidence interval, the overall strength of evidence was reduced from high to moderate based on possible confounding by comorbid conditions in the patient population that was prescribed a PPI (selection bias).

Figure J-2 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on composite of all-cause mortality or nonfatal myocardial infarction at 6 to 18 months

Abbreviations: CI=confidence interval; Clop=clopidogrel; PPI=proton pump inhibitor

This figure shows a forest plot of three studies that shows an odds ratio of 1.40 (95% CI, 1.24 to 1.59), favoring no proton pump inhibitor use.

### Effect on All-Cause Mortality After 1 Year

A random-effects meta-analysis of 16 observational studies5,7,10-14,16,17,21,23,25,28,30,33,34 (14 good quality, 2 fair quality) in 141,474 UA/NSTEMI patients reporting all-cause mortality between 6 and 18 months found an odds ratio of 1.48 (95% CI, 1.16 to 1.89), favoring no PPI use (Figure J-3). There was evidence of extreme heterogeneity, with a Q-value of 151.0 for 15 degrees of freedom, p<0.001. The strength of evidence was rated moderate for all-cause mortality after 1 year based on predominately good-quality studies and inconsistent findings of a direct outcome with a narrow confidence interval.

Figure J-3 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on all-cause mortality after 1 year

Abbreviations: CI=confidence interval; Clop=clopidogrel; PPI=proton pump inhibitor

This figure shows a forest plot of 16 studies that shows an odds ratio of 1.48 (95% CI, 1.16 to 1.89), favoring no proton pump inhibitor use.

One study was not included in the analysis since it presented data as adjusted RR only and event rates were not available. This study22 comparing PPI use versus no PPI use in 18,565 UA/NSTEMI patients found no significant difference in the risk of all-cause mortality at 6 months (RR 1.20; 95% CI, 0.84 to 1.70).

### Effect on Nonfatal MI at 1 Year

A random-effects meta-analysis of 8 observational studies5,7,8,11,13,16,17,33 (7 good quality, 1 fair quality) in 122,367 UA/NSTEMI patients reporting nonfatal MI between 6 and 18 months found an odds ratio of 1.65 (95% CI, 1.38 to 1.97), favoring no PPI use (Figure J-4). There was evidence of extreme heterogeneity, with a Q-value of 31.0 for 7 degrees of freedom, p<0.001. The I^2^ value was 77.4. The strength of evidence was rated moderate for nonfatal MI at 1 year based on primarily good quality studies, inconsistent results of a direct outcome, and a narrow confidence interval.

Figure J-4 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on nonfatal myocardial infarction at 1 year

Abbreviations: CI=confidence interval; Clop=clopidogrel; PPI=proton pump inhibitor

This figure shows a forest plot of eight studies that shows an odds ratio of 1.65 (95% CI, 1.38 to 1.97), favoring no proton pump inhibitor use.

Two studies were not included in the analysis because these studies reported adjusted OR/HR and actual event rates were not available. One study32 looking at the effect of concomitant use of PPIs with clopidogrel on nonfatal MI found that UA/NSTEMI patients discharged on PPI were at higher risk of nonfatal MI at 1 year compared with those discharged without PPI (adjusted OR1.62; 95% CI, 1.15 to 2.27). In the second study22 treatment with PPI resulted in a higher risk of nonfatal MI but did not reach statistical significance (HR 1.22; 95% CI, 0.99 to 1.51).

### Effect on Stroke at 1 Year

A random-effects meta-analysis of six good-quality observational studies5,7,17,23,28,33 in 57,501 UA/NSTEMI patients reporting stroke between 6 and 18 months found an odds ratio of 1.46 (95% CI, 1.15 to 1.86), favoring no PPI use (Figure J-5). There was evidence of heterogeneity, with a Q-value of 14.7 for 5 degrees of freedom, p= 0.01. The strength of evidence was rated moderate for stroke outcomes at 1 year based on six good-quality studies with inconsistent results of a direct outcome and a narrow confidence interval.

Figure J-5 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on stroke at 1 year

Abbreviations: CI=confidence interval; Clop=clopidogrel; PPI=proton pump inhibitor

This figure shows a forest plot of six studies that shows an odds ratio of 1.46 (95% CI, 1.15 to 1.86), favoring no proton pump inhibitor use.

### Effect on Revascularization at 1 Year

Two studies of omeprazole reported repeat revascularization—one RCT at 6 months3 and one observational study at 1 year35 after hospital discharge for UA/NSTEMI. Both studies found a similar rate of revascularization among patients discharged on omeprazole compared with those discharged without omeprazole (4.0% vs. 4.6% and 9.4% vs. 8.9%). The strength of evidence was rated insufficient for assessing revascularization outcomes based on imprecise estimates and insufficient power to detect a difference.

A random-effects meta-analysis of four good-quality observational studies of any PPI1,14,17,21 in 52,576 UA/NSTEMI patients reporting revascularization at 1 year found an odds ratio of 1.37 (95% CI, 1.19 to 1.58), favoring no PPI use (Figure J-6). There was evidence of heterogeneity, with a Q-value of 10.7 for 3 degrees of freedom, p=0.01.

Figure J-6 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on revascularization at 1 year

Abbreviations: CI=confidence interval; PPI=proton pump inhibitor

This figure shows a forest plot of four studies that shows an odds ratio of 1.37 (95% CI, 1.19 to 1.58), favoring no proton pump inhibitor use.

### Effect on Stent Thrombosis at 1 Year

A random-effects meta-analysis of four good-quality observational studies11,13,25,30 in 23,833 UA/NSTEMI patients reporting stent thrombosis between 6 and 18 months found an odds ratio of 1.29 (95% CI, 0.94 to 1.77) (Figure J-7). There was no evidence of heterogeneity, with a Q-value of 0.76 for 3 degrees of freedom, p=0.86. The strength of evidence was rated insufficient for stent thrombosis at 1 year based on good-quality studies with consistent results of a direct outcome and a wide confidence interval.

Figure J-7 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on stent thrombosis at 1 year

Abbreviations: CI=confidence interval; Clop=clopidogrel; PPI=proton pump inhibitor

This figure shows a forest plot of four studies that shows an odds ratio of 1.29 (95% CI, 0.94 to 1.77).

### Effect on Major Bleeding at 1 Year

A random-effects meta-analysis of three good-quality studies11,13,25 in 22,138 UA/NSTEMI patients reporting major bleeding at 1 year found an odds ratio of 1.25 (95% CI, 0.94 to 1.67) (Figure J-8). There was no evidence of heterogeneity, with a Q-value of 2.22 for 2 degrees of freedom, p=0.33. The strength of evidence was rated insufficient for major bleeding at 1 year based on good-quality studies with inconsistent results of a direct outcome and a narrow confidence interval.

Figure J-8 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on major bleeding at 1 year

Abbreviations: CI=confidence interval; Clop=clopidogrel; PPI=proton pump inhibitor

This figure shows a forest plot of three studies that shows an odds ratio of 1.25 (95% CI, 0.94 to 1.67).

### Effect on Rehospitalization at 1 Year

A random-effects meta-analysis of five good-quality observational studies14,15,21,29,30 in 25,715 UA/NSTEMI patients reporting rehospitalization at 1 year found an odds ratio of 3.39 (95% CI, 1.88 to 6.11), favoring no PPI use (Figure J-9). There was evidence of extreme heterogeneity, with a Q-value of 32.4 for 4 degrees of freedom, p<0.001. The strength of evidence was rated low for rehospitalization at 1 year based on good-quality studies with inconsistent results of an indirect outcome and a wide confidence interval.

Figure J-9 Meta-analysis of dual antiplatelet therapy with and without proton pump inhibitor on rehospitalization at 1 year

Abbreviations: CI=confidence interval; PPI=proton pump inhibitor

This figure shows a forest plot of five studies that shows an odds ratio of 3.39 (95% CI, 1.88 to 6.11), favoring no proton pump inhibitor use.

## References Cited in Appendix J

1 Banerjee S, Weideman RA, Weideman MW, et al. Effect of concomitant use of clopidogrel and proton pump inhibitors after percutaneous coronary intervention. Am J Cardiol. 2011;107(6):871-8. [pmid: 21247527].
2 Barada K, Karrowni W, Abdallah M, et al. Upper gastrointestinal bleeding in patients with acute coronary syndromes: clinical predictors and prophylactic role of proton pump inhibitors. J Clin Gastroenterol. 2008;42(4):368-72. [pmid: 18277903].
3 Bhatt DL, Cryer BL, Contant CF, et al. Clopidogrel with or without omeprazole in coronary artery disease. N Engl J Med. 2010;363(20):1909-17. [pmid: 20925534].
4 Bhurke SM, Martin BC, Li C, et al. Effect of the Clopidogrel-Proton Pump Inhibitor Drug Interaction on Adverse Cardiovascular Events in Patients with Acute Coronary Syndrome. Pharmacotherapy. 2012. [pmid: 22744772].
5 Charlot M, Ahlehoff O, Norgaard ML, et al. Proton-pump inhibitors are associated with increased cardiovascular risk independent of clopidogrel use: a nationwide cohort study. Ann Intern Med. 2010;153(6):378-86. [pmid: 20855802].
6 Charlot M, Grove EL, Hansen PR, et al. Proton pump inhibitor use and risk of adverse cardiovascular events in aspirin treated patients with first time myocardial infarction: nationwide propensity score matched study. BMJ. 2011;342:d2690. [pmid: 21562004].
7 Chitose T, Hokimoto S, Oshima S, et al. Clinical Outcomes Following Coronary Stenting in Japanese Patients Treated With and Without Proton Pump Inhibitor. Circ J. 2011. [pmid: 22130313].
8 Evanchan J, Donnally MR, Binkley P, et al. Recurrence of acute myocardial infarction in patients discharged on clopidogrel and a proton pump inhibitor after stent placement for acute myocardial infarction. Clin Cardiol. 2010;33(3):168-71. [pmid: 20235209].
9 Gao QP, Sun Y, Sun YX, et al. Early use of omeprazole benefits patients with acute myocardial infarction. J Thromb Thrombolysis. 2009;28(3):282-7. [pmid: 18830566].
10 Gaspar A, Ribeiro S, Nabais S, et al. Proton pump inhibitors in patients treated with aspirin and clopidogrel after acute coronary syndrome. Rev Port Cardiol. 2010;29(10):1511-20. [pmid: 21265493].
11 Goodman SG, Clare R, Pieper KS, et al. Association of Proton Pump Inhibitor Use on Cardiovascular Outcomes with Clopidogrel and Ticagrelor: Insights from PLATO. Circulation. 2012. [pmid: 22261200].
12 Gupta E, Bansal D, Sotos J, et al. Risk of adverse clinical outcomes with concomitant use of clopidogrel and proton pump inhibitors following percutaneous coronary intervention. Dig Dis Sci. 2010;55(7):1964-8. [pmid: 19731021].
13 Harjai KJ, Shenoy C, Orshaw P, et al. Clinical outcomes in patients with the concomitant use of clopidogrel and proton pump inhibitors after percutaneous coronary intervention: an analysis from the Guthrie Health Off-Label Stent (GHOST) investigators. Circ Cardiovasc Interv. 2011;4(2):162-70. [pmid: 21386091].
14 Ho PM, Maddox TM, Wang L, et al. Risk of adverse outcomes associated with concomitant use of clopidogrel and proton pump inhibitors following acute coronary syndrome. JAMA. 2009;301(9):937-44. [pmid: 19258584].
15 Hsiao FY, Mullins CD, Wen YW, et al. Relationship between cardiovascular outcomes and proton pump inhibitor use in patients receiving dual antiplatelet therapy after acute coronary syndrome. Pharmacoepidemiol Drug Saf. 2011;20(10):1043-9. [pmid: 21823195].
16 Juurlink DN, Gomes T, Ko DT, et al. A population-based study of the drug interaction between proton pump inhibitors and clopidogrel. CMAJ. 2009;180(7):713-8. [pmid: 19176635].
17 Kreutz RP, Stanek EJ, Aubert R, et al. Impact of proton pump inhibitors on the effectiveness of clopidogrel after coronary stent placement: the clopidogrel Medco outcomes study. Pharmacotherapy. 2010;30(8):787-96. [pmid: 20653354].
18 Ng FH, Wong SY, Lam KF, et al. Gastrointestinal bleeding in patients receiving a combination of aspirin, clopidogrel, and enoxaparin in acute coronary syndrome. Am J Gastroenterol. 2008;103(4):865-71. [pmid: 18177451].
19 Ng FH, Tunggal P, Chu WM, et al. Esomeprazole Compared With Famotidine in the Prevention of Upper Gastrointestinal Bleeding in Patients With Acute Coronary Syndrome or Myocardial Infarction. Am J Gastroenterol. 2011. [pmid: 22108447].
20 O'Donoghue ML, Braunwald E, Antman EM, et al. Pharmacodynamic effect and clinical efficacy of clopidogrel and prasugrel with or without a proton-pump inhibitor: an analysis of two randomised trials. Lancet. 2009;374(9694):989-97. [pmid: 19726078].
21 Ortolani P, Marino M, Marzocchi A, et al. One-year clinical outcome in patients with acute coronary syndrome treated with concomitant use of clopidogrel and proton pump inhibitors: results from a regional cohort study. J Cardiovasc Med (Hagerstown). 2011. [pmid: 21252697].
22 Rassen JA, Choudhry NK, Avorn J, et al. Cardiovascular outcomes and mortality in patients using clopidogrel with proton pump inhibitors after percutaneous coronary intervention or acute coronary syndrome. Circulation. 2009;120(23):2322-9. [pmid: 19933932].
23 Ray WA, Murray KT, Griffin MR, et al. Outcomes with concurrent use of clopidogrel and proton-pump inhibitors: a cohort study. Ann Intern Med. 2010;152(6):337-45. [pmid: 20231564].
24 Ren YH, Zhao M, Chen YD, et al. Omeprazole affects clopidogrel efficacy but not ischemic events in patients with acute coronary syndrome undergoing elective percutaneous coronary intervention. Chin Med J (Engl). 2011;124(6):856-61. [pmid: 21518592].
25 Rossini R, Capodanno D, Musumeci G, et al. Safety of clopidogrel and proton pump inhibitors in patients undergoing drug-eluting stent implantation. Coron Artery Dis. 2011;22(3):199-205. [pmid: 21358542].
26 Sarafoff N, Sibbing D, Sonntag U, et al. Risk of drug-eluting stent thrombosis in patients receiving proton pump inhibitors. Thromb Haemost. 2010;104(3):626-32. [pmid: 20664905].
27 Schmidt M, Johansen MB, Robertson DJ, et al. Concomitant use of clopidogrel and proton pump inhibitors is not associated with major adverse cardiovascular events following coronary stent implantation. Aliment Pharmacol Ther. 2012;35(1):165-74. [pmid: 22050009].
28 Simon T, Steg PG, Gilard M, et al. Clinical events as a function of proton pump inhibitor use, clopidogrel use, and cytochrome P450 2C19 genotype in a large nationwide cohort of acute myocardial infarction: results from the French Registry of Acute ST-Elevation and Non-ST-Elevation Myocardial Infarction (FAST-MI) registry. Circulation. 2011;123(5):474-82. [pmid: 21262992].
29 Stockl KM, Le L, Zakharyan A, et al. Risk of rehospitalization for patients using clopidogrel with a proton pump inhibitor. Arch Intern Med. 2010;170(8):704-10. [pmid: 20421557].
30 Tentzeris I, Jarai R, Farhan S, et al. Impact of concomitant treatment with proton pump inhibitors and clopidogrel on clinical outcome in patients after coronary stent implantation. Thromb Haemost. 2010;104(6):1211-8. [pmid: 20941464].
31 Tsai YW, Wen YW, Huang WF, et al. Cardiovascular and gastrointestinal events of three antiplatelet therapies: clopidogrel, clopidogrel plus proton-pump inhibitors, and aspirin plus proton-pump inhibitors in patients with previous gastrointestinal bleeding. J Gastroenterol. 2011;46(1):39-45. [pmid: 20811753].
32 Valkhoff VE, t Jong GW, Van Soest EM, et al. Risk of recurrent myocardial infarction with the concomitant use of clopidogrel and proton pump inhibitors. Aliment Pharmacol Ther. 2011;33(1):77-88. [pmid: 21083580].
33 van Boxel OS, van Oijen MG, Hagenaars MP, et al. Cardiovascular and gastrointestinal outcomes in clopidogrel users on proton pump inhibitors: results of a large Dutch cohort study. Am J Gastroenterol. 2010;105(11):2430-6. quiz 2437. [pmid: 20736935].
34 Wu CY, Chan FK, Wu MS, et al. Histamine2-receptor antagonists are an alternative to proton pump inhibitor in patients receiving clopidogrel. Gastroenterology. 2010;139(4):1165-71. [pmid: 20600012].
35 Zairis MN, Tsiaousis GZ, Patsourakos NG, et al. The impact of treatment with omeprazole on the effectiveness of clopidogrel drug therapy during the first year after successful coronary stenting. Can J Cardiol. 2010;26(2):e54-7. [pmid: 20151060].