# Sensitivity Analyses

## Key Question 2 Initial Conservative Approach for UA/NSTEMI

In an effort to explain between-study variations in the use of a glycoprotein IIb/IIIa inhibitor (GPI) plus unfractionated heparin versus heparin alone, we performed sensitivity analyses on features we suspected might account for the variations and that had suitable distributions among the studies. This appendix contains the forest plots of the sensitivity analyses we performed.

Sensitivity was evaluated by study size (<1000 vs. ≥1000 patients) and by aspirin-only use. Outcomes (up to 30 days) included mortality, nonfatal myocardial infarction (MI), recurrent ischemia, and minor bleeding.

Figure I-1 shows the forest plot of the sensitivity analysis by study size for mortality up to 30 days. The 4 larger studies gave an estimated odds ratio of 0.86 (95% CI, 0.74 to 1.00), favoring GPI plus heparin. The 4 smaller studies gave an estimated odds ratio of 0.36 (95% CI, 0.17 to 0.76), also favoring GPI plus heparin.

Figure I-1 Meta-analysis of glycoprotein inhibitors vs. unfractionated heparin on mortality up to 30 days by study size

Abbreviations: CI=confidence interval; GPI=glycoprotein inhibitor

This figure shows a forest plot of the sensitivity analysis by study size for mortality up to 30 days. The 4 larger studies gave an estimated odds ratio of 0.86 (95% CI, 0.74 to 1.00), favoring glycoprotein inhibitors plus heparin. The 4 smaller studies gave an estimated odds ratio of 0.36 (95% CI, 0.17 to 0.76), also favoring glycoprotein inhibitors plus heparin.

Figure I-2 shows the forest plot of the sensitivity analysis by aspirin-only use for mortality up to 30 days. The 6 aspirin-only studies gave an estimated odds ratio of 0.85 (95% CI, 0.73 to 0.99), favoring GPI plus heparin. The other 2 studies gave an estimated odds ratio of 0.37 (95% CI, 0.16 to 0.83), also favoring GPI plus heparin.

Figure I-2 Meta-analysis of glycoprotein inhibitors vs. unfractionated heparin on mortality up to 30 days by aspirin-only use

Abbreviations: CI=confidence interval; GPI=glycoprotein inhibitor

This figure shows the forest plot of the sensitivity analysis by aspirin-only use for mortality up to 30 days. The 6 aspirin-only studies gave an estimated odds ratio of 0.85 (95% CI, 0.73 to 0.99), favoring glycoprotein inhibitors plus heparin. The other 2 studies gave an estimated odds ratio of 0.37 (95% CI, 0.16 to 0.83), also favoring glycoprotein inhibitors plus heparin.

Figure I-3 shows the forest plot of the sensitivity analysis by study size for nonfatal MI up to 30 days. The summary estimate was significant from pooling the 5 smaller studies (OR 0.26; 95% CI, 0.13 to 0.52; p<0.001), favoring GPI plus heparin; it was nonsignificant from pooling the 4 larger studies (OR 0.94; 95% CI, 0.81 to 1.08; p=0.36).

Figure I-3 Meta-analysis of glycoprotein inhibitors vs. unfractionated heparin on nonfatal MI up to 30 days by study size

Abbreviations: CI=confidence interval; GPI=glycoprotein inhibitor

This figure shows the forest plot of the sensitivity analysis by study size for nonfatal myocardial infarction up to 30 days. The summary estimate was significant from pooling the 5 smaller studies (OR 0.26; 95% CI, 0.13 to 0.52; p<0.001), favoring glycoprotein inhibitors plus heparin; it was nonsignificant from pooling the 4 larger studies (OR 0.94; 95% CI, 0.81 to 1.08; p=0.36).

Figure I-4 shows the forest plot of the sensitivity analysis by aspirin-only use for nonfatal myocardial infarction up to 30 days. The 7 aspirin-only studies gave an estimated odds ratio of 0.89 (95% CI 0.74 to 1.08), favoring GPI plus heparin. The other 2 studies gave an estimated odds ratio of 0.20 (95% CI 0.05 to 0.89), also favoring GPI plus heparin.

Figure I-4 Meta-analysis of glycoprotein inhibitors vs. unfractionated heparin on nonfatal myocardial infarction up to 30 days by aspirin-only use

Abbreviations: CI=confidence interval; GPI=glycoprotein inhibitor

This figure shows the forest plot of the sensitivity analysis by aspirin-only use for nonfatal myocardial infarction up to 30 days. The 7 aspirin-only studies gave an estimated odds ratio of 0.89 (95% CI 0.74 to 1.08), favoring glycoprotein inhibitors plus heparin. The other 2 studies gave an estimated odds ratio of 0.20 (95% CI 0.05 to 0.89), also favoring glycoprotein inhibitors plus heparin.

Figure I-5 shows the forest plot of the sensitivity analysis by study size for recurrent ischemia up to 30 days. The 2 larger studies gave an estimated odds ratio of 1.11 (95% CI, 0.84 to 1.47), favoring heparin alone. The 4 smaller studies gave an estimated odds ratio of 0.51 (95% CI, 0.26 to 1.02), favoring GPI plus heparin.

Figure I-5 Meta-analysis of glycoprotein inhibitors vs. unfractionated heparin on recurrent ischemia up to 30 days by study size

Abbreviations: CI=confidence interval; GPI=glycoprotein inhibitor

This figure shows the forest plot of the sensitivity analysis by study size for recurrent ischemia up to 30 days. The 2 larger studies gave an estimated odds ratio of 1.11 (95% CI, 0.84 to 1.47), favoring heparin alone. The 4 smaller studies gave an estimated odds ratio of 0.51 (95% CI, 0.26 to 1.02), favoring glycoprotein inhibitors plus heparin.

Figure I-6 shows the forest plot of the sensitivity analysis by study size for minor bleeding up to 30 days. The 3 larger studies gave an estimated odds ratio of 1.61 (95% CI, 1.20 to 2.15), favoring heparin alone. The 2 smaller studies gave an estimated odds ratio of 3.33 (95% CI, 0.23 to 48.23), also favoring heparin alone.

Figure I-6 Meta-analysis of glycoprotein inhibitors vs. unfractionated heparin on minor bleeding up to 30 days by study size

Abbreviations: CI=confidence interval; GPI=glycoprotein inhibitor

This figure shows the forest plot of the sensitivity analysis by study size for minor bleeding up to 30 days. The 3 larger studies gave an estimated odds ratio of 1.61 (95% CI, 1.20 to 2.15), favoring heparin alone. The 2 smaller studies gave an estimated odds ratio of 3.33 (95% CI, 0.23 to 48.23), also favoring heparin alone.