# List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reason shown in italics. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Aalbers J. Prasugrel study addresses timing of thienopyridine loading dose in NSTEMI patients pre-PCI (the ACCOAST study). Cardiovasc J Afr. 2011;22(3):168. Exclude - not a Clinical Study. [pmid: 21713311].
Abdallah M, Karrowni W, Shamseddeen W, et al. Acute coronary syndromes: clinical characteristics, management, and outcomes at the American University of Beirut Medical Center, 2002-2005. Clin Cardiol. 2010;33(1):E6-E13. Exclude - no active comparator. [pmid: 20014175].
Abdel-Latif A, Moliterno DJ. Prasugrel versus clopidogrel in primary PCI: Considerations of the TRITON-TIMI 38 substudy. Curr Cardiol Rep. 2009;11(5):323-324. Exclude - not a Clinical Study. [pmid: 19709491].
Abu-Assi E, Raposeiras Roubin S, Agra-Bermejo RM, et al. Utility and reliability of the REACH risk score in evaluating the risk of post-discharge bleeding in a contemporary cohort of patients with ACS patients. Eur Heart J. 2011;32:735. Exclude - no outcomes of interest.
Acharji S, Baber U, Mehran R, et al. Prognostic significance of elevated baseline troponin in patients with acute coronary syndromes and chronic kidney disease treated with different antithrombotic regimens: a substudy from the ACUITY trial. Circ Cardiovasc Interv. 2012;5(2):157-65. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22354934].
Acikel S, Yildirir A, Aydinalp A, et al. The clinical importance of laboratory-defined aspirin resistance in patients presenting with non-ST elevation acute coronary syndromes. Blood Coagul Fibrinolysis. 2009;20(6):427-32. Exclude - no active comparator. [pmid: 19542882].
Agahtehrani A, Dangas GD. Bolus-only glycoprotein IIb/IIIa inhibitor revisited. J Invasive Cardiol. 2006;18(11):527. Exclude - not a Clinical Study. [pmid: 17090814].
Agema WR, Monraats PS, Zwinderman AH, et al. Current PTCA practice and clinical outcomes in The Netherlands: the real world in the pre-drug-eluting stent era. Eur Heart J. 2004;25(13):1163-70. Exclude - no active comparator. [pmid: 15231375].
Aguiar AA, Mourilhe-Rocha R, Esporcatte R, et al. Long-term analysis in acute coronary syndrome: are there any differences in morbidity and mortality?. Arq Bras Cardiol. 2010;95(6):705-12. Exclude - no active comparator. [pmid: 21152701].
Ahmad WA, Ramesh SV, Zambahari R. Malaysia-ACute CORonary syndromes Descriptive study (ACCORD): evaluation of compliance with existing guidelines in patients with acute coronary syndrome. Singapore Med J. 2011;52(7):508-11. Exclude - no active comparator. [pmid: 21808962].
Ahmad WAW, Ali RM, Zambahari R, et al. Highlights of the first Malaysian National Cardiovascular Disease Database (NCVD): Percutaneous Coronary Intervention (PCI) registry. CVD Prev Contr. 2011;6(2):57-61. Exclude - no active comparator.
Aihara H, Sato A, Takeyasu N, et al. Effect of individual proton pump inhibitors on cardiovascular events in patients treated with clopidogrel following coronary stenting:: Results From the Ibaraki Cardiac Assessment Study Registry. Catheter Cardiovasc Interv. 2012. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22234956].
Aiqing Z, Dongming X, Yihong Y. Clinical study of intracoronary injection of tirofiban during primary pci in treatment of acute coronary syndrome. Heart. 2011;97:A133-A134. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Ait Mokhtar O, Bonello L, Armero S, et al. Early and late outcomes of clopidogrel and coumadin combination for patients on oral anticoagulants undergoing coronary stenting. Cardiovasc Revasc Med. 2010;11(3):159-62. Exclude - no outcomes of interest. [pmid: 20599166].
Akhter N, Milford-Beland S, Roe MT, et al. Gender differences among patients with acute coronary syndromes undergoing percutaneous coronary intervention in the American College of Cardiology-National Cardiovascular Data Registry (ACC-NCDR). Am Heart J. 2009;157(1):141-8. Exclude - no outcomes of interest. [pmid: 19081410].
Akkerhuis KM, Deckers JW, Boersma E, et al. Geographic variability in outcomes within an international trial of glycoprotein IIb/IIIa inhibition in patients with acute coronary syndromes. Results from PURSUIT. Eur Heart J. 2000;21(5):371-81. Exclude - no outcomes of interest. [pmid: 10666351].
Akkerhuis KM, Maas AC, Klootwijk PA, et al. Recurrent ischemia during continuous 12-lead ECG-ischemia monitoring in patients with acute coronary syndromes treated with eptifibatide: relation with death and myocardial infarction. PURSUIT ECG-Ischemia Monitoring Substudy Investigators. Platelet glycoprotein IIb/IIIa in Unstable angina: Receptor Suppression Using Integrilin Therapy. J Electrocardiol. 2000;33(2):127-36. Exclude - no outcomes of interest. [pmid: 10819406].
Akkerhuis KM, Neuhaus KL, Wilcox RG, et al. Safety and preliminary efficacy of one month glycoprotein IIb/IIIa inhibition with lefradafiban in patients with acute coronary syndromes without ST-elevation; a phase II study. Eur Heart J. 2000;21(24):2042-55. Exclude -no outcomes of interest. [pmid: 11102255].
Akowuah E, Shrivastava V, Jamnadas B, et al. Comparison of two strategies for the management of antiplatelet therapy during urgent surgery. Ann Thorac Surg. 2005;80(1):149-52. Exclude - no active comparator. [pmid: 15975358].
Al Suwaidi J, Reddan DN, Williams K, et al. Prognostic implications of abnormalities in renal function in patients with acute coronary syndromes. Circulation. 2002;106(8):974-80. Exclude - not a Clinical Study. [pmid: 12186803].
Alexander JH, Becker RC, Bhatt DL, et al. Apixaban, an oral, direct, selective factor Xa inhibitor, in combination with antiplatelet therapy after acute coronary syndrome: results of the Apixaban for Prevention of Acute Ischemic and Safety Events (APPRAISE) trial. Circulation. 2009;119(22):2877-85. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19470889].
Alexander JH, Harrington RA, Tuttle RH, et al. Prior aspirin use predicts worse outcomes in patients with non-ST-elevation acute coronary syndromes. PURSUIT Investigators. Platelet IIb/IIIa in Unstable angina: Receptor Suppression Using Integrilin Therapy. Am J Cardiol. 1999;83(8):1147-51. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10215274].
Alexander JH, Lopes RD, James S, et al. Apixaban with antiplatelet therapy after acute coronary syndrome. N Engl J Med. 2011;365(8):699-708. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21780946].
Alexander JH, Yang H, Becker RC, et al. First experience with direct, selective factor Xa inhibition in patients with non-ST-elevation acute coronary syndromes: results of the XaNADU-ACS Trial. J Thromb Haemost. 2005;3(3):439-47. Exclude - no active comparator. [pmid: 15748230].
Alexander KP, Chen AY, Newby LK, et al. Sex differences in major bleeding with glycoprotein IIb/IIIa inhibitors: results from the CRUSADE (Can Rapid risk stratification of Unstable angina patients Suppress ADverse outcomes with Early implementation of the ACC/AHA guidelines) initiative. Circulation. 2006;114(13):1380-7. Exclude - no outcomes of interest. [pmid: 16982940].
Alexopoulos D, Galati A, Xanthopoulou I, et al. Ticagrelor versus prasugrel in acute coronary syndrome patients with high on-clopidogrel platelet reactivity following percutaneous coronary intervention: a pharmacodynamic study. J Am Coll Cardiol. 2012;60(3):193-9. Exclude - no outcomes of interest. [pmid: 22789884].
Alhabib KF, Hersi A, Alsheikh-Ali AA, et al. Prevalence, Predictors, and Outcomes of Conservative Medical Management in Non-ST-Segment Elevation Acute Coronary Syndromes in Gulf RACE-2. Angiology. 2011. Exclude - no active comparator. [pmid: 21561993].
Ali A, Hashem M, Rosman HS, et al. Glycoprotein IIb/IIIa receptor antagonists and risk of bleeding: a single-center experience in 1020 patients. J Clin Pharmacol. 2004;44(11):1328-32. Exclude - no active comparator. [pmid: 15496651].
Ali A, Rehan A, Ganji J, et al. Eptifibatide and risk of bleeding after failed thrombolysis. J Invasive Cardiol. 2004;16(1):20-2. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14699218].
Alidoosti M, Salarifar M, Kassaian SE, et al. In-hospital and late clinical outcomes of direct stenting strategy versus stenting after predilatation for the treatment of coronary artery lesions. Indian Heart J. 2008;60(4):318-24. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19242009].
Aliprandi-Costa B, Ranasinghe I, Chow V, et al. Management and outcomes of patients with acute coronary syndromes in Australia and New Zealand, 2000-2007. Med J Aust. 2011;195(3):116-21. Exclude - no active comparator. [pmid: 21806528].
Allen JK, Scott LB, Stewart KJ, et al. Disparities in women's referral to and enrollment in outpatient cardiac rehabilitation. J Gen Intern Med. 2004;19(7):747-53. Exclude - no active comparator. [pmid: 15209588].
Al-Mallah M, Bazari RN, Jankowski M, et al. Predictors and outcomes associated with gastrointestinal bleeding in patients with acute coronary syndromes. J Thromb Thrombolysis. 2007;23(1):51-5. Exclude - no outcomes of interest. [pmid: 17186397].
Almeda FQ, Hendel RC, Nathan S, et al. Improved in-hospital outcomes in acute coronary syndromes (unstable angina/non-ST segment elevation myocardial infarction) despite similar TIMI risk scores. J Invasive Cardiol. 2003;15(9):502-6. Exclude - no active comparator. [pmid: 12947210].
Alter DA, Khaykin Y, Austin PC, et al. Processes and outcomes of care for diabetic acute myocardial infarction patients in Ontario: do physicians undertreat?. Diabetes Care. 2003;26(5):1427-34. Exclude - no active comparator. [pmid: 12716800].
Amad H, Yan AT, Yan RT, et al. The Association Between Prior Use of Aspirin and/or Warfarin and the In-Hospital Management and Outcomes in Patients Presenting with Acute Coronary Syndromes: Insights from the Global Registry of Acute Coronary Events (GRACE). Can J Cardiol. 2011. Exclude - no active comparator. [pmid: 22112683].
Amane HS, Burte NP. A comparative study of dalteparin and unfractionated heparin in patients with unstable angina pectoris. Indian J Pharmacol. 2011;43(6):703-6. Exclude - no active comparator. [pmid: 22144778].
Amin AP, Kennedy KF, Pencina M, et al. Effect of clopidogrel pretreatment on ischemic complications of percutaneous coronary intervention among bivalirudin-treated patients (from the EVENT registry). Am J Cardiol. 2011;107(12):1751-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21640216].
Ammer M, Paget MA, Hronkova M, et al. Practice patterns and quality of life in acute coronary syndrome patients in 2008-2009: Baseline results for austria from the antiplatelet treatment observational registry ii (Aptor II). Value Health. 2010;13(7):A365. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Amsterdam EA, Peterson ED, Ou FS, et al. Comparative trends in guidelines adherence among patients with non-ST-segment elevation acute coronary syndromes treated with invasive versus conservative management strategies: Results from the CRUSADE quality improvement initiative. Am Heart J. 2009;158(5):748-754 e1. Exclude - no active comparator. [pmid: 19853692].
Anand SS. The Organization to Assess Strategies for Ischemic Syndromes (OASIS) Pilot Study: evaluation of acute and long-term therapies for patients with acute coronary syndromes without ST elevation. Am J Cardiol. 1999;84(5A):13M-19M. Exclude - no active comparator. [pmid: 10505538].
Anand SS, Xie CC, Mehta S, et al. Differences in the management and prognosis of women and men who suffer from acute coronary syndromes. J Am Coll Cardiol. 2005;46(10):1845-51. Exclude - no active comparator. [pmid: 16286169].
Anand SS, Yusuf S, Pogue J, et al. Relationship of activated partial thromboplastin time to coronary events and bleeding in patients with acute coronary syndromes who receive heparin. Circulation. 2003;107(23):2884-8. Exclude -no active comparator. [pmid: 12796128].
Anand SS, Yusuf S, Pogue J, et al. Long-term oral anticoagulant therapy in patients with unstable angina or suspected non-Q-wave myocardial infarction: organization to assess strategies for ischemic syndromes (OASIS) pilot study results. Circulation. 1998;98(11):1064-70. Exclude - no active comparator. [pmid: 9736592].
Anderson KM, Califf RM, Stone GW, et al. Long-term mortality benefit with abciximab in patients undergoing percutaneous coronary intervention. J Am Coll Cardiol. 2001;37(8):2059-65. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11419888].
Anonymous. Use of a monoclonal antibody directed against the platelet glycoprotein IIb/IIIa receptor in high-risk coronary angioplasty. The EPIC Investigation. N Engl J Med. 1994;330(14):956-61. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8121459].
Anonymous. A comparison of recombinant hirudin with heparin for the treatment of acute coronary syndromes. The Global Use of Strategies to Open Occluded Coronary Arteries (GUSTO) IIb investigators. N Engl J Med. 1996;335(11):775-82. Exclude - no active comparator. [pmid: 8778585].
Anonymous. Low-molecular-weight heparin during instability in coronary artery disease, Fragmin during Instability in Coronary Artery Disease (FRISC) study group. Lancet. 1996;347(9001):561-8. Exclude - no active comparator. [pmid: 8596317].
Anonymous. A randomised, blinded, trial of clopidogrel versus aspirin in patients at risk of ischaemic events (CAPRIE). CAPRIE Steering Committee. Lancet. 1996;348(9038):1329-39. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8918275].
Anonymous. Comparison of the effects of two doses of recombinant hirudin compared with heparin in patients with acute myocardial ischemia without ST elevation: a pilot study. Organization to Assess Strategies for Ischemic Syndromes (OASIS) Investigators. Circulation. 1997;96(3):769-77. Exclude - no active comparator. [pmid: 9264481].
Anonymous. Dose-ranging trial of enoxaparin for unstable angina: results of TIMI 11A. The Thrombolysis in Myocardial Infarction (TIMI) 11A Trial Investigators. J Am Coll Cardiol. 1997;29(7):1474-82. Exclude - no active comparator. [pmid: 9180107].
Anonymous. Effects of platelet glycoprotein IIb/IIIa blockade with tirofiban on adverse cardiac events in patients with unstable angina or acute myocardial infarction undergoing coronary angioplasty. The RESTORE Investigators. Randomized Efficacy Study of Tirofiban for Outcomes and REstenosis. Circulation. 1997;96(5):1445-53. Exclude - no outcomes of interest. [pmid: 9315530].
Anonymous. Platelet glycoprotein IIb/IIIa receptor blockade and low-dose heparin during percutaneous coronary revascularization. The EPILOG Investigators. N Engl J Med. 1997;336(24):1689-96. Exclude - no outcomes of interest. [pmid: 9182212].
Anonymous. Randomised double-blind trial of fixed low-dose warfarin with aspirin after myocardial infarction. Coumadin Aspirin Reinfarction Study (CARS) Investigators. Lancet. 1997;350(9075):389-96. Exclude - no active comparator. [pmid: 9259652].
Anonymous. Randomised placebo-controlled trial of abciximab before and during coronary intervention in refractory unstable angina: the CAPTURE Study. Lancet. 1997;349(9063):1429-35. Exclude - no outcomes of interest. [pmid: 9164316].
Anonymous. Randomised placebo-controlled trial of effect of eptifibatide on complications of percutaneous coronary intervention: IMPACT-II. Integrilin to Minimise Platelet Aggregation and Coronary Thrombosis-II. Lancet. 1997;349(9063):1422-8. Exclude -no outcomes of interest. [pmid: 9164315].
Anonymous. Thrombosis prevention trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. The Medical Research Council's General Practice Research Framework. Lancet. 1998;351(9098):233-41. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9457092].
Anonymous. Comparison of two treatment durations (6 days and 14 days) of a low molecular weight heparin with a 6-day treatment of unfractionated heparin in the initial management of unstable angina or non-Q wave myocardial infarction: FRAX.I.S. (FRAxiparine in Ischaemic Syndrome). Eur Heart J. 1999;20(21):1553-62. Exclude -no active comparator. [pmid: 10529323].
Anonymous. Effects of recombinant hirudin (lepirudin) compared with heparin on death, myocardial infarction, refractory angina, and revascularisation procedures in patients with acute myocardial ischaemia without ST elevation: a randomised trial. Organisation to Assess Strategies for Ischemic Syndromes (OASIS-2) Investigators. Lancet. 1999;353(9151):429-38. Exclude - no active comparator. [pmid: 9989712].
Anonymous. Invasive compared with non-invasive treatment in unstable coronary-artery disease: FRISC II prospective randomised multicentre study. FRagmin and Fast Revascularisation during InStability in Coronary artery disease Investigators. Lancet. 1999;354(9180):708-15. Exclude - no active comparator. [pmid: 10475181].
Anonymous. Long-term low-molecular-mass heparin in unstable coronary-artery disease: FRISC II prospective randomised multicentre study. FRagmin and Fast Revascularisation during InStability in Coronary artery disease Investigators. Lancet. 1999;354(9180):701-7. Exclude -no active comparator. [pmid: 10475180].
Anonymous. Rationale, design and organization of the Second Chinese Cardiac Study (CCS-2): a randomized trial of clopidogrel plus aspirin, and of metoprolol, among patients with suspected acute myocardial infarction. Second Chinese Cardiac Study (CCS-2) Collaborative Group. J Cardiovasc Risk. 2000;7(6):435-41. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11189013].
Anonymous. Effects of long-term, moderate-intensity oral anticoagulation in addition to aspirin in unstable angina. The Organization to Assess Strategies for Ischemic Syndromes (OASIS) Investigators. J Am Coll Cardiol. 2001;37(2):475-84. Exclude - no active comparator. [pmid: 11216966].
Anonymous. Randomized, placebo-controlled trial of titrated intravenous lamifiban for acute coronary syndromes. Circulation. 2002;105(3):316-21. Exclude - no active comparator. [pmid: 11804986].
Anonymous. Treatment modalities of non-ST-elevation acute coronary syndromes in the real world. Results of the prospective R.OS.A.I.-2 registry. Ital Heart J. 2003;4(11):782-90. Exclude - no active comparator. [pmid: 14699708].
Anonymous. Comparative efficacy of once daily parnaparin and unfractionated heparin in unstable angina pectoris: PRIME CARE study. Indian Heart J. 2005;57(6):648-54. Exclude - no active comparator. [pmid: 16521631].
Anonymous. Plavix reduces death risk following a heart attack. Health News. 2005;11(6):4. Exclude - not a Clinical Study. [pmid: 16127791].
Anonymous. Clinical trial update II: TRITON-TIMI 38 provides reassurance on concomitant use of proton pump inhibitors and thienopyridines. Eur Heart J. 2009;30(23):2820. Exclude - not a Clinical Study. [pmid: 19972642].
Anonymous. Prasugrel (Effient) vs. clopidogrel (Plavix). Med Lett Drugs Ther. 2009;51(1320):69-70. Exclude - not a Clinical Study. [pmid: 19738549].
Anonymous. Prasugrel after angioplasty and stenting: Continue to use aspirin + clopidogrel. Prescrire Int. 2009;18(103):193-195. Exclude - not a Clinical Study. [pmid: 19877380].
Anonymous. The Thrombin Receptor Antagonist for Clinical Event Reduction in Acute Coronary Syndrome (TRA*CER) trial: study design and rationale. Am Heart J. 2009;158(3):327-334 e4. Exclude - no active comparator. [pmid: 19699853].
Anonymous. Effect of PPIs on aspirin-treated patients with myocardial infarction. Aust J Pharm. 2011;92(1098):91. Exclude - not a Clinical Study.
Anonymous. Management of acute coronary syndromes in developing countries: ACute Coronary Events-a multinational Survey of current management Strategies. Am Heart J. 2011;162(5):852-859 e22. Exclude - no active comparator. [pmid: 22093201].
Antoniucci D. Glycoprotein IIb/IIIa inhibitors in acute myocardial infarction. Cardiol Int. 2006;7(3):104-110. Exclude - not a Clinical Study.
Antoniucci D, Migliorini A, Parodi G, et al. Abciximab-supported infarct artery stent implantation for acute myocardial infarction and long-term survival: a prospective, multicenter, randomized trial comparing infarct artery stenting plus abciximab with stenting alone. Circulation. 2004;109(14):1704-6. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15066943].
Antoniucci D, Rodriguez A, Hempel A, et al. A randomized trial comparing primary infarct artery stenting with or without abciximab in acute myocardial infarction. J Am Coll Cardiol. 2003;42(11):1879-85. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14662245].
Antoniucci D, Valenti R, Migliorini A, et al. Abciximab may reduce mortality for unselected patients with acute myocardial infarction receiving a stent. Evid-based Cardiovasc Med. 2003;7(1):15-16. Exclude - not a Clinical Study.
Applegate RJ, Grabarczyk MA, Sane DC, et al. PCI with and without abciximab after upstream eptifibatide use: outcomes in high-risk patients. J Invasive Cardiol. 2006;18(12):604-13. Exclude - no outcomes of interest. [pmid: 17197712].
Aronow WS, Ahn C. Reduction of coronary events with aspirin in older patients with prior myocardial infarction treated with and without statins. Heart Dis. 2002;4(3):159-61. Exclude - no active comparator. [pmid: 12028600].
Assiri AS. The underutilization of adjunctive pharmacotherapy in treating acute coronary syndrome patients admitted to a tertiary care hospital in southwest region, saudi arabia. Heart Views. 2010;11(3):99-102. Exclude - no active comparator. [pmid: 21577376].
Atar S, Cannon CP, Murphy SA, et al. Statins are associated with lower risk of gastrointestinal bleeding in patients with unstable coronary syndromes: analysis of the Orbofiban in Patients with Unstable coronary Syndromes-Thrombolysis In Myocardial Infarction 16 (OPUS-TIMI 16) trial. Am Heart J. 2006;151(5):976 e1-6. Exclude -no active comparator. [pmid: 16644315].
Aune E, Endresen K, Fox KA, et al. Effect of implementing routine early invasive strategy on one-year mortality in patients with acute myocardial infarction. Am J Cardiol. 2010;105(1):36-42. Exclude - no active comparator. [pmid: 20102887].
Avezum A, Makdisse M, Spencer F, et al. Impact of age on management and outcome of acute coronary syndrome: observations from the Global Registry of Acute Coronary Events (GRACE). Am Heart J. 2005;149(1):67-73. Exclude - no active comparator. [pmid: 15660036].
Awad HH, Zubaid M, Alsheikh-Ali AA, et al. Comparison of characteristics, management practices, and outcomes of patients between the global registry and the gulf registry of acute coronary events. Am J Cardiol. 2011;108(9):1252-8. Exclude - no active comparator. [pmid: 21880292].
Azar RR, McKay RG, Thompson PD, et al. Abciximab in primary coronary angioplasty for acute myocardial infarction improves short- and medium-term outcomes. J Am Coll Cardiol. 1998;32(7):1996-2002. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9857884].
Azzam ZS, Sa'ad E, Jabareen A, et al. Tolerability and feasibility of eptifibatide in acute coronary syndrome in patients at high risk for cardiovascular disease: A retrospective analysis. Curr Ther Res Clin Exp. 2005;66(6):501-510. Exclude - no outcomes of interest.
Baber U, Akhter M, Kothari S, et al. Efficacy of modified dual antiplatelet therapy combined with warfarin following percutaneous coronary intervention with drug-eluting stents. J Invasive Cardiol. 2010;22(2):80-3. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 20124594].
Bach RG, Cannon CP, Weintraub WS, et al. The effect of routine, early invasive management on outcome for elderly patients with non-ST-segment elevation acute coronary syndromes. Ann Intern Med. 2004;141(3):186-95. Exclude - no active comparator. [pmid: 15289215].
Bach RG, Cannon CP, Weintraub WS, et al. Differential effects by age of an early invasive strategy for non-ST-segment elevation acute coronary syndromes. J Clin Outcomes Manage. 2004;11(9):556-557. Exclude - not a Clinical Study.
Badar A, Richardson J, Scaife J, et al. Estimation of thromboembolic and bleeding risk in patients with atrial fibrillation undergoing percutaneous coronary intervention for acute coronary syndrome. EuroIntervention. 2010;6. Exclude - not original peer-reviewed data.
Badar A, Scaife J, Richardson J, et al. Influence of age on likelihood of provision of gastro-intestinal prophylactic medication in non-elective percutaneous coronary intervention patients with high bleeding risk. EuroIntervention. 2010;6. Exclude - not original peer-reviewed data.
Bagur R, Bertrand OF, Rodes-Cabau J, et al. Comparison of outcomes in patients > or =70 years versus <70 years after transradial coronary stenting with maximal antiplatelet therapy for acute coronary syndrome. Am J Cardiol. 2009;104(5):624-9. Exclude - no active comparator. [pmid: 19699334].
Bahit MC, Topol EJ, Califf RM, et al. Reactivation of ischemic events in acute coronary syndromes: results from GUSTO-IIb. Gobal Use of Strategies To Open occluded arteries in acute coronary syndromes. J Am Coll Cardiol. 2001;37(4):1001-7. Exclude - no active comparator. [pmid: 11263599].
Bahrmann P, Rach J, Desch S, et al. Incidence and distribution of occluded culprit arteries and impact of coronary collaterals on outcome in patients with non-ST-segment elevation myocardial infarction and early invasive treatment strategy. Clin Res Cardiol. 2011;100(5):457-67. Exclude - no active comparator. [pmid: 21165625].
Baim DS, Wahr D, George B, et al. Randomized trial of a distal embolic protection device during percutaneous intervention of saphenous vein aorto-coronary bypass grafts. Circulation. 2002;105(11):1285-90. Exclude -no active comparator. [pmid: 11901037].
Bakhai A, Collinson J, Flather MD, et al. Diabetic patients with acute coronary syndromes in the UK: high risk and under treated. Results from the prospective registry of acute ischaemic syndromes in the UK (PRAIS-UK). Int J Cardiol. 2005;100(1):79-84. Exclude - no active comparator. [pmid: 15820289].
Bakhai A, Ferrieres J, Iniguez A, et al. Clinical Outcomes, Resource Use, and Costs at 1 Year in Patients with Acute Coronary Syndrome Undergoing PCI:: Results from the Multinational APTOR Registry. BAKHAI, ET AL. CLINICAL OUTCOMES IN ACS PATIENTS UNDERGOING PCI. J Intervent Cardiol. 2011. Exclude - no active comparator.
Banerjee S, Varghese C, Samuel J, et al. Comparison of the impact of short (<1 year) and long-term (> or =1 year) clopidogrel use following percutaneous coronary intervention on mortality. Am J Cardiol. 2008;102(9):1159-62. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18940284].
Bangalore S, Cohen DJ, Kleiman NS, et al. Bleeding risk comparing targeted low-dose heparin with bivalirudin in patients undergoing percutaneous coronary intervention: results from a propensity score-matched analysis of the Evaluation of Drug-Eluting Stents and Ischemic Events (EVENT) registry. Circ Cardiovasc Interv. 2011;4(5):463-73. Exclude - no outcomes of interest. [pmid: 21972401].
Banihashemi B, Goodman SG, Yan RT, et al. Underutilization of clopidogrel and glycoprotein IIb/IIIa inhibitors in non-ST-elevation acute coronary syndrome patients: the Canadian global registry of acute coronary events (GRACE) experience. Am Heart J. 2009;158(6):917-24. Exclude - no active comparator. [pmid: 19958857].
Bansal D, Gaddam V, Aude YW, et al. Trends in the care of patients with acute myocardial infarction at a university-affiliated Veterans Affairs Medical Center. J Cardiovasc Pharmacol Ther. 2005;10(1):39-44. Exclude - no active comparator. [pmid: 15821837].
Bar Dayan Y, Amital H, Levy Y, et al. Low dose aspirin in patients with ischemic heart disease may precipitate secondary myocardial infarction. Isr J Med Sci. 1996;32(5):288-91. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8641865].
Barnato AE, Lucas FL, Staiger D, et al. Hospital-level racial disparities in acute myocardial infarction treatment and outcomes. Med Care. 2005;43(4):308-19. Exclude - no active comparator. [pmid: 15778634].
Bartholomew BA, Sheps DS, Monroe S, et al. A population-based evaluation of the thrombolysis in myocardial infarction risk score for unstable angina and non-ST elevation myocardial infarction. Clin Cardiol. 2004;27(2):74-8. Exclude - no active comparator. [pmid: 14979624].
Bartorelli AL, Trabattoni D, Montorsi P, et al. Aspirin alone antiplatelet regimen after intracoronary placement of the Carbostent: the ANTARES study. Catheter Cardiovasc Interv. 2002;55(2):150-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11835638].
Bassand JP, Berthe C, Bethencourt A, et al. Tolerability of percutaneous coronary interventions in patients receiving nadroparin calcium for unstable angina or non-Q-wave myocardial infarction: the Angiofrax study. Curr Med Res Opin. 2003;19(2):107-13. Exclude - no active comparator. [pmid: 12740154].
Batchelor WB, Mahaffey KW, Berger PB, et al. A randomized, placebo-controlled trial of enoxaparin after high-risk coronary stenting: the ATLAST trial. J Am Coll Cardiol. 2001;38(6):1608-13. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11704394].
Batchelor WB, Tolleson TR, Huang Y, et al. Randomized COMparison of platelet inhibition with abciximab, tiRofiban and eptifibatide during percutaneous coronary intervention in acute coronary syndromes: the COMPARE trial. Comparison Of Measurements of Platelet aggregation with Aggrastat, Reopro, and Eptifibatide. Circulation. 2002;106(12):1470-6. Exclude -no outcomes of interest. [pmid: 12234950].
Bauer T, Gitt AK, Junger C, et al. Guideline-recommended secondary prevention drug therapy after acute myocardial infarction: predictors and outcomes of nonadherence. Eur J Cardiovasc Prev Rehabil. 2010;17(5):576-81. Exclude - no active comparator. [pmid: 20351550].
Bauer T, Mollmann H, Weidinger F, et al. Predictors of hospital mortality in the elderly undergoing percutaneous coronary intervention for acute coronary syndromes and stable angina. Int J Cardiol. 2011;151(2):164-9. Exclude - no active comparator. [pmid: 20605241].
Bayturan O, Bilge AR, Sekuri C, et al. The effect of tirofiban on ST segment resolution in patients with non-ST elevated myocardial infarction. Jpn Heart J. 2004;45(6):913-20. Exclude - no outcomes of interest. [pmid: 15655266].
Becker RC, Cannon CP, Tracy RP, et al. Relation between systemic anticoagulation as determined by activated partial thromboplastin time and heparin measurements and in-hospital clinical events in unstable angina and non-Q wave myocardiaL infarction. Thrombolysis in Myocardial Ischemia III B Investigators. Am Heart J. 1996;131(3):421-33. Exclude - no outcomes of interest. [pmid: 8604620].
Becker RC, Spencer FA, Gibson M, et al. Influence of patient characteristics and renal function on factor Xa inhibition pharmacokinetics and pharmacodynamics after enoxaparin administration in non-ST-segment elevation acute coronary syndromes. Am Heart J. 2002;143(5):753-9. Exclude - no active comparator. [pmid: 12040334].
Bednarz B, Chamiec T, Maciejewski P, et al. Treatment of acute myocardial infarction and unstable angina in a typical intensive coronary care unit. Kardiol Pol. 2000;53(8):118-123. Exclude - no outcomes of interest.
Behar S, Battler A, Porath A, et al. A prospective national survey of management and clinical outcome of acute myocardial infarction in Israel, 2000. Isr Med Assoc J. 2003;5(4):249-54. Exclude - no active comparator. [pmid: 14509128].
Beinart SC, Kolm P, Veledar E, et al. Long-term cost effectiveness of early and sustained dual oral antiplatelet therapy with clopidogrel given for up to one year after percutaneous coronary intervention results: from the Clopidogrel for the Reduction of Events During Observation (CREDO) trial. J Am Coll Cardiol. 2005;46(5):761-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16139122].
Belanger P, Palisaitis DA, Diodati JG, et al. Effects of high ticlopidine doses on platelet function in acute coronary syndrome patients. J Cardiovasc Pharmacol. 2004;43(1):128-32. Exclude - no outcomes of interest. [pmid: 14668578].
Ben-Ami T, Gilutz H, Porath A, et al. No gender difference in the clinical management and outcome of unstable angina. Isr Med Assoc J. 2005;7(4):228-32. Exclude - no active comparator. [pmid: 15847201].
Ben-Gal Y, Moses JW, Mehran R, et al. Surgical versus percutaneous revascularization for multivessel disease in patients with acute coronary syndromes: analysis from the ACUITY (Acute Catheterization and Urgent Intervention Triage Strategy) trial. JACC Cardiovasc Interv. 2010;3(10):1059-67. Exclude - no active comparator. [pmid: 20965465].
Bennett K, Jennings S, Cavanagh B, et al. Coronary heart attack ireland register (CHAIR): the first four years. Eur J Cardiovasc Prev Rehabil. 2011;18(1):S84. Exclude - no active comparator.
Berger AK, Duval S, Krumholz HM. Aspirin, beta-blocker, and angiotensin-converting enzyme inhibitor therapy in patients with end-stage renal disease and an acute myocardial infarction. J Am Coll Cardiol. 2003;42(2):201-8. Exclude - no active comparator. [pmid: 12875751].
Berger JS, Frye CB, Harshaw Q, et al. Impact of clopidogrel in patients with acute coronary syndromes requiring coronary artery bypass surgery: a multicenter analysis. J Am Coll Cardiol. 2008;52(21):1693-701. Exclude -no outcomes of interest. [pmid: 19007688].
Berger JS, Sanborn TA, Sherman W, et al. Influence of sex on in-hospital outcomes and long-term survival after contemporary percutaneous coronary intervention. Am Heart J. 2006;151(5):1026-31. Exclude - no active comparator. [pmid: 16644329].
Berger PB, Bell MR, Grill DE, et al. Frequency of adverse clinical events in the 12 months following successful intracoronary stent placement in patients treated with aspirin and ticlopidine (without warfarin). Am J Cardiol. 1998;81(6):713-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9527080].
Berger PB, Mahaffey KW, Meier SJ, et al. Safety and efficacy of only 2 weeks of ticlopidine therapy in patients at increased risk of coronary stent thrombosis: results from the Antiplatelet Therapy alone versus Lovenox plus Antiplatelet therapy in patients at increased risk of Stent Thrombosis (ATLAST) trial. Am Heart J. 2002;143(5):841-6. Exclude - no active comparator. [pmid: 12040346].
Berkowitz SD, Stinnett S, Cohen M, et al. Prospective comparison of hemorrhagic complications after treatment with enoxaparin versus unfractionated heparin for unstable angina pectoris or non-ST-segment elevation acute myocardial infarction. Am J Cardiol. 2001;88(11):1230-4. Exclude - no outcomes of interest. [pmid: 11728348].
Bertrand ME, Rupprecht HJ, Urban P, et al. Double-blind study of the safety of clopidogrel with and without a loading dose in combination with aspirin compared with ticlopidine in combination with aspirin after coronary stenting : the clopidogrel aspirin stent international cooperative study (CLASSICS). Circulation. 2000;102(6):624-9. Exclude - no active comparator. [pmid: 10931801].
Best PJ, Berger PB, Davis BR, et al. Impact of mild or moderate chronic kidney disease on the frequency of restenosis: results from the PRESTO trial. J Am Coll Cardiol. 2004;44(9):1786-91. Exclude - no active comparator. [pmid: 15519008].
Bhatt DL, Chew DP, Hirsch AT, et al. Superiority of clopidogrel versus aspirin in patients with prior cardiac surgery. Circulation. 2001;103(3):363-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11157686].
Bhatt DL, Hirsch AT, Ringleb PA, et al. Reduction in the need for hospitalization for recurrent ischemic events and bleeding with clopidogrel instead of aspirin. CAPRIE investigators. Am Heart J. 2000;140(1):67-73. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10874265].
Bhatt DL, Roe MT, Peterson ED, et al. Utilization of early invasive management strategies for high-risk patients with non-ST-segment elevation acute coronary syndromes: results from the CRUSADE Quality Improvement Initiative. JAMA. 2004;292(17):2096-104. Exclude -no active comparator. [pmid: 15523070].
Bhatt DL, Topol EJ. Long-term protection from myocardial ischemic events after coronary angioplasty. Cardiol Rev. 1998;15(7):18-22. Exclude - not a Clinical Study.
Bhatt DL, Topol EJ. Clopidogrel added to aspirin versus aspirin alone in secondary prevention and high-risk primary prevention: rationale and design of the Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management, and Avoidance (CHARISMA) trial. Am Heart J. 2004;148(2):263-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15308995].
Bijsterveld NR, Moons AH, Meijers JC, et al. The impact on coagulation of an intravenous loading dose in addition to a subcutaneous regimen of low-molecular-weight heparin in the initial treatment of acute coronary syndromes. J Am Coll Cardiol. 2003;42(3):424-7. Exclude - no active comparator. [pmid: 12906966].
Bijsterveld NR, Moons AH, Meijers JC, et al. Rebound thrombin generation after heparin therapy in unstable angina. A randomized comparison between unfractionated and low-molecular-weight heparin. J Am Coll Cardiol. 2002;39(5):811-7. Exclude - no outcomes of interest. [pmid: 11869846].
Bijsterveld NR, Peters RJ, Murphy SA, et al. Recurrent cardiac ischemic events early after discontinuation of short-term heparin treatment in acute coronary syndromes: results from the Thrombolysis in Myocardial Infarction (TIMI) 11B and Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q-Wave Coronary Events (ESSENCE) studies. J Am Coll Cardiol. 2003;42(12):2083-9. Exclude - no active comparator. [pmid: 14680731].
Bittl JA, Ahmed WH. Relation between abrupt vessel closure and the anticoagulant response to heparin or bivalirudin during coronary angioplasty. Am J Cardiol. 1998;82(8B):50P-56P. Exclude - no outcomes of interest. [pmid: 9671008].
Bittl JA, Chaitman BR, Feit F, et al. Bivalirudin versus heparin during coronary angioplasty for unstable or postinfarction angina: Final report reanalysis of the Bivalirudin Angioplasty Study. Am Heart J. 2001;142(6):952-9. Exclude - no outcomes of interest. [pmid: 11717596].
Bittl JA, Feit F. A randomized comparison of bivalirudin and heparin in patients undergoing coronary angioplasty for postinfarction angina. Hirulog Angioplasty Study Investigators. Am J Cardiol. 1998;82(8B):43P-49P. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9671007].
Bittl JA, Strony J, Brinker JA, et al. Treatment with bivalirudin (Hirulog) as compared with heparin during coronary angioplasty for unstable or postinfarction angina. Hirulog Angioplasty Study Investigators. N Engl J Med. 1995;333(12):764-9. Exclude - no outcomes of interest. [pmid: 7643883].
Bizzarri F, Scolletta S, Tucci E, et al. Perioperative use of tirofiban hydrochloride (Aggrastat) does not increase surgical bleeding after emergency or urgent coronary artery bypass grafting. J Thorac Cardiovasc Surg. 2001;122(6):1181-5. Exclude - no outcomes of interest. [pmid: 11726894].
Bjessmo S, Ivert T. Blood loss after coronary artery bypass surgery: relations to patient variables and antithrombotic treatment. Scand Cardiovasc J. 2000;34(4):438-45. Exclude - no outcomes of interest. [pmid: 10983681].
Blankenship JC, Haldis T, Feit F, et al. Angiographic adverse events, creatine kinase-MB elevation, and ischemic end points complicating percutaneous coronary intervention (a REPLACE-2 substudy). Am J Cardiol. 2006;97(11):1591-6. Exclude - no active comparator. [pmid: 16728220].
Blankenship JC, Hellkamp AS, Aguirre FV, et al. Vascular access site complications after percutaneous coronary intervention with abciximab in the Evaluation of c7E3 for the Prevention of Ischemic Complications (EPIC) trial. Am J Cardiol. 1998;81(1):36-40. Exclude - no outcomes of interest. [pmid: 9462603].
Blankenship JC, Tasissa G, O'Shea JC, et al. Effect of glycoprotein IIb/IIIa receptor inhibition on angiographic complications during percutaneous coronary intervention in the ESPRIT trial. J Am Coll Cardiol. 2001;38(3):653-8. Exclude - no outcomes of interest. [pmid: 11527612].
Blomkalns AL, Chen AY, Hochman JS, et al. Gender disparities in the diagnosis and treatment of non-ST-segment elevation acute coronary syndromes: large-scale observations from the CRUSADE (Can Rapid Risk Stratification of Unstable Angina Patients Suppress Adverse Outcomes With Early Implementation of the American College of Cardiology/American Heart Association Guidelines) National Quality Improvement Initiative. J Am Coll Cardiol. 2005;45(6):832-7. Exclude - no active comparator. [pmid: 15766815].
Boccara A, Benamer H, Juliard JM, et al. A randomized trial of a fixed high dose vs a weight-adjusted low dose of intravenous heparin during coronary angioplasty. Eur Heart J. 1997;18(4):631-5. Exclude - no active comparator. [pmid: 9129894].
Boden WE. Interpreting new treatment guidelines for non-ST-segment elevation acute coronary syndromes. Am J Cardiol. 2001;88(8A):19K-24K. Exclude - not a Clinical Study. [pmid: 11694215].
Boden WE, O'Rourke RA, Crawford MH, et al. Outcomes in patients with acute non-Q-wave myocardial infarction randomly assigned to an invasive as compared with a conservative management strategy. Veterans Affairs Non-Q-Wave Infarction Strategies in Hospital (VANQWISH) Trial Investigators. N Engl J Med. 1998;338(25):1785-92. Exclude - no active comparator. [pmid: 9632444].
Boersma E, Akkerhuis KM, Theroux P, et al. Platelet glycoprotein IIb/IIIa receptor inhibition in non-ST-elevation acute coronary syndromes: early benefit during medical treatment only, with additional protection during percutaneous coronary intervention. Circulation. 1999;100(20):2045-8. Exclude - Systematic Review/Meta-Analysis. [pmid: 10562258].
Boersma E, Pieper KS, Steyerberg EW, et al. Predictors of outcome in patients with acute coronary syndromes without persistent ST-segment elevation. Results from an international trial of 9461 patients. The PURSUIT Investigators. Circulation. 2000;101(22):2557-67. Exclude -no outcomes of interest. [pmid: 10840005].
Boggon R, van Staa TP, Timmis A, et al. Clopidogrel discontinuation after acute coronary syndromes: frequency, predictors and associations with death and myocardial infarction--a hospital registry-primary care linked cohort (MINAP-GPRD). Eur Heart J. 2011;32(19):2376-86. Exclude -no active comparator. [pmid: 21875855].
Bogousslavsky J. Benefit of ADP receptor antagonists in atherothrombotic patients: new evidence. Cerebrovasc Dis. Suppl 2. 2001;11:5-10. Exclude - not a Clinical Study. [pmid: 11316916].
Bolognese L, Falsini G, Liistro F, et al. Randomized comparison of upstream tirofiban versus downstream high bolus dose tirofiban or abciximab on tissue-level perfusion and troponin release in high-risk acute coronary syndromes treated with percutaneous coronary interventions: the EVEREST trial. J Am Coll Cardiol. 2006;47(3):522-8. Exclude - no outcomes of interest. [pmid: 16458130].
Bonello L, Camoin-Jau L, Arques S, et al. Adjusted clopidogrel loading doses according to vasodilator-stimulated phosphoprotein phosphorylation index decrease rate of major adverse cardiovascular events in patients with clopidogrel resistance: a multicenter randomized prospective study. J Am Coll Cardiol. 2008;51(14):1404-11. Exclude -no outcomes of interest. [pmid: 18387444].
Bonello L, De Labriolle A, Lemesle G, et al. Comparison of outcomes of drug-eluting stents versus bare-metal stents in nonostial proximal left anterior descending coronary arteries. Am J Cardiol. 2009;103(4):496-500. Exclude -no outcomes of interest. [pmid: 19195509].
Bonello L, De Labriolle A, Lemesle G, et al. Prognosis of patients suffering an acute coronary syndrome while already under chronic clopidogrel therapy. Catheter Cardiovasc Interv. 2009;73(7):866-70. Exclude - no outcomes of interest. [pmid: 19198009].
Bonello L, Pansieri M, Camoin-Jau L, et al. High on-treatment platelet reactivity after prasugrel loading dose and cardiovascular events after percutaneous coronary interventions in acute coronary syndromes. Eur Heart J. 2011;32:249. Exclude - no outcomes of interest. [pmid: 21285076].
Bonello L, Pansieri M, Mancini J, et al. High on-treatment platelet reactivity after prasugrel loading dose and cardiovascular events after percutaneous coronary interventions in acute coronary syndromes. J Am Coll Cardiol. 2011;58(20):B17. Exclude - no outcomes of interest.
Bongard V, Cambou JP, Lezorovcz A, et al. Comparison of cardiovascular risk factors and drug use in 14,544 French patients with a history of myocardial infarction, ischaemic stroke and/or peripheral arterial disease. Eur J Cardiovasc Prev Rehabil. 2004;11(5):394-402. Exclude - no active comparator. [pmid: 15616412].
Bonz AW, Lengenfelder B, Strotmann J, et al. Effect of additional temporary glycoprotein IIb/IIIa receptor inhibition on troponin release in elective percutaneous coronary interventions after pretreatment with aspirin and clopidogrel (TOPSTAR trial). J Am Coll Cardiol. 2002;40(4):662-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12204495].
Borg S, Persson U, Allikmets K, et al. Comparative cost-effectiveness of anticoagulation with bivalirudin or heparin with and without a glycoprotein IIb/IIIa-receptor inhibitor in patients undergoing percutaneous coronary intervention in Sweden: a decision-analytic model. Clin Ther. 2006;28(11):1947-59. Exclude -not a Clinical Study. [pmid: 17213015].
Boucher M, Pharand C, Skidmore B. A critical appraisal of the CURE trial: role of clopidogrel in non-ST-segment elevation acute coronary syndromes. Can J Clin Pharmacol. 2004;11(1):e156-67. Exclude - not a Clinical Study. [pmid: 15300958].
Bourassa MG, Detre KM, Johnston JM, et al. Effect of prior revascularization on outcome following percutaneous coronary intervention; NHLBI Dynamic Registry. Eur Heart J. 2002;23(19):1546-55. Exclude - no active comparator. [pmid: 12242075].
Bozovich GE, Gurfinkel EP, Antman EM, et al. Superiority of enoxaparin versus unfractionated heparin for unstable angina/non-Q-wave myocardial infarction regardless of activated partial thromboplastin time. Am Heart J. 2000;140(4):637-42. Exclude - no outcomes of interest. [pmid: 11011339].
Bramlage P, Messer C, Bitterlich N, et al. The effect of optimal medical therapy on 1-year mortality after acute myocardial infarction. Heart. 2010;96(8):604-9. Exclude - no active comparator. [pmid: 20353936].
Brar SS, Kim J, Brar SK, et al. Long-term outcomes by clopidogrel duration and stent type in a diabetic population with de novo coronary artery lesions. J Am Coll Cardiol. 2008;51(23):2220-7. Exclude - no active comparator. [pmid: 18534267].
Breeman A, Mercado N, Lenzen M, et al. Characteristics, treatment and outcome of patients with non-ST-elevation acute coronary syndromes and multivessel coronary artery disease: observations from PURSUIT (platelet glycoprotein IIb/IIIa in unstable angina: receptor suppression using integrelin therapy). Cardiology. 2002;98(4):195-201. Exclude - no active comparator. [pmid: 12566649].
Brener SJ, Barr LA, Burchenal JE, et al. Randomized, placebo-controlled trial of platelet glycoprotein IIb/IIIa blockade with primary angioplasty for acute myocardial infarction. ReoPro and Primary PTCA Organization and Randomized Trial (RAPPORT) Investigators. Circulation. 1998;98(8):734-41. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9727542].
Brener SJ, Murphy SA, Gibson CM, et al. Efficacy and safety of multivessel percutaneous revascularization and tirofiban therapy in patients with acute coronary syndromes. Am J Cardiol. 2002;90(6):631-3. Exclude - no active comparator. [pmid: 12231091].
Brieger D, Solanki V, Gaynor M, et al. Optimal strategy for administering enoxaparin to patients undergoing coronary angiography without angioplasty for acute coronary syndromes. Am J Cardiol. 2002;89(10):1167-70. Exclude - no outcomes of interest. [pmid: 12008169].
Brilakis ES, Lichtenwalter C, de Lemos JA, et al. A randomized controlled trial of a paclitaxel-eluting stent versus a similar bare-metal stent in saphenous vein graft lesions the SOS (Stenting of Saphenous Vein Grafts) trial. J Am Coll Cardiol. 2009;53(11):919-28. Exclude - no outcomes of interest. [pmid: 19281920].
Brilakis ES, Wright RS, Kopecky SL, et al. Association of the PURSUIT risk score with predischarge ejection fraction, angiographic severity of coronary artery disease, and mortality in a nonselected, community-based population with non-ST-elevation acute myocardial infarction. Am Heart J. 2003;146(5):811-8. Exclude - no active comparator. [pmid: 14597929].
Bromberg-Marin G, Marin-Neto JA, Parsons LS, et al. Effectiveness and safety of glycoprotein IIb/IIIa inhibitors and clopidogrel alone and in combination in non-ST-segment elevation myocardial infarction (from the National Registry of Myocardial Infarction-4). Am J Cardiol. 2006;98(9):1125-31. Exclude - no outcomes of interest. [pmid: 17056312].
Brophy JM, Brassard P, Bourgault C. The benefit of cholesterol-lowering medications after coronary revascularization: a population study. Am Heart J. 2005;150(2):282-6. Exclude - no active comparator. [pmid: 16086931].
Brouse SD, Wiesehan VG. Evaluation of bleeding complications associated with glycoprotein IIb/IIIa inhibitors. Ann Pharmacother. 2004;38(11):1783-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15383640].
Brown RE, Henderson RA, Koster D, et al. Cost effectiveness of eptifibatide in acute coronary syndromes; an economic analysis of Western European patients enrolled in the PURSUIT trial. The Platelet IIa/IIb in unstable Angina: Receptor Suppression Using Integrilin Therapy. Eur Heart J. 2002;23(1):50-8. Exclude - not a Clinical Study. [pmid: 11741362].
Brugaletta S, Martin-Yuste V, Ferreira-Gonzalez I, et al. Adequate antiplatelet regimen in patients on chronic anti-vitamin K treatment undergoing percutaneous coronary intervention. World J Cardiol. 2011;3(11):367-73. Exclude - no active comparator. [pmid: 22125672].
Bruggenjurgen B, Lindgren P, Ehlken B, et al. Long-term cost-effectiveness of clopidogrel in patients with acute coronary syndrome without ST-segment elevation in Germany. Eur J Health Econ. 2007;8(1):51-7. Exclude - not a Clinical Study. [pmid: 17186199].
Brulotte S, Senechal M, Poirier P, et al. Safety of the cardiac triple therapy: the experience of the Quebec Heart Institute. Can J Cardiol. Suppl B. 2007;23:80B-83B. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17932593].
Bruno R, Baille P, Retout S, et al. Population pharmacokinetics and pharmacodynamics of enoxaparin in unstable angina and non-ST-segment elevation myocardial infarction. Br J Clin Pharmacol. 2003;56(4):407-14. Exclude - no outcomes of interest. [pmid: 12968985].
Budaj A, Brieger D, Steg PG, et al. Global patterns of use of antithrombotic and antiplatelet therapies in patients with acute coronary syndromes: insights from the Global Registry of Acute Coronary Events (GRACE). Am Heart J. 2003;146(6):999-1006. Exclude - no active comparator. [pmid: 14660991].
Burkard T, Kaiser CA, Brunner-La Rocca H, et al. Combined clopidogrel and proton pump inhibitor therapy is associated with higher cardiovascular event rates after percutaneous coronary intervention: a report from the BASKET trial. J Intern Med. 2011. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21726302].
Bush N, Nelson-Piercy C, Spark P, et al. Myocardial infarction in pregnancy and postpartum in the UK. Eur J Cardiovasc Prev Rehabil. 2011. Exclude - no active comparator. [pmid: 22127355].
Buszman PP, Bochenek A, Konkolewska M, et al. Early and long-term outcomes after surgical and percutaneous myocardial revascularization in patients with non-ST-elevation acute coronary syndromes and unprotected left main disease. J Invasive Cardiol. 2009;21(11):564-9. Exclude - no active comparator. [pmid: 19901409].
Byrne RA, Kastrati A, Massberg S, et al. Biodegradable polymer versus permanent polymer drug-eluting stents and everolimus- versus sirolimus-eluting stents in patients with coronary artery disease: 3-year outcomes from a randomized clinical trial. J Am Coll Cardiol. 2011;58(13):1325-31. Exclude - no active comparator. [pmid: 21920260].
Byrne RA, Mehilli J, Iijima R, et al. A polymer-free dual drug-eluting stent in patients with coronary artery disease: a randomized trial vs. polymer-based drug-eluting stents. Eur Heart J. 2009;30(8):923-31. Exclude - no outcomes of interest. [pmid: 19240066].
Byrne RA, Schulz S, Mehilli J, et al. Rationale and design of a randomized, double-blind, placebo-controlled trial of 6 versus 12 months clopidogrel therapy after implantation of a drug-eluting stent: The Intracoronary Stenting and Antithrombotic Regimen: Safety And EFficacy of 6 Months Dual Antiplatelet Therapy After Drug-Eluting Stenting (ISAR-SAFE) study. Am Heart J. 2009;157(4):620-4 e2. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19332187].
Calafiore AM, Di Mauro M, Canosa C, et al. Early and late outcome of myocardial revascularization with and without cardiopulmonary bypass in high risk patients (EuroSCORE > or = 6). Eur J Cardiothorac Surg. 2003;23(3):360-7. Exclude - no active comparator. [pmid: 12614807].
Califf RM, DeLong ER, Ostbye T, et al. Underuse of aspirin in a referral population with documented coronary artery disease. Am J Cardiol. 2002;89(6):653-61. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11897205].
Calver AL, Blows LJ, Harmer S, et al. Clopidogrel for prevention of major cardiac events after coronary stent implantation: 30-day and 6-month results in patients with smaller stents. Am Heart J. 2000;140(3):483-91. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10966552].
Cannon CP. Elderly Patients with Acute Coronary Syndromes: Higher Risk and Greater Benefit from Antithrombotic and Interventional Therapies. Am J Geriatr Cardiol. 2000;9(5):265-270. Exclude - not a Clinical Study. [pmid: 11416578].
Cannon CP. Effectiveness of clopidogrel versus aspirin in preventing acute myocardial infarction in patients with symptomatic atherothrombosis (CAPRIE trial). Am J Cardiol. 2002;90(7):760-2. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12356393].
Cannon CP. Small molecule glycoprotein IIb/IIIa receptor inhibitors as upstream therapy in acute coronary syndromes: insights from the TACTICS TIMI-18 trial. J Am Coll Cardiol. 2003;41(4 Suppl S):43S-48S. Exclude - not a Clinical Study. [pmid: 12644340].
Cannon CP, Weintraub WS, Demopoulos LA, et al. Invasive versus conservative strategies in unstable angina and non-Q-wave myocardial infarction following treatment with tirofiban: rationale and study design of the international TACTICS-TIMI 18 Trial. Treat Angina with Aggrastat and determine Cost of Therapy with an Invasive or Conservative Strategy. Thrombolysis In Myocardial Infarction. Am J Cardiol. 1998;82(6):731-6. Exclude - no outcomes of interest. [pmid: 9761082].
Cannon CP, Weintraub WS, Demopoulos LA, et al. Comparison of early invasive and conservative strategies in patients with unstable coronary syndromes treated with the glycoprotein IIb/IIIa inhibitor tirofiban. N Engl J Med. 2001;344(25):1879-87. Exclude -no active comparator. [pmid: 11419424].
Cantor WJ, Goodman SG, Cannon CP, et al. Early cardiac catheterization is associated with lower mortality only among high-risk patients with ST- and non-ST-elevation acute coronary syndromes: observations from the OPUS-TIMI 16 trial. Am Heart J. 2005;149(2):275-83. Exclude - no active comparator. [pmid: 15846265].
Cantor WJ, Kaplan AL, Velianou JL, et al. Effectiveness and safety of abciximab after failed thrombolytic therapy. Am J Cardiol. 2001;87(4):439-42. A4. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11179529].
Cantor WJ, Mahaffey KW, Huang Z, et al. Bleeding complications in patients with acute coronary syndrome undergoing early invasive management can be reduced with radial access, smaller sheath sizes, and timely sheath removal. Catheter Cardiovasc Interv. 2007;69(1):73-83. Exclude- no outcomes of interest. [pmid: 17139670].
Cantor WJ, Tcheng JE, Blankenship JC, et al. Temporal spectrum of ischemic complications with percutaneous coronary intervention: the ESPRIT experience. J Invasive Cardiol. 2004;16(9):475-81. Exclude - no active comparator. [pmid: 15353828].
Capodanno D, Di Salvo ME, Capranzano P, et al. Long term results of unprotected left main percutaneous coronary intervention with DES versus BMS. Minerva Cardioangiol. 2009;57(1):1-6. Exclude - no outcomes of interest. [pmid: 19202514].
Capodanno D, Di Salvo ME, Palmerini T, et al. Long-term clinical benefit of drug-eluting stents over bare-metal stents in diabetic patients with de novo left main coronary artery disease: results from a real-world multicenter registry. Catheter Cardiovasc Interv. 2009;73(3):310-6. Exclude- no active comparator. [pmid: 19214964].
Capodanno D, LaManna A, Sanfilippo A, et al. Clinical outcome of CATANIA coronary stent system with nanothin polyzene-f in a real-world unselected population: Assessment of the Atlanta-II study. Am J Cardiol. 2010;105(9):18B-19B. Exclude- not original peer-reviewed data.
Carnendran L, Borkowski R, Markabawi B, et al. Safety and efficacy of low-dose intravenous enoxaparin and GP IIb/IIIa inhibitor therapy during PCI. J Invasive Cardiol. 2003;15(5):235-8. Exclude - no active comparator. [pmid: 12730628].
Casterella PJ, Revenaugh JR, Burke JL, et al. Real-world safety and efficacy of glycoprotein IIb/IIIa inhibitors during percutaneous coronary intervention. J Invasive Cardiol. 2008;20(3):94-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18316822].
Catakoglu AB, Aytekin S, Celebi H, et al. The influence of aspirin resistance on non-fatal coronary events following percutaneous coronary interventions. Arch Med Sci. 2009;5(4):531-538. Exclude - no active comparator.
Cay S, Cagirci G, Aydogdu S, et al. Safety of clopidogrel in older patients: a nonrandomized, parallel-group, controlled, two-centre study. Drugs Aging. 2011;28(2):119-29. Exclude - no active comparator. [pmid: 21275437].
Cayla G, Silvain J, Barthelemy O, et al. Trans-radial approach for catheterisation in non-ST segment elevation acute coronary syndrome: an analysis of major bleeding complications in the ABOARD Study. Heart. 2011;97(11):887-91. Exclude - no active comparator. [pmid: 21421600].
Cea-Soriano L, Garcia Rodriguez LA, Johansson S. Risk of cardiovascular outcomes after low-dose acetylsalicylic acid discontinuation: A UK primary care study. Eur Heart J. 2011;32:484. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data).
Cerisano G, Bolognese L, Buonamici P, et al. Prognostic implications of restrictive left ventricular filling in reperfused anterior acute myocardial infarction. J Am Coll Cardiol. 2001;37(3):793-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11693754].
Cestac P, Bagheri H, Lapeyre-Mestre M, et al. Utilisation and safety of low molecular weight heparins: prospective observational study in medical inpatients. Drug Saf. 2003;26(3):197-207. Exclude - no active comparator. [pmid: 12580648].
Chacko M, Lincoff AM, Wolski KE, et al. Ischemic and bleeding outcomes in women treated with bivalirudin during percutaneous coronary intervention: a subgroup analysis of the Randomized Evaluation in PCI Linking Angiomax to Reduced Clinical Events (REPLACE)-2 trial. Am Heart J. 2006;151(5):1032 e1-7. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16644331].
Chadow HL, Hauptman RE, VanAuker M, et al. Drip and ship: a new strategy for the treatment of acute coronary syndromes. J Thromb Thrombolysis. 2000;10(1):77-82. Exclude - no active comparator. [pmid: 10947917].
Chan AW, Moliterno DJ. Optimization of glycoprotein IIb/IIIa blockade during percutaneous coronary interventions: Insights from TARGET after 1 year. Cardiovasc Rev Rep. 2003;24(10):506-512. Exclude - not a Clinical Study.
Chan FK, Ching JY, Hung LC, et al. Clopidogrel versus aspirin and esomeprazole to prevent recurrent ulcer bleeding. N Engl J Med. 2005;352(3):238-44. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15659723].
Chan MY, Mahaffey KW, Sun LJ, et al. Prevalence, predictors, and impact of conservative medical management for patients with non-ST-segment elevation acute coronary syndromes who have angiographically documented significant coronary disease. JACC Cardiovasc Interv. 2008;1(4):369-78. Exclude - no outcomes of interest. [pmid: 19463332].
Chan MY, Sun JL, Wang TY, et al. Patterns of discharge antiplatelet therapy and late outcomes among 8,582 patients with bleeding during acute coronary syndrome: a pooled analysis from PURSUIT, PARAGON-A, PARAGON-B, and SYNERGY. Am Heart J. 2010;160(6):1056-64. 1064 e2. Exclude - not a Clinical Study. [pmid: 21146658].
Chandra A, Glickman SW, Ou FS, et al. An analysis of the Association of Society of Chest Pain Centers Accreditation to American College of Cardiology/American Heart Association non-ST-segment elevation myocardial infarction guideline adherence. Ann Emerg Med. 2009;54(1):17-25. Exclude - no outcomes of interest. [pmid: 19282062].
Chandra KK, Malhotra S, Gupta M, et al. Changing trends in the hospital management of unstable angina: a drug utilization analysis. Int J Clin Pharmacol Ther. 2004;42(10):575-80. Exclude - no active comparator. [pmid: 15516028].
Chang WC, Boersma E, Granger CB, et al. Dynamic prognostication in non-ST-elevation acute coronary syndromes: insights from GUSTO-IIb and PURSUIT. Am Heart J. 2004;148(1):62-71. Exclude - no active comparator. [pmid: 15215793].
Chang WC, Midodzi WK, Westerhout CM, et al. Are international differences in the outcomes of acute coronary syndromes apparent or real? A multilevel analysis. J Epidemiol Community Health. 2005;59(5):427-33. Exclude - no active comparator. [pmid: 15831694].
Charlot M, Nielsen LH, Lindhardsen J, et al. Thrombotic events following clopidogrel discontinuation in patients with myocardial infarction: A nationwide cohort study. Eur Heart J. 2011;32:421. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Chastek B, Riedel AA, Wygant G, et al. Evaluation of hospitalization and follow-up care costs among patients hospitalized with ACS treated with a stent and clopidogrel. Curr Med Res Opin. 2009;25(12):2845-52. Exclude -no outcomes of interest. [pmid: 19831706].
Chen J, Bhatt DL, Dunn ES, et al. Cost-effectiveness of clopidogrel plus aspirin versus aspirin alone for secondary prevention of cardiovascular events: results from the CHARISMA trial. Value Health. 2009;12(6):872-9. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19490556].
Chen J, Shi C, Mahoney EM, et al. Clinical research economic evaluation of clopidogrel plus aspirin for secondary prevention of cardiovascular events in Canada for patients with established cardiovascular disease: Results from the CHARISMA trial. Can J Cardiol. 2011;27(2):222-231. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21459271].
Chen LY, Lennon RJ, Grantham JA, et al. In-hospital and long-term outcomes of multivessel percutaneous coronary revascularization after acute myocardial infarction. Am J Cardiol. 2005;95(3):349-54. Exclude - no active comparator. [pmid: 15670543].
Chen YH, Chen JW, Wu TC, et al. Safety and efficacy of the platelet glycoprotein IIb/IIIa inhibitor abciximab in Chinese patients undergoing high-risk angioplasty. Zhonghua Yi Xue Za Zhi (Taipei). 2000;63(1):8-15. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10645045].
Chen ZM, Jiang LX, Chen YP, et al. Addition of clopidogrel to aspirin in 45,852 patients with acute myocardial infarction: randomised placebo-controlled trial. Lancet. 2005;366(9497):1607-21. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16271642].
Cheng JWM, Greenberg KA, Mehl B. Utilization of glycoprotein IIB/IIIA receptor antagonists in the management of acute coronary syndrome: Focus on patient characteristics and formulary decisions. Hosp Pharm. 2001;36(10):1052-1059. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Chevalier P, Lamotte M. An epidemiological evaluation of the impact of percutaneous coronary interventions on the length of stay and mortality of patients hospitalized with acute coronary syndromes. Value Health. 2010;13(7):A344-A345. Exclude - not original peer-reviewed data.
Chieffo A, Melzi G, Rogacka R, et al. Safety and feasibility of Bivalirudin with either Cypher and Taxus drug-eluting stent during percutaneous coronary intervention. EuroIntervention. 2005;1(1):70-4. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19758880].
Chin MW, Yong G, Bulsara MK, et al. Predictive and protective factors associated with upper gastrointestinal bleeding after percutaneous coronary intervention: a case-control study. Am J Gastroenterol. 2007;102(11):2411-6. Exclude - no active comparator. [pmid: 17850413].
Chiu JH, Bhatt DL, Ziada KM, et al. Impact of female sex on outcome after percutaneous coronary intervention. Am Heart J. 2004;148(6):998-1002. Exclude - no active comparator. [pmid: 15632884].
Cho L, Bhatt DL, Marso SP, et al. An invasive strategy is associated with decreased mortality in patients with unstable angina and non-ST-elevation myocardial infarction: GUSTO IIb trial. Am J Med. 2003;114(2):106-11. Exclude - no active comparator. [pmid: 12586229].
Cho L, Marso SP, Bhatt DL, et al. Optimizing percutaneous coronary revascularization in diabetic women: analysis from the EPISTENT trial. J Womens Health Gend Based Med. 2000;9(7):741-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11025866].
Chong E, Shen L, Tan HC, et al. A cohort study of risk factors and clinical outcome predictors for patients presenting with unstable angina and non ST segment elevation myorardial infraction undergoing coronary intervention. Med J Malaysia. 2011;66(3):249-52. Exclude - no active comparator. [pmid: 22111450].
Cin VG, Temizhan A, Pekdemir H, et al. The effects of ticlopidine in acute myocardial infarction as an adjunctive treatment to aspirin in an intermediate term setting. Turk J Med Sci. 2002;32(4):329-334. Exclude - no active comparator.
Claessen BE, Smits PC, Kereiakes DJ, et al. Impact of Lesion Length and Vessel Size on Clinical Outcomes After Percutaneous Coronary Intervention With Everolimus- Versus Paclitaxel-Eluting Stents Pooled Analysis From the SPIRIT (Clinical Evaluation of the XIENCE V Everolimus Eluting Coronary Stent System) and COMPARE (Second-generation everolimus-eluting and paclitaxel-eluting stents in real-life practice) Randomized Trials. JACC Cardiovasc Interv. 2011;4(11):1209-15. Exclude - no active comparator. [pmid: 22115661].
Claeys MJ, Van der Planken MG, Bosmans JM, et al. Does pre-treatment with aspirin and loading dose clopidogrel obviate the need for glycoprotein IIb/IIIa antagonists during elective coronary stenting? A focus on peri-procedural myonecrosis. Eur Heart J. 2005;26(6):567-75. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15618034].
Clark SC, Vitale N, Zacharias J, et al. Effect of low molecular weight heparin (fragmin) on bleeding after cardiac surgery. Ann Thorac Surg. 2000;69(3):762-4. discussion 764-5. Exclude - no outcomes of interest. [pmid: 10750757].
Clayton TC, Pocock SJ, Henderson RA, et al. Do men benefit more than women from an interventional strategy in patients with unstable angina or non-ST-elevation myocardial infarction? The impact of gender in the RITA 3 trial. Eur Heart J. 2004;25(18):1641-50. Exclude -no active comparator. [pmid: 15351164].
Cohen DJ, Lincoff AM, Lavelle TA, et al. Economic evaluation of bivalirudin with provisional glycoprotein IIB/IIIA inhibition versus heparin with routine glycoprotein IIB/IIIA inhibition for percutaneous coronary intervention: results from the REPLACE-2 trial. J Am Coll Cardiol. 2004;44(9):1792-800. Exclude -no outcomes of interest. [pmid: 15519009].
Cohen M. Initial experience with the low-molecular-weight heparin, enoxaparin, in combination with the platelet glycoprotein IIb/IIIa blocker, tirofiban, in patients with non-ST segment elevation acute coronary syndromes. J Invasive Cardiol. Suppl E. 2000;12:E5-9. discussion E25-8. Exclude - not a Clinical Study. [pmid: 11156722].
Cohen M. The role of low-molecular-weight heparins in the management of unstable angina and non-ST-segment elevation myocardial infarction. J Thromb Thrombolysis. 2001;11(2):171-4. Exclude - not a Clinical Study. [pmid: 11406733].
Cohen M, Maritz F, Gensini GF, et al. The TETAMI trial: the safety and efficacy of subcutaneous enoxaparin versus intravenous unfractionated heparin and of tirofiban versus placebo in the treatment of acute myocardial infarction for patients not thrombolyzed: methods and design. J Thromb Thrombolysis. 2000;10(3):241-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11122544].
Cohen M, Theroux P, Weber S, et al. Combination therapy with tirofiban and enoxaparin in acute coronary syndromes. Int J Cardiol. 1999;71(3):273-81. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10636535].
Cohen MG, Pacchiana CM, Corbalan R, et al. Variation in patient management and outcomes for acute coronary syndromes in Latin America and North America: results from the Platelet IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy (PURSUIT) trial. Am Heart J. 2001;141(3):391-401. Exclude -no outcomes of interest. [pmid: 11231436].
Colivicchi F, Tubaro M, Mocini D, et al. Full-dose atorvastatin versus conventional medical therapy after non-ST-elevation acute myocardial infarction in patients with advanced non-revascularisable coronary artery disease. Curr Med Res Opin. 2010;26(6):1277-84. Exclude - no active comparator. [pmid: 20367555].
Collet JP, Montalescot G, Agnelli G, et al. Non-ST-segment elevation acute coronary syndrome in patients with renal dysfunction: benefit of low-molecular-weight heparin alone or with glycoprotein IIb/IIIa inhibitors on outcomes. The Global Registry of Acute Coronary Events. Eur Heart J. 2005;26(21):2285-93. Exclude -no outcomes of interest. [pmid: 15932908].
Collet JP, Montalescot G, Blanchet B, et al. Impact of prior use or recent withdrawal of oral antiplatelet agents on acute coronary syndromes. Circulation. 2004;110(16):2361-7. Exclude -no active comparator. [pmid: 15477397].
Collet JP, Montalescot G, Golmard JL, et al. Subcutaneous enoxaparin with early invasive strategy in patients with acute coronary syndromes. Am Heart J. 2004;147(4):655-61. Exclude -no active comparator. [pmid: 15077081].
Collet JP, Montalescot G, Lison L, et al. Percutaneous coronary intervention after subcutaneous enoxaparin pretreatment in patients with unstable angina pectoris. Circulation. 2001;103(5):658-63. Exclude - no active comparator. [pmid: 11156876].
Collet JP, Montalescot G, Steg PG, et al. Clinical outcomes according to permanent discontinuation of clopidogrel or placebo in the CHARISMA trial. Arch Cardiovasc Dis. 2009;102(6-7):485-96. Exclude - no outcomes of interest. [pmid: 19664568].
Conaglen P, Sebastian C, Jayaraman C, et al. Management of unstable angina and non-ST-elevation myocardial infarction: Do cardiologists do it better? A comparison of secondary and tertiary centre management in New Zealand. New Zealand Med J. 2004;117(1194). Exclude - no outcomes of interest.
Connolly SJ, Pogue J, Hart RG, et al. Effect of clopidogrel added to aspirin in patients with atrial fibrillation. N Engl J Med. 2009;360(20):2066-78. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19336502].
Conway B, O'Connor J, McClements B. Impact of serum troponin measurement on triage of chest pain in a district hospital. Ulster Med J. 2003;72(2):86-92. Exclude - no active comparator. [pmid: 14696818].
Coons JC, Seybert AL, Saul MI, et al. Outcomes and costs of abciximab versus eptifibatide for percutaneous coronary intervention. Ann Pharmacother. 2005;39(10):1621-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16105872].
Corominas N, Perez J, Ortiz J, et al. Tirofiban and eptifibatide treatment of patients presenting with acute coronary syndrome with non-ST segment elevation. Pharm World Sci. 2004;26(1):38-43. Exclude - no outcomes of interest. [pmid: 15018258].
Cortese B, Picchi A, Micheli A, et al. Comparison of prolonged bivalirudin infusion versus intraprocedural in preventing myocardial damage after percutaneous coronary intervention in patients with angina pectoris. Am J Cardiol. 2009;104(8):1063-8. Exclude - no active comparator. [pmid: 19801025].
Corteville DC, Armstrong DF, Montgomery DG, et al. Treatment and outcomes of first troponin-negative non-ST-segment elevation myocardial infarction. Am J Cardiol. 2011;107(1):24-9. Exclude - no active comparator. [pmid: 21146681].
Cote AV, Berger PB, Holmes DR Jr., et al. Hemorrhagic and vascular complications after percutaneous coronary intervention with adjunctive abciximab. Mayo Clin Proc. 2001;76(9):890-6. Exclude - no outcomes of interest. [pmid: 11560299].
Cotter G, Cannon CP, McCabe CH, et al. Prior peripheral arterial disease and cerebrovascular disease are independent predictors of adverse outcome in patients with acute coronary syndromes: are we doing enough? Results from the Orbofiban in Patients with Unstable Coronary Syndromes-Thrombolysis In Myocardial Infarction (OPUS-TIMI) 16 study. Am Heart J. 2003;145(4):622-7. Exclude - no active comparator. [pmid: 12679757].
Coufal Z, Berkenboom G, Pavlides G, et al. An international comparison of antiplatelet use at 6 months following hospital discharge in UA/NSTEMI and stemi patients undergoing PCI: Results from the antiplatelet treatment observational registry II (APTOR-II). Value Health. 2010;13(7):A366. Exclude - no outcomes of interest.
Cowper PA, Udayakumar K, Sketch MH Jr., et al. Economic effects of prolonged clopidogrel therapy after percutaneous coronary intervention. J Am Coll Cardiol. 2005;45(3):369-76. Exclude - no active comparator. [pmid: 15680714].
Creager MA. Results of the CAPRIE trial: efficacy and safety of clopidogrel. Clopidogrel versus aspirin in patients at risk of ischaemic events. Vasc Med. 1998;3(3):257-60. Exclude - not a Clinical Study. [pmid: 9892520].
Crespin DJ, Federspiel JJ, Biddle AK, et al. Ticagrelor versus genotype-driven antiplatelet therapy for secondary prevention after acute coronary syndrome: a cost-effectiveness analysis. Value Health. 2011;14(4):483-91. Exclude - not a Clinical Study. [pmid: 21669373].
Cronin L, Mehta SR, Zhao F, et al. Stroke in relation to cardiac procedures in patients with non-ST-elevation acute coronary syndrome: a study involving >18 000 patients. Circulation. 2001;104(3):269-74. Exclude - no outcomes of interest. [pmid: 11457743].
Cruz-Fernandez JM, Lopez-Bescos L, Garcia-Dorado D, et al. Randomized comparative trial of triflusal and aspirin following acute myocardial infarction. Eur Heart J. 2000;21(6):457-65. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10681486].
Cruz-Gonzalez I, Sanchez-Ledesma M, Baron SJ, et al. Efficacy and safety of argatroban with or without glycoprotein IIb/IIIa inhibitor in patients with heparin induced thrombocytopenia undergoing percutaneous coronary intervention for acute coronary syndrome. J Thromb Thrombolysis. 2008;25(2):214-8. Exclude - no outcomes of interest. [pmid: 17632689].
Cubbon RM, Gale CP, Rajwani A, et al. Aspirin and mortality in patients with diabetes sustaining acute coronary syndrome. Diabetes Care. 2008;31(2):363-5. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17959865].
Cuisset T, Frere C, Quilici J, et al. Glycoprotein IIb/IIIa inhibitors improve outcome after coronary stenting in clopidogrel nonresponders: a prospective, randomized study. JACC Cardiovasc Interv. 2008;1(6):649-53. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19463379].
Cuisset T, Frere C, Quilici J, et al. Comparison of omeprazole and pantoprazole influence on a high 150-mg clopidogrel maintenance dose the PACA (Proton Pump Inhibitors And Clopidogrel Association) prospective randomized study. J Am Coll Cardiol. 2009;54(13):1149-53. Exclude - no outcomes of interest. [pmid: 19761935].
Cuisset T, Quilici J, Cohen W, et al. Usefulness of high clopidogrel maintenance dose according to CYP2C19 genotypes in clopidogrel low responders undergoing coronary stenting for non ST elevation acute coronary syndrome. Am J Cardiol. 2011;108(6):760-5. Exclude - no outcomes of interest. [pmid: 21803320].
Cuisset T, Quilici J, Grosdidier C, et al. Comparison of platelet reactivity and clopidogrel response in patients </= 75 Years Versus > 75 years undergoing percutaneous coronary intervention for non-ST-segment elevation acute coronary syndrome. Am J Cardiol. 2011;108(10):1411-6. Exclude - no outcomes of interest. [pmid: 21872198].
Cura FA, Bhatt DL, Lincoff AM, et al. Pronounced benefit of coronary stenting and adjunctive platelet glycoprotein IIb/IIIa inhibition in complex atherosclerotic lesions. Circulation. 2000;102(1):28-34. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10880411].
Dakik HA, Koubeissi Z, Kleiman NS, et al. Acute myocardial infarction: clinical characteristics, management and outcome in a university medical centre in a developing Middle Eastern country. Can J Cardiol. 2004;20(8):789-93. Exclude - no active comparator. [pmid: 15229760].
Dalby M, Montalescot G, Bal dit Sollier C, et al. Eptifibatide provides additional platelet inhibition in non-ST-elevation myocardial infarction patients already treated with aspirin and clopidogrel. Results of the platelet activity extinction in non-Q-wave myocardial infarction with aspirin, clopidogrel, and eptifibatide (PEACE) study. J Am Coll Cardiol. 2004;43(2):162-8. Exclude - no outcomes of interest. [pmid: 14736431].
Damman P, Hirsch A, Windhausen F, et al. 5-year clinical outcomes in the ICTUS (Invasive versus Conservative Treatment in Unstable coronary Syndromes) trial a randomized comparison of an early invasive versus selective invasive management in patients with non-ST-segment elevation acute coronary syndrome. J Am Coll Cardiol. 2010;55(9):858-64. Exclude - no active comparator. [pmid: 20045278].
Damman P, Holmvang L, Tijssen JG, et al. Usefulness of the Admission Electrocardiogram to Predict Long-Term Outcomes After Non-ST-Elevation Acute Coronary Syndrome (from the FRISC II, ICTUS, and RITA-3 [FIR] Trials). Am J Cardiol. 2011;109(1):6-12. Exclude - no active comparator. [pmid: 21944677].
Damman P, Klomp M, Silber S, et al. Duration of dual antiplatelet therapy and outcomes after coronary stenting with the Genous bio-engineered R stent in patients from the e-HEALING registry. Catheter Cardiovasc Interv. 2012;79(2):243-52. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21542121].
Danchin N, Grenier O, Ferrieres J, et al. Use of secondary preventive drugs in patients with acute coronary syndromes treated medically or with coronary angioplasty: results from the nationwide French PREVENIR survey. Heart. 2002;88(2):159-62. Exclude - no active comparator. [pmid: 12117845].
Dangas G, Lasic Z, Mehran R, et al. Effectiveness of the concomitant use of bivalirudin and drug-eluting stents (from the prospective, multicenter BivAlirudin and Drug-Eluting STents [ADEST] study). Am J Cardiol. 2005;96(5):659-63. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16125490].
Dangas G, Mehran R, Feit F, et al. Impact of bivalirudin therapy on mortality in patients with high risk features undergoing PCI: A patient-level pooled analysis from the REPLACE-2, ACUITY and HORIZONS-AMI trials. Eur Heart J. 2011;32:232-233. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Daniels PR, McBane RD, Litin SC, et al. Peri-procedural anticoagulation management of mechanical prosthetic heart valve patients. Thromb Res. 2009;124(3):300-5. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19232682].
Daoulah A, Segev A, Leblanc K, et al. Postprocedural low molecular weight heparin in patients at high risk of subacute stent thrombosis. Cardiovasc Radiat Med. 2003;4(4):182-5. Exclude - no active comparator. [pmid: 15321055].
Dauerman HL, Andreou C, Perras MA, et al. Predictors of bleeding complications after rescue coronary interventions. J Thromb Thrombolysis. 2000;10(1):83-8. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10947918].
Dauerman HL, Yarzebski J, Gore JM, et al. Use of the invasive management strategy for patients with non-Q-wave myocardial infarction: an observational database report from the Worcester Heart Attack Study. Am Heart J. 2002;143(6):1033-9. Exclude - no active comparator. [pmid: 12075260].
Davies A, Sculpher MJ, Barrett A, et al. Prasugrel vs. clopidogrel in patients with acute coronary syndrome undergoing percutaneous coronary intervention: A Spanish model-based cost-effectiveness analysis. Value Health. 2010;13(7):A357. Exclude - no outcomes of interest.
de Araujo Goncalves P, Ferreira J, Aguiar C, et al. TIMI, PURSUIT, and GRACE risk scores: sustained prognostic value and interaction with revascularization in NSTE-ACS. Eur Heart J. 2005;26(9):865-72. Exclude - no active comparator. [pmid: 15764619].
De Carlo M, Borelli G, Gistri R, et al. Effectiveness of the transradial approach to reduce bleedings in patients undergoing urgent coronary angioplasty with GPIIb/IIIa inhibitors for acute coronary syndromes. Catheter Cardiovasc Interv. 2009;74(3):408-15. Exclude - no outcomes of interest. [pmid: 19360863].
De Felice F, Fiorilli R, Parma A, et al. One-year clinical outcome of patients treated with or without abciximab in rescue coronary angioplasty. Int J Cardiol. 2011. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21703701].
De Ferrari GM, Leonardi S, Baduena L, et al. Patients with acute coronary syndrome and nonobstructive coronary artery disease in the real world are markedly undertreated. J Cardiovasc Med (Hagerstown). 2011;12(10):700-8. Exclude - no active comparator. [pmid: 21738050].
De Luca L, De Persio G, Minati M, et al. Effects of abciximab and preprocedural glycemic control in diabetic patients undergoing elective coronary stenting. Am Heart J. 2005;149(6):1135. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15976799].
de Miguel Castro A, Cuellas Ramon C, Diego Nieto A, et al. Post-treatment platelet reactivity predicts long-term adverse events better than the response to clopidogrel in patients with non-ST-segment elevation acute coronary syndrome. Rev Esp Cardiol. 2009;62(2):126-35. Exclude - no active comparator. [pmid: 19232185].
De Servi S, Cavallini C, Dellavalle A, et al. Non-ST-elevation acute coronary syndrome in the elderly: treatment strategies and 30-day outcome. Am Heart J. 2004;147(5):830-6. Exclude - no active comparator. [pmid: 15131538].
Dean BB, Yu HT, Bae JP, et al. Pattern of clopidogrel use in hospitalized patients receiving percutaneous coronary interventions. Am J Health Syst Pharm. 2010;67(17):1430-7. Exclude - no outcomes of interest. [pmid: 20720242].
Decker C, Garavalia L, Garavalia B, et al. Clopidogrel-taking behavior by drug-eluting stent patients: Discontinuers versus continuers. Patient Prefer Adherence. 2008;2:167-75. Exclude - no outcomes of interest. [pmid: 19920959].
Deliargyris EN, Upadhya B, Applegate RJ, et al. Superior in-hospital and 30-day outcomes with abciximab versus eptifibatide: a contemporary analysis of 495 consecutive percutaneous coronary interventions. J Invasive Cardiol. 2004;16(11):611-6. Exclude - no outcomes of interest. [pmid: 15550727].
Demers C. ESSENCE trial results: breaking new ground. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q wave Coronary Events. Can J Cardiol. Suppl E. 1998;14:15E-19E. Exclude - not a Clinical Study. [pmid: 9779028].
Denardo SJ, Davis KE, Reid PR, et al. Efficacy and safety of minimal dose (< or =1,000 units) unfractionated heparin with abciximab in percutaneous coronary intervention. Am J Cardiol. 2003;91(1):1-5. Exclude - no active comparator. [pmid: 12505562].
Denardo SJ, Davis KE, Tcheng JE. Elective percutaneous coronary intervention using broad-spectrum antiplatelet therapy (eptifibatide, clopidogrel, and aspirin) alone, without scheduled unfractionated heparin or other antithrombin therapy. Am Heart J. 2005;149(1):138-44. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15660045].
Depta JP, Cannon CP, Fonarow GC, et al. Patient characteristics associated with the choice of triple antithrombotic therapy in acute coronary syndromes. Am J Cardiol. 2009;104(9):1171-8. Exclude - no outcomes of interest. [pmid: 19840557].
Dery JP, Campbell ME, Mathias J, et al. Complementary effects of thienopyridine pretreatment and platelet glycoprotein IIb/IIIa integrin blockade with eptifibatide in coronary stent intervention; results from the ESPRIT trial. Catheter Cardiovasc Interv. 2007;70(1):43-50. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17203469].
Detournay B, Huet X, Fagnani F, et al. Economic evaluation of enoxaparin sodium versus heparin in unstable angina. A French sub-study of the ESSENCE trial. Pharmacoeconomics. 2000;18(1):83-9. Exclude - no outcomes of interest. [pmid: 11010607].
Di Pasquale P, Cannizzaro S, Giambanco F, et al. Immediate versus delayed facilitated percutaneous coronary intervention: a pilot study. J Cardiovasc Pharmacol. 2005;46(1):83-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15965359].
Dickfeld T, Ruf A, Pogatsa-Murray G, et al. Differential antiplatelet effects of various glycoprotein IIb-IIIa antagonists. Thromb Res. 2001;101(2):53-64. Exclude - not a Clinical Study. [pmid: 11342206].
Diderholm E, Andren B, Frostfeldt G, et al. Effects of an early invasive strategy on ischemia and exercise tolerance among patients with unstable coronary artery disease. Am J Med. 2003;115(8):606-12. Exclude - no active comparator. [pmid: 14656612].
Diercks DB, Pollack CV Jr., Hollander JE, et al. The time dependence of antithrombin initiation in patients with non-ST-segment elevation acute coronary syndromes: subgroup analysis from the ACUITY trial. Ann Emerg Med. 2011;57(3):204-212. e1. 6. Exclude - no active comparator. [pmid: 20952100].
Diez JG, Medina HM, Cheong BY, et al. Safety of enoxaparin versus unfractionated heparin during percutaneous coronary intervention. Tex Heart Inst J. 2009;36(2):98-103. Exclude - no outcomes of interest. [pmid: 19436801].
Dobesh PP, Lanfear SL, Abu-Shanab JR, et al. Outcomes with changes in prescribing of glycoprotein IIb/IIIa inhibitors in PCI. Ann Pharmacother. 2003;37(10):1375-80. Exclude - no active comparator. [pmid: 14519056].
Doggrell S. Can bivalirudin and provisional GP IIb/IIIa blockade REPLACE heparin and planned glycoprotein IIb/IIIa blockade during percutaneous coronary intervention?. Expert Opin Pharmacother. 2003;4(8):1431-3. Exclude - not a Clinical Study. [pmid: 12877649].
Doggrell SA. Warfarin and aspirin give more benefit than aspirin alone but also more bleeding after myocardial infarction. Expert Opin Pharmacother. 2003;4(4):587-90. Exclude - not a Clinical Study. [pmid: 12667121].
Doggrell SA. Aspirin and esomeprazole are superior to clopidogrel in preventing recurrent ulcer bleeding. Expert Opin Pharmacother. 2005;6(7):1253-6. Exclude - not a Clinical Study. [pmid: 15957977].
Dokainish H, Pillai M, Murphy SA, et al. Prognostic implications of elevated troponin in patients with suspected acute coronary syndrome but no critical epicardial coronary disease: a TACTICS-TIMI-18 substudy. J Am Coll Cardiol. 2005;45(1):19-24. Exclude - no active comparator. [pmid: 15629367].
Doll JA, Nikolsky E, Stone GW, et al. Outcomes of patients with coronary artery perforation complicating percutaneous coronary intervention and correlations with the type of adjunctive antithrombotic therapy: pooled analysis from REPLACE-2, ACUITY, and HORIZONS-AMI trials. J Interv Cardiol. 2009;22(5):453-9. Exclude - no active comparator. [pmid: 19702677].
Don CW, Roe MT, Li S, et al. Temporal trends and practice variations in clopidogrel loading doses in patients with non-ST-segment elevation myocardial infarction, from the National Cardiovascular Data Registry. Am Heart J. 2011;161(4):689-97. Exclude - no active comparator. [pmid: 21473967].
Doucet S, Malekianpour M, Theroux P, et al. Randomized trial comparing intravenous nitroglycerin and heparin for treatment of unstable angina secondary to restenosis after coronary artery angioplasty. Circulation. 2000;101(9):955-61. Exclude - no active comparator. [pmid: 10704160].
Doughty M, Mehta R, Bruckman D, et al. Acute myocardial infarction in the young--The University of Michigan experience. Am Heart J. 2002;143(1):56-62. Exclude - no active comparator. [pmid: 11773912].
Douglas IJ, Evans SJ, Hingorani AD, et al. Clopidogrel and interaction with proton pump inhibitors: comparison between cohort and within person study designs. BMJ. 2012;345:e4388. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22782731].
Doven O, Akkus MN, Camsari A, et al. Impact of invasive strategy for the management of patients with cardiogenic shock after acute myocardial infarction. Coron Artery Dis. 2004;15(6):361-6. Exclude - no active comparator. [pmid: 15346095].
Doyle F, De La Harpe D, McGee H, et al. Gender differences in the presentation and management of acute coronary syndromes: a national sample of 1365 admissions. Eur J Cardiovasc Prev Rehabil. 2005;12(4):376-9. Exclude - no active comparator. [pmid: 16079646].
Dudek D, Rakowski T, Legutko J, et al. Efficacy and safety of percutaneous coronary interventions in patients with non ST segment elevation acute coronary syndrome in catheterisation laboratory without on-site surgical back-up. Kardiol Pol. 2003;58(5):356-65. discussion: 365. Exclude - no active comparator. [pmid: 14523483].
Dumaine R, Gibson CM, Murphy SA, et al. Association of a history of systemic hypertension with mortality, thrombotic, and bleeding complications following non-ST-segment elevation acute coronary syndrome. J Clin Hypertens (Greenwich). 2006;8(5):315-22. Exclude - not a Clinical Study. [pmid: 16687939].
Durand-Zaleski I, Bertrand M. The value of clopidogrel versus aspirin in reducing atherothrombotic events: the CAPRIE study. Pharmacoeconomics. Suppl 4. 2004;22:19-27. Exclude - no outcomes of interest. [pmid: 15876009].
Dyke CM, Bhatia D, Lorenz TJ, et al. Immediate coronary artery bypass surgery after platelet inhibition with eptifibatide: results from PURSUIT. Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrelin Therapy. Ann Thorac Surg. 2000;70(3):866-71. discussion 871-2. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11016325].
Dziewierz A, Siudak Z, Dykla D, et al. Management and mortality in patients with non-ST-segment elevation vs. ST-segment elevation myocardial infarction. Data from the Malopolska Registry of Acute Coronary Syndromes. Kardiol Pol. 2009;67(2):115-20. discussion 121-2. Exclude - no active comparator. [pmid: 19288373].
Dziewierz A, Siudak Z, Rakowski T, et al. More aggressive pharmacological treatment may improve clinical outcome in patients with non-ST-elevation acute coronary syndromes treated conservatively. Coron Artery Dis. 2007;18(4):299-303. Exclude - no outcomes of interest. [pmid: 17496494].
Ebbinghaus J, Maier B, Schoeller R, et al. Routine early invasive strategy and in-hospital mortality in women with non-ST-elevation myocardial infarction Results from the Berlin Myocardial Infarction Registry (BMIR). Int J Cardiol. 2011. Exclude - no active comparator. [pmid: 21277642].
Ebrahimi R, Dyke C, Mehran R, et al. Outcomes following pre-operative clopidogrel administration in patients with acute coronary syndromes undergoing coronary artery bypass surgery: the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. J Am Coll Cardiol. 2009;53(21):1965-72. Exclude - no outcomes of interest. [pmid: 19460609].
Eccleston D, Patching K, Holt G, et al. Long-term outcomes are better with long-term dual anti-platelet therapy after drug-eluting stents: Insights from a multi-centre Australian study. Heart Lung Circ. 2011;20:S135. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Echols MR, Mahaffey KW, Banerjee A, et al. Racial differences among high-risk patients presenting with non-ST-segment elevation acute coronary syndromes (results from the SYNERGY trial). Am J Cardiol. 2007;99(3):315-21. Exclude - no outcomes of interest. [pmid: 17261389].
Eikelboom JW, Anand SS, Mehta SR, et al. Prognostic significance of thrombocytopenia during hirudin and heparin therapy in acute coronary syndrome without ST elevation: Organization to Assess Strategies for Ischemic Syndromes (OASIS-2)study. Circulation. 2001;103(5):643-50. Exclude - no outcomes of interest. [pmid: 11156874].
Eikelboom JW, Mehta SR, Anand SS, et al. Adverse impact of bleeding on prognosis in patients with acute coronary syndromes. Circulation. 2006;114(8):774-82. Exclude - no active comparator. [pmid: 16908769].
Eisenberg MJ, Okrainec K, Lefkovits J, et al. Medical therapy in patients undergoing percutaneous coronary intervention: results from the ROSETTA registry. Can J Cardiol. 2003;19(9):1009-15. Exclude - no active comparator. [pmid: 12915928].
Eisenstein EL, Anstrom KJ, Kong DF, et al. Clopidogrel use and long-term clinical outcomes after drug-eluting stent implantation. JAMA. 2007;297(2):159-68. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17148711].
Elbarasi E, Goodman SG, Yan RT, et al. Management patterns of non-ST segment elevation acute coronary syndromes in relation to prior coronary revascularization. Am Heart J. 2010;159(1):40-6. Exclude - no active comparator. [pmid: 20102865].
Elbarouni B, Elmanfud O, Yan RT, et al. Temporal trend of in-hospital major bleeding among patients with non ST-elevation acute coronary syndromes. Am Heart J. 2010;160(3):420-7. Exclude - no active comparator. [pmid: 20826248].
El-Jack S, Kerr A. Secondary prevention in coronary artery disease patients in South Auckland: moving targets and the current treatment gap. N Z Med J. 2003;116(1185):U664. Exclude -no active comparator. [pmid: 14615806].
Ellis SG, Lincoff AM, Miller D, et al. Reduction in complications of angioplasty with abciximab occurs largely independently of baseline lesion morphology. EPIC and EPILOG Investigators. Evaluation of 7E3 for the Prevention of Ischemic Complications. Evaluation of PTCA To Improve Long-term Outcome with abciximab GPIIb/IIIa Receptor Blockade. J Am Coll Cardiol. 1998;32(6):1619-23. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9822087].
El-Omar MM, Dangas G, Stone GW. A Comparison of Tirofiban and Abciximab in Patients Undergoing Coronary Stent Implantation: Rationale, Design, and Results of the TARGET Trial. Curr Interv Cardiol Rep. 2001;3(4):336-345. Exclude -not a Clinical Study. [pmid: 11696300].
Erdem G, Bakhai A, Taneja AK, et al. Causes and pattern of death of non ST elevation acute coronary syndromes: Ten year outcome of prospective registry of acute ischaemic syndromes in the UK (PRAIS-UK). Eur Heart J. 2011;32:736. Exclude - no active comparator.
Ernofsson M, Strekerud F, Toss H, et al. Low-molecular weight heparin reduces the generation and activity of thrombin in unstable coronary artery disease. Thromb Haemost. 1998;79(3):491-4. Exclude - no outcomes of interest. [pmid: 9531028].
Ernst FR, Johnston S, Curkendall S, et al. Effect of early clopidogrel discontinuation on rehospitalization in acute coronary syndrome: results from two distinct patient populations. Am J Health Syst Pharm. 2011;68(11):1015-24. Exclude -no active comparator. [pmid: 21593230].
Exaire JE, Butman SM, Ebrahimi R, et al. Provisional glycoprotein IIb/IIIa blockade in a randomized investigation of bivalirudin versus heparin plus planned glycoprotein IIb/IIIa inhibition during percutaneous coronary intervention: predictors and outcome in the Randomized Evaluation in Percutaneous coronary intervention Linking Angiomax to Reduced Clinical Events (REPLACE)-2 trial. Am Heart J. 2006;152(1):157-63. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16824849].
Farkouh ME, Kirshner H, Harrington RA, et al. Comparison of lumiracoxib with naproxen and ibuprofen in the Therapeutic Arthritis Research and Gastrointestinal Event Trial (TARGET), cardiovascular outcomes: randomised controlled trial. Lancet. 2004;364(9435):675-84. Exclude - no active comparator. [pmid: 15325832].
Federspiel JJ, Stearns SC, Reiter KL, et al. Disappearing and reappearing differences in drug-eluting stent use by race. J Eval Clin Pract. 2011. Exclude - no active comparator. [pmid: 22132712].
Feldman DN, Fakorede F, Minutello RM, et al. Efficacy of high-dose clopidogrel treatment (600 mg) less than two hours before percutaneous coronary intervention in patients with non-ST-segment elevation acute coronary syndromes. Am J Cardiol. 2010;105(3):323-32. Exclude - no outcomes of interest. [pmid: 20102943].
Feldman DN, Minutello RM, Bergman G, et al. Efficacy and safety of bivalirudin in patients receiving clopidogrel therapy after diagnostic angiography for percutaneous coronary intervention in acute coronary syndromes. Catheter Cardiovasc Interv. 2010;76(4):513-24. Exclude - no outcomes of interest. [pmid: 20882655].
Feldman DN, Wong SC, Bergman G, et al. Frequency and outcomes of provisional glycoprotein IIb/IIIa blockade in patients receiving bivalirudin during percutaneous coronary intervention. J Invasive Cardiol. 2009;21(6):258-63. Exclude - no outcomes of interest. [pmid: 19494400].
Feldman DN, Wong SC, Gade CL, et al. Impact of bivalirudin on outcomes after percutaneous coronary revascularization with drug-eluting stents. Am Heart J. 2007;154(4):695-701. Exclude -no outcomes of interest. [pmid: 17892994].
Feng D, McKenna C, Murillo J, et al. Effect of aspirin dosage and enteric coating on platelet reactivity. Am J Cardiol. 1997;80(2):189-93. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9230157].
Ferguson JJ. Combining low-molecular-weight heparin and glycoprotein IIb/IIIa antagonists for the treatment of acute coronary syndromes: the NICE 3 story. National Investigators Collaborating on Enoxaparin. J Invasive Cardiol. Suppl E. 2000;12:E10-3. discussion E25-8. Exclude - not a Clinical Study. [pmid: 11156723].
Ferguson JJ, Antman EM, Bates ER, et al. Combining enoxaparin and glycoprotein IIb/IIIa antagonists for the treatment of acute coronary syndromes: final results of the National Investigators Collaborating on Enoxaparin-3 (NICE-3) study. Am Heart J. 2003;146(4):628-34. Exclude - no outcomes of interest. [pmid: 14564315].
Ferguson JJ 3rd, Gonzalez ER, Kannel WB, et al. Clinical safety and efficacy of clopidogrel--implications of the Clopidogrel versus Aspirin in Patients at Risk of Ischemic Events (CAPRIE) study for future management of atherosclerotic disease. Clin Ther. Suppl B. 1998;20:B42-53. Exclude - not a Clinical Study. [pmid: 9589830].
Fermann GJ, Raja AS, Peterson ED, et al. Early treatment for non-ST-segment elevation acute coronary syndrome is associated with appropriate discharge care. Clin Cardiol. 2009;32(9):519-25. Exclude - no active comparator. [pmid: 19743495].
Fernandes LS, Tcheng JE, O'Shea JC, et al. Is glycoprotein IIb/IIIa antagonism as effective in women as in men following percutaneous coronary intervention?. Lessons from the ESPRIT study. J Am Coll Cardiol. 2002;40(6):1085-91. Exclude - no active comparator. [pmid: 12354432].
Fernando H, Bassler N, Habersberger J, et al. Randomised double blind placebo controlled crossover study to determine the effects of esomeprazole on the inhibition of platelet function by clopidogrel. Heart Lung Circ. 2011;20:S214-S215. Exclude - no outcomes of interest.
Ferrari E, Benhamou M, Cerboni P, et al. Coronary syndromes following aspirin withdrawal: a special risk for late stent thrombosis. J Am Coll Cardiol. 2005;45(3):456-9. Exclude - no active comparator. [pmid: 15680728].
Ferreira J, Monteiro P, Mimoso J. National Registry of Acute Coronary Syndromes: results of the hospital phase in 2002. Rev Port Cardiol. 2004;23(10):1251-72. Exclude - no active comparator. [pmid: 15641292].
Ferreiro JL, Angiolillo DJ. Diabetes and antiplatelet therapy in acute coronary syndrome. Circulation. 2011;123(7):798-813. Exclude -not a Clinical Study. [pmid: 21343595].
Ferreiros ER, Kevorkian R, Fuselli JJ, et al. First national survey on management strategies in non ST-elevation acute ischaemic syndromes in Argentina. Results of the STRATEG-SIA study. Eur Heart J. 2002;23(13):1021-9. Exclude - no active comparator. [pmid: 12093054].
Ferrieres J, Bakhai A, Iniguez A, et al. Treatment patterns in patients with acute coronary syndrome undergoing percutaneous coronary intervention. Curr Med Res Opin. 2010;26(9):2193-202. Exclude - no active comparator. [pmid: 20673167].
Ferrieres J, Sartral M, Tcherny-Lessenot S, et al. A prospective observational study of treatment practice patterns in acute coronary syndrome patients undergoing percutaneous coronary intervention in Europe. Arch Cardiovasc Dis. 2011;104(2):104-14. Exclude - no active comparator. [pmid: 21402345].
Ferro M, Crivello R, Rizzotti M. Comparison of subcutaneous calcium heparin and acetylsalicylic acid in the prevention of ischemic events and death after myocardial infarction: a randomized trial in a consecutive series of 90 patients. Heart Dis. 2000;2(4):278-81. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11728269].
Figueras J, Domingo E, Hermosilla E. Long-term prognosis of clinical variables, coronary reserve and extent of coronary disease in patients with a first episode of unstable angina. Int J Cardiol. 2005;98(1):27-34. Exclude - no active comparator. [pmid: 15676162].
Filippi A, D'Ambrosio G, Giustini SE, et al. Pharmacological treatment after acute myocardial infarction from 2001 to 2006: a survey in Italian primary care. J Cardiovasc Med (Hagerstown). 2009;10(9):714-8. Exclude - no active comparator. [pmid: 19465867].
Fintel DJ, Ledley GS. Management of patients with non-ST-segment elevation acute coronary syndromes: insights from the PURSUIT trial. Clin Cardiol. Suppl 5. 2000;23:V1-12. Exclude - not a Clinical Study. [pmid: 11019716].
Fiore L, Ezekowitz M, Bromphy M, et al. Aspirin monotherapy is as effective as aspirin plus warfarin for reducing mortality after myocardial infarction. Evid-based Cardiovasc Med. 2002;6(4):133-134. Exclude - not a Clinical Study.
Fiore LD, Ezekowitz MD, Brophy MT, et al. Department of Veterans Affairs Cooperative Studies Program Clinical Trial comparing combined warfarin and aspirin with aspirin alone in survivors of acute myocardial infarction: primary results of the CHAMP study. Circulation. 2002;105(5):557-63. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11827919].
Fiore LD, Ezekowitz MD, Brophy MT, et al. Warfarin combined with low dose aspirin in myocardial infarction did not provide clinical benefit beyond that of aspirin alone. Evid-Based Med. 2002;7(5):140. Exclude - not a Clinical Study.
Fitchett D, Welsh R, Langer A, et al. Enoxaparin and percutaneous coronary intervention: a Canadian perspective. Can J Cardiol. 2005;21(6):501-7. Exclude - no active comparator. [pmid: 15917879].
Fiutowski M, Waszyrowski T, Krzeminska-Pakula M, et al. Clinical presentation and pharmacological therapy in patients with cardiogenic pulmonary oedema. Kardiol Pol. 2004;61(12):561-9. discussion 570. Exclude - no active comparator. [pmid: 15815756].
Fjeldheim R, Welch J, Koo J. A retrospective review of short-term outcomes after switching patients from clopidogrel to alternative antiplatelet therapy. Hosp Pharm. 2009;44(12):1103-1111. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Flather MD, Babalis D, Booth J, et al. Cluster-randomized trial to evaluate the effects of a quality improvement program on management of non-ST-elevation acute coronary syndromes: The European Quality Improvement Programme for Acute Coronary Syndromes (EQUIP-ACS). Am Heart J. 2011;162(4):700-707 e1. Exclude -no active comparator. [pmid: 21982663].
Flather MD, Weitz JI, Yusuf S, et al. Reactivation of coagulation after stopping infusions of recombinant hirudin and unfractionated heparin in unstable angina and myocardial infarction without ST elevation: results of a randomized trial. OASIS Pilot Study Investigators. Organization to Assess Strategies for Ischemic++ Syndromes. Eur Heart J. 2000;21(17):1473-81. Exclude -no outcomes of interest. [pmid: 10952840].
Foody JM, Ferdinand FD, Galusha D, et al. Patterns of secondary prevention in older patients undergoing coronary artery bypass grafting during hospitalization for acute myocardial infarction. Circulation. Suppl 1. 2003;108:II24-8. Exclude - no active comparator. [pmid: 12970203].
Fosbol EL, Wang T, Piccini J, et al. Comparative effectiveness and safety of antithrombotic therapy in older patients with atrial fibrillation and non-st elevation myocardial infarction (NSTEMI) treated with coronary stenting. Journal of the American College of Cardiology. 2012;59(13):E1866. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Foussas S, Alexopoulos D, Stefanadis C, et al. Antiplatelet is superior to anticoagulant treatment after coronary stenting: fewer coronary and other events within 30 days after stenting. Angiology. 2000;51(4):289-94. Exclude - no active comparator. [pmid: 10778998].
Foussas SG, Zairis MN, Tsirimpis VG, et al. The impact of aspirin resistance on the long-term cardiovascular mortality in patients with non-ST segment elevation acute coronary syndromes. Clin Cardiol. 2009;32(3):142-7. Exclude - no active comparator. [pmid: 19301289].
Fox KA. r-hirudin in unstable angina pectoris. Rationale and preliminary data from the APT pilot study. Eur Heart J. Suppl D. 1995;16:28-32. Exclude - no active comparator. [pmid: 8542869].
Fox KA. Implications of the Organization to Assess Strategies for Ischemic Syndromes-2 (OASIS-2) study and the results in the context of other trials. Am J Cardiol. 1999;84(5A):26M-31M. Exclude - not a Clinical Study. [pmid: 10505540].
Fox KA, Carruthers K, Steg PG, et al. Has the frequency of bleeding changed over time for patients presenting with an acute coronary syndrome? The global registry of acute coronary events. Eur Heart J. 2010;31(6):667-75. Exclude - no active comparator. [pmid: 20007159].
Fox KA, Goodman S, Bigonzi F, et al. Inter-regional differences and outcome in unstable angina; analysis of the international ESSENCE trial. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q-wave Coronary Events. Eur Heart J. 2000;21(17):1433-9. Exclude - no outcomes of interest. [pmid: 10952835].
Fox KA, Poole-Wilson PA, Henderson RA, et al. Interventional versus conservative treatment for patients with unstable angina or non-ST-elevation myocardial infarction: the British Heart Foundation RITA 3 randomised trial. Randomized Intervention Trial of unstable Angina. Lancet. 2002;360(9335):743-51. Exclude -no active comparator. [pmid: 12241831].
Fox KAA, Poole-Wilson A, Henderson R, et al. Interventional strategy is better than an expectant strategy for unstable coronary artery disease. Evid-based Cardiovasc Med. 2003;7(1):5-7. Exclude - not a Clinical Study.
Frakes MA. Introducing glycoprotein IIb/IIIa inhibitor therapy to air medical practice. Air Med J. 2001;20(6):23-5. Exclude - not a Clinical Study. [pmid: 11692135].
Francois SJ, Erne P, Urban P, et al. Impact of a normal or non-specific admission ECG on the treatment and early outcome of patients with myocardial infarction in Swiss hospitals between 2003 and 2008. Swiss Med Wkly. 2010;140:w13078. Exclude - no active comparator. [pmid: 20799102].
Franklin K, Goldberg RJ, Spencer F, et al. Implications of diabetes in patients with acute coronary syndromes. The Global Registry of Acute Coronary Events. Arch Intern Med. 2004;164(13):1457-63. Exclude -no active comparator. [pmid: 15249356].
Freeman RV, Mehta RH, Al Badr W, et al. Influence of concurrent renal dysfunction on outcomes of patients with acute coronary syndromes and implications of the use of glycoprotein IIb/IIIa inhibitors. J Am Coll Cardiol. 2003;41(5):718-24. Exclude - no active comparator. [pmid: 12628712].
Frilling B, Zahn R, Fraiture B, et al. Comparison of efficacy and complication rates after percutaneous coronary interventions in patients with and without renal insufficiency treated with abciximab. Am J Cardiol. 2002;89(4):450-2. Exclude - no outcomes of interest. [pmid: 11835927].
Fuchs J, Cannon CP. Hirulog in the treatment of unstable angina. Results of the Thrombin Inhibition in Myocardial Ischemia (TIMI) 7 trial. Circulation. 1995;92(4):727-33. Exclude - no active comparator. [pmid: 7641350].
Fuchs S, Kornowski R, Mehran R, et al. Clinical outcomes following “rescue” administration of abciximab in patients undergoing percutaneous coronary angioplasty. J Invasive Cardiol. 2000;12(10):497-501. Exclude -not a Clinical Study. [pmid: 11022207].
Furman MI, Kereiakes DJ, Krueger LA, et al. Leukocyte-platelet aggregation, platelet surface P-selectin, and platelet surface glycoprotein IIIa after percutaneous coronary intervention: Effects of dalteparin or unfractionated heparin in combination with abciximab. Am Heart J. 2001;142(5):790-8. Exclude - no outcomes of interest. [pmid: 11685164].
Gabriel Steg P, Iung B, Feldman LJ, et al. Determinants of use and outcomes of invasive coronary procedures in acute coronary syndromes: results from ENACT. Eur Heart J. 2003;24(7):613-22. Exclude - no active comparator. [pmid: 12657219].
Gaglia MA Jr., Torguson R, Hanna N, et al. Relation of proton pump inhibitor use after percutaneous coronary intervention with drug-eluting stents to outcomes. Am J Cardiol. 2010;105(6):833-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 20211327].
Gaglia MA Jr., Torguson R, Xue Z, et al. Outcomes of patients with acute myocardial infarction from a saphenous vein graft culprit undergoing percutaneous coronary intervention. Catheter Cardiovasc Interv. 2011;78(1):23-9. Exclude - no active comparator. [pmid: 21061247].
Galatro KM, Adams PC, Cohen M, et al. Bleeding Complications and INR Control of Combined Warfarin and Low-Dose Aspirin Therapy in Patients with Unstable Angina and Non-Q-Wave Myocardial Infarction. J Thromb Thrombolysis. 1998;5(3):249-255. Exclude - no active comparator. [pmid: 10767121].
Gangasani SR, O'Neill WW, Grines CL. Role of prolonged intravenous heparin in unstable angina patients prior to coronary angioplasty. J Interv Cardiol. 2001;14(4):423-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12053496].
Gao F, Zhou YJ, Wang ZJ, et al. Comparison of different antithrombotic regime in patients with atrial fibrillation undergoing drug-eluting stent implantation. EuroIntervention. 2010;6. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Garachemani AR, Fleisch M, Windecker S, et al. Heparin and coumadin versus acetylsalicylic acid for prevention of restenosis after coronary angioplasty. Catheter Cardiovasc Interv. 2002;55(3):315-20. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11870934].
Garcia Rodriguez LA, Cea-Soriano L, Johansson S. Concomitant use of clopidogrel and proton pump inhibitors is not associated with an increased risk of coronary events. Eur Heart J. 2011;32:415. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Garcia Rodriguez LA, Martin-Merino E, Johansson S. Discontinuation of low-dose acetylsalicylic acid treatment for secondary prevention of cardiovascular outcomes: Incidence and predictors. Value Health. 2010;13(7):A344. Exclude - not original peer-reviewed data.
Garcia-Castillo A, Jerjes-Sanchez C, Martinez Bermudez P, et al. Mexican Registry of Acute Coronary Syndromes. Arch Cardiol Mex. Suppl 1. 2005;75:S6-32. Exclude - no active comparator. [pmid: 16001714].
Ge J, Han Y, Jiang H, et al. RACTS: a prospective randomized antiplatelet trial of cilostazol versus ticlopidine in patients undergoing coronary stenting: long-term clinical and angiographic outcome. J Cardiovasc Pharmacol. 2005;46(2):162-6. Exclude - no active comparator. [pmid: 16044027].
George BJ, Eckart RE, Shry EA, et al. Glycoprotein IIb/IIIa inhibitor-associated thrombocytopenia: clinical predictors and effect on outcome. Cardiology. 2004;102(4):184-7. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15452390].
Gibney EM, Casebeer AW, Schooley LM, et al. Cardiovascular medication use after coronary bypass surgery in patients with renal dysfunction: a national Veterans Administration study. Kidney Int. 2005;68(2):826-32. Exclude - no active comparator. [pmid: 16014062].
Gibson CM, Goel M, Cohen DJ, et al. Six-month angiographic and clinical follow-up of patients prospectively randomized to receive either tirofiban or placebo during angioplasty in the RESTORE trial. Randomized Efficacy Study of Tirofiban for Outcomes and Restenosis. J Am Coll Cardiol. 1998;32(1):28-34. Exclude - no outcomes of interest. [pmid: 9669245].
Gibson CM, Mega JL, Burton P, et al. Rationale and design of the Anti-Xa therapy to lower cardiovascular events in addition to standard therapy in subjects with acute coronary syndrome-thrombolysis in myocardial infarction 51 (ATLAS-ACS 2 TIMI 51) trial: a randomized, double-blind, placebo-controlled study to evaluate the efficacy and safety of rivaroxaban in subjects with acute coronary syndrome. Am Heart J. 2011;161(5):815-821 e6. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21570509].
Gibson CM, Singh KP, Murphy SA, et al. Association between duration of tirofiban therapy before percutaneous intervention and tissue level perfusion (a TACTICS-TIMI 18 substudy). Am J Cardiol. 2004;94(4):492-4. Exclude - no outcomes of interest. [pmid: 15325937].
Gibson CM, Ten Y, Murphy SA, et al. Association of prerandomization anticoagulant switching with bleeding in the setting of percutaneous coronary intervention (A REPLACE-2 analysis). Am J Cardiol. 2007;99(12):1687-90. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17560876].
Giglioli C, Cecchi E, Landi D, et al. Early invasive strategy and outcomes of non-ST-elevation acute coronary syndrome patients: is time really the major determinant?. Intern Emerg Med. 2011. Exclude - no active comparator. [pmid: 21647690].
Gilard M, Arnaud B, Cornily JC, et al. Influence of omeprazole on the antiplatelet action of clopidogrel associated with aspirin: the randomized, double-blind OCLA (Omeprazole CLopidogrel Aspirin) study. J Am Coll Cardiol. 2008;51(3):256-60. Exclude - no outcomes of interest. [pmid: 18206732].
Gilchrist IC, Berkowitz SD, Thompson TD, et al. Heparin dosing and outcome in acute coronary syndromes: the GUSTO-IIb experience. Global Use of Strategies to Open Occluded Coronary Arteries. Am Heart J. 2002;144(1):73-80. Exclude - no active comparator. [pmid: 12094191].
Girasis C, Garg S, Raber L, et al. SYNTAX score and Clinical SYNTAX score as predictors of very long-term clinical outcomes in patients undergoing percutaneous coronary interventions: a substudy of SIRolimus-eluting stent compared with pacliTAXel-eluting stent for coronary revascularization (SIRTAX) trial. Eur Heart J. 2011;32(24):3115-27. Exclude - no active comparator. [pmid: 21951630].
Glaser R, Glick HA, Herrmann HC, et al. The role of risk stratification in the decision to provide upstream versus selective glycoprotein IIb/IIIa inhibitors for acute coronary syndromes: a cost-effectiveness analysis. J Am Coll Cardiol. 2006;47(3):529-37. Exclude - not a Clinical Study. [pmid: 16458131].
Glauser J, Emerman CL, Bhatt DL, et al. Platelet aspirin resistance in ED patients with suspected acute coronary syndrome. Am J Emerg Med. 2010;28(4):440-4. Exclude - no active comparator. [pmid: 20466222].
Goch A, Misiewicz P, Rysz J, et al. The clinical manifestation of myocardial infarction in elderly patients. Clin Cardiol. 2009;32(6):E46-51. Exclude - no active comparator. [pmid: 19382276].
Goldman LE, Okrainec K, Eisenberg MJ, et al. Six-month outcomes after single- and multi-lesion percutaneous coronary intervention: results from the ROSETTA registry. Can J Cardiol. 2004;20(6):608-12. Exclude - no active comparator. [pmid: 15152290].
Goldschmidt-Clermont PJ, Schulman SP, Bray PF, et al. Refining the treatment of women with unstable angina--a randomized, double-blind, comparative safety and efficacy evaluation of Integrelin versus aspirin in the management of unstable angina. Clin Cardiol. 1996;19(11):869-74. Exclude - no outcomes of interest. [pmid: 8914780].
Goldstein RE, Andrews M, Hall WJ, et al. Marked reduction in long-term cardiac deaths with aspirin after a coronary event. Multicenter Myocardial Ischemia Research Group. J Am Coll Cardiol. 1996;28(2):326-30. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8800105].
Goodman SG, Barr A, Sobtchouk A, et al. Low molecular weight heparin decreases rebound ischemia in unstable angina or non-Q-wave myocardial infarction: the Canadian ESSENCE ST segment monitoring substudy. J Am Coll Cardiol. 2000;36(5):1507-13. Exclude - no outcomes of interest. [pmid: 11079650].
Goodman SG, Fitchett D, Armstrong PW, et al. Enoxaparin is safer and more effective than heparin in acute coronary syndrome. Evid-based Cardiovasc Med. 2003;7(3):129-130. Exclude - not a Clinical Study.
Goodman SG, Huang W, Yan AT, et al. The expanded Global Registry of Acute Coronary Events: baseline characteristics, management practices, and hospital outcomes of patients with acute coronary syndromes. Am Heart J. 2009;158(2):193-201. e1. 5. Exclude - no active comparator. [pmid: 19619694].
Goto S, Bhatt DL, Rother J, et al. Prevalence, clinical profile, and cardiovascular outcomes of atrial fibrillation patients with atherothrombosis. Am Heart J. 2008;156(5):855-63. 863 e2. Exclude - no active comparator. [pmid: 19061698].
Graber MA, Dachs R, Darby-Stewart A. Is prasugrel more effective than clopidogrel in patients with acute coronary syndrome scheduled for PCI?. Am Fam Physician. 2008;78(11):1252-3. Exclude - not a Clinical Study. [pmid: 19069017].
Graham MM, Ghali WA, Faris PD, et al. Sex differences in the prognostic importance of diabetes in patients with ischemic heart disease undergoing coronary angiography. Diabetes Care. 2003;26(11):3142-7. Exclude - no active comparator. [pmid: 14578252].
Granada JF, Kleiman NS. Therapeutic use of intravenous eptifibatide in patients undergoing percutaneous coronary intervention: acute coronary syndromes and elective stenting. Am J Cardiovasc Drugs. 2004;4(1):31-41. Exclude -not a Clinical Study. [pmid: 14967064].
Granger CB, Miller JM, Bovill EG, et al. Rebound increase in thrombin generation and activity after cessation of intravenous heparin in patients with acute coronary syndromes. Circulation. 1995;91(7):1929-35. Exclude - no outcomes of interest. [pmid: 7895349].
Granger CB, Steg PG, Peterson E, et al. Medication performance measures and mortality following acute coronary syndromes. Am J Med. 2005;118(8):858-65. Exclude - no active comparator. [pmid: 16084178].
Green B, Greenwood M, Saltissi D, et al. Dosing strategy for enoxaparin in patients with renal impairment presenting with acute coronary syndromes. Br J Clin Pharmacol. 2005;59(3):281-90. Exclude - no active comparator. [pmid: 15752373].
Greenbaum AB, Harrington RA, Hudson MP, et al. Therapeutic value of eptifibatide at community hospitals transferring patients to tertiary referral centers early after admission for acute coronary syndromes. PURSUIT Investigators. J Am Coll Cardiol. 2001;37(2):492-8. Exclude - no outcomes of interest. [pmid: 11216968].
Gregorini L, Marco J, Fajadet J, et al. Ticlopidine and aspirin pretreatment reduces coagulation and platelet activation during coronary dilation procedures. J Am Coll Cardiol. 1997;29(1):13-20. Exclude - no outcomes of interest. [pmid: 8996289].
Gruberg L, Milo S, Ben Tzvi M, et al. Comparison of bypass surgery and stenting for the treatment of multivessel disease: results from the ARTS trial in Israel. Isr Med Assoc J. 2003;5(8):539-42. Exclude - no active comparator. [pmid: 12929288].
Gruberg L, Suleiman M, Kapeliovich M, et al. Glycoprotein IIb/IIIa inhibitors during rescue percutaneous coronary intervention in acute myocardial infarction. J Invasive Cardiol. 2006;18(2):59-62. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16446517].
Guerrero M, Harjai K, Stone GW, et al. Usefulness of the presence of peripheral vascular disease in predicting mortality in acute myocardial infarction patients treated with primary angioplasty (from the Primary Angioplasty in Myocardial Infarction Database). Am J Cardiol. 2005;96(5):649-54. Exclude - no active comparator. [pmid: 16125488].
Gulati M, Patel S, Jaffe AS, et al. Impact of contemporary guideline compliance on risk stratification models for acute coronary syndromes in The Registry of Acute Coronary Syndromes. Am J Cardiol. 2004;94(7):873-8. Exclude - no active comparator. [pmid: 15464668].
Gullov AL, Koefoed BG, Petersen P. Bleeding during warfarin and aspirin therapy in patients with atrial fibrillation: the AFASAK 2 study. Atrial Fibrillation Aspirin and Anticoagulation. Arch Intern Med. 1999;159(12):1322-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10386508].
Gum PA, Thamilarasan M, Watanabe J, et al. Aspirin use and all-cause mortality among patients being evaluated for known or suspected coronary artery disease: A propensity analysis. JAMA. 2001;286(10):1187-94. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11559263].
Gumina RJ, Yang EH, Sandhu GS, et al. Survival benefit with concomitant clopidogrel and glycoprotein IIb/IIIa inhibitor therapy at ad hoc percutaneous coronary intervention. Mayo Clin Proc. 2008;83(9):995-1001. Exclude -no outcomes of interest. [pmid: 18775199].
Gupta V, Aravamuthan BR, Baskerville S, et al. Reduction of subacute stent thrombosis (SAT) using heparin-coated stents in a large-scale, real world registry. J Invasive Cardiol. 2004;16(6):304-10. Exclude - no active comparator. [pmid: 15155999].
Gurbel PA, Tantry US, Kereiakes DJ. Interaction between clopidogrel and proton-pump inhibitors and management strategies in patients with cardiovascular diseases. Drug Healthc Patient Saf. 2010;2(1):233-240. Exclude - not a Clinical Study. [pmid: 21701635].
Gurfinkel EP, Manos EJ, Mejail RI, et al. Low molecular weight heparin versus regular heparin or aspirin in the treatment of unstable angina and silent ischemia. J Am Coll Cardiol. 1995;26(2):313-8. Exclude - no active comparator. [pmid: 7608429].
Gurfinkel EP, Santopinto J, Bozovich GE, et al. Low-molecular-weight heparin alone versus a combination of unfractionated heparin and low-molecular-weight heparin. Am Heart J. 2000;140(1):E12-8. Exclude - no active comparator. [pmid: 10874258].
Gurjeva OS, Bukhman G, Murphy S, et al. Treatment and outcomes of eastern Europeans with coronary syndromes in OPUS-TIMI 16. Int J Cardiol. 2005;100(1):101-7. Exclude - no active comparator. [pmid: 15820292].
Gurm HS, Rajagopal V, Fathi R, et al. Effectiveness and safety of bivalirudin during percutaneous coronary intervention in a single medical center. Am J Cardiol. 2005;95(6):716-21. Exclude - no outcomes of interest. [pmid: 15757596].
Hachinohe D, Jeong MH, Saito S, et al. Management of non-ST-segment elevation acute myocardial infarction in patients with chronic kidney disease (from the Korea Acute Myocardial Infarction Registry). Am J Cardiol. 2011;108(2):206-13. Exclude - no active comparator. [pmid: 21712106].
Hafner G, Rupprecht HJ, Luz M, et al. Recombinant hirudin as a periprocedural antithrombotic in coronary angioplasty for unstable angina pectoris. Eur Heart J. 1996;17(8):1207-15. Exclude - no active comparator. [pmid: 8869862].
Hai-feng L, Ming Y, Jian-ying C, et al. Platelet function and tirofiban treatment in patients with non-ST-segment elevation acute coronary syndromes following stenting. J Clin Rehab Tissue Eng Res. 2010;14(39):7285-7290. Exclude - not available in English.
Halim SA, Mulgund J, Chen AY, et al. Use of guidelines-recommended management and outcomes among women and men with low-level troponin elevation: insights from CRUSADE. Circ Cardiovasc Qual Outcomes. 2009;2(3):199-206. Exclude - no active comparator. [pmid: 20031838].
Hall M, McGettigan M, O'Callaghan P, et al. Comparison of secondary prevention of heart disease in Europe: lifestyle getting worse, therapy getting better in Ireland. Ir Med J. 2002;95(9):272-4. Exclude - no active comparator. [pmid: 12469998].
Hall P, Nakamura S, Maiello L, et al. A randomized comparison of combined ticlopidine and aspirin therapy versus aspirin therapy alone after successful intravascular ultrasound-guided stent implantation. Circulation. 1996;93(2):215-22. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8548891].
Halvorsen S, Eritsland J, Abdelnoor M, et al. Gender differences in management and outcome of acute myocardial infarctions treated in 2006-2007. Cardiology. 2009;114(2):83-8. Exclude - no outcomes of interest. [pmid: 19420934].
Hamm CW, Heeschen C, Goldmann B, et al. Benefit of abciximab in patients with refractory unstable angina in relation to serum troponin T levels. c7E3 Fab Antiplatelet Therapy in Unstable Refractory Angina (CAPTURE) Study Investigators. N Engl J Med. 1999;340(21):1623-9. Exclude - no outcomes of interest. [pmid: 10341274].
Hamon M. In hospital and 30 day outcomes in all-comer percutaneous coronary intervention with bivalirudin: Initial report of the prospective EUROVISION Registry. Hamon M, Nienaber C, Galli S, Huber K, Gulba D, Hill J, Lafont A, Cequier A, Bernstein D, Deliargyris e. J Am Coll Cardiol. 2011;58(20):B47. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Han Y, Li Y, Wang S, et al. Cilostazol in addition to aspirin and clopidogrel improves long-term outcomes after percutaneous coronary intervention in patients with acute coronary syndromes: a randomized, controlled study. Am Heart J. 2009;157(4):733-9. Exclude - no outcomes of interest. [pmid: 19332203].
Han YL, Chen JY, Xu B, et al. Real world clinical performance of the zotarolimus eluting coronary stent system in Chinese patients: a prospective, multicenter registry study. Chin Med J (Engl). 2011;124(20):3255-9. Exclude -no active comparator. [pmid: 22088517].
Han YL, Wang B, Li Y, et al. A high maintenance dose of clopidogrel improves short-term clinical outcomes in patients with acute coronary syndrome undergoing drug-eluting stent implantation. Chin Med J (Engl). 2009;122(7):793-7. Exclude - no outcomes of interest. [pmid: 19493391].
Hanania G, Cambou JP, Gueret P, et al. Management and in-hospital outcome of patients with acute myocardial infarction admitted to intensive care units at the turn of the century: results from the French nationwide USIC 2000 registry. Heart. 2004;90(12):1404-10. Exclude -no active comparator. [pmid: 15547013].
Hanefeld C, Sirtl C, Spiecker M, et al. Prehospital therapy with the platelet glycoprotein IIb/IIIa inhibitor eptifibatide in patients with suspected acute coronary syndromes: the Bochum feasibility study. Chest. 2004;126(3):935-41. Exclude - no outcomes of interest. [pmid: 15364776].
Hankey GJ. Current oral antiplatelet agents to prevent atherothrombosis. Cerebrovasc Dis. Suppl 2. 2001;11:11-7. Exclude - not a Clinical Study. [pmid: 11316917].
Hanna EB, Chen AY, Roe MT, et al. Characteristics and in-hospital outcomes of patients with non-ST-segment elevation myocardial infarction and chronic kidney disease undergoing percutaneous coronary intervention. JACC Cardiovasc Interv. 2011;4(9):1002-8. Exclude - no active comparator. [pmid: 21939940].
Hara H, Aoki J, Hashimoto T, et al. Impact of substantial 5-year dual antiplatelet therapy after sirolimus-eluting stents implantation. Circulation. 2011;124(21). Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Harjai KJ, Sattur S, Orshaw P, et al. Long-Term Safety and Effectiveness of Drug-Eluting Stents Compared to Bare Metal Stents following Successful PCI in Non-ST-Elevation Myocardial Infarction: Findings from the Guthrie Health Off-Label StenT (GHOST) Registry. J Interv Cardiol. 2011. Exclude - no active comparator. [pmid: 21981467].
Harker LA, Boissel JP, Pilgrim AJ, et al. Comparative safety and tolerability of clopidogrel and aspirin: results from CAPRIE. CAPRIE Steering Committee and Investigators. Clopidogrel versus aspirin in patients at risk of ischaemic events. Drug Saf. 1999;21(4):325-35. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10514023].
Harmsze AM, van Werkum JW, Souverein PC, et al. Combined influence of proton-pump inhibitors, calcium-channel blockers and CYP2C19*2 on on-treatment platelet reactivity and on the occurrence of atherothrombotic events after percutaneous coronary intervention. J Thromb Haemost. 2011;9(10):1892-901. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21854540].
Harrell L, Schunkert H, Palacios IF. Risk predictors in patients scheduled for percutaneous coronary revascularization. Catheter Cardiovasc Interv. 1999;48(3):253-60. Exclude - no active comparator. [pmid: 10525222].
Harrington RA, Block PC. Clopidogrel for high atherothrombotic risk, ischemic stabilization, management, and avoidance: The CHARISMA trial. ACC Cardiosource Rev J. 2006;15(9):70-75. Exclude- not a Clinical Study.
Harris S, Tepper D, Ip R. Increased mortality associated with low use of clopidogrel in patients with heart failure and acute myocardial infarction not undergoing percutaneous coronary intervention. Congestive Heart Fail. 2010;16(5):239-239. Exclude- not a Clinical Study.
Hasdai D, Behar S, Wallentin L, et al. A prospective survey of the characteristics, treatments and outcomes of patients with acute coronary syndromes in Europe and the Mediterranean basin; the Euro Heart Survey of Acute Coronary Syndromes (Euro Heart Survey ACS). Eur Heart J. 2002;23(15):1190-201. Exclude - no active comparator. [pmid: 12127921].
Hasdai D, Haim M, Behar S, et al. Acute coronary syndromes in patients with prior cerebrovascular events: lessons from the Euro-Heart Survey of Acute Coronary Syndromes. Am Heart J. 2003;146(5):832-8. Exclude - no active comparator. [pmid: 14597932].
Hasdai D, Holmes DR Jr., Criger DA, et al. Cigarette smoking status and outcome among patients with acute coronary syndromes without persistent ST-segment elevation: effect of inhibition of platelet glycoprotein IIb/IIIa with eptifibatide. The PURSUIT trial investigators. Am Heart J. 2000;139(3):454-60. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10689260].
Hasin T, Hochadel M, Gitt AK, et al. Comparison of treatment and outcome of acute coronary syndrome in patients with versus patients without diabetes mellitus. Am J Cardiol. 2009;103(6):772-8. Exclude - no outcomes of interest. [pmid: 19268730].
Hassan W, Al-Sergani H, Al Buraiki J, et al. Immediate and intermediate results of intracoronary stand-alone bolus administration of eptifibatide during coronary intervention (ICE) study. Am Heart J. 2007;154(2):345-51. Exclude -no outcomes of interest. [pmid: 17643587].
Hausleiter J, Kastrati A, Mehilli J, et al. A randomized trial comparing phosphorylcholine-coated stenting with balloon angioplasty as well as abciximab with placebo for restenosis reduction in small coronary arteries. J Intern Med. 2004;256(5):388-97. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15485474].
Hawkey CJ. NSAIDs and COX-2 inhibitors: what can we learn from large outcomes trials? The gastroenterologist's perspective. Clin Exp Rheumatol. 2001;19(6 Suppl 25):S23-30. Exclude - not a Clinical Study. [pmid: 11695247].
Hayashi F, Iijima R, Nakamura M, et al. Safety and efficacy of clopidogrel treatment in Japanese patients undergoing drug-eluting stent implantation. J Cardiol. 2010;55(1):34-40. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 20122546].
Haydar AA, Abchee AB, El H II, et al. Bleeding post coronary artery bypass surgery. Clopidogrel--cure or culprit?. J Med Liban. 2006;54(1):11-6. Exclude - no outcomes of interest. [pmid: 17044627].
Heeg BM, Peters RJ, Botteman M, et al. Long-term clopidogrel therapy in patients receiving percutaneous coronary intervention. Pharmacoeconomics. 2007;25(9):769-82. Exclude - no active comparator. [pmid: 17803335].
Heer T, Juenger C, Gitt AK, et al. Efficacy and safety of optimized antithrombotic therapy with aspirin, clopidogrel and enoxaparin in patients with non-ST segment elevation acute coronary syndromes in clinical practice. J Thromb Thrombolysis. 2009;28(3):325-32. Exclude - no outcomes of interest. [pmid: 19101783].
Heidland UE, Heintzen MP, Michel CJ, et al. Adjunctive intracoronary dipyridamole in the interventional treatment of small coronary arteries: a prospectively randomized trial. Am Heart J. 2000;139(6):1039-45. Exclude -no active comparator. [pmid: 10827385].
Helqvist S, Kelbaek H, Thuesen L, et al. Efficiency and safety of the sirolimus eluting stent in complex coronary artery lesions after cessation of dual antiplatelet therapy: fifteen months clinical outcome of the randomised Stenting Coronary Arteries in Non-stress/benestent Disease (SCANDSTENT) trial. EuroIntervention. 2007;3(3):309-314. Exclude - no outcomes of interest. [pmid: 19737710].
Henderson RA, Pocock SJ, Clayton TC, et al. Seven-year outcome in the RITA-2 trial: coronary angioplasty versus medical therapy. J Am Coll Cardiol. 2003;42(7):1161-70. Exclude - no active comparator. [pmid: 14522473].
Hendler A, Katz M, Gurevich Y, et al. 30-day outcome after percutaneous coronary angioplasty in nonagenarians: feasibility and specific considerations in different clinical settings. J Invasive Cardiol. 2011;23(12):521-4. Exclude - no active comparator. [pmid: 22147401].
Herlitz J, Holm J, Peterson M, et al. Factors associated with development of stroke long-term after myocardial infarction: experiences from the LoWASA trial. J Intern Med. 2005;257(2):201-7. Exclude - no active comparator. [pmid: 15656879].
Herrmann HC, Murphy SA, Dibattiste PM, et al. Greater benefit of early invasive strategy for unstable angina and non-ST elevation myocardial infarction in United States compared with non-United States patients: a TACTICS-TIMI 18 substudy. Crit Pathw Cardiol. 2004;3(2):95-100. Exclude - no outcomes of interest. [pmid: 18340148].
Herrmann HC, Swierkosz TA, Kapoor S, et al. Comparison of degree of platelet inhibition by abciximab versus tirofiban in patients with unstable angina pectoris and non-Q-wave myocardial infarction undergoing percutaneous coronary intervention. Am J Cardiol. 2002;89(11):1293-7. Exclude - no outcomes of interest. [pmid: 12031731].
Hillegass WB, Newman AR, Raco DL. Economic issues in glycoprotein IIb/IIIa receptor therapy. Am Heart J. 1999;138(1 Pt 2):S24-32. Exclude - not a Clinical Study. [pmid: 10385788].
Hirayama A, Kodama K, Yui Y, et al. Effect of trapidil on cardiovascular events in patients with coronary artery disease (results from the Japan Multicenter Investigation for Cardiovascular Diseases-Mochida [JMIC-M]). Am J Cardiol. 2003;92(7):789-93. Exclude - no active comparator. [pmid: 14516877].
Hirsch A, Verouden NJ, Koch KT, et al. Comparison of long-term mortality after percutaneous coronary intervention in patients treated for acute ST-elevation myocardial infarction versus those with unstable and stable angina pectoris. Am J Cardiol. 2009;104(3):333-7. Exclude - no outcomes of interest. [pmid: 19616663].
Hirsch A, Windhausen F, Tijssen JG, et al. Diverging associations of an intended early invasive strategy compared with actual revascularization, and outcome in patients with non-ST-segment elevation acute coronary syndrome: the problem of treatment selection bias. Eur Heart J. 2009;30(6):645-54. Exclude - no outcomes of interest. [pmid: 18824461].
Ho PM, Peterson ED, Wang L, et al. Incidence of death and acute myocardial infarction associated with stopping clopidogrel after acute coronary syndrome. JAMA. 2008;299(5):532-9. Exclude - no outcomes of interest. [pmid: 18252883].
Ho PM, Tsai TT, Maddox TM, et al. Delays in filling clopidogrel prescription after hospital discharge and adverse outcomes after drug-eluting stent implantation: implications for transitions of care. Circ Cardiovasc Qual Outcomes. 2010;3(3):261-6. Exclude - no active comparator. [pmid: 20407117].
Ho PM, Tsai TT, Wang TY, et al. Adverse events after stopping clopidogrel in post-acute coronary syndrome patients: Insights from a large integrated healthcare delivery system. Circ Cardiovasc Qual Outcomes. 2010;3(3):303-8. Exclude - no outcomes of interest. [pmid: 20354221].
Hoang C, Kolenic G, Kline-Rogers E, et al. Mapping geographic areas of high and low drug adherence in patients prescribed continuing treatment for acute coronary syndrome after discharge. Pharmacotherapy. 2011;31(10):927-33. Exclude - no active comparator. [pmid: 21950639].
Hochberg MC. What have we learned from the large outcomes trials of COX-2 selective inhibitors? The rheumatologist's perspective. Clin Exp Rheumatol. 2001;19(6 Suppl 25):S15-22. Exclude - not a Clinical Study. [pmid: 11695246].
Hochman JS, Reynolds HR, Dzavik V, et al. Long-Term Effects of Percutaneous Coronary Intervention of the Totally Occluded Infarct-Related Artery in the Subacute Phase After Myocardial Infarction. Circulation. 2011;124(21):2320-2328. Exclude - no active comparator. [pmid: 22025606].
Hoekstra JW, Roe MT, Peterson ED, et al. Early glycoprotein IIb/IIIa inhibitor use for non-ST-segment elevation acute coronary syndrome: patient selection and associated treatment patterns. Acad Emerg Med. 2005;12(5):431-8. Exclude - no active comparator. [pmid: 15863399].
Hong EH, Kim MY, Park JE, et al. Efficacy and safety of abciximab in combination with cilostazol in patients undergoing stenting. Int J Clin Pharmacol Ther. 2007;45(6):355-65. Exclude- no outcomes of interest. [pmid: 17595893].
Hong MK, Kim BK, Shin DH, et al. A new strategy for discontinuation of dual antiplatelet therapy: Real safety and efficacy of 3 months dual antiplatelet therapy following endeavor zotarolimuseluting stent implantation. Journal of the American College of Cardiology. 2012;59(13):E7. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item). [pmid: 22261172].
Hong YJ, Jeong MH, Lee SH, et al. The use of low molecular weight heparin to predict clinical outcome in patients with unstable angina that had undergone percutaneous coronary intervention. Korean J Intern Med. 2003;18(3):167-73. Exclude- no active comparator. [pmid: 14619386].
Houghton AR, Patel M, Hudson I. Cost implications of routine tirofiban use in the management of acute coronary syndromes. Int J Cardiol. 2001;81(2-3):257-62. Exclude - no outcomes of interest. [pmid: 11744144].
Hsieh TH, Wang JD, Tsai LM. Improving in-hospital mortality in elderly patients after acute coronary syndrome-A nationwide analysis of 97,220 patients in Taiwan during 2004-2008. Int J Cardiol. 2011. Exclude - no active comparator. [pmid: 22062897].
Huang R, Sacks J, Thai H, et al. Impact of stents and abciximab on survival from cardiogenic shock treated with percutaneous coronary intervention. Catheter Cardiovasc Interv. 2005;65(1):25-33. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15800889].
Huber TS. Anand, Yusuf, Xie, et al. The Warfarin Antiplatelet Vascular Evaluation Trial Investigators. Oral anticoagulation and antiplatelet therapy and peripheral arterial disease. N Engl J Med. 2007;357:217-227. Perspect Vasc Surg Endovasc Ther. 2008;20(4):383-384. Exclude - not a Clinical Study. [pmid: 19095638].
Huff CM, Hsu A, Cho L. In patients with acute coronary syndrome who receive a glycoprotein IIb/IIIa inhibitor during PCI, the incidence of bleeding is not increased by a high clopidogrel loading dose. Journal of the American College of Cardiology. 2012;59(13):E524. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Hulot JS, Collet JP, Cayla G, et al. CYP2C19 but not PON1 genetic variants influence clopidogrel pharmacokinetics, pharmacodynamics, and clinical efficacy in post-myocardial infarction patients. Circ Cardiovasc Interv. 2011;4(5):422-8. Exclude - no active comparator. [pmid: 21972404].
Hulot JS, Montalescot G, Lechat P, et al. Dosing strategy in patients with renal failure receiving enoxaparin for the treatment of non-ST-segment elevation acute coronary syndrome. Clin Pharmacol Ther. 2005;77(6):542-52. Exclude - no active comparator. [pmid: 15961985].
Hung J, Brieger DB, Amerena JV, et al. Treatment disparities and effect on late mortality in patients with diabetes presenting with acute myocardial infarction: observations from the ACACIA registry. Med J Aust. 2009;191(10):539-43. Exclude - no active comparator. [pmid: 19912085].
Hurlen M, Abdelnoor M, Smith P, et al. Warfarin, aspirin, or both after myocardial infarction. N Engl J Med. 2002;347(13):969-74. Exclude - no active comparator. [pmid: 12324552].
Hurlen M, Eikvar L, Seljeflot I, et al. Occult bleeding in three different antithrombotic regimes after myocardial infarction. A WARIS-II subgroup analysis. Thromb Res. 2006;118(4):433-8. Exclude - no outcomes of interest. [pmid: 16139331].
Hurlen M, Smith P, Arnesen H. Effects of warfarin, aspirin and the two combined, on mortality and thromboembolic morbidity after myocardial infarction. The WARIS-II (Warfarin-Aspirin Reinfarction Study) design. Scand Cardiovasc J. 2000;34(2):168-71. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10872704].
Husted S, Harrington RA, Cannon CP, et al. Bleeding risk with AZD6140, a reversible P2Y12 receptor antagonist, vs. clopidogrel in patients undergoing coronary artery bypass grafting in the DISPERSE2 trial. Int J Clin Pract. 2009;63(4):667-70. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19335707].
Husted SE, Wallentin L, Lagerqvist B, et al. Benefits of extended treatment with dalteparin in patients with unstable coronary artery disease eligible for revascularization. Eur Heart J. 2002;23(15):1213-8. Exclude - no active comparator. [pmid: 12127923].
Hutchinson-Jaffe AB, Goodman SG, Yan RT, et al. Comparison of baseline characteristics, management and outcome of patients with non-ST-segment elevation acute coronary syndrome in versus not in clinical trials. Am J Cardiol. 2010;106(10):1389-96. Exclude - no active comparator. [pmid: 21059426].
Huynh T, Theroux P, Bogaty P, et al. Aspirin, warfarin, or the combination for secondary prevention of coronary events in patients with acute coronary syndromes and prior coronary artery bypass surgery. Circulation. 2001;103(25):3069-74. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11425770].
Iacono A. Mean-term calcium heparin treatment in acute transmural anterior myocardial infarction: effects on left ventricular thrombosis and its complications. Cardiologia. 1997;42(12):1251-5. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9534319].
Iakobishvili Z, Behar S, Boyko V, et al. Does current treatment of cardiogenic shock complicating the acute coronary syndromes comply with guidelines?. Am Heart J. 2005;149(1):98-103. Exclude - no active comparator. [pmid: 15660040].
Iakovou I, Sangiorgi GM, Stankovic G, et al. Results and follow-up after implantation of four or more sirolimus-eluting stents in the same patient. Catheter Cardiovasc Interv. 2005;64(4):436-9. discussion 440-1. Exclude - no active comparator. [pmid: 15789401].
Ibbotson T, McGavin JK, Goa KL. Abciximab: an updated review of its therapeutic use in patients with ischaemic heart disease undergoing percutaneous coronary revascularisation. Drugs. 2003;63(11):1121-63. Exclude - not a Clinical Study. [pmid: 12749745].
Ikari Y, Kotani J, Kozuma K, et al. Assessment of sirolimus-eluting coronary stent implantation with aspirin plus low dose ticlopidine administration: one year results from CYPHER Stent Japan Post-Marketing Surveillance Registry (J-PMS). Circ J. 2009;73(6):1038-44. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19367015].
Iqbal O, Adiguzel C, Lewis BE, et al. Argatroban for percutaneous coronary interventions. Semin Thromb Hemost. 2008;34(SUPPL. 1):62-74. Exclude - no active comparator.
Ishikawa K, Kanamasa K, Hama J, et al. Aspirin plus either dipyridamole or ticlopidine is effective in preventing recurrent myocardial infarction. Secondary Prevention Group. Jpn Circ J. 1997;61(1):38-45. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9070958].
Jackevicius CA, Pinto R, Daly P, et al. Routine use of glycoprotein IIb/IIIa inhibitor therapy is associated with an improved in-hospital outcome after percutaneous coronary intervention: Insights from a large, prospective, single-centre registry. Can J Cardiol. 2005;21(1):27-32. Exclude - no active comparator. [pmid: 15685299].
Jackson EA, Sivasubramian R, Spencer FA, et al. Changes over time in the use of aspirin in patients hospitalized with acute myocardial infarction (1975 to 1997): a population-based perspective. Am Heart J. 2002;144(2):259-68. Exclude -no active comparator. [pmid: 12177643].
Jacobsen MD, Wagner GS, Holmvang L, et al. Quantitative T-wave analysis predicts 1 year prognosis and benefit from early invasive treatment in the FRISC II study population. Eur Heart J. 2005;26(2):112-8. Exclude - no active comparator. [pmid: 15618066].
James S. Coagulation, inflammation and myocardial dysfunction in unstable coronary artery disease and the influence of glycoprotein IIb/IIIa inhibition and low molecular weight heparin. Ups J Med Sci. 2004;109(2):71-122. Exclude - not a Clinical Study. [pmid: 15259448].
James S, Armstrong P, Califf R, et al. Safety and efficacy of abciximab combined with dalteparin in treatment of acute coronary syndromes. Eur Heart J. 2002;23(19):1538-45. Exclude -no active comparator. [pmid: 12242074].
James SK, Siegbahn A, Armstrong P, et al. Activation of the inflammation, coagulation, and fibrinolysis systems, without influence of abciximab infusion in patients with non-ST-elevation acute coronary syndromes treated with dalteparin: a GUSTO IV substudy. Am Heart J. 2004;147(2):267-74. Exclude - no active comparator. [pmid: 14760324].
Jang IK, Lewis BE, Matthai WH Jr., et al. Argatroban anticoagulation in conjunction with glycoprotein IIb/IIIa inhibition in patients undergoing percutaneous coronary intervention: an open-label, nonrandomized pilot study. J Thromb Thrombolysis. 2004;18(1):31-7. Exclude - no active comparator. [pmid: 15744551].
Janion-Sadowska A, Sielski J, Gierlotka M, et al. Pharmacological approach to patients with non-ST segment elevation myocardial infarction: does sex make a difference?. Pol Arch Med Wewn. 2011;121(1-2):18-22. Exclude - no active comparator. [pmid: 21346693].
Januzzi JL Jr., Buros J, Cannon CP. Peripheral arterial disease, acute coronary syndromes, and early invasive management: the TACTICS TIMI 18 trial. Clin Cardiol. 2005;28(5):238-42. Exclude - no active comparator. [pmid: 15971459].
Januzzi JL, Cannon CP, DiBattiste PM, et al. Effects of renal insufficiency on early invasive management in patients with acute coronary syndromes (The TACTICS-TIMI 18 Trial). Am J Cardiol. 2002;90(11):1246-9. Exclude - no active comparator. [pmid: 12450608].
Januzzi JL Jr., Sabatine MS, Wan Y, et al. Interactions between age, outcome of acute coronary syndromes, and tirofiban therapy. Am J Cardiol. 2003;91(4):457-61. Exclude - no active comparator. [pmid: 12586266].
Janzon M, Levin LA, Swahn E. Cost effectiveness of extended treatment with low molecular weight heparin (dalteparin) in unstable coronary artery disease: results from the FRISC II trial. Heart. 2003;89(3):287-92. Exclude - no outcomes of interest. [pmid: 12591833].
Janzon M, Levin LA, Swahn E. Invasive treatment in unstable coronary artery disease promotes health-related quality of life: results from the FRISC II trial. Am Heart J. 2004;148(1):114-21. Exclude - no active comparator. [pmid: 15215800].
Jedrzkiewicz S, Goodman SG, Yan RT, et al. Temporal trends in the use of invasive cardiac procedures for non-ST segment elevation acute coronary syndromes according to initial risk stratification. Can J Cardiol. 2009;25(11):e370-6. Exclude - no active comparator. [pmid: 19898699].
Jeger R, Sorensen R, Von Felten S, et al. Effect of different dual antiplatelet therapy strategies on 2-year outcome after drug-eluting vs. bare-metal stent implantation. Eur Heart J. 2011;32:417-418. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Jelinski SE, Ghali WA, Parsons GA, et al. Absence of sex differences in pharmacotherapy for acute myocardial infarction. Can J Cardiol. 2004;20(9):899-905. Exclude - no active comparator. [pmid: 15266360].
Jensen LO, Kaltoft A, Thayssen P, et al. Outcome in high risk patients with unprotected left main coronary artery stenosis treated with percutaneous coronary intervention. Catheter Cardiovasc Interv. 2010;75(1):101-8. Exclude - no active comparator. [pmid: 19670299].
Jeong HC, Ahn Y, Jeong MH, et al. Long-Term clinical outcomes according to initial management and thrombolysis in myocardial infarction risk score in patients with acute non-ST-segment elevation myocardial infarction. Yonsei Med J. 2010;51(1):58-68. Exclude - no active comparator. [pmid: 20046515].
Jeong HC, Ahn YK, Jeong MH, et al. Intensive pharmacologic treatment in patients with acute non ST-segment elevation myocardial infarction who did not undergo percutaneous coronary intervention. Circ J. 2008;72(9):1403-9. Exclude - no outcomes of interest. [pmid: 18724013].
Jeong JH, Chun KJ, Park YH, et al. Safety of tirofiban therapy in korean patients with acute coronary syndrome. Circ J. 2005;69(6):650-3. Exclude - no active comparator. [pmid: 15914940].
Jeong YH, Hwang JY, Kim IS, et al. Adding cilostazol to dual antiplatelet therapy achieves greater platelet inhibition than high maintenance dose clopidogrel in patients with acute myocardial infarction: Results of the adjunctive cilostazol versus high maintenance dose clopidogrel in patients with AMI (ACCEL-AMI) study. Circ Cardiovasc Interv. 2010;3(1):17-26. Exclude - no active comparator. [pmid: 20118150].
Jha AK, Perlin JB, Steinman MA, et al. Quality of ambulatory care for women and men in the Veterans Affairs Health Care System. J Gen Intern Med. 2005;20(8):762-5. Exclude - no active comparator. [pmid: 16050889].
Jhaveri R, Jeger R, Reynolds H, et al. Low rate of heart failure hospitalization after myocardial infarction in the occluded artery trial (OAT). J Card Fail. 2010;16(8):S83. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Jibran R, Khan JA, Hoye A. Gender disparity in patients undergoing percutaneous coronary intervention for acute coronary syndromes - does it still exist in contemporary practice?. Ann Acad Med Singapore. 2010;39(3):173-8. Exclude - no active comparator. [pmid: 20372751].
Johnson SG, Rogers K, Delate T, et al. Outcomes associated with combined antiplatelet and anticoagulant therapy. Chest. 2008;133(4):948-54. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18198244].
Johnston N, Schenck-Gustafsson K, Lagerqvist B. Are we using cardiovascular medications and coronary angiography appropriately in men and women with chest pain?. Eur Heart J. 2011;32(11):1331-1336. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21317147].
Jolly S, Tan M, Mendelsohn A, et al. Comparison of effectiveness of enoxaparin versus unfractionated heparin to reduce silent and clinically apparent acute myocardial infarction in patients presenting with non-ST-segment elevation acute coronary syndrome. Am J Cardiol. 2007;99(2):186-8. Exclude - no outcomes of interest. [pmid: 17223416].
Jones HU, Muhlestein JB, Jones KW, et al. Preoperative use of enoxaparin compared with unfractionated heparin increases the incidence of re-exploration for postoperative bleeding after open-heart surgery in patients who present with an acute coronary syndrome: clinical investigation and reports. Circulation. 2002;106(12 Suppl 1):I19-22. Exclude - no outcomes of interest. [pmid: 12354703].
Juergens CP, White HD, Belardi JA, et al. A multicenter study of the tolerability of tirofiban versus placebo in patients undergoing planned intracoronary stent placement. Clin Ther. 2002;24(8):1332-44. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12240783].
Julian DG, Chamberlain DA, Pocock SJ. A comparison of aspirin and anticoagulation following thrombolysis for myocardial infarction (the AFTER study): a multicentre unblinded randomised clinical trial. BMJ. 1996;313(7070):1429-31. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8973228].
Kadakia MB, Desai NR, Alexander KP, et al. Use of anticoagulant agents and risk of bleeding among patients admitted with myocardial infarction: a report from the NCDR ACTION Registry--GWTG (National Cardiovascular Data Registry Acute Coronary Treatment and Intervention Outcomes Network Registry--Get With the Guidelines). JACC Cardiovasc Interv. 2010;3(11):1166-77. Exclude - no outcomes of interest. [pmid: 21087753].
Kaehler J, Koester R, Billmann W, et al. 13-year follow-up of the German angioplasty bypass surgery investigation. Eur Heart J. 2005;26(20):2148-53. Exclude - no active comparator. [pmid: 15975991].
Kahn J, Stone GW, Leon MB, et al. TCT 2008: New data lead to new directions in treating cardiovascular disease. Rev Cardiovasc Med. 2008;9(4):269-274. Exclude - not a Clinical Study.
Kahn JK, Kodali U, Savas V, et al. Effects of chronic warfarin therapy on complications of coronary angioplasty during acute myocardial infarction. Am J Cardiol. 1995;75(10):724. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 7900670].
Kakkar VV, Iyengar SS, De Lorenzo F, et al. Low molecular weight heparin for treatment of acute myocardial infarction (FAMI): Fragmin (dalteparin sodium) in acute myocardial infarction. Indian Heart J. 2000;52(5):533-9. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11256775].
Kalapatapu K, Shao J, Aronow WS, et al. Prevalence of in-hospital complications in 500 patients undergoing percutaneous coronary intervention treated with heparin 5000 IU administered systemically versus 500 age-matched and sex-matched patients treated with heparin 70 IU/kg administered systemically. Am J Ther. 2010;17(6):e179-81. Exclude - no active comparator. [pmid: 19352143].
Kalaria VG, Chaudhary I, Jacobson S, et al. Evolution in the practice of primary angioplasty: effect of adjunctive coronary stenting and glycoprotein IIb/IIIa inhibitors on long-term outcomes. Catheter Cardiovasc Interv. 2001;54(3):327-32. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11747157].
Kaltoft A, Jensen LO, Maeng M, et al. 2-year clinical outcomes after implantation of sirolimus-eluting, paclitaxel-eluting, and bare-metal coronary stents: results from the WDHR (Western Denmark Heart Registry). J Am Coll Cardiol. 2009;53(8):658-64. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19232897].
Kalyanasundaram A, Blankenship JC, Berger P, et al. Thrombus predicts ischemic complications during percutaneous coronary intervention in saphenous vein grafts: results from TARGET (do Tirofiban and ReoPro give similar efficacy trial?). Catheter Cardiovasc Interv. 2007;69(5):623-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17192960].
Kamath A, Shanbhag T, Shenoy S. A descriptive study of the influence of age and gender on drug utilization in acute myocardial infarction. J Clin Diagn Res. 2010;4(1):2041-2046. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data).
Kanamasa K, Ishikawa K, Hayashi T, et al. Increased cardiac mortality in women compared with men in patients with acute myocardial infarction. Intern Med. 2004;43(10):911-8. Exclude - no active comparator. [pmid: 15575239].
Kandzari DE, Barker CS, Leon MB, et al. Dual antiplatelet therapy duration and clinical outcomes following treatment with zotarolimus-eluting stents. JACC Cardiovasc Interv. 2011;4(10):1119-28. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22017938].
Kandzari DE, Berger PB, Kastrati A, et al. Influence of treatment duration with a 600-mg dose of clopidogrel before percutaneous coronary revascularization. J Am Coll Cardiol. 2004;44(11):2133-6. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15582309].
Kandzari DE, Tcheng JE, Grines CL, et al. Influence of admission and discharge aspirin use on survival after primary coronary angioplasty for acute myocardial infarction. Am J Cardiol. 2004;94(8):1029-33. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15476618].
Kang KW, Kim BK, Jang JY, et al. Comparison of three-year clinical outcomes with nonextended versus extended dual antiplatelet therapy between first- and second-generation drug-eluting stent implantation in patients with acute myocardial infarction: Data from the infarct prognosis study registry. Journal of Interventional Cardiology. 2012;25(3):245-252. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22409626].
Kao J, Lincoff AM, Topol EJ, et al. Direct thrombin inhibition appears to be a safe and effective anticoagulant for percutaneous bypass graft interventions. Catheter Cardiovasc Interv. 2006;68(3):352-6. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16892428].
Karjalainen PP, Vikman S, Niemela M, et al. Safety of percutaneous coronary intervention during uninterrupted oral anticoagulant treatment. Eur Heart J. 2008;29(8):1001-10. Exclude -no outcomes of interest. [pmid: 18346963].
Karsch KR, Preisack MB, Baildon R, et al. Low molecular weight heparin (reviparin) in percutaneous transluminal coronary angioplasty. Results of a randomized, double-blind, unfractionated heparin and placebo-controlled, multicenter trial (REDUCE trial). Reduction of Restenosis After PTCA, Early Administration of Reviparin in a Double-Blind Unfractionated Heparin and Placebo-Controlled Evaluation. J Am Coll Cardiol. 1996;28(6):1437-43. Exclude - no active comparator. [pmid: 8917255].
Karthikeyan G, Mehta SR, Eikelboom JW. Fondaparinux in the treatment of acute coronary syndromes: evidence from OASIS 5 and 6. Expert Rev Cardiovasc Ther. 2009;7(3):241-9. Exclude - not a Clinical Study. [pmid: 19296760].
Kassam S, Cantor WJ, Patel D, et al. Radial versus femoral access for rescue percutaneous coronary intervention with adjuvant glycoprotein IIb/IIIa inhibitor use. Can J Cardiol. 2004;20(14):1439-42. Exclude - no active comparator. [pmid: 15614338].
Kassem-Moussa H, Mahaffey KW, Graffagnino C, et al. Incidence and characteristics of stroke during 90-day follow-up in patients stabilized after an acute coronary syndrome. Am Heart J. 2004;148(3):439-46. Exclude - no active comparator. [pmid: 15389230].
Kastrati A, Mehilli J, Schuhlen H, et al. A clinical trial of abciximab in elective percutaneous coronary intervention after pretreatment with clopidogrel. N Engl J Med. 2004;350(3):232-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14724302].
Katsouras C, Michalis LK, Papamichael N, et al. Enoxaparin versus tinzaparin in non-ST-segment elevation acute coronary syndromes: results of the enoxaparin versus tinzaparin (EVET) trial at 6 months. Am Heart J. 2005;150(3):385-91. Exclude - no outcomes of interest. [pmid: 16169312].
Kaul P, Newby LK, Fu Y, et al. Relation between baseline risk and treatment decisions in non-ST elevation acute coronary syndromes: an examination of international practice patterns. Heart. 2005;91(7):876-81. Exclude - no active comparator. [pmid: 15958353].
Kawai Y, Hisamatsu K, Matsubara H, et al. Intravenous administration of nicorandil immediately before percutaneous coronary intervention can prevent slow coronary flow phenomenon. Eur Heart J. 2009;30(7):765-72. Exclude - no outcomes of interest. [pmid: 19276198].
Kawata M, Kuramoto E, Kataoka T, et al. Comparative inhibitory effects of cilostazol and ticlopidine on subacute stent thrombosis and platelet function in acute myocardial infarction patients with percutaneous coronary intervention. Int Heart J. 2005;46(1):13-22. Exclude - no active comparator. [pmid: 15858933].
Kazmierski M, Wieczorek P, Ochala A. Bleeding complications after percutaneous coronary interventions in patients treated with abciximab in relation to dose of clopidogrel. Postepy Kardiol Interwencyjnej. 2009;5(4):172-175. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data).
Ke X, Yu H, Wang Q. Safety and efficacy of dalteparin in percutaneous coronary intervention in Chinese patients with non-ST-elevation acute coronary artery syndromes: Comparison with unfractionated heparin. J Geriatr Cardiol. 2009;6(2):95-98. Exclude - no active comparator.
Kellett J. How many patients in atrial fibrillation admitted to an acute medical unit will benefit from oral anticoagulation? Application of the results of the major randomized controlled trials to 141 consecutive, unselected, elderly patients using a decision support computer program. Eur J Intern Med. 2005;16(2):97-104. Exclude - no outcomes of interest. [pmid: 15833675].
Kennon S, Price CP, Mills PG, et al. The effect of aspirin on C-reactive protein as a marker of risk in unstable angina. J Am Coll Cardiol. 2001;37(5):1266-70. Exclude - no outcomes of interest. [pmid: 11300433].
Kent DM, Langa KM, Selker HP. The potential use of ECG-based prognostic instruments in clinical trials and cost-effectiveness analyses of new therapies in acute cardiac ischemia. J Electrocardiol. 2000;33(Suppl):263-8. Exclude - not a Clinical Study. [pmid: 11265732].
Kereiakes DJ, Kleiman NS, Ambrose J, et al. Randomized, double-blind, placebo-controlled dose-ranging study of tirofiban (MK-383) platelet IIb/IIIa blockade in high risk patients undergoing coronary angioplasty. J Am Coll Cardiol. 1996;27(3):536-42. Exclude - no outcomes of interest. [pmid: 8606262].
Kereiakes DJ, Kleiman NS, Fry E, et al. Dalteparin in combination with abciximab during percutaneous coronary intervention. Am Heart J. 2001;141(3):348-52. Exclude - no active comparator. [pmid: 11231430].
Kereiakes DJ, Obenchain RL, Barber BL, et al. Abciximab provides cost-effective survival advantage in high-volume interventional practice. Am Heart J. 2000;140(4):603-10. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11011333].
Khaisombat N, Saokaew S, Chaiyakunapruk N, et al. Attributable cost and length of stay for patients with enoxaparin-associated bleeding. Value Health. 2010;13(7):A506. Exclude - no active comparator.
Kim HS, Park SJ, Park DW, et al. Comparison of the efficacy and safety of paclitaxel-eluting coroflex please stents and paclitaxel-eluting stents in patients with coronary artery disease: A randomized PIPA Trial. Catheter Cardiovasc Interv. 2011. Exclude - no active comparator. [pmid: 22120995].
Kim JH, Jeong MH, Yun KH, et al. Myocardial protective effects of nicorandil during percutaneous coronary intervention in patients with unstable angina. Circ J. 2005;69(3):306-10. Exclude - no active comparator. [pmid: 15731536].
Kim JH, Park KW, Lim WH, et al. Comparison of two-year clinical outcomes between zotarolimus-, sirolimus-, and paclitaxel-eluting stents in real life clinical practice. Catheter Cardiovasc Interv. 2011. Exclude - no active comparator. [pmid: 22105990].
Kim LK, Wong SC, Minutello RM, et al. Efficacy and safety of bivalirudin in patients with diabetes mellitus undergoing percutaneous coronary intervention in current clinical practice. J Invasive Cardiol. 2010;22(3):94-100. Exclude - no outcomes of interest. [pmid: 20197573].
Kim MC, Ahn Y, Jang SY, et al. Comparison of clinical outcomes of hydrophilic and lipophilic statins in patients with acute myocardial infarction. Korean J Intern Med. 2011;26(3):294-303. Exclude - no active comparator. [pmid: 22016590].
Kim MC, Jeong MH, Ahn Y, et al. What is optimal revascularization strategy in patients with multivessel coronary artery disease in non-ST-elevation myocardial infarction? Multivessel or culprit-only revascularization. Int J Cardiol. 2011;153(2):148-53. Exclude - no active comparator. [pmid: 20843572].
Kim MS, Wang TY, Ou FS, et al. Association of prior coronary artery bypass graft surgery with quality of care of patients with non-ST-segment elevation myocardial infarction: a report from the National Cardiovascular Data Registry Acute Coronary Treatment and Intervention Outcomes Network Registry-Get With the Guidelines. Am Heart J. 2010;160(5):951-7. Exclude - no active comparator. [pmid: 21095285].
Kim W, Jeong MH, Hong YJ, et al. The long-term clinical results of a platelet glycoprotein IIb/IIIa receptor blocker (Abciximab: Reopro) coated stent in patients with coronary artery disease. Korean J Intern Med. 2004;19(4):220-9. Exclude -no active comparator. [pmid: 15683110].
Kim W, Jeong MH, Hwang SH, et al. Comparison of abciximab combined with dalteparin or unfractionated heparin in high-risk percutaneous coronary intervention in acute myocardial infarction patients. Int Heart J. 2006;47(6):821-31. Exclude - no outcomes of interest. [pmid: 17268117].
Kimmelstiel C, Badar J, Covic L, et al. Pharmacodynamics and pharmacokinetics of the platelet GPIIb/IIIa inhibitor tirofiban in patients undergoing percutaneous coronary intervention: implications for adjustment of tirofiban and clopidogrel dosage. Thromb Res. 2005;116(1):55-66. Exclude - no outcomes of interest. [pmid: 15850609].
Kimmelstiel C, Phang R, Rehman A, et al. Short-term comparative outcomes associated with the use of GP IIb/IIIa antagonists in patients undergoing coronary intervention. J Thromb Thrombolysis. 2001;11(3):203-9. Exclude - no active comparator. [pmid: 11577258].
King SB 3rd. Do elderly patients with non-ST-segment elevation acute coronary syndromes benefit from early invasive treatment?. Nat Clin Pract Cardiovasc Med. 2006;3(4):188-9. Exclude - not a Clinical Study. [pmid: 16568125].
Kini AS, Chen VH, Krishnan P, et al. Bolus-only versus bolus + infusion of glycoprotein IIb/IIIa inhibitors during percutaneous coronary intervention. Am Heart J. 2008;156(3):513-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18760134].
Kinjo K, Sato H, Ohnishi Y, et al. Prognostic significance of atrial fibrillation/atrial flutter in patients with acute myocardial infarction treated with percutaneous coronary intervention. Am J Cardiol. 2003;92(10):1150-4. Exclude - no active comparator. [pmid: 14609587].
Kinlay S, Gaziano M, Young M, et al. Prolonged use of clopidogrel and risk of death and myocardial infarction 4 years after coronary stenting in diabetes: The VA des study. Circulation. 2011;124(21). Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Kinnaird TD, Stabile E, Mintz GS, et al. Incidence, predictors, and prognostic implications of bleeding and blood transfusion following percutaneous coronary interventions. Am J Cardiol. 2003;92(8):930-5. Exclude - no active comparator. [pmid: 14556868].
Kirtane AJ, Piazza G, Murphy SA, et al. Correlates of bleeding events among moderate- to high-risk patients undergoing percutaneous coronary intervention and treated with eptifibatide: observations from the PROTECT-TIMI-30 trial. J Am Coll Cardiol. 2006;47(12):2374-9. Exclude - no active comparator. [pmid: 16781361].
Kjoller-Hansen L, Steffensen R, Grande P. Extended follow-up of patients randomly assigned in the Angiotensin-converting enzyme inhibition Post-Revascularization Study (APRES). Am Heart J. 2004;148(3):475-80. Exclude - no active comparator. [pmid: 15389235].
Klauss V, Erdin P, Rieber J, et al. Fractional flow reserve for the prediction of cardiac events after coronary stent implantation: results of a multivariate analysis. Heart. 2005;91(2):203-6. Exclude - no active comparator. [pmid: 15657233].
Kleiman NS, Lincoff AM, Kereiakes DJ, et al. Diabetes mellitus, glycoprotein IIb/IIIa blockade, and heparin: evidence for a complex interaction in a multicenter trial. EPILOG Investigators. Circulation. 1998;97(19):1912-20. Exclude - no outcomes of interest. [pmid: 9609084].
Klein LW, Wahid F, VandenBerg BJ, et al. Comparison of heparin therapy for < or = 48 hours to > 48 hours in unstable angina pectoris. Am J Cardiol. 1997;79(3):259-63. Exclude - no active comparator. [pmid: 9036741].
Klein W, Buchwald A, Hillis SE, et al. Comparison of low-molecular-weight heparin with unfractionated heparin acutely and with placebo for 6 weeks in the management of unstable coronary artery disease. Fragmin in unstable coronary artery disease study (FRIC). Circulation. 1997;96(1):61-8. Exclude - no active comparator. [pmid: 9236418].
Klein W, Buchwald A, Hillis WS, et al. Fragmin in unstable angina pectoris or in non-Q-wave acute myocardial infarction (the FRIC study). Fragmin in Unstable Coronary Artery Disease. Am J Cardiol. 1997;80(5A):30E-34E. Exclude - no active comparator. [pmid: 9296467].
Klein W, Kraxner W, Hodl R, et al. Patterns of use of heparins in ACS. Correlates and hospital outcomes: the Global Registry of Acute Coronary Events (GRACE). Thromb Haemost. 2003;90(3):519-27. Exclude - no active comparator. [pmid: 12958622].
Kleopatra K, Muth K, Zahn R, et al. Effect of an invasive strategy on in-hospital outcome and one-year mortality in women with non-ST-elevation myocardial infarction. Int J Cardiol. 2011;153(3):291-295. Exclude -no active comparator. [pmid: 20851476].
Klootwijk P, Meij S, Melkert R, et al. Reduction of recurrent ischemia with abciximab during continuous ECG-ischemia monitoring in patients with unstable angina refractory to standard treatment (CAPTURE). Circulation. 1998;98(14):1358-64. Exclude - no outcomes of interest. [pmid: 9760288].
Knottenbelt C, Brennan PJ, Meade TW. Antithrombotic treatment and the incidence of angina pectoris. Arch Intern Med. 2002;162(8):881-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11966338].
Koefoed BG, Gullov AL, Petersen P. Second Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulant Therapy Study (AFASAK 2): Methods and Design. J Thromb Thrombolysis. 1995;2(2):125-130. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10608015].
Kohli P, Udell J, Murphy S, et al. Discharge aspirin dose and clinical outcomes in patients with acs: An analysis from the TRITON-TIMI 38 study. Journal of the American College of Cardiology. 2012;59(13):E342. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Kong DF, Hasselblad V, Kandzari DE, et al. Seeking the optimal aspirin dose in acute coronary syndromes. Am J Cardiol. 2002;90(6):622-5. Exclude - not a Clinical Study. [pmid: 12231088].
Konishi N, Hiroe K, Shinozawa E, et al. Antithrombotic profiles of TAK-442, a novel oral factor Xa inhibitor, in venous and arterial thrombosis model. J Thromb Haemost. 2009;7(S2):759-760. Exclude - not a Clinical Study.
Kontny F. Improving outcomes in acute coronary syndromes--the FRISC II trial. Clin Cardiol. 2001;24(3 Suppl):I3-7. Exclude -not a Clinical Study. [pmid: 11286312].
Kontos MC, de Lemos JA, Ou FS, et al. Troponin-positive, MB-negative patients with non-ST-elevation myocardial infarction: An undertreated but high-risk patient group: Results from the National Cardiovascular Data Registry Acute Coronary Treatment and Intervention Outcomes Network-Get With The Guidelines (NCDR ACTION-GWTG) Registry. Am Heart J. 2010;160(5):819-25. Exclude - no active comparator. [pmid: 21095267].
Kontos MC, Ornato JP, Schmidt KL, et al. Incidence of high-risk acute coronary syndromes and eligibility for glycoprotein IIb/IIIa inhibitors among patients admitted for possible myocardial ischemia. Am Heart J. 2002;143(1):70-5. Exclude - no outcomes of interest. [pmid: 11773914].
Koo S, Kucher N, Nguyen PL, et al. The effect of excessive anticoagulation on mortality and morbidity in hospitalized patients with anticoagulant-related major hemorrhage. Arch Intern Med. 2004;164(14):1557-60. Exclude -no active comparator. [pmid: 15277289].
Kornelia Kotseva K, Jennings C, Turner E, et al. Risk factor management and use of cardioprotective medication in patients with coronary heart disease: Results from ASPIRE-2-PREVENT survey in the UK. Eur J Cardiovasc Prev Rehabil. 2011;18(1):S6. Exclude - no active comparator.
Koul S, Smith JG, Schersten F, et al. Effect of upstream clopidogrel treatment in patients with ST-segment elevation myocardial infarction undergoing primary percutaneous coronary intervention. Eur Heart J. 2011;32(23):2989-97. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21719452].
Koyama Y, Hansen PS, Hanratty CG, et al. Prevalence of coronary occlusion and outcome of an immediate invasive strategy in suspected acute myocardial infarction with and without ST-segment elevation. Am J Cardiol. 2002;90(6):579-84. Exclude - no active comparator. [pmid: 12231080].
Kozuch M, Kralisz P, Korecki J, et al. Early and long-term prognosis of patients with coronary artery disease treated with percutaneous coronary interventions in 2005. Experience of single large-volume PCI center. Adv Med Sci. 2011;56(2):222-30. Exclude - no active comparator. [pmid: 21940265].
Kralev S, Krause B, Papavassiliu T, et al. Clinical outcome of patients with diabetes presenting with ST-elevation myocardial infarction and treated with concomitant use of glycoprotein IIb/IIIa inhibitors. Cardiol J. 2009;16(3):234-40. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19437397].
Krause MW, Massing M, Kshirsagar A, et al. Combination therapy improves survival after acute myocardial infarction in the elderly with chronic kidney disease. Ren Fail. 2004;26(6):715-25. Exclude - no active comparator. [pmid: 15600265].
Krimly A, Yan RT, Yan AT, et al. Use of clopidogrel post-coronary artery bypass surgery in canadian patients with acute coronary syndromes. Can J Cardiol. 2011;27(6):711-5. Exclude - no outcomes of interest. [pmid: 21875778].
Kronish IM, Rieckmann N, Shimbo D, et al. Aspirin adherence, aspirin dosage, and C-reactive protein in the first 3 months after acute coronary syndrome. Am J Cardiol. 2010;106(8):1090-4. Exclude - no outcomes of interest. [pmid: 20920644].
Krumholz HM, Gross CP, Peterson ED, et al. Is there evidence of implicit exclusion criteria for elderly subjects in randomized trials? Evidence from the GUSTO-1 study. Am Heart J. 2003;146(5):839-47. Exclude - no active comparator. [pmid: 14597933].
Krumholz HM, Hennen J, Ridker PM, et al. Use and effectiveness of intravenous heparin therapy for treatment of acute myocardial infarction in the elderly. J Am Coll Cardiol. 1998;31(5):973-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9561996].
Kubo S, Kadota K, Habara S, et al. Timing of late stent thrombosis occurrence: Necessity of dual antiplatelet therapy continuation for acute myocardial infarction cases after one month. Journal of the American College of Cardiology. 2012;59(13):E2095. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Kuchulakanti P, Wolfram R, Torguson R, et al. Bivalirudin compared with IIb/IIIa inhibitors in patients with in-stent restenosis undergoing intracoronary brachytherapy. Cardiovasc Revasc Med. 2005;6(4):154-9. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16326376].
Kugelmass AD, Sadanandan S, Lakkis N, et al. Early invasive strategy improves outcomes in patients with acute coronary syndrome with previous coronary artery bypass graft surgery: a report from TACTICS-TIMI 18. Crit Pathw Cardiol. 2006;5(3):167-72. Exclude - no outcomes of interest. [pmid: 18340233].
Kumana CR, Cheung G, Lauder IJ, et al. Long-term combination therapy with aspirin and clopidogrel. J Cardiovasc Pharmacol Ther. 2004;9(4):223-5. Exclude - not a Clinical Study. [pmid: 15678241].
Kumar R, Mangla A, Puma J, et al. Comparison of bivalirudin to heparin and glycoprotein IIB/IIIA inhibitors in patients undergoing PCI: In-hospital results from the TAXUS Liberte Post-Approval Study. Catheterization and Cardiovascular Interventions. 2012;79:S80. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
La Vecchia L, Martini M, Bottero M, et al. Abciximab in rescue coronary angioplasty after full-dose tissue-type plasminogen activator. Ital Heart J. 2001;2(4):301-5. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11374500].
Labinaz M, Kilaru R, Pieper K, et al. Outcomes of patients with acute coronary syndromes and prior coronary artery bypass grafting: results from the platelet glycoprotein IIb/IIIa in unstable angina: receptor suppression using integrilin therapy (PURSUIT) trial. Circulation. 2002;105(3):322-7. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11804987].
Lablanche JM, McFadden EP, Meneveau N, et al. Effect of nadroparin, a low-molecular-weight heparin, on clinical and angiographic restenosis after coronary balloon angioplasty: the FACT study. Fraxiparine Angioplastie Coronaire Transluminale. Circulation. 1997;96(10):3396-402. Exclude - no active comparator. [pmid: 9396433].
Labos C, Dasgupta K, Nedjar H, et al. Risk of bleeding associated with combined use of selective serotonin reuptake inhibitors and antiplatelet therapy following acute myocardial infarction. CMAJ. 2011;183(16):1835-43. Exclude -no active comparator. [pmid: 21948719].
Lage MJ, Barber BL, Bala M, et al. Association between abciximab and length of stay in intensive care for patients undergoing percutaneous coronary intervention. A 2-stage econometric model in a naturalistic setting. Pharmacoeconomics. 2000;18(6):581-9. Exclude - no outcomes of interest. [pmid: 11227396].
Lage MJ, Barber BL, Bowman L, et al. Shorter hospital stays for angioplasty patients who receive abciximab. J Invasive Cardiol. 2000;12(4):179-86. Exclude - no outcomes of interest. [pmid: 10785670].
Lage MJ, Barber BL, McCollam PL, et al. Impact of abciximab versus tirofiban on hospital length of stay for PCI patients. Catheter Cardiovasc Interv. 2001;52(3):298-305. Exclude - no outcomes of interest. [pmid: 11246240].
Lagerqvist B, Husted S, Kontny F, et al. Benefits of early invasive strategy for unstable coronary artery disease remain after 2 years. Evid-based Cardiovasc Med. 2003;7(2):70-72. Exclude - not a Clinical Study.
Lagerqvist B, Safstrom K, Stahle E, et al. Is early invasive treatment of unstable coronary artery disease equally effective for both women and men? FRISC II Study Group Investigators. J Am Coll Cardiol. 2001;38(1):41-8. Exclude - no outcomes of interest. [pmid: 11451294].
Lakkis N, Tsyboulev V, Gibson CM, et al. Outcome of patients with acute coronary syndrome admitted to hospitals with or without onsite cardiac catheterization laboratory: a TACTICS-TIMI 18 substudy. Crit Pathw Cardiol. 2002;1(4):232-7. Exclude - no outcomes of interest. [pmid: 18340309].
L'Allier PL, Aronow HD, Cura FA, et al. Clopidogrel is associated with better in-hospital and 30-day outcomes than ticlopidine after coronary stenting. Can J Cardiol. 2003;19(9):1041-6. Exclude - no active comparator. [pmid: 12915931].
Lamberts M, Hansen M, Olesen J, et al. Risk of major bleeding after initiation of dual or triple antithrombotic drug therapy in atrial fibrillation patients following myocardial infarction and coronary stenting: A nationwide cohort study. Journal of the American College of Cardiology. 2012;59(13):E512. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Lamy A, Noiseux N, Kieser T, et al. Impact of clopidogrel on patients with acs undergoing coronary bypass surgery: The practice study. Can J Cardiol. 2011;27(5):S254. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Lancaster GI, Lancaster CJ, Radley D, et al. Prior aspirin use in unstable angina predisposes to higher risk: the aspirin paradox. Int J Cardiol. 2001;80(2-3):201-7. Exclude - no outcomes of interest. [pmid: 11578715].
Landenhed M, Johansson M, Erlinge D, et al. Fondaparinux or enoxaparin: a comparative study of postoperative bleeding in coronary artery bypass grafting surgery. Scand Cardiovasc J. 2010;44(2):100-6. Exclude - no active comparator. [pmid: 19961287].
Lang C, Gullickson D, Bartosz C, et al. Bayesian meta-analysis and net clinical benefit of clopidogrel and proton pump inhibitors in adverse cardiovascular and gastrointestinal events. Journal of the American College of Cardiology. 2012;59(13):E1763. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Lansky AJ, Goto K, Cristea E, et al. Clinical and angiographic predictors of short- and long-term ischemic events in acute coronary syndromes: results from the Acute Catheterization and Urgent Intervention Triage strategY (ACUITY) trial. Circ Cardiovasc Interv. 2010;3(4):308-16. Exclude - no outcomes of interest. [pmid: 20647564].
Laskey WK, Selzer F, Vlachos HA, et al. Comparison of in-hospital and one-year outcomes in patients with and without diabetes mellitus undergoing percutaneous catheter intervention (from the National Heart, Lung, and Blood Institute Dynamic Registry). Am J Cardiol. 2002;90(10):1062-7. Exclude - no active comparator. [pmid: 12423704].
Latacz P, Rostoff P, Gackowski A, et al. Comparison of the efficacy and safety of pharmacological treatment versus percutaneous coronary angioplasty in patients with intermediate coronary artery lesions. Kardiol Pol. 2009;67(8A):1004-12. Exclude - no outcomes of interest. [pmid: 19784905].
Latib A, Ielasi A, Ferri L, et al. Aspirin intolerance and the need for dual antiplatelet therapy after stent implantation: A proposed alternative regimen. Int J Cardiol. 2011. Exclude - no active comparator. [pmid: 21968077].
Latini R, Santoro E, Masson S, et al. Aspirin does not interact with ACE inhibitors when both are given early after acute myocardial infarction: results of the GISSI-3 Trial. Heart Dis. 2000;2(3):185-90. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11728260].
Latour-Perez J, de-Miguel-Balsa E. Cost effectiveness of fondaparinux in non-ST-elevation acute coronary syndrome. Pharmacoeconomics. 2009;27(7):585-95. Exclude - no outcomes of interest. [pmid: 19663529].
Latour-Perez J, Fuset-Cabanes MP, Ruano Marco M, et al. Early invasive strategy in non-ST-segment elevation acute coronary syndrome. The paradox continues. Med Intensiva. 2011. Exclude - no active comparator. [pmid: 22074816].
Lauer MA, Houghtaling PL, Peterson JG, et al. Attenuation of rebound ischemia after discontinuation of heparin therapy by glycoprotein IIb/IIIa inhibition with eptifibatide in patients with acute coronary syndromes: observations from the platelet IIb/IIIa in unstable angina: receptor suppression using integrilin therapy (PURSUIT) trial. Circulation. 2001;104(23):2772-7. Exclude - no outcomes of interest. [pmid: 11733393].
Laynez A, Torguson R, Hauville C, et al. Safety and efficacy for the use of prasugrel in patients undergoing percutaneous coronary intervention and anticoagulated with bivalirudin. J Am Coll Cardiol. 2011;58(20):B45. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Le May M, Kurdi M, Labinaz M, et al. Safety of coronary stenting with eptifibatide and ultra-low-dose heparin. Am J Cardiol. 2005;95(5):630-2. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15721106].
Le Pen C, Lilliu H. Choice of GPIIb/IIIa antagonist in percutaneous coronary intervention: how should economic criteria be factored in?. Pharm World Sci. 2005;27(2):83-91. Exclude - not a Clinical Study. [pmid: 15999917].
Leborgne L, Cheneau E, Wolfram R, et al. Comparison of baseline characteristics and one-year outcomes between African-Americans and Caucasians undergoing percutaneous coronary intervention. Am J Cardiol. 2004;93(4):389-93. Exclude - no active comparator. [pmid: 14969608].
Lee CH, de Feyter P, Serruys PW, et al. Beneficial effects of fluvastatin following percutaneous coronary intervention in patients with unstable and stable angina: results from the Lescol intervention prevention study (LIPS). Heart. 2004;90(10):1156-61. Exclude - no active comparator. [pmid: 15367512].
Lee DP, Herity NA, Hiatt BL, et al. Adjunctive platelet glycoprotein IIb/IIIa receptor inhibition with tirofiban before primary angioplasty improves angiographic outcomes: results of the TIrofiban Given in the Emergency Room before Primary Angioplasty (TIGER-PA) pilot trial. Circulation. 2003;107(11):1497-501. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12654606].
Lee DS, Bhatt DL, Moliterno DJ, et al. The combination of enoxaparin, glycoprotein IIb/IIIa inhibitors and an early invasive approach among acute coronary syndrome patients. J Invasive Cardiol. 2004;16(2):46-51. Exclude - no active comparator. [pmid: 14760188].
Lee HJ, Song YB, Hahn JY, et al. Multivessel vs single-vessel revascularization in patients with non-ST-segment elevation acute coronary syndrome and multivessel disease in the drug-eluting stent era. Clin Cardiol. 2011;34(3):160-5. Exclude - no active comparator. [pmid: 21400543].
Lee K, Lee SW, Lee JW, et al. The significance of clopidogrel low-responsiveness on stent thrombosis and cardiac death assessed by the verifynow p(2)y(12) assay in patients with acute coronary syndrome within 6 months after drug-eluting stent implantation. Korean Circ J. 2009;39(12):512-8. Exclude - no active comparator. [pmid: 20049136].
Lee LC, Poh KK, Tang TP, et al. The impact of gender on the outcomes of invasive versus conservative management of patients with non-ST-segment elevation myocardial infarction. Ann Acad Med Singapore. 2010;39(3):168-72. Exclude - no active comparator. [pmid: 20372750].
Lee MS, Wali AU, Menon V, et al. The determinants of activated partial thromboplastin time, relation of activated partial thromboplastin time to clinical outcomes, and optimal dosing regimens for heparin treated patients with acute coronary syndromes: a review of GUSTO-IIb. J Thromb Thrombolysis. 2002;14(2):91-101. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12714828].
Lee SP, Bae JW, Park KW, et al. Inhibitory interaction between calcium channel blocker and clopidogrel. -Efficacy of cilostazol to overcome it. Circ J. 2011;75(11):2581-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21857144].
Lee SW, Park SW, Hong MK, et al. Triple versus dual antiplatelet therapy after coronary stenting: impact on stent thrombosis. J Am Coll Cardiol. 2005;46(10):1833-7. Exclude - no active comparator. [pmid: 16286167].
Lee SW, Park SW, Hong MK, et al. Comparison of cilostazol and clopidogrel after successful coronary stenting. Am J Cardiol. 2005;95(7):859-62. Exclude - no active comparator. [pmid: 15781016].
Lee SW, Park SW, Kim YH, et al. Comparison of triple versus dual antiplatelet therapy after drug-eluting stent implantation (from the DECLARE-Long trial). Am J Cardiol. 2007;100(7):1103-8. Exclude - no outcomes of interest. [pmid: 17884371].
Lee SW, Park SW, Kim YH, et al. A randomized, double-blind, multicenter comparison study of triple antiplatelet therapy with dual antiplatelet therapy to reduce restenosis after drug-eluting stent implantation in long coronary lesions: results from the DECLARE-LONG II (Drug-Eluting Stenting Followed by Cilostazol Treatment Reduces Late Restenosis in Patients with Long Coronary Lesions) trial. J Am Coll Cardiol. 2011;57(11):1264-70. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21392640].
Lee SW, Park SW, Yun SC, et al. Triple antiplatelet therapy reduces ischemic events after drug-eluting stent implantation: Drug-Eluting stenting followed by Cilostazol treatment REduces Adverse Serious cardiac Events (DECREASE registry). Am Heart J. 2010;159(2):284-291 e1. Exclude -no active comparator. [pmid: 20152228].
Lefkovits J, Blankenship JC, Anderson KM, et al. Increased risk of non-Q wave myocardial infarction after directional atherectomy is platelet dependent: evidence from the EPIC trial. Evaluation of c7E3 for the Prevention of Ischemic Complications. J Am Coll Cardiol. 1996;28(4):849-55. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8837559].
Lefkovits J, Ivanhoe RJ, Califf RM, et al. Effects of platelet glycoprotein IIb/IIIa receptor blockade by a chimeric monoclonal antibody (abciximab) on acute and six-month outcomes after percutaneous transluminal coronary angioplasty for acute myocardial infarction. EPIC investigators. Am J Cardiol. 1996;77(12):1045-51. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8644655].
Legalery P, Schiele F, Seronde MF, et al. One-year outcome of patients submitted to routine fractional flow reserve assessment to determine the need for angioplasty. Eur Heart J. 2005;26(24):2623-9. Exclude - no active comparator. [pmid: 16141256].
Legrand V, Finianos L, Martinez C, et al. Outcome of ad hoc coronary stenting in patients with unstable angina pretreated with ticlopidine. Acta Cardiol. 1997;52(6):527-528. Exclude - no active comparator.
Lemos PA, Lee CH, Degertekin M, et al. Early outcome after sirolimus-eluting stent implantation in patients with acute coronary syndromes: insights from the Rapamycin-Eluting Stent Evaluated At Rotterdam Cardiology Hospital (RESEARCH) registry. J Am Coll Cardiol. 2003;41(11):2093-9. Exclude - no active comparator. [pmid: 12798587].
Lenderink T, Boersma E, Heeschen C, et al. Elevated troponin T and C-reactive protein predict impaired outcome for 4 years in patients with refractory unstable angina, and troponin T predicts benefit of treatment with abciximab in combination with PTCA. Eur Heart J. 2003;24(1):77-85. Exclude - no outcomes of interest. [pmid: 12559939].
Lenzen MJ, Boersma E, Bertrand ME, et al. Management and outcome of patients with established coronary artery disease: the Euro Heart Survey on coronary revascularization. Eur Heart J. 2005;26(12):1169-79. Exclude -no active comparator. [pmid: 15802360].
Leon MB, Baim DS, Popma JJ, et al. A clinical trial comparing three antithrombotic-drug regimens after coronary-artery stenting. Stent Anticoagulation Restenosis Study Investigators. N Engl J Med. 1998;339(23):1665-71. Exclude -no active comparator. [pmid: 9834303].
Leung VW, Sunderji R, Zed PJ, et al. Switching from abciximab to eptifibatide for percutaneous coronary interventions: a local analysis (SWAP study). Can J Cardiol. 2003;19(7):809-14. Exclude - no active comparator. [pmid: 12813615].
Lev EI, Hasdai D, Scapa E, et al. Administration of eptifibatide to acute coronary syndrome patients receiving enoxaparin or unfractionated heparin: effect on platelet function and thrombus formation. J Am Coll Cardiol. 2004;43(6):966-71. Exclude - no outcomes of interest. [pmid: 15028351].
Levine GN, Ferguson JJ 3rd. Low-molecular-weight heparin during percutaneous coronary interventions: rationale, results, and recommendations. Catheter Cardiovasc Interv. 2003;60(2):185-93. Exclude - not a Clinical Study. [pmid: 14517923].
Li K, Huo Y, Ding YS. Clinical profile and outcomes of atrial fibrillation in elderly patients with acute myocardial infarction. Chin Med J (Engl). 2008;121(23):2388-91. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19102954].
Liem A, Zijlstra F, Ottervanger JP, et al. High dose heparin as pretreatment for primary angioplasty in acute myocardial infarction: the Heparin in Early Patency (HEAP) randomized trial. J Am Coll Cardiol. 2000;35(3):600-4. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10716460].
Liistro F, Angioli P, Falsini G, et al. Early invasive strategy in elderly patients with non-ST elevation acute coronary syndrome: comparison with younger patients regarding 30 day and long term outcome. Heart. 2005;91(10):1284-8. Exclude - no active comparator. [pmid: 15761051].
Lim HS, Stub D, Ajani AE, et al. Survival in patients with myocardial infarction complicated by out-of-hospital cardiac arrest undergoing emergency percutaneous coronary intervention. Int J Cardiol. 2011. Exclude - no active comparator. [pmid: 22133465].
Lim MJ, Eagle KA, Gore JM, et al. Treating patients with acute coronary syndromes with aggressive antiplatelet therapy (from the Global Registry of Acute Coronary Events). Am J Cardiol. 2005;96(7):917-21. Exclude - no active comparator. [pmid: 16188516].
Lin CF, Shen LJ, Wu FL, et al. Cardiovascular Outcomes Associated with Concomitant Use of Clopidogrel and Proton Pump Inhibitors in Patients of Acute Coronary Syndrome in Taiwan. Br J Clin Pharmacol. 2012. Exclude - no outcomes of interest. [pmid: 22364155].
Lincoff AM. GUSTO IV: expanding therapeutic options in acute coronary syndromes. Am Heart J. 2000;140(6 Suppl):S103-14. Exclude - not a Clinical Study. [pmid: 11100004].
Lincoff AM, Bittl JA, Harrington RA, et al. Bivalirudin and provisional glycoprotein IIb/IIIa blockade compared with heparin and planned glycoprotein IIb/IIIa blockade during percutaneous coronary intervention: REPLACE-2 randomized trial. JAMA. 2003;289(7):853-63. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12588269].
Lincoff AM, Bittl JA, Harrinton R, et al. Bivalirudin combined with provisional gp IIb/IIIa blockade is safer than heparin plus planned gp IIb/IIIa blockade during percutaneous coronary intervention. Evid-based Cardiovasc Med. 2003;7(4):173-175. Exclude -not a Clinical Study.
Lincoff AM, Bittl JA, Kleiman NS, et al. Comparison of bivalirudin versus heparin during percutaneous coronary intervention (the Randomized Evaluation of PCI Linking Angiomax to Reduced Clinical Events [REPLACE]-1 trial). Am J Cardiol. 2004;93(9):1092-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15110198].
Lincoff AM, Califf RM, Anderson KM, et al. Evidence for prevention of death and myocardial infarction with platelet membrane glycoprotein IIb/IIIa receptor blockade by abciximab (c7E3 Fab) among patients with unstable angina undergoing percutaneous coronary revascularization. EPIC Investigators. Evaluation of 7E3 in Preventing Ischemic Complications. J Am Coll Cardiol. 1997;30(1):149-56. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9207636].
Lincoff AM, Califf RM, Moliterno DJ, et al. Complementary clinical benefits of coronary-artery stenting and blockade of platelet glycoprotein IIb/IIIa receptors. Evaluation of Platelet IIb/IIIa Inhibition in Stenting Investigators. N Engl J Med. 1999;341(5):319-27. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10423466].
Lincoff AM, Kleiman NS, Kereiakes DJ, et al. Long-term efficacy of bivalirudin and provisional glycoprotein IIb/IIIa blockade vs heparin and planned glycoprotein IIb/IIIa blockade during percutaneous coronary revascularization: REPLACE-2 randomized trial. JAMA. 2004;292(6):696-703. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15304466].
Lincoff AM, Kleiman NS, Kottke-Marchant K, et al. Bivalirudin with planned or provisional abciximab versus low-dose heparin and abciximab during percutaneous coronary revascularization: results of the Comparison of Abciximab Complications with Hirulog for Ischemic Events Trial (CACHET). Am Heart J. 2002;143(5):847-53. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12040347].
Lincoff AM, LeNarz LA, Despotis GJ, et al. Abciximab and bleeding during coronary surgery: results from the EPILOG and EPISTENT trials. Improve Long-term Outcome with abciximab GP IIb/IIIa blockade. Evaluation of Platelet IIb/IIIa Inhibition in STENTing. Ann Thorac Surg. 2000;70(2):516-26. Exclude - no outcomes of interest. [pmid: 10969673].
Lincoff AM, Tcheng JE, Califf RM, et al. Sustained suppression of ischemic complications of coronary intervention by platelet GP IIb/IIIa blockade with abciximab: one-year outcome in the EPILOG trial. Evaluation in PTCA to Improve Long-term Outcome with abciximab GP IIb/IIIa blockade. Circulation. 1999;99(15):1951-8. Exclude - no outcomes of interest. [pmid: 10208997].
Lindgren P, Jonsson B, Yusuf S. Cost-effectiveness of clopidogrel in acute coronary syndromes in Sweden: a long-term model based on the CURE trial. J Intern Med. 2004;255(5):562-70. Exclude - no outcomes of interest. [pmid: 15078498].
Lindmark E, Diderholm E, Wallentin L, et al. Relationship between interleukin 6 and mortality in patients with unstable coronary artery disease: effects of an early invasive or noninvasive strategy. JAMA. 2001;286(17):2107-13. Exclude -no outcomes of interest. [pmid: 11694151].
Lindsey JB, Cohen DJ, Stolker JM, et al. The impact of bivalirudin on percutaneous coronary intervention-related bleeding. EuroIntervention. 2010;6(2):206-13. Exclude - no outcomes of interest. [pmid: 20562070].
Lip GY, Karpha M. Anticoagulant and antiplatelet therapy use in patients with atrial fibrillation undergoing percutaneous coronary intervention: the need for consensus and a management guideline. Chest. 2006;130(6):1823-7. Exclude - no outcomes of interest. [pmid: 17167003].
Long KH, Ting HH, McMurtry EK, et al. A longitudinal analysis of outcomes associated with abciximab and eptifibatide in a consecutive series of 3074 percutaneous coronary interventions. Value Health. 2008;11(3):462-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18489669].
Looi KL, Chow KL, Looi JL, et al. Under-use of secondary prevention medication in acute coronary syndrome patients treated with in-hospital coronary artery bypass graft surgery. N Z Med J. 2011;124(1343):18-27. Exclude -no active comparator. [pmid: 21964009].
Lopes RD, Peterson ED, Chen AY, et al. Antithrombotic strategy in non-ST-segment elevation myocardial infarction patients undergoing percutaneous coronary intervention: insights from the ACTION (Acute Coronary Treatment and Intervention Outcomes Network) Registry. JACC Cardiovasc Interv. 2010;3(6):669-77. Exclude - no outcomes of interest. [pmid: 20630461].
Lopes RD, White JA, Atar D, et al. Antithrombotic use and outcomes in patients with atrial fibrillation complicating acute coronary syndromes. Circulation. 2011;124(21). Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Lopes RD, White JA, Tricoci P, et al. Age, treatment, and outcomes in high-risk non-ST-segment elevation acute coronary syndrome patients: Insights from the EARLY ACS trial. Int J Cardiol. 2012. Exclude - no active comparator. [pmid: 22795720].
Loubeyre C, Morice MC, Berzin B, et al. Emergency coronary artery bypass surgery following coronary angioplasty and stenting: results of a French multicenter registry. Catheter Cardiovasc Interv. 1999;47(4):441-8. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10470474].
Lourenco C, Teixeira R, Antonio N, et al. Invasive strategy in non-ST elevation acute coronary syndromes: risks and benefits in an elderly population. Rev Port Cardiol. 2010;29(10):1451-72. Exclude - no active comparator. [pmid: 21265489].
Louvard Y, Benamer H, Garot P, et al. Comparison of transradial and transfemoral approaches for coronary angiography and angioplasty in octogenarians (the OCTOPLUS study). Am J Cardiol. 2004;94(9):1177-80. Exclude - no active comparator. [pmid: 15518616].
Lucore CL, Trask RV, Mishkel GJ, et al. Impact of abciximab and coronary stenting on outcomes and costs of percutaneous coronary interventions in a community hospital. Coron Artery Dis. 2001;12(2):135-42. Exclude - no active comparator. [pmid: 11281302].
Lui HK. Dosage, pharmacological effects and clinical outcomes for bivalirudin in percutaneous coronary intervention. J Invasive Cardiol. Suppl F. 2000;12:41F-52. Exclude - not a Clinical Study. [pmid: 10731264].
Luksiene D, Milvidaite I, Slapikas R, et al. The impact of myocardial revascularization after acute coronary syndromes on one-year cardiovascular mortality. Medicina (Kaunas). 2011;47(6):305-12. Exclude - no active comparator. [pmid: 21968882].
Ma HY, Zhou YJ, Dick RJ, et al. Long-term outcome of patients of over 85 years old with acute coronary syndrome undergoing percutaneous coronary stenting: a comparison of bare metal stent and drug eluting stent. Chin Med J (Engl). 2008;121(10):887-91. Exclude - no outcomes of interest. [pmid: 18706201].
Macaione F, Montaina C, Evola S, et al. Impact of Dual Antiplatelet Therapy with Proton Pump Inhibitors on the Outcome of Patients with Acute Coronary Syndrome Undergoing Drug-Eluting Stent Implantation. ISRN Cardiol. 2012;2012:692761. Exclude - no active comparator. [pmid: 22792485].
Machraoui A, Germing A, von Dryander S, et al. High Pressure Coronary Stenting: Efficacy and Safety of Aspirin Versus Coumadin Plus Aspirin N Preliminary Results of a Randomized Study. J Invasive Cardiol. 1997;9(3):171-176. Exclude - no active comparator. [pmid: 10762894].
Machraoui A, Germing A, von Dryander S, et al. Comparison of the efficacy and safety of aspirin alone with coumadin plus aspirin after provisional coronary stenting: final and follow-up results of a randomized study. Am Heart J. 1999;138(4 Pt 1):663-9. Exclude - no active comparator. [pmid: 10502211].
Macie C, Forbes L, Foster GA, et al. Dosing practices and risk factors for bleeding in patients receiving enoxaparin for the treatment of an acute coronary syndrome. Chest. 2004;125(5):1616-21. Exclude - no active comparator. [pmid: 15136367].
Macri M, Patti G, Pasceri V, et al. Safety and efficacy comparison of bivalirudin vs unfractionated heparin in high-risk patients undergoing percutaneous coronary intervention. Final results from the armyda-7 bivalve study. Giornale Italiano di Cardiologia. 2011;12(12):e147. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Madan M, Labinaz M, Cohen EA, et al. A comparison of clinical outcomes between Canadian and American patients after nonurgent coronary stenting. Can J Cardiol. 2004;20(13):1343-9. Exclude - no active comparator. [pmid: 15570357].
Madan M, Marquis JF, de May MR, et al. Coronary stenting in unstable angina: early and late clinical outcomes. Can J Cardiol. 1998;14(9):1109-14. Exclude - no active comparator. [pmid: 9779015].
Madan M, Radhakrishnan S, Reis M, et al. Comparison of enoxaparin versus heparin during elective percutaneous coronary intervention performed with either eptifibatide or tirofiban (the ACTION Trial). Am J Cardiol. 2005;95(11):1295-301. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15904632].
Madsen JK, Chevalier B, Darius H, et al. Ischaemic events and bleeding in patients undergoing percutaneous coronary intervention with concomitant bivalirudin treatment. EuroIntervention. 2008;3(5):610-6. Exclude - no active comparator. [pmid: 19608489].
Magid DJ, Masoudi FA, Vinson DR, et al. Older emergency department patients with acute myocardial infarction receive lower quality of care than younger patients. Ann Emerg Med. 2005;46(1):14-21. Exclude - no active comparator. [pmid: 15988420].
Magnani B, Dal Palu C, Zanchetti A. Current standard of care in patients affected by coronary heart disease in Italy: the MC'95 study. Ital Heart J. 2002;3(2):86-95. Exclude - no active comparator. [pmid: 11926017].
Mahabaleshwarkar R, Yang Y, Datar M, et al. Risk of adverse cardiovascular outcomes associated with concomitant use of clopidogrel and proton pump inhibitors in elderly medicare beneficiaries. Value in Health. 2012;15(4):A112. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Mahaffey KW, Harrington RA, Simoons ML, et al. Stroke in patients with acute coronary syndromes: incidence and outcomes in the platelet glycoprotein IIb/IIIa in unstable angina. Receptor suppression using integrilin therapy (PURSUIT) trial. The PURSUIT Investigators. Circulation. 1999;99(18):2371-7. Exclude - no outcomes of interest. [pmid: 10318656].
Mahaffey KW, Roe MT, Kilaru R, et al. Characterization of myocardial infarction as an end point in two large trials of acute coronary syndromes. Am J Cardiol. 2005;95(12):1404-8. Exclude - no active comparator. [pmid: 15950560].
Mahaffey KW, Tonev ST, Spinler SA, et al. Obesity in patients with non-ST-segment elevation acute coronary syndromes: results from the SYNERGY trial. Int J Cardiol. 2010;139(2):123-33. Exclude - no active comparator. [pmid: 19012977].
Mahaffey KW, Yang Q, Pieper KS, et al. Prediction of one-year survival in high-risk patients with acute coronary syndromes: results from the SYNERGY trial. J Gen Intern Med. 2008;23(3):310-6. Exclude - no outcomes of interest. [pmid: 18196350].
Mahmoudi M, Syed AI, Ben-Dor I, et al. Safety and efficacy of clopidogrel reloading in patients on chronic clopidogrel therapy who present with an acute coronary syndrome and undergo percutaneous coronary intervention. Am J Cardiol. 2011;107(12):1779-82. Exclude -no outcomes of interest. [pmid: 21640217].
Mahoney E, Wang K, Yang BM, et al. Hospitalization costs in South Korea for patients without identified risk factors for bleeding who have acute coronary syndromes with planned percutaneous coronary intervention treated with prasugrel vs. clopidogrel in the TRITON-TIMI 38 trial. Value Health. 2010;13(7):A348. Exclude - not original peer-reviewed data.
Mahoney EM, Jurkovitz CT, Chu H, et al. Cost and cost-effectiveness of an early invasive vs conservative strategy for the treatment of unstable angina and non-ST-segment elevation myocardial infarction. JAMA. 2002;288(15):1851-8. Exclude - no active comparator. [pmid: 12377083].
Mahoney EM, Mehta S, Yuan Y, et al. Long-term cost-effectiveness of early and sustained clopidogrel therapy for up to 1 year in patients undergoing percutaneous coronary intervention after presenting with acute coronary syndromes without ST-segment elevation. Am Heart J. 2006;151(1):219-27. Exclude - no outcomes of interest. [pmid: 16368322].
Mainie PM, Moore G, Riddell JW, et al. To examine the effectiveness of a hospital-based nurse-led secondary prevention clinic. Eur J Cardiovasc Nurs. 2005;4(4):308-13. Exclude - no active comparator. [pmid: 15993647].
Mak KH, Bhatt DL, Shao M, et al. Ethnic variation in adverse cardiovascular outcomes and bleeding complications in the Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management, and Avoidance (CHARISMA) study. Am Heart J. 2009;157(4):658-65. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19332192].
Makkar R, Goff B, Eigler N, et al. Effect of glycoprotein IIb/IIIa inhibition without thrombolytic therapy on reperfusion in acute myocardial infarction: results of ReoMI pilot study. Catheter Cardiovasc Interv. 1999;48(4):430-4. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10559827].
Mangano DT. Aspirin and mortality from coronary bypass surgery. N Engl J Med. 2002;347(17):1309-17. Exclude - no outcomes of interest. [pmid: 12397188].
Mann T, Cubeddu RJ, Raynor L, et al. Coronary stenting in stable patients: identification of a low-risk subgroup that may not require adjunctive antiplatelet therapy. Catheter Cardiovasc Interv. 2003;58(4):459-66. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12652495].
Manolis AS, Chiladakis J, Hahalis G, et al. Initial experience with a newer generation coronary stent. J Invasive Cardiol. 2001;13(3):217-22. Exclude - no active comparator. [pmid: 11231647].
Manzano-Fernandez S, Marin F, Pastor-Perez FJ, et al. Impact of chronic kidney disease on major bleeding complications and mortality in patients with indication for oral anticoagulation undergoing coronary stenting. Chest. 2009;135(4):983-90. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19017872].
Manzano-Fernandez S, Pastor FJ, Marin F, et al. Increased major bleeding complications related to triple antithrombotic therapy usage in patients with atrial fibrillation undergoing percutaneous coronary artery stenting. Chest. 2008;134(3):559-67. Exclude - no outcomes of interest. [pmid: 18641090].
Marcucci R, Gori AM, Paniccia R, et al. Cardiovascular death and nonfatal myocardial infarction in acute coronary syndrome patients receiving coronary stenting are predicted by residual platelet reactivity to ADP detected by a point-of-care assay: a 12-month follow-up. Circulation. 2009;119(2):237-42. Exclude - no outcomes of interest. [pmid: 19118249].
Marcucci R, Gori AM, Paniccia R, et al. High on-treatment platelet reactivity by more than one agonist predicts 12-month follow-up cardiovascular death and non-fatal myocardial infarction in acute coronary syndrome patients receiving coronary stenting. Thromb Haemost. 2010;104(2):279-86. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 20508896].
Mardikar HM, Hiremath MS, Moliterno DJ, et al. Optimal platelet inhibition in patients undergoing PCI: data from the Multicenter Registry of High-Risk Percutaneous Coronary Intervention and Adequate Platelet Inhibition (MR PCI) study. Am Heart J. 2007;154(2):344 e1-5. Exclude -no outcomes of interest. [pmid: 17643586].
Maresta A, Balducelli M, Latini R, et al. Starc II, a multicenter randomized placebo-controlled double-blind clinical trial of trapidil for 1-year clinical events and angiographic restenosis reduction after coronary angioplasty and stenting. Catheter Cardiovasc Interv. 2005;64(3):375-82. Exclude - no active comparator. [pmid: 15736248].
Mariani M, Mariani G, De Servi S. Efficacy and safety of prasugrel compared with clopidogrel in patients with acute coronary syndromes: results of TRITON-TIMI 38 trials. Expert Rev Cardiovasc Ther. 2009;7(1):17-23. Exclude -not original peer-reviewed data. [pmid: 19105763].
Mark DB, Pan W, Clapp-Channing NE, et al. Quality of life after late invasive therapy for occluded arteries. N Engl J Med. 2009;360(8):774-83. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19228620].
Marmur JD, Mitre CA, Barnathan E, et al. Benefit of bolus-only platelet glycoprotein IIb/IIIa inhibition during percutaneous coronary intervention: insights from the very early outcomes in the Evaluation of 7E3 for the Prevention of Ischemic Complications (EPIC) trial. Am Heart J. 2006;152(5):876-81. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17070148].
Marmur JD, Poludasu S, Lazar J, et al. Long-term mortality after bolus-only administration of abciximab, eptifibatide, or tirofiban during percutaneous coronary intervention. Catheter Cardiovasc Interv. 2009;73(2):214-21. Exclude - no outcomes of interest. [pmid: 19156882].
Maron DJ, Spertus JA, Mancini GB, et al. Impact of an initial strategy of medical therapy without percutaneous coronary intervention in high-risk patients from the Clinical Outcomes Utilizing Revascularization and Aggressive DruG Evaluation (COURAGE) trial. Am J Cardiol. 2009;104(8):1055-62. Exclude - no active comparator. [pmid: 19801024].
Maroo A, Lincoff AM. Bivalirudin in PCI: an overview of the REPLACE-2 trial. Semin Thromb Hemost. 2004;30(3):329-36. Exclude - not a Clinical Study. [pmid: 15282655].
Marrugat J, Garcia M, Elosua R, et al. Short-term (28 days) prognosis between genders according to the type of coronary event (Q-wave versus non-Q-wave acute myocardial infarction versus unstable angina pectoris). Am J Cardiol. 2004;94(9):1161-5. Exclude - no active comparator. [pmid: 15518611].
Marso SP, Bhatt DL, Roe MT, et al. Enhanced efficacy of eptifibatide administration in patients with acute coronary syndrome requiring in-hospital coronary artery bypass grafting. PURSUIT Investigators. Circulation. 2000;102(24):2952-8. Exclude - no outcomes of interest. [pmid: 11113045].
Marso SP, Giorgi LV, Johnson WL, et al. Diabetes mellitus is associated with a shift in the temporal risk profile of inhospital death after percutaneous coronary intervention: an analysis of 25,223 patients over 20 years. Am Heart J. 2003;145(2):270-7. Exclude - no active comparator. [pmid: 12595844].
Marso SP, Lincoff AM, Ellis SG, et al. Optimizing the percutaneous interventional outcomes for patients with diabetes mellitus: results of the EPISTENT (Evaluation of platelet IIb/IIIa inhibitor for stenting trial) diabetic substudy. Circulation. 1999;100(25):2477-84. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10604884].
Martin JL, Fry ET, Martin T, et al. The pharmacodynamics of enoxaparin in percutaneous coronary intervention with precise rapid enoxaparin loading (PEPCI-PRE study). J Thromb Thrombolysis. 2009;28(2):224-8. Exclude - no outcomes of interest. [pmid: 19291367].
Masoudi FA, Plomondon ME, Magid DJ, et al. Renal insufficiency and mortality from acute coronary syndromes. Am Heart J. 2004;147(4):623-9. Exclude - no active comparator. [pmid: 15077076].
Matar F, Donoghue C, Rossi P, et al. Angiographic and clinical outcomes of bivalirudin versus heparin in patients with acute coronary syndrome undergoing percutaneous coronary intervention. Can J Cardiol. 2006;22(13):1139-45. Exclude -no outcomes of interest. [pmid: 17102832].
Mathew V, Gersh BJ, Williams BA, et al. Outcomes in patients with diabetes mellitus undergoing percutaneous coronary intervention in the current era: a report from the Prevention of REStenosis with Tranilast and its Outcomes (PRESTO) trial. Circulation. 2004;109(4):476-80. Exclude - no active comparator. [pmid: 14732749].
Mattichak SJ, Reed PS, Gallagher MJ, et al. Evaluation of safety of warfarin in combination with antiplatelet therapy for patients treated with coronary stents for acute myocardial infarction. J Interv Cardiol. 2005;18(3):163-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15966919].
Mattioli AV, Castellani ET, Goedecke L, et al. Efficacy and tolerability of a very low molecular weight heparin compared with standard heparin in patients with unstable angina: a pilot study. Clin Cardiol. 1999;22(3):213-7. Exclude - no active comparator. [pmid: 10084064].
Mauri L, Kereiakes DJ, Normand SL, et al. Rationale and design of the dual antiplatelet therapy study, a prospective, multicenter, randomized, double-blind trial to assess the effectiveness and safety of 12 versus 30 months of dual antiplatelet therapy in subjects undergoing percutaneous coronary intervention with either drug-eluting stent or bare metal stent placement for the treatment of coronary artery lesions. Am Heart J. 2010;160(6):1035-41. 1041 e1. Exclude - no outcomes of interest. [pmid: 21146655].
Mauskopf JA, Graham JB, Bae JP, et al. Cost-effectiveness of prasugrel in a US managed care population. J Med Econ. 2011. Exclude - not original peer-reviewed data. [pmid: 22066985].
Maxwell CB, Holdford DA, Crouch MA, et al. Cost-effectiveness analysis of anticoagulation strategies in non-ST-elevation acute coronary syndromes. Ann Pharmacother. 2009;43(4):586-95. Exclude - no outcomes of interest. [pmid: 19336655].
Mazur W, Kaluza GL, Sapp S, et al. Glycoprotein IIb-IIIa inhibition with abciximab and postprocedural risk assessment: lessons from the evaluation of platelet IIb/IIIa inhibitor for stenting trial and implication for ad hoc use of glycoprotein IIb-IIIa antagonists. Am Heart J. 2002;143(4):594-601. Exclude - no active comparator. [pmid: 11923795].
Mazurek M, Kowalczyk J, Lenarczyk R, et al. The impact of unsuccessful percutaneous coronary intervention on short- and long-term prognosis in STEMI and NSTEMI. Catheter Cardiovasc Interv. 2011;78(4):514-22. Exclude - no active comparator. [pmid: 21626653].
McClure MW, Berkowitz SD, Sparapani R, et al. Clinical significance of thrombocytopenia during a non-ST-elevation acute coronary syndrome. The platelet glycoprotein IIb/IIIa in unstable angina: receptor suppression using integrilin therapy (PURSUIT) trial experience. Circulation. 1999;99(22):2892-900. Exclude -no outcomes of interest. [pmid: 10359733].
McCollam P, Nasuti P, Rex J, et al. Use of proton pump inhibitors (PPIS) in acute coronary syndrome patients treated with clopidogrel in Germany, France, and the United Kingdom. Value Health. 2010;13(7):A364-A365. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
McCullough PA, Gibson CM, Dibattiste PM, et al. Timing of angiography and revascularization in acute coronary syndromes: an analysis of the TACTICS-TIMI-18 trial. J Interv Cardiol. 2004;17(2):81-6. Exclude - no active comparator. [pmid: 15104769].
McGuire DK, Emanuelsson H, Granger CB, et al. Influence of diabetes mellitus on clinical outcomes across the spectrum of acute coronary syndromes. Findings from the GUSTO-IIb study. GUSTO IIb Investigators. Eur Heart J. 2000;21(21):1750-8. Exclude - no active comparator. [pmid: 11052839].
McKay RG, Boden WE. Small peptide GP IIb/IIIa receptor inhibitors as upstream therapy in non-ST-segment elevation acute coronary syndromes: results of the PURSUIT, PRISM, PRISM-PLUS, TACTICS, and PARAGON trials. Curr Opin Cardiol. 2001;16(6):364-9. Exclude - not a Clinical Study. [pmid: 11704707].
McLeod AL, Brooks L, Taylor V, et al. Secondary prevention for coronary artery disease. QJM. 2004;97(3):127-31. Exclude - no active comparator. [pmid: 14976269].
Medina A, Suarez de Lezo J, Pan M, et al. Sirolimus-eluting stents for treatment of in-stent restenosis: immediate and late results. Tex Heart Inst J. 2005;32(1):11-5. Exclude - no active comparator. [pmid: 15902815].
Mega JL, Braunwald E, Mohanavelu S, et al. Rivaroxaban versus placebo in patients with acute coronary syndromes (ATLAS ACS-TIMI 46): a randomised, double-blind, phase II trial. Lancet. 2009;374(9683):29-38. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19539361].
Mega JL, Braunwald E, Wiviott SD, et al. Rivaroxaban in Patients with a Recent Acute Coronary Syndrome. N Engl J Med. 2011. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22077192].
Mega JL, Morrow DA, Sabatine MS, et al. Correlation between the TIMI risk score and high-risk angiographic findings in non-ST-elevation acute coronary syndromes: observations from the Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) trial. Am Heart J. 2005;149(5):846-50. Exclude - no active comparator. [pmid: 15894966].
Mehilli J, Kastrati A, Schuhlen H, et al. Randomized clinical trial of abciximab in diabetic patients undergoing elective percutaneous coronary interventions after treatment with a high loading dose of clopidogrel. Circulation. 2004;110(24):3627-35. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15531766].
Mehran R, Aymong ED, Ashby DT, et al. Safety of an aspirin-alone regimen after intracoronary stenting with a heparin-coated stent: final results of the HOPE (HEPACOAT and an Antithrombotic Regimen of Aspirin Alone) study. Circulation. 2003;108(9):1078-83. Exclude - no active comparator. [pmid: 12925457].
Mehta RH, Roe MT, Mulgund J, et al. Acute clopidogrel use and outcomes in patients with non-ST-segment elevation acute coronary syndromes undergoing coronary artery bypass surgery. J Am Coll Cardiol. 2006;48(2):281-6. Exclude - no outcomes of interest. [pmid: 16843176].
Mehta SR, Eikelboom JW, Demers C, et al. Congestive heart failure complicating non-ST segment elevation acute coronary syndrome: incidence, predictors, and clinical outcomes. Can J Physiol Pharmacol. 2005;83(1):98-103. Exclude - no active comparator. [pmid: 15759056].
Mehta SR, Eikelboom JW, Rupprecht HJ, et al. Efficacy of hirudin in reducing cardiovascular events in patients with acute coronary syndrome undergoing early percutaneous coronary intervention. Eur Heart J. 2002;23(2):117-23. Exclude - no active comparator. [pmid: 11785993].
Mehta SR, Eikelboom JW, Yusuf S. Long-term management of unstable angina and non-Q-wave myocardial infarction. Eur Heart J Suppl. 2000;2(E):E6-E12. Exclude - not a Clinical Study.
Mehta SR, Granger CB, Boden WE, et al. Early versus delayed invasive intervention in acute coronary syndromes. N Engl J Med. 2009;360(21):2165-75. Exclude -no outcomes of interest. [pmid: 19458363].
Merchant FM, Weiner RB, Rao SR, et al. In-hospital outcomes of emergent and elective percutaneous coronary intervention in octogenarians. Coron Artery Dis. 2009;20(2):118-23. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19293712].
Michalis LK, Katsouras CS, Papamichael N, et al. Enoxaparin versus tinzaparin in non-ST-segment elevation acute coronary syndromes: the EVET trial. Am Heart J. 2003;146(2):304-10. Exclude - no active comparator. [pmid: 12891200].
Michalis LK, Stroumbis CS, Pappas K, et al. Treatment of refractory unstable angina in geographically isolated areas without cardiac surgery. Invasive versus conservative strategy (TRUCS study). Eur Heart J. 2000;21(23):1954-9. Exclude - no outcomes of interest. [pmid: 11071801].
Michelson AD, Frelinger AL 3rd, Braunwald E, et al. Pharmacodynamic assessment of platelet inhibition by prasugrel vs. clopidogrel in the TRITON-TIMI 38 trial. Eur Heart J. 2009;30(14):1753-63. Exclude -no outcomes of interest. [pmid: 19435740].
Miguel Angel Ramirez-Marrero MA, Jimenez-Navarro M, Garcia-Pinilla JM, et al. Are there gender differences in the long-term prognosis of patients with non-STsegment-elevation coronary syndromes following hospital discharge?. Eur J Cardiovasc Prev Rehabil. 2011;18(1):S110. Exclude - not original peer-reviewed data.
Miller C, Lipscomb K, Curzen N. Are district general hospital patients with unstable angina at a disadvantage?. Postgrad Med J. 2003;79(928):93-8. Exclude - no active comparator. [pmid: 12612324].
Miller L, Gupta A, Bertolet BD. Use of clopidogrel loading, enoxaparin, and double-bolus eptifibatide in the setting of early percutaneous coronary intervention for acute coronary syndromes. J Invasive Cardiol. 2002;14(5):247-50. Exclude - no active comparator. [pmid: 11983945].
Minai K, Horie H, Takahashi M, et al. Long-term outcome of primary percutaneous transluminal coronary angioplasty for low-risk acute myocardial infarction in patients older than 80 years: a single-center, open, randomized trial. Am Heart J. 2002;143(3):497-505. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11868057].
Miner P Jr., Katz PO, Chen Y, et al. Gastric acid control with esomeprazole, lansoprazole, omeprazole, pantoprazole, and rabeprazole: a five-way crossover study. Am J Gastroenterol. 2003;98(12):2616-20. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14687806].
Mishkel GJ, Moore AL, Markwell SJ, et al. Bivalirudin versus heparin plus glycoprotein IIb/IIIa inhibitors in drug-eluting stent implantations in the absence of acute myocardial infarction: clinical and economic results. J Invasive Cardiol. 2007;19(2):63-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17268039].
Mitka M. Results of CURE trial for acute coronary syndrome. JAMA. 2001;285(14):1828-9. Exclude - not a Clinical Study. [pmid: 11308379].
Mitra S, Findley K, Frohnapple D, et al. Trends in long-term management of survivors of acute myocardial infarction by cardiologists in a government university-affiliated teaching hospital. Clin Cardiol. 2002;25(1):16-8. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11808833].
Mitrovska S, Jovanova S. Low-molecular weight heparin enoxaparin in the treatment of acute coronary syndromes without ST segment elevation. Bratisl Lek Listy. 2009;110(1):45-8. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19408831].
Moliterno DJ, Hermiller JB, Kereiakes DJ, et al. A novel point-of-care enoxaparin monitor for use during percutaneous coronary intervention. Results of the Evaluating Enoxaparin Clotting Times (ELECT) Study. J Am Coll Cardiol. 2003;42(6):1132-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 13678943].
Montalescot G, Bal-dit-Sollier C, Chibedi D, et al. Comparison of effects on markers of blood cell activation of enoxaparin, dalteparin, and unfractionated heparin in patients with unstable angina pectoris or non-ST-segment elevation acute myocardial infarction (the ARMADA study). Am J Cardiol. 2003;91(8):925-30. Exclude - no outcomes of interest. [pmid: 12686329].
Montalescot G, Barragan P, Wittenberg O, et al. Platelet glycoprotein IIb/IIIa inhibition with coronary stenting for acute myocardial infarction. N Engl J Med. 2001;344(25):1895-903. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11419426].
Montalescot G, Bolognese L, Dudek D, et al. A comparison of prasugrel at the time of percutaneous coronary intervention or as pretreatment at the time of diagnosis in patients with non-ST-segment elevation myocardial infarction: design and rationale for the ACCOAST study. Am Heart J. 2011;161(4):650-656 e1. Exclude -no outcomes of interest. [pmid: 21473962].
Montalescot G, Collet JP, Lison L, et al. Effects of various anticoagulant treatments on von Willebrand factor release in unstable angina. J Am Coll Cardiol. 2000;36(1):110-4. Exclude - no outcomes of interest. [pmid: 10898421].
Montalescot G, Collet JP, Tanguy ML, et al. Anti-Xa activity relates to survival and efficacy in unselected acute coronary syndrome patients treated with enoxaparin. Circulation. 2004;110(4):392-8. Exclude - no active comparator. [pmid: 15249498].
Montalescot G, Ongen Z, Guindy R, et al. Predictors of outcome in patients undergoing PCI. Results of the RIVIERA study. Int J Cardiol. 2008;129(3):379-87. Exclude - no outcomes of interest. [pmid: 18055032].
Montalescot G, Philippe F, Ankri A, et al. Early increase of von Willebrand factor predicts adverse outcome in unstable coronary artery disease: beneficial effects of enoxaparin. French Investigators of the ESSENCE Trial. Circulation. 1998;98(4):294-9. Exclude - no outcomes of interest. [pmid: 9711933].
Montalescot G, Van de Werf F, Gulba DC, et al. Stenting and glycoprotein IIb/IIIa inhibition in patients with acute myocardial infarction undergoing percutaneous coronary intervention: findings from the global registry of acute coronary events (GRACE). Catheter Cardiovasc Interv. 2003;60(3):360-7. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14571488].
Moreno R, Zamorano JL, Serra V, et al. Myocardial perfusion in real-time using power modulation. In vivo evidence for microcirculatory damage after acute myocardial infarction. Int J Cardiol. 2003;91(2-3):187-91. Exclude - no active comparator. [pmid: 14559129].
Morrow DA, Antman EM, Snapinn SM, et al. An integrated clinical approach to predicting the benefit of tirofiban in non-ST elevation acute coronary syndromes. Application of the TIMI Risk Score for UA/NSTEMI in PRISM-PLUS. Eur Heart J. 2002;23(3):223-9. Exclude - no outcomes of interest. [pmid: 11792137].
Moscucci M, Share D, Smith D, et al. Relationship between operator volume and adverse outcome in contemporary percutaneous coronary intervention practice: an analysis of a quality-controlled multicenter percutaneous coronary intervention clinical database. J Am Coll Cardiol. 2005;46(4):625-32. Exclude - no active comparator. [pmid: 16098426].
Moses JW, Mehran R, Nikolsky E, et al. Outcomes with the paclitaxel-eluting stent in patients with acute coronary syndromes: analysis from the TAXUS-IV trial. J Am Coll Cardiol. 2005;45(8):1165-71. Exclude - no active comparator. [pmid: 15837244].
Moshfegh K, Redondo M, Julmy F, et al. Antiplatelet effects of clopidogrel compared with aspirin after myocardial infarction: enhanced inhibitory effects of combination therapy. J Am Coll Cardiol. 2000;36(3):699-705. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10987587].
Motivala AA, Cannon CP, Srinivas VS, et al. Changes in myocardial infarction guideline adherence as a function of patient risk: an end to paradoxical care?. J Am Coll Cardiol. 2011;58(17):1760-5. Exclude - no active comparator. [pmid: 21996387].
Moukarbel GV, Signorovitch JE, Pfeffer MA, et al. Gastrointestinal bleeding in high risk survivors of myocardial infarction: the VALIANT Trial. Eur Heart J. 2009;30(18):2226-32. Exclude - no outcomes of interest. [pmid: 19556260].
Mould D, Chapelsky M, Aluri J, et al. A population pharmacokinetic-pharmacodynamic and logistic regression analysis of lotrafiban in patients. Clin Pharmacol Ther. 2001;69(4):210-22. Exclude - no active comparator. [pmid: 11309549].
Mudrick DW, Chen AY, Roe MT, et al. Changes in glycoprotein IIb/IIIa inhibitor excess dosing with site-specific safety feedback in the Can Rapid risk stratification of Unstable angina patients Suppress ADverse outcomes with Early implementation of the ACC/AHA guidelines (CRUSADE) initiative. Am Heart J. 2010;160(6):1072-8. Exclude - no active comparator. [pmid: 21146660].
Mueller C, Buettner HJ, Hodgson JM, et al. Inflammation and long-term mortality after non-ST elevation acute coronary syndrome treated with a very early invasive strategy in 1042 consecutive patients. Circulation. 2002;105(12):1412-5. Exclude - no active comparator. [pmid: 11914246].
Mueller C, Neumann FJ, Perruchoud AP, et al. Renal function and long term mortality after unstable angina/non-ST segment elevation myocardial infarction treated very early and predominantly with percutaneous coronary intervention. Heart. 2004;90(8):902-7. Exclude - no active comparator. [pmid: 15253964].
Mueller C, Neumann FJ, Roskamm H, et al. Women do have an improved long-term outcome after non-ST-elevation acute coronary syndromes treated very early and predominantly with percutaneous coronary intervention: a prospective study in 1,450 consecutive patients. J Am Coll Cardiol. 2002;40(2):245-50. Exclude - no active comparator. [pmid: 12106927].
Mueller C, Roskamm H, Neumann FJ, et al. A randomized comparison of clopidogrel and aspirin versus ticlopidine and aspirin after the placement of coronary artery stents. J Am Coll Cardiol. 2003;41(6):969-73. Exclude - no active comparator. [pmid: 12651043].
Muhlestein JB, Anderson JL, Cui C, et al. Improved long-term survival associated with stent deployment during percutaneous coronary interventions: results from a registry of 3399 patients. Am Heart J. 2005;150(1):182-7. Exclude - no active comparator. [pmid: 16084167].
Mukherjee D, Mahaffey KW, Moliterno DJ, et al. Promise of combined low-molecular-weight heparin and platelet glycoprotein IIb/IIIa inhibition: results from Platelet IIb/IIIa Antagonist for the Reduction of Acute coronary syndrome events in a Global Organization Network B (PARAGON B). Am Heart J. 2002;144(6):995-1002. Exclude - no active comparator. [pmid: 12486423].
Mukherjee D, Reginelli JP, Moliterno DJ, et al. Unexpected mortality reduction with abciximab for in-stent restenosis. J Invasive Cardiol. 2000;12(11):540-4. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11060563].
Mukherjee D, Topol EJ, Moliterno DJ, et al. Extracardiac vascular disease and effectiveness of sustained clopidogrel treatment. Heart. 2006;92(1):49-51. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15845611].
Muller C, Buttner HJ, Petersen J, et al. A randomized comparison of clopidogrel and aspirin versus ticlopidine and aspirin after the placement of coronary-artery stents. Circulation. 2000;101(6):590-3. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10673248].
Muller C, Neumann FJ, Ferenc M, et al. Impact of diabetes mellitus on long-term outcome after unstable angina and non-ST-segment elevation myocardial infarction treated with a very early invasive strategy. Diabetologia. 2004;47(7):1188-95. Exclude - no active comparator. [pmid: 15235772].
Muller D, Schnitzer L, Brandt J, et al. The accuracy of an out-of-hospital 12-lead ECG for the detection of ST-elevation myocardial infarction immediately after resuscitation. Ann Emerg Med. 2008;52(6):658-64. Exclude - no outcomes of interest. [pmid: 18722690].
Muller I, Seyfarth M, Rudiger S, et al. Effect of a high loading dose of clopidogrel on platelet function in patients undergoing coronary stent placement. Heart. 2001;85(1):92-3. Exclude -no outcomes of interest. [pmid: 11119474].
Muller-Nordhorn J, Kulig M, Binting S, et al. Regional variation in medication following coronary events in Germany. Int J Cardiol. 2005;102(1):47-53. Exclude - no active comparator. [pmid: 15939098].
Munoz-Torrero JF, Escudero D, Suarez C, et al. Concomitant use of proton pump inhibitors and clopidogrel in patients with coronary, cerebrovascular, or peripheral artery disease in the factores de Riesgo y ENfermedad Arterial (FRENA) registry. J Cardiovasc Pharmacol. 2011;57(1):13-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 21164357].
Musumeci G, Rossini R, Lettieri C, et al. Prognostic implications of early and long-term bleeding events in patients on one-year dual antiplatelet therapy following drug-eluting stent implantation. Catheter Cardiovasc Interv. 2011. Exclude -no active comparator. [pmid: 22109961].
Naidu SS, Krucoff MW, Rutledge DR, et al. Contemporary Incidence and Predictors of Stent Thrombosis and Other Major Adverse Cardiac Events in the Year After XIENCE V Implantation: Results From the 8,061-Patient XIENCE V United States Study. JACC Cardiovasc Interv. 2012;5(6):626-35. Exclude - no active comparator. [pmid: 22721657].
Nakamura M, Yamashita T, Yajima J, et al. Clinical outcome after acute coronary syndrome in Japanese patients: an observational cohort study. J Cardiol. 2010;55(1):69-76. Exclude - no active comparator. [pmid: 20122551].
Natarajan MK, Velianou JL, Turpie AG, et al. A randomized pilot study of dalteparin versus unfractionated heparin during percutaneous coronary interventions. Am Heart J. 2006;151(1):175. Exclude - no active comparator. [pmid: 16368313].
Ndrepepa G, Kastrati A, Neumann FJ, et al. Five-year outcome of patients with acute myocardial infarction enrolled in a randomised trial assessing the value of abciximab during coronary artery stenting. Eur Heart J. 2004;25(18):1635-40. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15351163].
Ndrepepa G, Mehilli J, Bollwein H, et al. Sex-associated differences in clinical outcomes after coronary stenting in patients with diabetes mellitus. Am J Med. 2004;117(11):830-6. Exclude - no active comparator. [pmid: 15589486].
Neri Serneri GG, Modesti PA, Gensini GF, et al. Randomised comparison of subcutaneous heparin, intravenous heparin, and aspirin in unstable angina. Studio Epoorine Sottocutanea nell'Angina Instobile (SESAIR) Refrattorie Group. Lancet. 1995;345(8959):1201-4. Exclude -no active comparator. [pmid: 7739307].
Neumann FJ, Blasini R, Schmitt C, et al. Effect of glycoprotein IIb/IIIa receptor blockade on recovery of coronary flow and left ventricular function after the placement of coronary-artery stents in acute myocardial infarction. Circulation. 1998;98(24):2695-701. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9851955].
Neumann FJ, Kastrati A, Pogatsa-Murray G, et al. Evaluation of prolonged antithrombotic pretreatment (“cooling-off” strategy) before intervention in patients with unstable coronary syndromes: a randomized controlled trial. JAMA. 2003;290(12):1593-9. Exclude -no active comparator. [pmid: 14506118].
Neumann FJ, Kastrati A, Schmitt C, et al. Effect of glycoprotein IIb/IIIa receptor blockade with abciximab on clinical and angiographic restenosis rate after the placement of coronary stents following acute myocardial infarction. J Am Coll Cardiol. 2000;35(4):915-21. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10732888].
Newby LK, Bhapkar MV, White HD, et al. Aspirin use post-acute coronary syndromes: intolerance, bleeding and discontinuation. J Thromb Thrombolysis. 2003;16(3):119-28. Exclude - no active comparator. [pmid: 15087598].
Newby LK, Bhapkar MV, White HD, et al. Predictors of 90-day outcome in patients stabilized after acute coronary syndromes. Eur Heart J. 2003;24(2):172-81. Exclude - no active comparator. [pmid: 12573274].
Newby LK, Harrington RA, Bhapkar MV, et al. An automated strategy for bedside aPTT determination and unfractionated heparin infusion adjustment in acute coronary syndromes: insights from PARAGON A. J Thromb Thrombolysis. 2002;14(1):33-42. Exclude - no outcomes of interest. [pmid: 12652148].
Newby LK, Ohman EM, Christenson RH, et al. Benefit of glycoprotein IIb/IIIa inhibition in patients with acute coronary syndromes and troponin t-positive status: the paragon-B troponin T substudy. Circulation. 2001;103(24):2891-6. Exclude - no outcomes of interest. [pmid: 11413076].
Niccoli G, Giubilato S, Leo A, et al. Predictors of thromboxane levels in patients with non-ST-elevation acute coronary syndromes on chronic aspirin therapy. Thromb Haemost. 2012;108(1):133-9. Exclude - no outcomes of interest. [pmid: 22535468].
Nicolau JC, Franken M, Lotufo PA, et al. Use of demonstrably effective therapies in the treatment of acute coronary syndromes: comparison between different brazilian regions. Analysis of the Brazilian Registry on Acute Coronary Syndromes (BRACE). Arq Bras Cardiol. 2012;98(4):282-289. Exclude - no outcomes of interest. [pmid: 22735909].
Nikcevic G, Raspopovic S, Pejic M, et al. Prognostic implications of acute gastrointestinal bleeding in acute coronary syndrome: Intrahospital follow up. Eur Heart J. 2011;32:100. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Nikolic E, Janzon M, Hauch O, et al. Cost-effectiveness of treating acute coronary syndrome patients with ticagrelor for 12 months: results from the PLATO study. Eur Heart J. 2012. Exclude - not a Clinical Study. [pmid: 22719022].
Nilsen DW, Goransson L, Larsen AI, et al. Systemic thrombin generation and activity resistant to low molecular weight heparin administered prior to streptokinase in patients with acute myocardial infarction. Thromb Haemost. 1997;77(1):57-61. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9031450].
Nishida T, Colombo A, Briguori C, et al. Contemporary percutaneous treatment of saphenous vein graft stenosis: immediate and late outcomes. J Invasive Cardiol. 2000;12(10):505-12. Exclude - no active comparator. [pmid: 11022209].
Nishigaki K, Yamazaki T, Kitabatake A, et al. Percutaneous coronary intervention plus medical therapy reduces the incidence of acute coronary syndrome more effectively than initial medical therapy only among patients with low-risk coronary artery disease a randomized, comparative, multicenter study. JACC Cardiovasc Interv. 2008;1(5):469-79. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19463347].
Norhammar A, Malmberg K, Diderholm E, et al. Diabetes mellitus: the major risk factor in unstable coronary artery disease even after consideration of the extent of coronary artery disease and benefits of revascularization. J Am Coll Cardiol. 2004;43(4):585-91. Exclude - no active comparator. [pmid: 14975468].
Noronha BT, Osula S, Andron M, et al. Fondaparinaux substantially reduces bleeding risk as compared to enoxaparin in Non-St Elevation Myocardial Infarction (NSTEMI). American Journal of Cardiology. 2012;109(7):13S-14S. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
O'Connor CM, Gattis WA, Hellkamp AS, et al. Comparison of two aspirin doses on ischemic stroke in post-myocardial infarction patients in the warfarin (Coumadin) Aspirin Reinfarction Study (CARS). Am J Cardiol. 2001;88(5):541-6. Exclude - no outcomes of interest. [pmid: 11524065].
O'Connor FF, Shields DC, Fitzgerald A, et al. Genetic variation in glycoprotein IIb/IIIa (GPIIb/IIIa) as a determinant of the responses to an oral GPIIb/IIIa antagonist in patients with unstable coronary syndromes. Blood. 2001;98(12):3256-60. Exclude - no outcomes of interest. [pmid: 11719362].
Odell A, Gudnason T, Andersson T, et al. One-year outcome after percutaneous coronary intervention for stable and unstable angina pectoris with or without application of general usage of stents in unselected European patient groups. Am J Cardiol. 2002;90(2):112-8. Exclude - no active comparator. [pmid: 12106838].
O'Donoghue ML, Bhatt DL, Wiviott SD, et al. Safety and tolerability of atopaxar in the treatment of patients with acute coronary syndromes: the lessons from antagonizing the cellular effects of Thrombin-Acute Coronary Syndromes Trial. Circulation. 2011;123(17):1843-53. Exclude -no active comparator. [pmid: 21502577].
Ogita M, Nakamura T, Fujiwara N, et al. Long-term clinical follow-up after sirolimus-eluting stent versus bare metal stent implantation in patients with acute coronary syndrome. J Interv Cardiol. 2009;22(3):216-21. Exclude - no outcomes of interest. [pmid: 19490360].
Ohman EM, Kleiman NS, Gacioch G, et al. Combined accelerated tissue-plasminogen activator and platelet glycoprotein IIb/IIIa integrin receptor blockade with Integrilin in acute myocardial infarction. Results of a randomized, placebo-controlled, dose-ranging trial. IMPACT-AMI Investigators. Circulation. 1997;95(4):846-54. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9054741].
Okmen E, Ozen E, Uyarel H, et al. Effects of enoxaparin and nadroparin on major cardiac events in high-risk unstable angina treated with a glycoprotein IIb/IIIa inhibitor. Jpn Heart J. 2003;44(6):899-906. Exclude - no active comparator. [pmid: 14711185].
Oldgren J, Budaj A, Granger CB, et al. Dabigatran vs. placebo in patients with acute coronary syndromes on dual antiplatelet therapy: a randomized, double-blind, phase II trial. Eur Heart J. 2011;32(22):2781-2789. Exclude -no outcomes of interest. [pmid: 21551462].
Oldgren J, Linder R, Grip L, et al. Coagulation activity and clinical outcome in unstable coronary artery disease. Arterioscler Thromb Vasc Biol. 2001;21(6):1059-64. Exclude - no outcomes of interest. [pmid: 11397720].
Oldgren J, Siegbahn A, Grip L, et al. Myocardial damage, coagulation activity and the response to thrombin inhibition in unstable coronary artery disease. Thromb Haemost. 2004;91(2):381-7. Exclude - no active comparator. [pmid: 14961168].
Olsen TS, Rasmussen BH, Kammersgaard LP, et al. Strokes attributable to underuse of warfarin and antiplatelets. J Stroke Cerebrovasc Dis. 2005;14(2):55-57. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17904001].
Oqueli E, Dick R. Percutaneous coronary intervention in very elderly patients. In-hospital mortality and clinical outcome. Heart Lung Circ. 2011;20(10):622-8. Exclude - no active comparator. [pmid: 20926341].
Orford JL, Fasseas P, Melby S, et al. Safety and efficacy of aspirin, clopidogrel, and warfarin after coronary stent placement in patients with an indication for anticoagulation. Am Heart J. 2004;147(3):463-7. Exclude - no active comparator. [pmid: 14999195].
Orlewska E, Budaj A, Tereszkowski-Kaminski D. Cost-effectiveness analysis of enoxaparin versus unfractionated heparin in patients with acute coronary syndrome in Poland: modelling study from the hospital perspective. Pharmacoeconomics. 2003;21(10):737-48. Exclude - no outcomes of interest. [pmid: 12828495].
O'Shea JC, Buller CE, Cantor WJ, et al. Long-term efficacy of platelet glycoprotein IIb/IIIa integrin blockade with eptifibatide in coronary stent intervention. JAMA. 2002;287(5):618-21. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11829701].
O'Shea JC, Tcheng JE. Eptifibatide in Percutaneous Coronary Intervention: The ESPRIT Trial Results. Curr Interv Cardiol Rep. 2001;3(1):62-68. Exclude - not a Clinical Study. [pmid: 11177721].
O'Shea JC, Tcheng JE. Eptifibatide: a potent inhibitor of the platelet receptor integrin glycoprotein IIb/IIIa. Expert Opin Pharmacother. 2002;3(8):1199-210. Exclude - not a Clinical Study. [pmid: 12150697].
Ottervanger JP, Armstrong P, Barnathan ES, et al. Association of revascularisation with low mortality in non-ST elevation acute coronary syndrome, a report from GUSTO IV-ACS. Eur Heart J. 2004;25(17):1494-501. Exclude -no active comparator. [pmid: 15342168].
Ouattara A, Bouzguenda H, Le Manach Y, et al. Impact of aspirin with or without clopidogrel on postoperative bleeding and blood transfusion in coronary surgical patients treated prophylactically with a low-dose of aprotinin. Eur Heart J. 2007;28(8):1025-32. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 17431000].
Owsiak M, Pelc-Nowicka A, Badacz L, et al. Increased prevalence of cardiovascular risk factors in patients with acute coronary syndrome and indications for treatment with oral anticoagulation. Kardiol Pol. 2011;69(9):907-12. Exclude - no active comparator. [pmid: 21928197].
Ozdemir M, Erdem G, Turkoglu S, et al. Head-to-head comparison of two different low-molecular-weight heparins in acute coronary syndrome: a single center experience. Jpn Heart J. 2002;43(5):433-42. Exclude - no active comparator. [pmid: 12452301].
Pache J, Kastrati A, Mehilli J, et al. Clopidogrel therapy in patients undergoing coronary stenting: value of a high-loading-dose regimen. Catheter Cardiovasc Interv. 2002;55(4):436-41. Exclude - no active comparator. [pmid: 11948888].
Palmer ND, Causer JP, Ramsdale DR, et al. Effect of completeness of revascularization on clinical outcome in patients with multivessel disease presenting with unstable angina who undergo percutaneous coronary intervention. J Invasive Cardiol. 2004;16(4):185-8. Exclude - no active comparator. [pmid: 15152143].
Palmerini T, Dangas G, Mehran R, et al. Predictors and Implications of Stent Thrombosis in Non-ST-Segment Elevation Acute Coronary Syndromes: The ACUITY Trial. Circ Cardiovasc Interv. 2011. Exclude - no active comparator. [pmid: 22028471].
Panduranga P, Sulaiman K, Al-Zakwani I, et al. Acute coronary syndrome in young adults from oman: results from the gulf registry of acute coronary events. Heart Views. 2010;11(3):93-8. Exclude - no active comparator. [pmid: 21577375].
Papp E, Havasi V, Bene J, et al. Glycoprotein IIIA gene (PlA) polymorphism and aspirin resistance: is there any correlation?. Ann Pharmacother. 2005;39(6):1013-8. Exclude - no active comparator. [pmid: 15840736].
Pappalardo A, Mamas MA, Imola F, et al. Percutaneous coronary intervention of unprotected left main coronary artery disease as culprit lesion in patients with acute myocardial infarction. JACC Cardiovasc Interv. 2011;4(6):618-26. Exclude - no active comparator. [pmid: 21700247].
Parikh R, Chennareddy S, Debari V, et al. Percutaneous coronary interventions in nonagenarians: in-hospital mortality and outcome at one year follow-up. Clin Cardiol. 2009;32(12):E16-21. Exclude - no active comparator. [pmid: 20014200].
Park DW, Yun SC, Lee SW, et al. Stent thrombosis, clinical events, and influence of prolonged clopidogrel use after placement of drug-eluting stent data from an observational cohort study of drug-eluting versus bare-metal stents. JACC Cardiovasc Interv. 2008;1(5):494-503. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19463351].
Park JS, Lee HC, Lee HW, et al. Prognosis according to the timing of percutaneous coronary intervention in non-ST segment elevation myocardial infarction, based on the Korean Acute Myocardial Infarction Registry (KAMIR). Cardiol J. 2011;18(4):421-9. Exclude - no active comparator. [pmid: 21769823].
Park KH, Jeong MH, Lee MG, et al. Efficacy of triple anti-platelet therapy including cilostazol in acute myocardial infarction patients undergoing drug-eluting stent implantation. Korean Circ J. 2009;39(5):190-7. Exclude - no outcomes of interest. [pmid: 19949578].
Park SJ, Park DW, Kim YH, et al. Duration of dual antiplatelet therapy after implantation of drug-eluting stents. N Engl J Med. 2010;362(15):1374-82. Exclude - no outcomes of interest. [pmid: 20231231].
Parodi G, Bellandi B, Venditti F, et al. Impact of bleedings on prasugrel adherence in real world patients. J Am Coll Cardiol. 2011;58(20):B43. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Parodi G, Marcucci R, Valenti R, et al. High residual platelet reactivity after clopidogrel loading and long-term cardiovascular events among patients with acute coronary syndromes undergoing PCI. JAMA. 2011;306(11):1215-23. Exclude -no active comparator. [pmid: 21934054].
Parodi G, Sciagra R, Migliorini A, et al. A randomized trial comparing clopidogrel versus ticlopidine therapy in patients undergoing infarct artery stenting for acute myocardial infarction with abciximab as adjunctive therapy. Am Heart J. 2005;150(2):220. Exclude - no active comparator. [pmid: 16086921].
Parsons E, Newby LK, Bhapkar MV, et al. Postmenopausal hormone use in women with acute coronary syndromes. J Womens Health (Larchmt). 2004;13(8):863-71. Exclude - no active comparator. [pmid: 15671702].
Pasceri V, Patti G, Pristipino C, et al. Safety of drug eluting stents in patients on chronic anticoagulation using long-term single antiplatelet treatment with clopidogrel. Catheter Cardiovasc Interv. 2010;75(6):936-42. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 20146326].
Pate GE, Curtin R, Talbot A, et al. Audit of acute myocardial infarctions at Saint James's Hospital, Dublin, from 1996 to 1999. Ir Med J. 2002;95(9):274-6. Exclude - no active comparator. [pmid: 12469999].
Patel TN, Goldberg KC. Use of aspirin and ibuprofen compared with aspirin alone and the risk of myocardial infarction. Arch Intern Med. 2004;164(8):852-6. Exclude - no active comparator. [pmid: 15111370].
Patsa C, Toutouzas K, Tsiamis E, et al. The role of dual antiplatelet therapy in late and very late thrombotic events in the era of new generation DES. Eur Heart J. 2011;32:251-252. Exclude - no active comparator. [pmid: 21370551].
Pattanaik S, Malhotra S, Sharma YP, et al. Effect of cilostazol on platelet aggregation in patients with non-ST elevation acute coronary syndrome. Int J Clin Pharmacol Ther. 2010;48(2):93-102. Exclude - no active comparator. [pmid: 20137761].
Pavei A, Oreglia JA, Martin G, et al. Long-term follow-up of percutaneous coronary intervention of unprotected left main lesions with drug eluting stents: predictors of clinical outcome. EuroIntervention. 2009;4(4):457-63. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19284067].
Pavlides G, Coufal Z, Mohacsi A, et al. An international comparison of dual antiplatelet use by stent type at 6 months following hospital discharge after acute coronary syndrome: Results from the antiplatelet treatment observational registry II (APTOR-II). Value Health. 2010;13(7):A365-A366. Exclude - no outcomes of interest.
Pelc-Nowicka A, Bryniarski L, Mirek-Bryniarska E, et al. Dual antiplatelet therapy and antithrombotic treatment in patients with acute coronary syndrome--does everyday medical practice reflects current recommendations? A pilot study. Kardiol Pol. 2009;67(12):1335-41. Exclude -no active comparator. [pmid: 20054764].
Pepe C, Machado M, Olimpio A, et al. Cost-effectiveness of fondaparinux in patients with acute coronary syndrome without ST-segment Elevation. Arq Bras Cardiol. 2012. Exclude -not a Clinical Study. [pmid: 22735867].
Pereira H. The 2002 Portuguese Interventional Cardiology Registry. Rev Port Cardiol. 2004;23(1):7-14. Exclude - no active comparator. [pmid: 15058143].
Perers E, Caidahl K, Herlitz J, et al. Treatment and short-term outcome in women and men with acute coronary syndromes. Int J Cardiol. 2005;103(2):120-7. Exclude - no active comparator. [pmid: 16080968].
Pershukov I, Omarov A, Batyraliev T, et al. Clopidogrel 150 mg/day versus 75 mg/day in real clinical practice of percutaneous coronary interventions. Eur Heart J. 2011;32:245. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Peruga JZ, Krecki R, Krzeminska-Pakual M. Analysis of the rate of restenosis in patients with acute coronary syndrome without ST elevation and concomitant diabetes mellitus type 2 according to the kind of stent. Postepy Kardiol Interwencyjnej. 2011;7(3):206-213. Exclude - no active comparator.
Pesarini G, Ferrero V, Tomai F, et al. Steroid-eluting stents in patients with acute coronary syndromes. Angiographic results of DESIRE: Dexamethasone-Eluting Stent Italian REgistry. J Invasive Cardiol. 2009;21(3):86-91. Exclude - no outcomes of interest. [pmid: 19258636].
Peters S, Trummel M, Meyners W, et al. Valsartan versus ACE inhibition after bare metal stent implantation--results of the VALVACE trial. Int J Cardiol. 2005;98(2):331-5. Exclude - no active comparator. [pmid: 15686787].
Petersen LA, Normand SL, Leape LL, et al. Comparison of use of medications after acute myocardial infarction in the Veterans Health Administration and Medicare. Circulation. 2001;104(24):2898-904. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11739303].
Peterson JG, Topol EJ, Roe MT, et al. Prognostic importance of concomitant heparin with eptifibatide in acute coronary syndromes. PURSUIT Investigators. Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy. Am J Cardiol. 2001;87(5):532-6. Exclude - no active comparator. [pmid: 11230834].
Pfisterer M, Buser P, Osswald S, et al. Invasive and medical management result in similar quality of life at 1 year in elderly people with coronary artery disease. Evid-based Cardiovasc Med. 2003;7(3):119-121. Exclude - not a Clinical Study.
Philpott AC, Southern DA, Clement FM, et al. Long-term outcomes of patients receiving drug-eluting stents. CMAJ. 2009;180(2):167-74. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19095719].
Piamsomboon C, Laothavorn P, Chatlaong B, et al. Effectiveness of clopidogrel and aspirin versus ticlopidine and aspirin after coronary stent implantation: 1 and 6-month follow-up. J Med Assoc Thai. 2001;84(12):1701-7. Exclude - no active comparator. [pmid: 11999816].
Piamsomboon C, Wong PM, Mathur A, et al. Does platelet glycoprotein IIb/IIIa receptor antibody improve in-hospital outcome of coronary stenting in high-risk thrombus containing lesions?. Catheter Cardiovasc Interv. 1999;46(4):415-20. Exclude - no active comparator. [pmid: 10216005].
Picarra BC, Santos AR, Celeiro M, et al. Non-cardiac comorbidities in the very elderly with acute myocardial infarction: prevalence and influence on management and in-hospital mortality. Rev Port Cardiol. 2011;30(4):379-92. Exclude - no active comparator. [pmid: 21815522].
Piper WD, Malenka DJ, Ryan TJ Jr., et al. Predicting vascular complications in percutaneous coronary interventions. Am Heart J. 2003;145(6):1022-9. Exclude - no active comparator. [pmid: 12796758].
Pissimissis EG, Garoufalis SE. Prognosis and management of diabetic patients with acute coronary syndrome. Hellenic J Cardiol. 2005;46(2):139-47. Exclude - not a Clinical Study. [pmid: 15847135].
Planer D, Smits PC, Kereiakes DJ, et al. Comparison of everolimus- and paclitaxel-eluting stents in patients with acute and stable coronary syndromes: pooled results from the SPIRIT (A Clinical Evaluation of the XIENCE V Everolimus Eluting Coronary Stent System) and COMPARE (A Trial of Everolimus-Eluting Stents and Paclitaxel-Eluting Stents for Coronary Revascularization in Daily Practice) Trials. JACC Cardiovasc Interv. 2011;4(10):1104-15. Exclude - no active comparator. [pmid: 22017936].
Poh KK, Tan HC, Yip JW, et al. ReoPro Observational Registry (RAPOR): insights from the multicentre use of abciximab in Asia. Singapore Med J. 2005;46(8):407-13. Exclude - no active comparator. [pmid: 16049611].
Polonski L, Gasior M, Gierlotka M, et al. Temporal trends in treatment and outcomes of patients with non-ST-segment elevation myocardial infarction (NSTEMI) in clinical practice - Analysis from the PL-ACS registry. Eur Heart J. 2011;32:658. Exclude - no active comparator.
Poludasu S, Baber U, Clark AE, et al. Impact of major bleeding on long term mortality in patients with and without anemia undergoing percutaneous coronary intervention with Bivalirudin. J Am Coll Cardiol. 2011;58(20):B16-B17. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Popma JJ, Suk J. Use of coronary revascularization in patients with unstable and non-ST-segment elevation acute myocardial infarction. Am J Cardiol. 2001;88(8A):25K-29K. Exclude -not a Clinical Study. [pmid: 11694216].
Prakash R, Malkin C, Chew D, et al. The impact of advanced age on clinical outcome from an early invasive strategy in patients with acute coronary syndrome. The acute coronary syndrome prospective audit registry (ACACIA). Heart Lung Circ. 2011;20:S149. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Prati F, Capodanno D, Pawlowski T, et al. Local delivery versus intracoronary infusion of abciximab in patients with acute coronary syndromes. JACC Cardiovasc Interv. 2010;3(9):928-34. Exclude - no active comparator. [pmid: 20850091].
Prati F, Kwiatkowski P, Caroselli C, et al. Use of abciximab prevents microcirculatory impairment in patients treated with coronary angioplasty for unstable angina: results of a prospective randomized study. Catheter Cardiovasc Interv. 2005;66(2):165-9. Exclude - no outcomes of interest. [pmid: 16142802].
Pregowski J, Przyluski J, Karcz M, et al. Relation of subacute stent thrombosis and resistance to acetylsalicylic acid and clopidogrel in patients with acute coronary syndrome. Insights from the ANIN Myocardial Infarction Registry. Postepy Kardiol Interwencyjnej. 2010;6(4):154-160. Exclude - no outcomes of interest.
Price M, Lillie E, Angiolillo D, et al. Platelet reactivity on clopidogrel therapy and cardiovascular outcomes after percutaneous coronary intervention: A time-dependent pharmacodynamic analysis of the GRAVITAS trial. Eur Heart J. 2011;32:507-508. Exclude - no outcomes of interest.
Price MJ, Angiolillo DJ, Teirstein PS, et al. Platelet reactivity and cardiovascular outcomes after percutaneous coronary intervention: a time-dependent analysis of the Gauging Responsiveness with a VerifyNow P2Y12 assay: Impact on Thrombosis and Safety (GRAVITAS) trial. Circulation. 2011;124(10):1132-7. Exclude - no outcomes of interest. [pmid: 21875913].
Pride YB, Canto JG, Frederick PD, et al. Outcomes among patients with non-ST-segment elevation myocardial infarction presenting to interventional hospitals with and without on-site cardiac surgery. JACC Cardiovasc Interv. 2009;2(10):944-52. Exclude - no active comparator. [pmid: 19850253].
Proimos G. Platelet aggregation inhibition with glycoprotein IIb--IIIa inhibitors. J Thromb Thrombolysis. 2001;11(2):99-110. Exclude - not a Clinical Study. [pmid: 11406724].
Puricel S, Adorjan P, Oberhansli M, et al. Clinical outcomes after PCI for acute coronary syndrome in unprotected left main coronary artery disease: insights from the Swiss Acute Left Main Coronary Vessel Percutaneous Management (SALVage) study. EuroIntervention. 2011;7(6):697-704. Exclude - no active comparator. [pmid: 21986328].
Puymirat E, Aissaoui N, Lemesle G, et al. Compared long-term survival of reperfused STEMI, non-reperfused STEMI and NSTEMI with or without PCI: 3-year results from the FAST-MI registry. Eur Heart J. 2011;32:868-869. Exclude - no active comparator.
Puymirat E, Mangiacapra F, Peace A, et al. Long-term clinical outcome in patients with small vessel disease treated with drug-eluting versus bare-metal stenting. Am Heart J. 2011;162(5):907-13. Exclude - no active comparator. [pmid: 22093208].
Quirke W, Cahill MR, Conway J, et al. Warfarin prevalence, indications for use and haemorrhagic events. Ir Med J. 2007;100(3). Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Rabah M, Mason D, Muller DW, et al. Heparin after percutaneous intervention (HAPI): a prospective multicenter randomized trial of three heparin regimens after successful coronary intervention. J Am Coll Cardiol. 1999;34(2):461-7. Exclude - no active comparator. [pmid: 10440160].
Rao SV, Kaul PR, Liao L, et al. Association between bleeding, blood transfusion, and costs among patients with non-ST-segment elevation acute coronary syndromes. Am Heart J. 2008;155(2):369-74. Exclude - no active comparator. [pmid: 18215610].
Rao SV, O'Grady K, Pieper KS, et al. A comparison of the clinical impact of bleeding measured by two different classifications among patients with acute coronary syndromes. J Am Coll Cardiol. 2006;47(4):809-16. Exclude - no outcomes of interest. [pmid: 16487850].
Rasoul S, Van 't Hof A, Clare R, et al. Routine early eptifibatide, infarct size, and outcomes in non-ST-segment elevation acute coronary syndrome patients with elevated troponin on admission. Journal of the American College of Cardiology. 2012;59(13):E498. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Rassen JA, Mittleman MA, Glynn RJ, et al. Safety and effectiveness of bivalirudin in routine care of patients undergoing percutaneous coronary intervention. Eur Heart J. 2010;31(5):561-72. Exclude - no outcomes of interest. [pmid: 19942600].
Rasty S, Borzak S, Tisdale JE. Bleeding associated with eptifibatide targeting higher risk patients with acute coronary syndromes: incidence and multivariate risk factors. J Clin Pharmacol. 2002;42(12):1366-73. Exclude -no active comparator. [pmid: 12463732].
Rathore SS, Foody JM, Radford MJ, et al. Sex differences in use of coronary revascularization in elderly patients after acute myocardial infarction: a tale of two therapies. Chest. 2003;124(6):2079-86. Exclude - no active comparator. [pmid: 14665483].
Rathore SS, Masoudi FA, Havranek EP, et al. Regional variations in racial differences in the treatment of elderly patients hospitalized with acute myocardial infarction. Am J Med. 2004;117(11):811-22. Exclude - no active comparator. [pmid: 15589484].
Rathore SS, Mehta RH, Wang Y, et al. Effects of age on the quality of care provided to older patients with acute myocardial infarction. Am J Med. 2003;114(4):307-15. Exclude - no active comparator. [pmid: 12681459].
Ray KK, Francis S, Crossman DC. A potential pharmacogenomic strategy for anticoagulant treatment in non-ST elevation acute coronary syndromes: the role of interleukin-1 receptor antagonist genotype. J Thromb Haemost. 2005;3(2):287-91. Exclude - no active comparator. [pmid: 15670034].
Razzouk L, Mathew V, Lennon RJ, et al. Aspirin use is associated with an improved long-term survival in an unselected population presenting with unstable angina. Clin Cardiol. 2010;33(9):553-8. Exclude - no active comparator. [pmid: 20842739].
Rebeiz AG, Dery JP, Tsiatis AA, et al. Optimal duration of eptifibatide infusion in percutaneous coronary intervention (an ESPRIT substudy). Am J Cardiol. 2004;94(7):926-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15464679].
Reczuch K, Jankowska E, Porada A, et al. Long-term outcome of conservatively treated patients with borderline coronary lesions--role of the fractional flow reserve measurement. Kardiol Pol. 2005;62(1):6-11. discussion 12-3. Exclude - no active comparator. [pmid: 15815774].
Reed SO, Mullins CD, Magder LS. Cost effectiveness of abciximab during routine medical practice. Pharmacoeconomics. 2000;18(3):265-74. Exclude - no outcomes of interest. [pmid: 11147393].
Reis-Santos K, Ferreira J, Aguiar C, et al. Influence of prior medication on mode of presentation and prognosis of acute coronary syndromes. Rev Port Cardiol. 2002;21(3):317-26. Exclude - no active comparator. [pmid: 12017803].
Ren YH, Yang TS, Wang Y, et al. Evaluation of triple anti-platelet therapy by modified thrombelastography in patients with acute coronary syndrome. Chin Med J (Engl). 2008;121(9):850-2. Exclude - not original peer-reviewed data. [pmid: 18701053].
Rich JD, Cannon CP, Murphy SA, et al. Prior aspirin use and outcomes in acute coronary syndromes. J Am Coll Cardiol. 2010;56(17):1376-85. Exclude - no outcomes of interest. [pmid: 20946994].
Ricottini E, Patti G, Vizzi V, et al. Outcome comparison of 600 mg vs 300 mg loading dose of clopidogrel in patients undergoing primary percutaneous coronary intervention for stemi. Results from the armyda-6 MI randomized study. Giornale Italiano di Cardiologia. 2011;12(12):e147. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Ridker PM, O'Donnell CJ, Hennekens CH. Direct Comparison of Aspirin Plus Hirudin, Aspirin Plus Heparin, and Aspirin Alone Among 12,000 Patients with Acute Myocardial Infarction Not Receiving Thrombolysis: Rationale and Design of the First American Study of Infarct Survival (ASIS-1). J Thromb Thrombolysis. 1995;1(2):119-124. Exclude - no active comparator. [pmid: 10603520].
Riesmeyer JS, Salazar DE, Weerakkody GJ, et al. Relationship between exposure to prasugrel active metabolite and clinical outcomes in the TRITON-TIMI 38 substudy. Journal of Clinical Pharmacology. 2012;52(6):789-797. Exclude - no outcomes of interest. [pmid: 21628601].
Riezebos RK, Ronner E, Ter Bals E, et al. Immediate versus deferred coronary angioplasty in non-ST-segment elevation acute coronary syndromes. Heart. 2009;95(10):807-12. Exclude - no outcomes of interest. [pmid: 19098058].
Rinfret S, Bagur R, Rodes-Cabau J, et al. Telephone contacts to improve adherence to dual anti-platelet therapy following drug-eluting stent implantation; a randomized controlled-trial. Catheterization and Cardiovascular Interventions. 2012;79:S79-S80. Exclude - no active comparator.
Ringleb PA, Bhatt DL, Hirsch AT, et al. Benefit of clopidogrel over aspirin is amplified in patients with a history of ischemic events. Stroke. 2004;35(2):528-32. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14739421].
Robertson JO, Lincoff AM, Wolski K, et al. Planned versus provisional use of glycoprotein IIb/IIIa inhibitors in smokers undergoing percutaneous coronary intervention. Am J Cardiol. 2006;97(12):1679-84. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16765113].
Rodrigues EJ, Simpson E, Richard H, et al. Regional variation in the management of acute myocardial infarction in the province of Quebec. Can J Cardiol. 2002;18(10):1067-76. Exclude -no active comparator. [pmid: 12420042].
Rodriguez AE, Rodriguez-Granillo AM, Antoniucci D, et al. Randomized comparison of cost-saving and effectiveness of oral rapamycin plus bare-metal stents with drug-eluting stents: Three-year outcome from the randomized oral rapamycin in Argentina (ORAR) III trial. Catheter Cardiovasc Interv. 2011. Exclude - no active comparator. [pmid: 22109997].
Rodriguez-Granillo GA, Valgimigli M, Garcia-Garcia HM, et al. One-year clinical outcome after coronary stenting of very small vessels using 2.25 mm sirolimus- and paclitaxel-eluting stents: a comparison between the RESEARCH and T-SEARCH registries. J Invasive Cardiol. 2005;17(8):409-12. Exclude - no active comparator. [pmid: 16079445].
Roe MT, Granger CB, Puma JA, et al. Comparison of benefits and complications of hirudin versus heparin for patients with acute coronary syndromes undergoing early percutaneous coronary intervention. Am J Cardiol. 2001;88(12):1403-6. A6. Exclude - no active comparator. [pmid: 11741559].
Roe MT, Harrington RA, Prosper DM, et al. Clinical and therapeutic profile of patients presenting with acute coronary syndromes who do not have significant coronary artery disease.The Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy (PURSUIT) Trial Investigators. Circulation. 2000;102(10):1101-6. Exclude - no outcomes of interest. [pmid: 10973837].
Roe MT, Messenger JC, Weintraub WS, et al. Treatments, trends, and outcomes of acute myocardial infarction and percutaneous coronary intervention. J Am Coll Cardiol. 2010;56(4):254-63. Exclude - no active comparator. [pmid: 20633817].
Roe MT, Parsons LS, Pollack CV Jr., et al. Quality of care by classification of myocardial infarction: treatment patterns for ST-segment elevation vs non-ST-segment elevation myocardial infarction. Arch Intern Med. 2005;165(14):1630-6. Exclude - no active comparator. [pmid: 16043682].
Roe MT, Peterson ED, Li Y, et al. Relationship between risk stratification by cardiac troponin level and adherence to guidelines for non-ST-segment elevation acute coronary syndromes. Arch Intern Med. 2005;165(16):1870-6. Exclude - no active comparator. [pmid: 16157831].
Rogacka R, Chieffo A, Michev I, et al. Dual antiplatelet therapy after percutaneous coronary intervention with stent implantation in patients taking chronic oral anticoagulation. JACC Cardiovasc Interv. 2008;1(1):56-61. Exclude -no outcomes of interest. [pmid: 19393145].
Roguin A, Steinberg BA, Watkins SP, et al. Safety of bivalirudin during percutaneous coronary interventions in patients with abnormal renal function. Int J Cardiovasc Intervent. 2005;7(2):88-92. Exclude - no active comparator. [pmid: 16093217].
Romagnoli E, Burzotta F, Trani C, et al. Angiographic evaluation of the effect of intracoronary abciximab administration in patients undergoing urgent PCI. Int J Cardiol. 2005;105(3):250-5. Exclude - no outcomes of interest. [pmid: 16274764].
Ronner E, Boersma E, Laarman GJ, et al. Early angioplasty in acute coronary syndromes without persistent ST-segment elevation improves outcome but increases the need for six-month repeat revascularization: an analysis of the PURSUIT Trial. Platelet glycoprotein IIB/IIIA in Unstable angina: Receptor Suppression Using Integrilin Therapy. J Am Coll Cardiol. 2002;39(12):1924-9. Exclude - no active comparator. [pmid: 12084589].
Rosenberg L, Rao RS, Palmer JR. A case-control study of acetaminophen use in relation to the risk of first myocardial infarction in men. Pharmacoepidemiol Drug Saf. 2003;12(6):459-65. Exclude - no active comparator. [pmid: 14513659].
Rossini R, Musumeci G, Lettieri C, et al. Premature discontinuation of dual antiplatelet therapy after drug-eluting stent implantation: Predictors and long-term prognosis. EuroIntervention. 2010;6. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Roth GA, Morden NE, Zhou W, et al. Clopidogrel Use and Early Outcomes Among Older Patients Receiving a Drug-Eluting Coronary Artery Stent. Circ Cardiovasc Qual Outcomes. 2011. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22147885].
Roubille F, Lairez O, Mewton N, et al. Cardioprotection by clopidogrel in acute ST-elevated myocardial infarction patients: a retrospective analysis. Basic Res Cardiol. 2012;107(4):275. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22718009].
Roy S, Kumar S, Majumdar A, et al. Percutaneous treatment of bifurcation coronary stenosis: a long-term follow-up. Indian Heart J. 2008;60(6):558-62. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19276496].
Rubboli A, Bolognese L, Di Pasquale G, et al. A prospective multicentre observational study on the management of patients on oral anticoagulation undergoing coronary artery stenting: rationale and design of the ongoing warfarin and coronary stenting (WAR-STENT) registry. J Cardiovasc Med (Hagerstown). 2009;10(2):200-3. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19377385].
Rubboli A, Colletta M, Sangiorgio P, et al. Antithrombotic strategies in patients with an indication for long-term anticoagulation undergoing coronary artery stenting: safety and efficacy data from a single center. Ital Heart J. 2004;5(12):919-25. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15706997].
Ruiz-Nodar JM, Marin F, Sanchez-Paya J, et al. Efficacy and safety of drug-eluting stent use in patients with atrial fibrillation. Eur Heart J. 2009;30(8):932-9. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19246502].
Sabate M, Abizaid A, Banning A, et al. Outcomes of patients under anti-vitamin K treatment receiving the Sirolimus-eluting CYPHER Select plus stent, 1-year results from the e-SELECT registry. EuroIntervention. 2010;6. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Sabatine MS, Antman EM, Widimsky P, et al. Otamixaban for the treatment of patients with non-ST-elevation acute coronary syndromes (SEPIA-ACS1 TIMI 42): a randomised, double-blind, active-controlled, phase 2 trial. Lancet. 2009;374(9692):787-95. Exclude -no active comparator. [pmid: 19717184].
Sabatine MS, Blake GJ, Drazner MH, et al. Influence of race on death and ischemic complications in patients with non-ST-elevation acute coronary syndromes despite modern, protocol-guided treatment. Circulation. 2005;111(10):1217-24. Exclude - no active comparator. [pmid: 15769761].
Sabatine MS, Januzzi JL, Snapinn S, et al. A risk score system for predicting adverse outcomes and magnitude of benefit with glycoprotein IIb/IIIa inhibitor therapy in patients with unstable angina pectoris. Am J Cardiol. 2001;88(5):488-92. Exclude - no outcomes of interest. [pmid: 11524055].
Sabatine MS, McCabe CH, Morrow DA, et al. Identification of patients at high risk for death and cardiac ischemic events after hospital discharge. Am Heart J. 2002;143(6):966-70. Exclude - no active comparator. [pmid: 12075250].
Sabatine MS, Morrow DA, Cannon CP, et al. Relationship between baseline white blood cell count and degree of coronary artery disease and mortality in patients with acute coronary syndromes: a TACTICS-TIMI 18 (Treat Angina with Aggrastat and determine Cost of Therapy with an Invasive or Conservative Strategy- Thrombolysis in Myocardial Infarction 18 trial)substudy. J Am Coll Cardiol. 2002;40(10):1761-8. Exclude - no active comparator. [pmid: 12446059].
Sabatine MS, Morrow DA, Giugliano RP, et al. Implications of upstream glycoprotein IIb/IIIa inhibition and coronary artery stenting in the invasive management of unstable angina/non-ST-elevation myocardial infarction: a comparison of the Thrombolysis In Myocardial Infarction (TIMI) IIIB trial and the Treat angina with Aggrastat and determine Cost of Therapy with Invasive or Conservative Strategy (TACTICS)-TIMI 18 trial. Circulation. 2004;109(7):874-80. Exclude - no active comparator. [pmid: 14757697].
Sabouret P, Asseman P, Dallongeville J, et al. Observational study of adherence to European clinical practice guidelines for the management of acute coronary syndrome in revascularized versus non-revascularized patients - the CONNECT Study. Arch Cardiovasc Dis. 2010;103(8-9):437-46. Exclude - no active comparator. [pmid: 21074122].
Sachdeva A, Bavisetty S, Beckham G, et al. The association between duration of clopidogrel therapy after saphenous vein graft intervention and long-term death and myocardial infarction. J Am Coll Cardiol. 2011;58(20):B46. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Sadeghi HM, Grines CL, Chandra HR, et al. Percutaneous coronary interventions in octogenarians. glycoprotein IIb/IIIa receptor inhibitors' safety profile. J Am Coll Cardiol. 2003;42(3):428-32. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12906967].
Saini SD, Fendrick AM, Scheiman JM. Cost-effectiveness analysis: Cardiovascular benefits of proton pump inhibitor co-therapy in patients using aspirin for secondary prevention. Aliment Pharmacol Ther. 2011;34(2):243-251. Exclude - not a Clinical Study. [pmid: 21615437].
Saito S, Hosokawa FG, Kim K, et al. Primary stent implantation without coumadin in acute myocardial infarction. J Am Coll Cardiol. 1996;28(1):74-81. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8752797].
Salvioni A, Casilli F, Assanelli E, et al. Comparison of enoxaparin and unfractionated heparin on thrombin generation in acute coronary syndromes without ST-segment elevation. Thromb Haemost. 2001;86(4):991-4. Exclude - no outcomes of interest. [pmid: 11686357].
Sambola Ayala A, Tornos P, Alfonso F, et al. High risk of interruption of triple therapy: Warfarin plus dual antiplatelet after percutaneous coronary intervention. Eur Heart J. 2011;32:398-399. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Sanborn TA, Block PC. Routine vs. selective use of GP IIb/IIIa inhibitors in ACS: The ACUITY timing trial. ACC Cardiosource Rev J. 2006;15(7):53-56. Exclude - not a Clinical Study.
Sane DC, Damaraju LV, Topol EJ, et al. Occurrence and clinical significance of pseudothrombocytopenia during abciximab therapy. J Am Coll Cardiol. 2000;36(1):75-83. Exclude - no outcomes of interest. [pmid: 10898416].
Sangiorgi GM, Morice MC, Bramucci E, et al. Evaluating the safety of very short-term (10 days) dual antiplatelet therapy after Genous bio-engineered R stent implantation: the multicentre pilot GENOUS trial. EuroIntervention. 2011;7(7):813-9. Exclude - no active comparator. [pmid: 22082577].
Santopinto J, Gurfinkel EP, Torres V, et al. Prior aspirin users with acute non-ST-elevation coronary syndromes are at increased risk of cardiac events and benefit from enoxaparin. Am Heart J. 2001;141(4):566-72. Exclude - no active comparator. [pmid: 11275921].
Santos JF, Ferreira J, Aguiar C, et al. Prognosis of non-ST-segment elevation acute coronary syndrome in patients with prior percutaneous coronary intervention. Rev Port Cardiol. 2005;24(6):805-16. Exclude - no active comparator. [pmid: 16121673].
Sarafoff N, Ndrepepa G, Mehilli J, et al. Aspirin and clopidogrel with or without phenprocoumon after drug eluting coronary stent placement in patients on chronic oral anticoagulation. J Intern Med. 2008;264(5):472-80. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18624903].
Sardella G, Mancone M, Biondi-Zoccai G, et al. Beneficial Impact of Prolonged Dual Antiplatelet Therapy after Drug-Eluting Stent Implantation. J Interv Cardiol. 2012. Exclude - no active comparator. [pmid: 22248370].
Sardi GL, Gaglia MA Jr., Maluenda G, et al. Outcome of percutaneous coronary intervention utilizing drug-eluting stents in patients with reduced left ventricular ejection fraction. Am J Cardiol. 2012;109(3):344-51. Exclude - no active comparator. [pmid: 22112742].
Satre H, Holmvang L, Wagner GS, et al. Reduction of myocardial damage by prolonged treatment with subcutaneous low molecular weight heparin in unstable coronary artery disease. FRISC study group. Fragmin during Instability in Coronary Artery Disease. Eur Heart J. 1999;20(9):645-52. Exclude - no active comparator. [pmid: 10208784].
Saucedo JF, Lui HK, Garza L, et al. Comparative pharmacodynamic evaluation of eptifibatide and abciximab in patients with non-ST-segment elevation acute coronary syndromes: the TAM2 study. J Thromb Thrombolysis. 2004;18(2):67-74. Exclude - no outcomes of interest. [pmid: 15789173].
Savonitto S, De Servi S, Petronio AS, et al. Early aggressive vs. initially conservative treatment in elderly patients with non-ST-elevation acute coronary syndrome: the Italian Elderly ACS study. J Cardiovasc Med (Hagerstown). 2008;9(3):217-26. Exclude - no outcomes of interest. [pmid: 18301136].
Saw J, Densem C, Walsh S, et al. The effects of aspirin and clopidogrel response on myonecrosis after percutaneous coronary intervention: a BRIEF-PCI (Brief Infusion of Intravenous Eptifibatide Following Successful Percutaneous Coronary Intervention) trial substudy. JACC Cardiovasc Interv. 2008;1(6):654-9. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19463380].
Saw J, Lincoff AM, DeSmet W, et al. Lack of clopidogrel pretreatment effect on the relative efficacy of bivalirudin with provisional glycoprotein IIb/IIIa blockade compared to heparin with routine glycoprotein IIb/IIIa blockade: a REPLACE-2 substudy. J Am Coll Cardiol. 2004;44(6):1194-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15364319].
Sawhney N, Moses JW, Leon MB, et al. Treatment of left anterior descending coronary artery disease with sirolimus-eluting stents. Circulation. 2004;110(4):374-9. Exclude - no active comparator. [pmid: 15249503].
Sayin T, Berkalp B, Akyurek O, et al. Angiographic and clinical follow-up after coronary implantation of the ACS Multilink Duet stent: a single center experience. Jpn Heart J. 2001;42(4):409-16. Exclude - no active comparator. [pmid: 11693277].
Schellings DA, Dambrink JH, Hoorntje JC, et al. Long-term comparison of balloon angioplasty with provisional stenting versus routine stenting in patients with non-ST-elevation acute coronary syndrome. Neth Heart J. 2010;18(6):307-13. Exclude - no active comparator. [pmid: 20657676].
Schiariti M, Saladini A, Papalia F, et al. GPIIb/IIIa Receptor Antagonism Using Small Molecules Provides no Additive Long-Term Protection after Percutaneous Coronary Intervention as Compared to Clopidogrel Plus Aspirin. Open Cardiovasc Med J. 2010;4:151-6. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 20922049].
Schiele F, Gardel C, Derumeaux G, et al. Age and gender disparities in prescriptions at discharge after acute ST segment elevation myocardial infarction. A French nationwide assessment of quality of care. Eur Heart J. 2011;32:419. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Schiele F, Meneveau N, Seronde MF, et al. Changes in management of elderly patients with myocardial infarction. Eur Heart J. 2009;30(8):987-94. Exclude - no outcomes of interest. [pmid: 19176538].
Schleinitz MD. The cost-effectiveness of clopidogrel: A review by indication. Expert Rev Pharmacoecon Outcomes Res. 2006;6(2):123-130. Exclude - not a Clinical Study. [pmid: 20528547].
Schleinitz MD, Heidenreich PA. A cost-effectiveness analysis of combination antiplatelet therapy for high-risk acute coronary syndromes: clopidogrel plus aspirin versus aspirin alone. Ann Intern Med. 2005;142(4):251-9. Exclude - no outcomes of interest. [pmid: 15710958].
Schnell O, Schafer O, Kleybrink S, et al. Intensification of therapeutic approaches reduces mortality in diabetic patients with acute myocardial infarction: the Munich registry. Diabetes Care. 2004;27(2):455-60. Exclude - no active comparator. [pmid: 14747228].
Schoenenberger AW, Radovanovic D, Stauffer JC, et al. Acute coronary syndromes in young patients: Presentation, treatment and outcome. Int J Cardiol. 2011;148(3):300-304. Exclude - no active comparator. [pmid: 19942306].
Schoenhoff F, Kayhan N, Thomas G, et al. Bridge to operation with the GPIIb/IIIa inhibitor abciximab in high-risk coronary patients. Thorac Cardiovasc Surg. 2006;54(3):150-6. Exclude - no outcomes of interest. [pmid: 16639674].
Schomig A, Hall D, Walter H, et al. Antiplatelet therapy - Better than anticoagulation after stent placement. Cardiol Rev. 1998;15(1):41-44. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data).
Schomig A, Neumann FJ, Kastrati A, et al. A randomized comparison of antiplatelet and anticoagulant therapy after the placement of coronary-artery stents. N Engl J Med. 1996;334(17):1084-9. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 8598866].
Schomig A, Neumann FJ, Walter H, et al. Coronary stent placement in patients with acute myocardial infarction: comparison of clinical and angiographic outcome after randomization to antiplatelet or anticoagulant therapy. J Am Coll Cardiol. 1997;29(1):28-34. Exclude - no active comparator. [pmid: 8996291].
Schomig A, Schmitt C, Dibra A, et al. One year outcomes with abciximab vs. placebo during percutaneous coronary intervention after pre-treatment with clopidogrel. Eur Heart J. 2005;26(14):1379-84. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15734767].
Schreiner GC, Laine L, Murphy SA, et al. Evaluation of proton pump inhibitor use in patients with acute coronary syndromes based on risk factors for gastrointestinal bleed. Crit Pathw Cardiol. 2007;6(4):169-72. Exclude - no outcomes of interest. [pmid: 18091407].
Schuhlen H, Hadamitzky M, Walter H, et al. Major benefit from antiplatelet therapy for patients at high risk for adverse cardiac events after coronary Palmaz-Schatz stent placement: analysis of a prospective risk stratification protocol in the Intracoronary Stenting and Antithrombotic Regimen (ISAR) trial. Circulation. 1997;95(8):2015-21. Exclude - no active comparator. [pmid: 9133509].
Schuhlen H, Kastrati A, Pache J, et al. Incidence of thrombotic occlusion and major adverse cardiac events between two and four weeks after coronary stent placement: analysis of 5,678 patients with a four-week ticlopidine regimen. J Am Coll Cardiol. 2001;37(8):2066-73. Exclude - no active comparator. [pmid: 11419889].
Schuhlen H, Kastrati A, Pache J, et al. Sustained benefit over four years from an initial combined antiplatelet regimen after coronary stent placement in the ISAR trial. Intracoronary Stenting and Antithrombotic Regimen. Am J Cardiol. 2001;87(4):397-400. Exclude - no active comparator. [pmid: 11179521].
Schulman SP, Goldschmidt-Clermont PJ, Topol EJ, et al. Effects of integrelin, a platelet glycoprotein IIb/IIIa receptor antagonist, in unstable angina. A randomized multicenter trial. Circulation. 1996;94(9):2083-9. Exclude - no outcomes of interest. [pmid: 8901655].
Schulz S, Mehilli J, Ndrepepa G, et al. Influence of abciximab on evolution of left ventricular function in patients with non-ST-segment elevation acute coronary syndromes undergoing PCI after clopidogrel pretreatment: lessons from the ISAR-REACT 2 trial. Clin Res Cardiol. 2011;100(8):691-9. Exclude - no outcomes of interest. [pmid: 21384174].
Schwarz AK, Zahn R, Hochadel M, et al. Age-related differences in antithrombotic therapy, success rate and in-hospital mortality in patients undergoing percutaneous coronary intervention: results of the quality control registry of the Arbeitsgemeinschaft Leitende Kardiologische Krankenhausarzte (ALKK). Clin Res Cardiol. 2011;100(9):773-80. Exclude - no active comparator. [pmid: 21509588].
Schwenkglenks M, Brazier JE, Szucs TD, et al. Cost-effectiveness of bivalirudin versus heparin plus glycoprotein IIb/IIIa inhibitor in the treatment of non-ST-segment elevation acute coronary syndromes. Value Health. 2011;14(1):24-33. Exclude - no outcomes of interest. [pmid: 21211483].
Sciagra R, Parodi G, Pupi A, et al. Gated SPECT evaluation of outcome after abciximab-supported primary infarct artery stenting for acute myocardial infarction: the scintigraphic data of the abciximab and carbostent evaluation (ACE) randomized trial. J Nucl Med. 2005;46(5):722-7. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15872342].
Sciahbasi A, Biondi-Zoccai G, Romagnoli E, et al. Routine upstream versus selective downstream administration of glycoprotein IIb/IIIa inhibitors in patients with non-ST-elevation acute coronary syndromes: a meta-analysis of randomized trials. Int J Cardiol. 2012;155(2):243-8. Exclude - Systematic Review/Meta-Analysis. [pmid: 21035214].
Sciahbasi A, Pristipino C, Ambrosio G, et al. Arterial access-site-related outcomes of patients undergoing invasive coronary procedures for acute coronary syndromes (from the ComPaRison of Early Invasive and Conservative Treatment in Patients With Non-ST-ElevatiOn Acute Coronary Syndromes [PRESTO-ACS] Vascular Substudy). Am J Cardiol. 2009;103(6):796-800. Exclude -no outcomes of interest. [pmid: 19268734].
Scott IA, Darwin IC, Harvey KH, et al. Multisite, quality-improvement collaboration to optimise cardiac care in Queensland public hospitals. Med J Aust. 2004;180(8):392-7. Exclude - no active comparator. [pmid: 15089729].
Scott IA, Duke AB, Darwin IC, et al. Variations in indicated care of patients with acute coronary syndromes in Queensland hospitals. Med J Aust. 2005;182(7):325-30. Exclude - no active comparator. [pmid: 15804222].
Seddon ME, Ayanian JZ, Landrum MB, et al. Quality of ambulatory care after myocardial infarction among Medicare patients by type of insurance and region. Am J Med. 2001;111(1):24-32. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11448657].
Sedlis SP, Morrison DA, Lorin JD, et al. Percutaneous coronary intervention versus coronary bypass graft surgery for diabetic patients with unstable angina and risk factors for adverse outcomes with bypass: outcome of diabetic patients in the AWESOME randomized trial and registry. J Am Coll Cardiol. 2002;40(9):1555-66. Exclude - no active comparator. [pmid: 12427406].
Sels JW, Tonino PA, Siebert U, et al. Fractional Flow Reserve in Unstable Angina and Non-ST-Segment Elevation Myocardial Infarction Experience From the FAME (Fractional flow reserve versus Angiography for Multivessel Evaluation) Study. JACC Cardiovasc Interv. 2011;4(11):1183-9. Exclude - no active comparator. [pmid: 22115657].
Serruys PW, Morice MC, Kappetein AP, et al. Percutaneous coronary intervention versus coronary-artery bypass grafting for severe coronary artery disease. N Engl J Med. 2009;360(10):961-72. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19228612].
Serruys PW, Ormiston JA, Onuma Y, et al. A bioabsorbable everolimus-eluting coronary stent system (ABSORB): 2-year outcomes and results from multiple imaging methods. Lancet. 2009;373(9667):897-910. Exclude - no outcomes of interest. [pmid: 19286089].
Seth A, Sinha N, Parikh K, et al. Safety and efficacy of indigenously developed and manufactured bivalirudin in moderate/high-risk Indian patients undergoing percutaneous coronary intervention: the Bivaflo Registry. Indian Heart J. 2008;60(4):333-41. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19242012].
Seyfarth M, Kastrati A, Mann JF, et al. Prognostic value of kidney function in patients with ST-elevation and non-ST-elevation acute myocardial infarction treated with percutaneous coronary intervention. Am J Kidney Dis. 2009;54(5):830-9. Exclude - no outcomes of interest. [pmid: 19592145].
Shah BR, Peterson ED, Chen AY, et al. Influence of clinical trial participation on subsequent antithrombin use. Clin Cardiol. 2010;33(3):E49-55. Exclude - no active comparator. [pmid: 20127904].
Shah PB, Ahmed WH, Ganz P, et al. Bivalirudin compared with heparin during coronary angioplasty for thrombus-containing lesions. J Am Coll Cardiol. 1997;30(5):1264-9. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9350925].
Shahi CN, Rathore SS, Wang Y, et al. Quality of care among elderly patients hospitalized with unstable angina. Am Heart J. 2001;142(2):263-70. Exclude - no outcomes of interest. [pmid: 11479465].
Shalev A, Zahger D, Novack V, et al. Incidence, predictors and outcome of upper gastrointestinal bleeding in patients with acute coronary syndromes. Int J Cardiol. 2011. Exclude - no active comparator. [pmid: 21277643].
Shalev A, Zahger D, Novack V, et al. Incidence, predictors and outcome of upper gastrointestinal bleeding in patients with acute coronary syndromes. Int J Cardiol. 2012;157(3):386-90. Exclude - no active comparator. [pmid: 21277643].
Sharma S, Forrester JS. A novel regimen of alternate day clopidogrel would provide a cost-effective strategy to prevent very late stent thrombosis. Med Hypotheses. 2012;78(1):166-170. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22075236].
Shavelle DM, Parsons L, Sada MJ, et al. Is there a benefit to early angiography in patients with ST-segment depression myocardial infarction? An observational study. Am Heart J. 2002;143(3):488-96. Exclude - no outcomes of interest. [pmid: 11868056].
Sheikh A, Baig K. An audit of the use and complications of glycoprotein IIb/IIIa inhibitors in percutaneous coronary intervention against national UK standards. Cardiovasc Revasc Med. 2006;7(4):237-9. Exclude - no active comparator. [pmid: 17174871].
Sheikh-Taha MT, Strickland WL. Evaluation of eptifibatide treatment in patients undergoing percutaneous coronary intervention. J Pharm Technol. 2002;18(6):316-318. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Shennib H, Endo M, Benhameid O. A feasibility study of the safety and efficacy of a combined clopidogrel and aspirin regimen following off-pump coronary artery bypass grafting. Heart Surg Forum. 2003;6(5):288-91. Exclude - no outcomes of interest. [pmid: 14721795].
Sheridan BC, Stearns SC, Rossi JS, et al. Three-year outcomes of multivessel revascularization in very elderly acute coronary syndrome patients. Ann Thorac Surg. 2010;89(6):1889-94. discussion 1894-5. Exclude - no active comparator. [pmid: 20494044].
Shimizu Y, Io H, Hagiwara S, et al. Concomitant use of clopidogrel and proton pump inhibitors may attenuate the prognosis of coronary heart disease in hemodialysis patients. Dial Trasplant. 2011. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Sibbing D, Bernlochner I, Schulz S, et al. Prognostic Value of a High On-Clopidogrel Treatment Platelet Reactivity in Bivalirudin Versus Abciximab Treated Non-ST-Segment Elevation Myocardial Infarction Patients: ISAR-REACT-4 (Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment-4) Platelet Substudy. J Am Coll Cardiol. 2012. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22682553].
Siddique AM. Comparison of the Use of Secondary Prophylaxis for Myocardial Infarction over Ten Years in a Tertiary Centre in Saudi Arabia. J Bahrain Med Soc. 2003;15(4):193-198. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Sigurdsson EL, Jonsson JS, Thorgeirsson G. Medical treatment and secondary prevention of coronary heart disease in general practice in Iceland. Scand J Prim Health Care. 2002;20(1):10-5. Exclude - no active comparator. [pmid: 12086276].
Siller-Matula JM, Delle-Karth G, Christ G, et al. Dual non-responsiveness to antiplatelet treatment is a stronger predictor of cardiac adverse events than isolated non-responsiveness to clopidogrel or aspirin. Int J Cardiol. 2012. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22305813].
Silvain J, Bellemain-Appaix A, Barthelemy O, et al. Optimal use of thienopyridines in non-ST-elevation acute coronary syndrome following CURRENT-OASIS 7. Circ Cardiovasc Interv. 2011;4(1):95-103. Exclude - not a Clinical Study. [pmid: 21325198].
Silvain J, Beygui F, Barthelemy O, et al. Efficacy and safety of enoxaparin versus unfractionated heparin during percutaneous coronary intervention: systematic review and meta-analysis. BMJ. 2012;344:e553. Exclude -Systematic Review/Meta-Analysis. [pmid: 22306479].
Sim DS, Jeong MH, Kim W, et al. Long-term clinical benefits of a platelet glycoprotein IIb/IIIa receptor blocker, abciximab (ReoPro), in high-risk diabetic patients undergoing percutaneous coronary intervention. Korean J Intern Med. 2003;18(3):129-37. Exclude - no active comparator. [pmid: 14619381].
Simon T, Steg P, Gilard M, et al. Clinical events as a function of PPI use, clopidogrel use and CYP2C19 genotype in a large nationwide cohort of acute myocardial infarction: Results from the FAST-MI registry. Fundamental and Clinical Pharmacology. 2011;25:101-102. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Simoons ML, Bobbink IW, Boland J, et al. A dose-finding study of fondaparinux in patients with non-ST-segment elevation acute coronary syndromes: the Pentasaccharide in Unstable Angina (PENTUA) Study. J Am Coll Cardiol. 2004;43(12):2183-90. Exclude - no outcomes of interest. [pmid: 15193678].
Simpson E, Beck C, Richard H, et al. Drug prescriptions after acute myocardial infarction: dosage, compliance, and persistence. Am Heart J. 2003;145(3):438-44. Exclude - no active comparator. [pmid: 12660666].
Singh M, Nuttall GA, Ballman KV, et al. Effect of abciximab on the outcome of emergency coronary artery bypass grafting after failed percutaneous coronary intervention. Mayo Clin Proc. 2001;76(8):784-8. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11499816].
Singh M, Ting HH, Gersh BJ, et al. Percutaneous coronary intervention for ST-segment and non-ST-segment elevation myocardial infarction at hospitals with and without on-site cardiac surgical capability. Mayo Clin Proc. 2004;79(6):738-44. Exclude - no active comparator. [pmid: 15182087].
Singh SM, Alter DA. Is routine early invasive management of non-ST-segment elevation myocardial infarction beneficial in elderly patients?. CMAJ. 2004;171(9):1046-7. Exclude - not a Clinical Study. [pmid: 15546173].
Sirois C, Moisan J, Gregoire JP. Aspirin use is not associated with reduced myocardial infarction in elderly with type 2 diabetes with or without prior history of cardiovascular disease. Value Health. 2010;13(7):A343. Exclude - not original peer-reviewed data.
Slader SAA, Welch SA, Finckh A, et al. Evaluation of a weight-based heparin dosing protocol. J Pharm Res. 2005;35(1):15-17. Exclude - no active comparator.
Sloane PD, Gruber-Baldini AL, Zimmerman S, et al. Medication undertreatment in assisted living settings. Arch Intern Med. 2004;164(18):2031-7. Exclude - no active comparator. [pmid: 15477439].
Smith EE, Cannon CP, Murphy S, et al. Risk factors for stroke after acute coronary syndromes in the Orbofiban in Patients with Unstable Coronary Syndromes--Thrombolysis In Myocardial Infarction (OPUS-TIMI) 16 study. Am Heart J. 2006;151(2):338-44. Exclude - no outcomes of interest. [pmid: 16442896].
Smith PJ, Hurlen M, Abdelnoor M, et al. Less benefit from warfarin in diabetics after myocardial infarction?. Cardiology. 2008;111(3):161-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18434719].
Smith PK, Goodnough LT, Levy JH, et al. Mortality Benefit With Prasugrel in the TRITON-TIMI 38 Coronary Artery Bypass Grafting Cohort: Risk-Adjusted Retrospective Data Analysis. J Am Coll Cardiol. 2012. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22633653].
Snider JB, Moreno R, Fuller DJ, et al. The effect of simple interventions on paramedic aspirin administration rates. Prehosp Emerg Care. 2004;8(1):41-5. Exclude - no active comparator. [pmid: 14691786].
Solinas E, Gobbi G, Dangas G, et al. Comparison of the effects of pretreatment with tirofiban, clopidogrel or both on the inhibition of platelet aggregation and activation in patients with acute coronary syndromes. J Thromb Thrombolysis. 2009;27(1):36-43. Exclude - no outcomes of interest. [pmid: 18049795].
Solomon DH, Stone PH, Glynn RJ, et al. Use of risk stratification to identify patients with unstable angina likeliest to benefit from an invasive versus conservative management strategy. J Am Coll Cardiol. 2001;38(4):969-76. Exclude - no outcomes of interest. [pmid: 11583866].
Sonel AF, Good CB, Mulgund J, et al. Racial variations in treatment and outcomes of black and white patients with high-risk non-ST-elevation acute coronary syndromes: insights from CRUSADE (Can Rapid Risk Stratification of Unstable Angina Patients Suppress Adverse Outcomes With Early Implementation of the ACC/AHA Guidelines?). Circulation. 2005;111(10):1225-32. Exclude - no active comparator. [pmid: 15769762].
Song SW, Youn YN, Yi G, et al. Effects of continuous administration of clopidogrel before off-pump coronary artery bypass grafting in patients with acute coronary syndrome. Circ J. 2008;72(4):626-32. Exclude - no outcomes of interest. [pmid: 18362436].
Song YB, Hahn JY, Kim JH, et al. Comparison of angiographic and other findings and mortality in non-ST-segment elevation versus ST-segment elevation myocardial infarction in patients undergoing early invasive intervention. Am J Cardiol. 2010;106(10):1397-403. Exclude -no active comparator. [pmid: 21059427].
Sonson JM, Lum JJ, Madison JR, et al. Gender differences in therapy for patients admitted for unstable angina and myocardial infarction with underlying chronic kidney disease. Hawaii Med J. 2004;63(11):337-40. Exclude - not a Clinical Study. [pmid: 15633660].
Sorajja P, Gersh BJ, Cox DA, et al. Impact of delay to angioplasty in patients with acute coronary syndromes undergoing invasive management: analysis from the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. J Am Coll Cardiol. 2010;55(14):1416-24. Exclude - no active comparator. [pmid: 20359590].
Sorensen R, Abildstrom SZ, Hansen PR, et al. Efficacy of post-operative clopidogrel treatment in patients revascularized with coronary artery bypass grafting after myocardial infarction. J Am Coll Cardiol. 2011;57(10):1202-9. Exclude - no active comparator. [pmid: 21371637].
Sorensen R, Abildstrom SZ, Weeke P, et al. Duration of clopidogrel treatment and risk of mortality and recurrent myocardial infarction among 11 680 patients with myocardial infarction treated with percutaneous coronary intervention: a cohort study. BMC Cardiovasc Disord. 2010;10:6. Exclude - no outcomes of interest. [pmid: 20113477].
Sousa P, Imperator E, Aguiar P, et al. Quality improvement in interventional cardiology: the role of risk adjustment in evaluation of health outcomes. Rev Port Cardiol. 2005;24(1):39-47. Exclude - no active comparator. [pmid: 15773665].
Sousa P, Marques N, Santos W, et al. Atrial fibrillation in patients with non-ST-elevation acute coronary syndromes - Follow-up at 6 months. J Cardiovasc Electrophysiol. 2011;22:S92. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Spacek R, Widimsky P, Straka Z, et al. Value of first day angiography/angioplasty in evolving Non-ST segment elevation myocardial infarction: an open multicenter randomized trial. The VINO Study. Eur Heart J. 2002;23(3):230-8. Exclude - no active comparator. [pmid: 11792138].
Spectre G, Mosseri M, Abdelrahman NM, et al. Clinical and prognostic implications of the initial response to aspirin in patients with acute coronary syndrome. Am J Cardiol. 2011;108(8):1112-8. Exclude - no active comparator. [pmid: 21821226].
Spencer FA, Santopinto JJ, Gore JM, et al. Impact of aspirin on presentation and hospital outcomes in patients with acute coronary syndromes (The Global Registry of Acute Coronary Events [GRACE]). Am J Cardiol. 2002;90(10):1056-61. Exclude - no active comparator. [pmid: 12423703].
Spertus JA, Kettelkamp R, Vance C, et al. Prevalence, predictors, and outcomes of premature discontinuation of thienopyridine therapy after drug-eluting stent placement: results from the PREMIER registry. Circulation. 2006;113(24):2803-9. Exclude - no active comparator. [pmid: 16769908].
Spiess A, Roos M, Frisullo R, et al. Cardiovascular drug utilization and its determinants in unselected medical patients with ischemic heart disease. Eur J Intern Med. 2002;13(1):57-64. Exclude - no outcomes of interest. [pmid: 11836084].
Spinler SA, Ou FS, Roe MT, et al. Weight-based dosing of enoxaparin in obese patients with non-ST-segment elevation acute coronary syndromes: results from the CRUSADE initiative. Pharmacotherapy. 2009;29(6):631-8. Exclude - no outcomes of interest. [pmid: 19476416].
Stagmo M, Israelsson B, Brandstrom H, et al. The Swedish National Programme for Quality Control of Secondary Prevention of Coronary Artery Disease--results after one year. Eur J Cardiovasc Prev Rehabil. 2004;11(1):18-24. Exclude - no active comparator. [pmid: 15167202].
Stalnikowicz-Darvasi R. Gastrointestinal bleeding during low-dose aspirin administration for prevention of arterial occlusive events. A critical analysis. J Clin Gastroenterol. 1995;21(1):13-6. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 7560825].
Stauffer JC, Goy JJ, Duvoisin N, et al. Dramatic effect of early clopidogrel administration in reducing mortality and MACE rates in ACS patients. Data from the Swiss registry AMIS-Plus. Swiss Med Wkly. 2012;142:w13573. Exclude - no active comparator. [pmid: 22573491].
Steg PG, Harrington RA, Storey R, et al. Stent thrombosis with ticagrelor versus clopidogrel in patients with acute coronary syndromes undergoing percutaneous coronary intervention -an analysis from the prospective randomized PLATO trial. Eur Heart J. 2011;32:415-416. Exclude - no outcomes of interest.
Steg PG, Iung B, Feldman LJ, et al. Impact of availability and use of coronary interventions on the prescription of aspirin and lipid lowering treatment after acute coronary syndromes. Heart. 2002;88(1):20-4. Exclude - no active comparator. [pmid: 12067934].
Steg PG, Mehta SR, Jukema JW, et al. RUBY-1: a randomized, double-blind, placebo-controlled trial of the safety and tolerability of the novel oral factor Xa inhibitor darexaban (YM150) following acute coronary syndrome. Eur Heart J. 2011;32(20):2541-54. Exclude - no active comparator. [pmid: 21878434].
Stein R, Alboim C, Campos C, et al. Variability among cardiologists in the management of patients under secondary prevention of ischemic heart disease. Arq Bras Cardiol. 2004;83(3):223-6. 219. 22. Exclude - no active comparator. [pmid: 15375470].
Steinberg DH, Shah P, Kinnaird T, et al. Bleeding risk and outcomes of Bivalirudin versus Glycoprotein IIb/IIIa inhibitors with targeted low-dose unfractionated Heparin in patients having percutaneous coronary intervention for either stable or unstable angina pectoris. Am J Cardiol. 2008;102(2):160-4. Exclude - no outcomes of interest. [pmid: 18602514].
Steiner S, Chen L, Coyle D, et al. Effects of prasugrel, ticagrelor and high dose clopidogrel compared to placebo evaluated by three different statistical approaches for indirect treatment comparisons. Eur Heart J. 2011;32:252. Exclude -Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Steinhubl SR, Berger PB, Brennan DM, et al. Optimal timing for the initiation of pre-treatment with 300 mg clopidogrel before percutaneous coronary intervention. J Am Coll Cardiol. 2006;47(5):939-43. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16516075].
Steinhubl SR, Bhatt DL, Brennan DM, et al. Aspirin to prevent cardiovascular disease: the association of aspirin dose and clopidogrel with thrombosis and bleeding. Ann Intern Med. 2009;150(6):379-86. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19293071].
Steinhubl SR, Ellis SG, Wolski K, et al. Ticlopidine pretreatment before coronary stenting is associated with sustained decrease in adverse cardiac events: data from the Evaluation of Platelet IIb/IIIa Inhibitor for Stenting (EPISTENT) Trial. Circulation. 2001;103(10):1403-9. Exclude -no active comparator. [pmid: 11245644].
Steinhubl SR, Lauer MS, Mukherjee DP, et al. The duration of pretreatment with ticlopidine prior to stenting is associated with the risk of procedure-related non-Q-wave myocardial infarctions. J Am Coll Cardiol. 1998;32(5):1366-70. Exclude - no active comparator. [pmid: 9809949].
Steinhubl SR, Talley JD, Braden GA, et al. Point-of-care measured platelet inhibition correlates with a reduced risk of an adverse cardiac event after percutaneous coronary intervention: results of the GOLD (AU-Assessing Ultegra) multicenter study. Circulation. 2001;103(21):2572-8. Exclude - no active comparator. [pmid: 11382726].
Stenestrand U, Lindback J, Wallentin L. Hospital therapy traditions influence long-term survival in patients with acute myocardial infarction. Am Heart J. 2005;149(1):82-90. Exclude - no active comparator. [pmid: 15660038].
Stewart DW, Kincaid EH, Kon ND, et al. Effects of preoperative abciximab and eptifibatide on bleeding indices in coronary artery bypass graft patients. J Pharm Technol. 2008;24(2):63-68. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data).
Stiles MK, Dabbous OH, Fox KA. Bleeding events with antithrombotic therapy in patients with unstable angina or non-ST-segment elevation myocardial infarction; insights from a large clinical practice registry (GRACE). Heart Lung Circ. 2008;17(1):5-8. Exclude - no outcomes of interest. [pmid: 17419100].
Stone GW, Ellis SG, Colombo A, et al. Effect of prolonged thienopyridine use after drug-eluting stent implantation (from the TAXUS landmark trials data). Am J Cardiol. 2008;102(8):1017-22. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18929702].
Storey RF, Husted S, Harrington RA, et al. Inhibition of platelet aggregation by AZD6140, a reversible oral P2Y12 receptor antagonist, compared with clopidogrel in patients with acute coronary syndromes. J Am Coll Cardiol. 2007;50(19):1852-6. Exclude - no outcomes of interest. [pmid: 17980251].
Storey RF, Oldroyd KG, Wilcox RG. Open multicentre study of the P2T receptor antagonist AR-C69931MX assessing safety, tolerability and activity in patients with acute coronary syndromes. Thromb Haemost. 2001;85(3):401-7. Exclude - no active comparator. [pmid: 11307804].
Subherwal S, Peterson ED, Chen AY, et al. Admission international normalized ratio levels, early treatment strategies, and major bleeding risk among non-ST-segment-elevation myocardial infarction patients on home warfarin therapy: insights from the National Cardiovascular Data Registry. Circulation. 2012;125(11):1414-23. Exclude -no active comparator. [pmid: 22319105].
Sulaiman K, Panduranga P, Al-Zakwani I. Gender-related differences in the presentation, management, and outcomes among patients with acute coronary syndrome from Oman. J Saudi Heart Assoc. 2011;23(1):17-22. Exclude - no active comparator. [pmid: 23960630].
Suryapranata H, Van't Hof AWJ, Hoorntje JCA, et al. Randomised comparison of coronary stenting with balloon angioplasty in selected patients with acute myocardial infarction. Asia Pac Heart J. 1998;7(3):193-197. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Svensson AM, Abrahamsson P, McGuire DK, et al. Influence of diabetes on long-term outcome among unselected patients with acute coronary events. Scand Cardiovasc J. 2004;38(4):229-34. Exclude - no active comparator. [pmid: 15553934].
Swahn E, Wallentin L. Low-molecular-weight heparin (Fragmin) during instability in coronary artery disease (FRISC). FRISC Study Group. Am J Cardiol. 1997;80(5A):25E-29E. Exclude - no active comparator. [pmid: 9296466].
Szucs TD, Meyer BJ, Kiowski W. Economic assessment of tirofiban in the management of acute coronary syndromes in the hospital setting: an analysis based on the PRISM PLUS trial. Eur Heart J. 1999;20(17):1253-60. Exclude -no outcomes of interest. [pmid: 10454977].
Tada T, Natsuaki M, Morimoto T, et al. Duration of Dual Antiplatelet Therapy and Long-Term Clinical Outcome After Coronary Drug-Eluting Stent Implantation: Landmark Analyses From the CREDO-Kyoto PCI/CABG Registry Cohort-2. Circ Cardiovasc Interv. 2012;5(3):381-391. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22619260].
Tada T, Natsuaki MN, Morimoto T, et al. Long-term clinical outcomes and duration of dual antiplatelet therapy after drug-eluting stent implantation: Landmark analyses from CREDO-KYOTO Cohort-2 registry. Eur Heart J. 2011;32:509. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item). [pmid: 20494901].
Tamburino C, Angiolillo DJ, Capranzano P, et al. Long-term clinical outcomes after drug-eluting stent implantation in unprotected left main coronary artery disease. Catheter Cardiovasc Interv. 2009;73(3):291-8. Exclude - no outcomes of interest. [pmid: 19214963].
Tamburino C, Di Salvo ME, Capodanno D, et al. Comparison of drug-eluting stents and bare-metal stents for the treatment of unprotected left main coronary artery disease in acute coronary syndromes. Am J Cardiol. 2009;103(2):187-93. Exclude - no outcomes of interest. [pmid: 19121434].
Tandjung K, Basalus MW, Muurman E, et al. Incidence of periprocedural myocardial infarction following stent implantation: Comparison between first- and second-generation drug-eluting stents. Catheter Cardiovasc Interv. 2011. Exclude - no active comparator. [pmid: 22109857].
Taneja AK, Collinson J, Flather MD, et al. Mortality following non-ST elevation acute coronary syndrome: 4 years follow-up of the PRAIS UK Registry (Prospective Registry of Acute Ischaemic Syndromes in the UK). Eur Heart J. 2004;25(22):2013-8. Exclude - no active comparator. [pmid: 15541837].
Tangelder MJ, Frison L, Weaver D, et al. Effect of ximelagatran on ischemic events and death in patients with atrial fibrillation after acute myocardial infarction in the efficacy and safety of the oral direct thrombin inhibitor ximelagatran in patients with recent myocardial damage (ESTEEM) trial. Am Heart J. 2008;155(2):382-7. Exclude - no outcomes of interest. [pmid: 18215612].
Taniuchi M, Kurz HI, Lasala JM. Randomized comparison of ticlopidine and clopidogrel after intracoronary stent implantation in a broad patient population. Circulation. 2001;104(5):539-43. Exclude - no active comparator. [pmid: 11479250].
Tatu-Chitoiu G, Teodorescu C, Dan M, et al. Efficacy and safety of a new streptokinase regimen with enoxaparin in acute myocardial infarction. J Thromb Thrombolysis. 2003;15(3):171-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14739626].
Tcheng JE, Harrington RA, Kottke-Marchant K, et al. Multicenter, randomized, double-blind, placebo-controlled trial of the platelet integrin glycoprotein IIb/IIIa blocker Integrelin in elective coronary intervention. IMPACT Investigators. Circulation. 1995;91(8):2151-7. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 7697843].
Teirstein PS, Kao J, Watkins M, et al. Impact of platelet glycoprotein IIb/IIIa Inhibition on the paclitaxel-eluting stent in patients with stable or unstable angina pectoris or provocable myocardial ischemia (a TAXUS IV substudy). Am J Cardiol. 2005;96(4):500-5. Exclude - no outcomes of interest. [pmid: 16098300].
Teixeira M, Sa I, Mendes JS, et al. Acute coronary syndrome in young adults. Rev Port Cardiol. 2010;29(6):947-55. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 20964107].
Teixeira R, Lourenco C, Baptista R, et al. Invasive versus conservative strategy in non-sT elevation acute coronary syndromes: data from a single Portuguese center. Rev Port Cardiol. 2009;28(4):355-73. Exclude - no active comparator. [pmid: 19634494].
Tello-Montoliu A, Jover E, Marin F, et al. Influence of CYP2C19 Polymorphisms in Platelet Reactivity and Prognosis in an Unselected Population of Non ST Elevation Acute Coronary Syndrome. Rev Esp Cardiol. 2011. Exclude - no active comparator. [pmid: 22116003].
ten Berg JM, Hutten BA, Kelder JC, et al. Oral anticoagulant therapy during and after coronary angioplasty the intensity and duration of anticoagulation are essential to reduce thrombotic complications. Circulation. 2001;103(16):2042-7. Exclude - no active comparator. [pmid: 11319192].
ten Berg JM, Kelder JC, Plokker TH, et al. Costs and effectiveness of using coumarins before, during and after coronary angioplasty. Pharmacoeconomics. 2002;20(12):847-53. Exclude - no outcomes of interest. [pmid: 12236806].
ten Berg JM, Kelder JC, Suttorp MJ, et al. Effect of coumarins started before coronary angioplasty on acute complications and long-term follow-up: a randomized trial. Circulation. 2000;102(4):386-91. Exclude - no active comparator. [pmid: 10908209].
Ten Berg JM, Kelder JC, Suttorp MJ, et al. Provisional stenting in the real world: results in 1058 consecutive patients undergoing percutaneous coronary angioplasty. Int J Cardiovasc Intervent. 2001;4(3):127-133. Exclude - no active comparator. [pmid: 12036466].
Tentzeris I. Impact of concomitant treatment with proton pump inhibitors and clopidogrel on hard outcome parameters stent thrombosis and death. EuroIntervention. 2010;6. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Teplitsky I, Assali A, Golovchiner G, et al. Acute and intermediate-term results of percutaneous coronary stenting in octogenarian patients. Int J Cardiovasc Intervent. 2003;5(4):195-9. Exclude - no active comparator. [pmid: 14630562].
Thel MC, Califf RM, Tardiff BE, et al. Timing of and risk factors for myocardial ischemic events after percutaneous coronary intervention (IMPACT-II). Integrilin to Minimize Platelet Aggregation and Coronary Thrombosis. Am J Cardiol. 2000;85(4):427-34. Exclude - no outcomes of interest. [pmid: 10728945].
Theroux P, Alexander J Jr., Dupuis J, et al. Upstream use of tirofiban in patients admitted for an acute coronary syndrome in hospitals with or without facilities for invasive management. PRISM-PLUS Investigators. Am J Cardiol. 2001;87(4):375-80. Exclude - no outcomes of interest. [pmid: 11179517].
Thiele H, Rach J, Klein N, et al. Optimal timing of invasive angiography in stable non-ST-elevation myocardial infarction: the Leipzig Immediate versus early and late PercutaneouS coronary Intervention triAl in NSTEMI (LIPSIA-NSTEMI Trial). Eur Heart J. 2011. Exclude - no active comparator. [pmid: 22108830].
Thomas CN, Williams DH, Hinds A, et al. Stenting of partial and total coronary occlusions in Trinidad and Tobago. West Indian Med J. 2001;50(1):22-6. Exclude - no active comparator. [pmid: 11398282].
Thompson CR, Humphries KH, Gao M, et al. Revascularization use and survival outcomes after cardiac catheterization in British Columbia and Alberta. Can J Cardiol. 2004;20(14):1417-23. Exclude - no active comparator. [pmid: 15614334].
Tickoo S, Roe MT, Peterson ED, et al. Patterns of aspirin dosing in non-ST-elevation acute coronary syndromes in the CRUSADE Quality Improvement Initiative. Am J Cardiol. 2007;99(11):1496-9. Exclude - no outcomes of interest. [pmid: 17531568].
Tiryaki F, Nutescu EA, Hennenfent JA, et al. Anticoagulation therapy for hospitalized patients: Patterns of use, compliance with national guidelines, and performance on quality measures. Am J Health-Syst Pharm. 2011;68(13):1239-1244. Exclude - no outcomes of interest. [pmid: 21690430].
Tizon-Marcos H, Bertrand OF, Rodes-Cabau J, et al. Impact of female gender and transradial coronary stenting with maximal antiplatelet therapy on bleeding and ischemic outcomes. Am Heart J. 2009;157(4):740-5. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19332204].
Tolleson T, Carr J, Ball M, et al. Clinical outcomes with 6 months versus 12 months versus 24 months dual antiplatelet therapy in patients treated with the resolute zotarolimus eluting stent: Insights from the resolute US trial. Catheterization and Cardiovascular Interventions. 2012;79:S86-S87. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Tolleson TR, Newby LK, Harrington RA, et al. Frequency of stent thrombosis after acute coronary syndromes (from the SYMPHONY and 2nd SYMPHONY trials). Am J Cardiol. 2003;92(3):330-3. Exclude - no active comparator. [pmid: 12888148].
Tolleson TR, O'Shea JC, Bittl JA, et al. Relationship between heparin anticoagulation and clinical outcomes in coronary stent intervention: observations from the ESPRIT trial. J Am Coll Cardiol. 2003;41(3):386-93. Exclude - no active comparator. [pmid: 12575964].
Tomoda H, Aoki N. Pathophysiology of early coronary angioplasty with stenting on non-Q-wave vs Q-wave myocardial infarction. Angiology. 2001;52(10):671-9. Exclude - no active comparator. [pmid: 11666131].
Topol EJ, Califf RM, Weisman HF, et al. Randomised trial of coronary intervention with antibody against platelet IIb/IIIa integrin for reduction of clinical restenosis: results at six months. The EPIC Investigators. Lancet. 1994;343(8902):881-6. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 7908357].
Topol EJ, Easton D, Harrington RA, et al. Randomized, double-blind, placebo-controlled, international trial of the oral IIb/IIIa antagonist lotrafiban in coronary and cerebrovascular disease. Circulation. 2003;108(4):399-406. Exclude - no active comparator. [pmid: 12874182].
Topol EJ, Ferguson JJ, Weisman HF, et al. Long-term protection from myocardial ischemic events in a randomized trial of brief integrin beta3 blockade with percutaneous coronary intervention. EPIC Investigator Group. Evaluation of Platelet IIb/IIIa Inhibition for Prevention of Ischemic Complication. JAMA. 1997;278(6):479-84. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9256222].
Topol EJ, Lincoff AM, Kereiakes DJ, et al. Multi-year follow-up of abciximab therapy in three randomized, placebo-controlled trials of percutaneous coronary revascularization. Am J Med. 2002;113(1):1-6. Exclude - not a Clinical Study. [pmid: 12106616].
Topol EJ, Mark DB, Lincoff AM, et al. Outcomes at 1 year and economic implications of platelet glycoprotein IIb/IIIa blockade in patients undergoing coronary stenting: results from a multicentre randomised trial. EPISTENT Investigators. Evaluation of Platelet IIb/IIIa Inhibitor for Stenting. Lancet. 1999;354(9195):2019-24. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 10636365].
Torres M, Rocha S, Marques J, et al. Impact of atrial fibrillation in acute coronary syndromes. Rev Port Cardiol. 2008;27(11):1407-18. Exclude - no outcomes of interest. [pmid: 19227808].
Toss H, Wallentin L, Siegbahn A. Influences of sex and smoking habits on anticoagulant activity in low-molecular-weight heparin treatment of unstable coronary artery disease. Am Heart J. 1999;137(1):72-8. Exclude - no active comparator. [pmid: 9878938].
Trabattoni D, Bartorelli AL, Montorsi P, et al. Comparison of outcomes in women and men treated with coronary stent implantation. Catheter Cardiovasc Interv. 2003;58(1):20-8. Exclude - no active comparator. [pmid: 12508192].
Trenk D, Stone GW, Gawaz M, et al. A Randomized Trial of Prasugrel Versus Clopidogrel in Patients With High Platelet Reactivity on Clopidogrel After Elective Percutaneous Coronary Intervention With Implantation of Drug-Eluting Stents: Results of the TRIGGER-PCI (Testing Platelet Reactivity In Patients Undergoing Elective Stent Placement on Clopidogrel to Guide Alternative Therapy With Prasugrel) Study. J Am Coll Cardiol. 2012;59(24):2159-64. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22520250].
Tricoci P, Roe MT, Mulgund J, et al. Clopidogrel to treat patients with non-ST-segment elevation acute coronary syndromes after hospital discharge. Arch Intern Med. 2006;166(7):806-11. Exclude - no outcomes of interest. [pmid: 16606819].
Tsai TT, Ho PM, Xu S, et al. Increased risk of bleeding in patients on clopidogrel therapy after drug-eluting stents implantation: insights from the HMO Research Network-Stent Registry (HMORN-stent). Circ Cardiovasc Interv. 2010;3(3):230-5. Exclude - no outcomes of interest. [pmid: 20442361].
Tuppin P, Neumann A, Danchin N, et al. Combined secondary prevention after hospitalization for myocardial infarction in France: analysis from a large administrative database. Arch Cardiovasc Dis. 2009;102(4):279-92. Exclude - no outcomes of interest. [pmid: 19427605].
Tyagi V, Jayasuriya C. Discharge management of patients with acute coronary syndrome- An outer metropolitan hospital experience in Queensland. Heart Lung Circ. 2011;20:S246. Exclude - not a Clinical Study.
Tymchak W, Armstrong PW, Westerhout CM, et al. Mode of hospital presentation in patients with non-ST-elevation myocardial infarction: implications for strategic management. Am Heart J. 2011;162(3):436-43. Exclude - no active comparator. [pmid: 21884858].
Uchmanowicz I, Loboz-Grudzien K, Jankowska-Polanska B, et al. Influence of diabetes on health-related quality of life results in patients with acute coronary syndrome treated with coronary angioplasty. Acta Diabetol. 2011. Exclude - no active comparator. [pmid: 21442428].
Ueshima K, Fukami K, Hiramori K, et al. Is angiotensin-converting enzyme inhibitor useful in a Japanese population for secondary prevention after acute myocardial infarction? A final report of the Japanese Acute Myocardial Infarction Prospective (JAMP) study. Am Heart J. 2004;148(2):e8. Exclude - no active comparator. [pmid: 15309011].
Umans VA, Cornel JH, Velthoven SS, et al. Safety and efficacy of treatment with platelet GPIIb/IIIa receptor blockade in unstable angina patients awaiting PTCA at a referring clinic. Int J Cardiovasc Intervent. 1999;2(4):223-230. Exclude - no active comparator. [pmid: 12623572].
Underwood P, Beck P. Secondary prevention following myocardial infarction: evidence from an audit in South Wales that the National Service Framework for coronary heart disease does not address all the issues. Qual Saf Health Care. 2002;11(3):230-2. Exclude - no active comparator. [pmid: 12486986].
Urban P, Abizaid A, Banning A, et al. Stent thrombosis, major bleeding and antiplatelet therapy in the e-SELECT registry: 1-year follow-up of 15,000 patients treated with the Sirolimus-eluting CYPHER Select plus stent. EuroIntervention. 2010;6. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Urban P, Macaya C, Rupprecht HJ, et al. Randomized evaluation of anticoagulation versus antiplatelet therapy after coronary stent implantation in high-risk patients: the multicenter aspirin and ticlopidine trial after intracoronary stenting (MATTIS). Circulation. 1998;98(20):2126-32. Exclude - no active comparator. [pmid: 9815866].
Vaccarino V, Rathore SS, Wenger NK, et al. Sex and racial differences in the management of acute myocardial infarction, 1994 through 2002. N Engl J Med. 2005;353(7):671-82. Exclude - no active comparator. [pmid: 16107620].
Vaina S, Voudris V, Morice MC, et al. Effect of gender differences on early and mid-term clinical outcome after percutaneous or surgical coronary revascularisation in patients with multivessel coronary artery disease: insights from ARTS I and ARTS II. EuroIntervention. 2009;4(4):492-501. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19284072].
Vakili BA, Kaplan RC, Slater JN, et al. A propensity analysis of the impact of platelet glycoprotein IIb/IIIa inhibitor therapy on in-hospital outcomes after percutaneous coronary intervention. Am J Cardiol. 2003;91(8):946-50. Exclude - no outcomes of interest. [pmid: 12686333].
Valencia J, Mainar V, Bordes P, et al. Observance of antiplatelet therapy after stent implantation in patients under chronic oral anticoagulant treatment. J Interv Cardiol. 2008;21(3):218-24. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 18422520].
Valgimigli M, Campo G, de Cesare N, et al. Intensifying platelet inhibition with tirofiban in poor responders to aspirin, clopidogrel, or both agents undergoing elective coronary intervention: results from the double-blind, prospective, randomized Tailoring Treatment with Tirofiban in Patients Showing Resistance to Aspirin and/or Resistance to Clopidogrel study. Circulation. 2009;119(25):3215-22. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19528337].
Valgimigli M, Okmen E. Trial finds high-dose bolus tirofiban is safe and effective for preventing complications in high-risk percutaneous coronary intervention. Evid-based Cardiovasc Med. 2004;8(4):353-356. Exclude - not a Clinical Study. [pmid: 16379971].
Valgimigli M, Percoco G, Barbieri D, et al. The additive value of tirofiban administered with the high-dose bolus in the prevention of ischemic complications during high-risk coronary angioplasty: the ADVANCE Trial. J Am Coll Cardiol. 2004;44(1):14-9. Exclude - no outcomes of interest. [pmid: 15234398].
Valgimigli M, Percoco G, Cicchitelli G, et al. High-dose bolus tirofiban and sirolimus eluting stent versus abiciximab and bare metal stent in acute myocardial infarction (STRATEGY) study--protocol design and demography of the first 100 patients. Cardiovasc Drugs Ther. 2004;18(3):225-30. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15229391].
Van Belle E, McFadden EP, Lablanche JM, et al. Two-pronged antiplatelet therapy with aspirin and ticlopidine without systemic anticoagulation: an alternative therapeutic strategy after bailout stent implantation. Coron Artery Dis. 1995;6(4):341-5. Exclude - no active comparator. [pmid: 7655719].
Van de Werf F, Gore JM, Avezum A, et al. Access to catheterisation facilities in patients admitted with acute coronary syndrome: multinational registry study. BMJ. 2005;330(7489):441. Exclude - no active comparator. [pmid: 15665006].
van den Brand M, Laarman GJ, Steg PG, et al. Assessment of coronary angiograms prior to and after treatment with abciximab, and the outcome of angioplasty in refractory unstable angina patients. Angiographic results from the CAPTURE trial. Eur Heart J. 1999;20(21):1572-8. Exclude - no outcomes of interest. [pmid: 10529325].
van der Elst ME, Cisneros-Gonzalez N, de Blaey CJ, et al. Oral antithrombotic use among myocardial infarction patients. Ann Pharmacother. 2003;37(1):143-6. Exclude - no active comparator. [pmid: 12503950].
van der Vleuten PA, Wijpkema JS, van den Heuvel AF, et al. Treatment synergy of silicon carbide-coated stenting and abciximab for complex coronary artery lesions: clinical results of a single-center study. Ital Heart J. 2004;5(9):663-6. Exclude - no active comparator. [pmid: 15568593].
van Domburg RT, Sonnenschein K, Nieuwlaat R, et al. Sustained benefit 20 years after reperfusion therapy in acute myocardial infarction. J Am Coll Cardiol. 2005;46(1):15-20. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15992629].
van Es RF, Jonker JJ, Verheugt FW, et al. Aspirin and coumadin after acute coronary syndromes (the ASPECT-2 study): a randomised controlled trial. Lancet. 2002;360(9327):109-13. Exclude - no outcomes of interest. [pmid: 12126819].
van Es RF, Jonker JJ, Verheugt FW, et al. Coumadin alone or aspirin plus coumadin reduced coronary evens and death after acute myocardial infarction or unstable angina. Evid-Based Med. 2003;8(1):16. Exclude - not a Clinical Study.
van Hout BA, Serruys PW, Lemos PA, et al. One year cost effectiveness of sirolimus eluting stents compared with bare metal stents in the treatment of single native de novo coronary lesions: an analysis from the RAVEL trial. Heart. 2005;91(4):507-12. Exclude - no active comparator. [pmid: 15772214].
Varenhorst C, Alstrom U, Scirica BM, et al. Cardiac events, infections and bleeds contribute to higher vascular and non-vascular mortality with clopidogrel compared to ticagrelor treatment in patients undergoing coronary artery bypass grafting. Eur Heart J. 2011;32:414. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Vavuranakis M, Latsios G, Aggelis D, et al. Randomized comparison of the effects of ASA plus clopidogrel versus ASA alone on early platelet activation in acute coronary syndromes with elevated high-sensitivity C-reactive protein and soluble CD40 ligand levels. Clin Ther. 2006;28(6):860-71. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 16860169].
Vecchio S, Zanolla L, Valencia J, et al. Coronary stenting for ST-elevation myocardial infarction vs. other indications in patients on oral anticoagulation: any difference in in-hospital management and outcome?. Minerva Cardioangiol. 2011;59(5):499-506. Exclude - no active comparator. [pmid: 21983310].
Velianou JL, Strauss BH, Kreatsoulas C, et al. Evaluation of the role of abciximab (Reopro) as a rescue agent during percutaneous coronary interventions: in-hospital and six-month outcomes. Catheter Cardiovasc Interv. 2000;51(2):138-44. Exclude - no active comparator. [pmid: 11025564].
Venge P, Lagerqvist B, Diderholm E, et al. Clinical performance of three cardiac troponin assays in patients with unstable coronary artery disease (a FRISC II substudy). Am J Cardiol. 2002;89(9):1035-41. Exclude - no active comparator. [pmid: 11988191].
Venkatesh K, Mann T. Transitioning from heparin to bivalirudin in patients undergoing ad hoc transradial interventional procedures: a pilot study. J Invasive Cardiol. 2006;18(3):120-4. Exclude - no active comparator. [pmid: 16598111].
Verheugt FW. Warfarin for ischemic heart disease. Cardiol Rev. 2001;9(6):325-8. Exclude - not a Clinical Study. [pmid: 11696261].
Verheugt FW, Liem A, Zijlstra F, et al. High dose bolus heparin as initial therapy before primary angioplasty for acute myocardial infarction: results of the Heparin in Early Patency (HEAP) pilot study. J Am Coll Cardiol. 1998;31(2):289-93. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 9462569].
Verheye S, Agostoni P, Dubois CL, et al. 9-month clinical, angiographic, and intravascular ultrasound results of a prospective evaluation of the Axxess self-expanding biolimus A9-eluting stent in coronary bifurcation lesions: the DIVERGE (Drug-Eluting Stent Intervention for Treating Side Branches Effectively) study. J Am Coll Cardiol. 2009;53(12):1031-9. Exclude - no outcomes of interest. [pmid: 19298915].
Veselka J, Prochazkova S, Duchonova R, et al. Lack of efficacy of ticlopidine pre-treatment in the reduction of troponin I release following percutaneous intervention in stable angina patients. Vnitr Lek. 2005;51(9):940-944. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data).
Vidi VD, Matheny ME, Agarwal V, et al. Validation of long-term benefits of bivalirudin versus unfractionated heparin in routine clinical practice after percutaneous coronary intervention. Am J Cardiol. 2010;106(9):1234-40. Exclude - no outcomes of interest. [pmid: 21029818].
Vikman S, Airaksinen KE, Tierala I, et al. Improved adherence to practice guidelines yields better outcome in high-risk patients with acute coronary syndrome without ST elevation: findings from nationwide FINACS studies. J Intern Med. 2004;256(4):316-23. Exclude - no active comparator. [pmid: 15367174].
Vogel B, Hahne S, Kozanli I, et al. Influence of updated guidelines on short- and long-term mortality in patients with non-ST-segment elevation acute coronary syndrome (NSTE-ACS). Int J Cardiol. 2011. Exclude - no active comparator. [pmid: 21447430].
von Beckerath N, Koch W, Mehilli J, et al. Glycoprotein Ia C807T polymorphism and risk of restenosis following coronary stenting. Atherosclerosis. 2001;156(2):463-8. Exclude - no active comparator. [pmid: 11395045].
Vonkeman H, Meek I, van de Laar M. Risk management of risk management: Combining proton pump inhibitors with low-dose aspirin. Drug Healthc Patient Saf. 2010;2(1):191-204. Exclude - not a Clinical Study. [pmid: 21701631].
Voudris VA, Skoularigis JS, Dimitriou YK, et al. Diabetes mellitus and unstable coronary artery disease: improved clinical outcome of coronary artery stenting in an era of glycoprotein IIb/IIIa inhibitors and lipid-lowering therapy. Coron Artery Dis. 2004;15(6):353-9. Exclude -no active comparator. [pmid: 15346094].
Vulic D, Loncar S, Krneta M, et al. Risk factor control and adherence to treatment in patients with coronary heart disease in the Republic of Srpska, Bosnia and Herzegovina in 2005-2006. Arch Med Sci. 2010;6(2):183-187. Exclude - no active comparator. [pmid: 22371744].
Waksman R, Wolfram RM, Torguson RL, et al. Switching from Enoxaparin to Bivalirudin in Patients with Acute Coronary Syndromes without ST-segment Elevation who Undergo Percutaneous Coronary Intervention. Results from SWITCH--a multicenter clinical trial. J Invasive Cardiol. 2006;18(8):370-5. Exclude - no active comparator. [pmid: 16877786].
Wallentin L. Low-molecular-weight heparin as a bridge to timely revascularization in unstable coronary artery disease -- an update of the Fragmin during Instability in Coronary Artery Disease II Trial. Haemostasis. Suppl 2. 2000;30:108-13. discussion 106-7. Exclude - no active comparator. [pmid: 11251353].
Wallentin L, Husted S, Kontny F, et al. Long-term low-molecular-weight heparin (Fragmin) and/or early revascularization during instability in coronary artery disease (the FRISC II Study). Am J Cardiol. 1997;80(5A):61E-63E. Exclude - no outcomes of interest. [pmid: 9205021].
Wallentin L, Lagerqvist B, Husted S, et al. Outcome at 1 year after an invasive compared with a non-invasive strategy in unstable coronary-artery disease: the FRISC II invasive randomised trial. FRISC II Investigators. Fast Revascularisation during Instability in Coronary artery disease. Lancet. 2000;356(9223):9-16. Exclude -no outcomes of interest. [pmid: 10892758].
Wallentin L, Wilcox RG, Weaver WD, et al. Oral ximelagatran for secondary prophylaxis after myocardial infarction: the ESTEEM randomised controlled trial. Lancet. 2003;362(9386):789-97. Exclude - no active comparator. [pmid: 13678873].
Walter DH, Fichtlscherer S, Sellwig M, et al. Preprocedural C-reactive protein levels and cardiovascular events after coronary stent implantation. J Am Coll Cardiol. 2001;37(3):839-46. Exclude - no outcomes of interest. [pmid: 11693760].
Wang F, Stouffer GA, Waxman S, et al. Late coronary stent thrombosis: early vs. late stent thrombosis in the stent era. Catheter Cardiovasc Interv. 2002;55(2):142-7. Exclude - no outcomes of interest. [pmid: 11835636].
Wang H, Li C, Wang L, et al. Initial Experience with a Magnetic Navigation System for Invasive Treatment in Patients with Non-ST-Segment Elevation Acute Coronary Syndromes. J Interv Cardiol. 2011. Exclude - no active comparator. [pmid: 21883473].
Wang TY, Xiao L, Alexander KP, et al. Antiplatelet therapy use after discharge among acute myocardial infarction patients with in-hospital bleeding. Circulation. 2008;118(21):2139-45. Exclude - no outcomes of interest. [pmid: 18981304].
Wang Y, Liu Q, Zhu J, et al. Procoagulant effects of thrombolytic therapy in acute myocardial infarction. Chin Med Sci J. 2002;17(1):36-9. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12894883].
Waters DD. Early pharmacologic intervention and plaque stability in acute coronary syndromes. Am J Cardiol. 2001;88(8A):30K-36K. Exclude - not a Clinical Study. [pmid: 11423054].
Watson K, Seybert AL, Saul MI, et al. Comparison of patient outcomes with bivalirudin versus unfractionated heparin in percutaneous coronary intervention. Pharmacotherapy. 2007;27(5):647-56. Exclude - no outcomes of interest. [pmid: 17461699].
Weber ZA, Rodgers PT. The clinical significance of the interaction between proton pump inhibitors and clopidogrel. J Pharm Technol. 2010;26(1):22-26. Exclude - not a Clinical Study.
Weintraub WS, Culler S, Boccuzzi SJ, et al. Economic impact of GPIIB/IIIA blockade after high-risk angioplasty: results from the RESTORE trial. Randomized Efficacy Study of Tirofiban for Outcomes and Restenosis. J Am Coll Cardiol. 1999;34(4):1061-6. Exclude - no outcomes of interest. [pmid: 10520791].
Weintraub WS, Mahoney EM, Lamy A, et al. Long-term cost-effectiveness of clopidogrel given for up to one year in patients with acute coronary syndromes without ST-segment elevation. J Am Coll Cardiol. 2005;45(6):838-45. Exclude - no active comparator. [pmid: 15766816].
Wexler LF, Blaustein AS, Lavori PW, et al. Non-Q-wave myocardial infarction following thrombolytic therapy: a comparison of outcomes in patients randomized to invasive or conservative post-infarct assessment strategies in the Veterans Affairs non-Q-wave Infarction Strategies In-Hospital (VANQWISH) Trial. J Am Coll Cardiol. 2001;37(1):19-25. Exclude - no outcomes of interest. [pmid: 11153737].
Wicks EC, Rathod K, Jones D, et al. Improved survival with abciximab if used during PCI for NSTEMI patients under 75 years of age. Heart. 2010;96:A23. Exclude - Grey Literature (meeting abstract, poster, other non-peer-reviewed item).
Wiederkehr D, Berenson K, Casciano R, et al. Clinical impact of early clopidogrel discontinuation following acute myocardial infarction hospitalization or stent implantation: analysis in a single integrated health network. Curr Med Res Opin. 2009;25(9):2317-25. Exclude - no active comparator. [pmid: 19635042].
Wienbergen H, Gitt AK, Schiele R, et al. Different treatments and outcomes of consecutive patients with non-ST-elevation myocardial infarction depending on initial electrocardiographic changes (results of the Acute Coronary Syndromes [ACOS] Registry). Am J Cardiol. 2004;93(12):1543-6. Exclude - no active comparator. [pmid: 15194032].
Wijpkema JS, Jessurun GA, Van Boven AJ, et al. Clinical impact of abciximab on long-term outcome after complex coronary angioplasty. Catheter Cardiovasc Interv. 2003;60(3):339-43. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14571484].
Wildimsky P, Bove AA. Pre-PCI clopidogrel loading: 600 mg before every coronary angioraphy versus 600 mg in cath-lab only for PCI patients (PRAGUE-8). ACC Cardiosource Rev J. 2008;17(2):33-37. Exclude - not a Clinical Study.
Williams MJ, Morison IM, Parker JH, et al. Progression of the culprit lesion in unstable coronary artery disease with warfarin and aspirin versus aspirin alone: preliminary study. J Am Coll Cardiol. 1997;30(2):364-9. Exclude - no active comparator. [pmid: 9247506].
Williams RI, Fraser AG, West RR. Gender differences in management after acute myocardial infarction: not ‘sexism’ but a reflection of age at presentation. J Public Health (Oxf). 2004;26(3):259-63. Exclude - no active comparator. [pmid: 15454593].
Wilson JM, Dougherty KG, Ellis KO, et al. Activated clotting times in acute coronary syndromes and percutaneous transluminal coronary angioplasty. Cathet Cardiovasc Diagn. 1995;34(1):1-5. Exclude - no active comparator. [pmid: 7728844].
Wilson SR, Vakili BA, Sherman W, et al. Effect of diabetes on long-term mortality following contemporary percutaneous coronary intervention: analysis of 4,284 cases. Diabetes Care. 2004;27(5):1137-42. Exclude - no active comparator. [pmid: 15111534].
Wilson WM, Andrianopoulos N, Clark D, et al. Long-term predictors of mortality after percutaneous coronary intervention in the era of drug-eluting stents. Am J Cardiol. 2011;108(7):936-42. Exclude - no active comparator. [pmid: 21920184].
Windecker S, Remondino A, Eberli FR, et al. Sirolimus-eluting and paclitaxel-eluting stents for coronary revascularization. N Engl J Med. 2005;353(7):653-62. Exclude - no active comparator. [pmid: 16105989].
Wise GR, Schwartz BP, Dittoe N, et al. Comparative effectiveness analysis of anticoagulant strategies in a large observational database of percutaneous coronary interventions. Journal of Interventional Cardiology. 2012;25(3):278-288. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 22463372].
Witkowski A, Maciejewski P, Wasek W, et al. Influence of different antiplatelet treatment regimens for primary percutaneous coronary intervention on all-cause mortality. Eur Heart J. 2009;30(14):1736-43. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19376786].
Witte K, Thackray S, Clark AL, et al. Clinical trials update: IMPROVEMENT-HF, COPERNICUS, MUSTIC, ASPECT-II, APRICOT and HEART. Eur J Heart Fail. 2000;2(4):455-60. Exclude - not a Clinical Study. [pmid: 11113724].
Wiviott SD, Antman EM, Winters KJ, et al. Randomized comparison of prasugrel (CS-747, LY640315), a novel thienopyridine P2Y12 antagonist, with clopidogrel in percutaneous coronary intervention: results of the Joint Utilization of Medications to Block Platelets Optimally (JUMBO)-TIMI 26 trial. Circulation. 2005;111(25):3366-73. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 15967851].
Wiviott SD, Flather MD, O'Donoghue ML, et al. Randomized trial of atopaxar in the treatment of patients with coronary artery disease: the lessons from antagonizing the cellular effect of Thrombin-Coronary Artery Disease Trial. Circulation. 2011;123(17):1854-63. Exclude -no active comparator. [pmid: 21502571].
Wiviott SD, Trenk D, Frelinger AL, et al. Prasugrel compared with high loading- and maintenance-dose clopidogrel in patients with planned percutaneous coronary intervention: the Prasugrel in Comparison to Clopidogrel for Inhibition of Platelet Activation and Aggregation-Thrombolysis in Myocardial Infarction 44 trial. Circulation. 2007;116(25):2923-32. Exclude - no outcomes of interest. [pmid: 18056526].
Wohrle J, Grebe OC, Nusser T, et al. Reduction of major adverse cardiac events with intracoronary compared with intravenous bolus application of abciximab in patients with acute myocardial infarction or unstable angina undergoing coronary angioplasty. Circulation. 2003;107(14):1840-3. Exclude - no active comparator. [pmid: 12682003].
Wolak A, Amit G, Cafri C, et al. Increased long term rates of stent thrombosis and mortality in patients given clopidogrel as compared to ticlopidine following coronary stent implantation. Int J Cardiol. 2005;103(3):293-7. Exclude - no active comparator. [pmid: 16098392].
Wolak A, Ayzenberg Y, Cafri C, et al. Can enoxaparin safely replace unfractionated heparin during coronary intervention in acute coronary syndromes?. Int J Cardiol. 2004;96(2):151-5. Exclude - no outcomes of interest. [pmid: 15262028].
Worrall AP, Amoah V, Nevill A, et al. Testing for clopidogrel and aspirin anti-platelet activity in patients with acute coronary syndromes (ACS): Should we test, and if so when?. Heart. 2010;96:A61. Exclude - no active comparator.
Wu AH, Goss JR, Maynard C, et al. Predictors of hospital outcomes after percutaneous coronary intervention in the community. J Interv Cardiol. 2004;17(3):151-8. Exclude - no active comparator. [pmid: 15209577].
Wu H, Jing Q, Wang J, et al. Pantoprazole for the prevention of gastrointestinal bleeding in high-risk patients with acute coronary syndromes. J Crit Care. 2011;26(4):434 e1-6. Exclude - no outcomes of interest. [pmid: 21273036].
Wu TG, Zhao Q, Huang WG, et al. Effect of intracoronary tirofiban in patients undergoing percutaneous coronary intervention for acute coronary syndrome. Circ J. 2008;72(10):1605-9. Exclude - no outcomes of interest. [pmid: 18753700].
Wu WC, Waring ME, Lessard D, et al. Six-month mortality and cardiac catheterization in non-ST-segment elevation myocardial infarction patients with anemia. Coron Artery Dis. 2011;22(5):317-23. Exclude - no active comparator. [pmid: 21738102].
Wylie JV, Murphy SA, Morrow DA, et al. Validated risk score predicts the development of congestive heart failure after presentation with unstable angina or non-ST-elevation myocardial infarction: results from OPUS-TIMI 16 and TACTICS-TIMI 18. Am Heart J. 2004;148(1):173-80. Exclude - no active comparator. [pmid: 15215808].
Yan AT, Tan M, Fitchett D, et al. One-year outcome of patients after acute coronary syndromes (from the Canadian Acute Coronary Syndromes Registry). Am J Cardiol. 2004;94(1):25-9. Exclude - no active comparator. [pmid: 15219503].
Yan AT, Yan RT, Huynh T, et al. Bleeding and outcome in acute coronary syndrome: insights from continuous electrocardiogram monitoring in the Integrilin and Enoxaparin Randomized Assessment of Acute Coronary Syndrome Treatment (INTERACT) Trial. Am Heart J. 2008;156(4):769-75. Exclude - no outcomes of interest. [pmid: 18926160].
Yan AT, Yan RT, Tan M, et al. Optimal medical therapy at discharge in patients with acute coronary syndromes: temporal changes, characteristics, and 1-year outcome. Am Heart J. 2007;154(6):1108-15. Exclude - no outcomes of interest. [pmid: 18035083].
Yan BP, Clark DJ, Buxton B, et al. Clinical characteristics and early mortality of patients undergoing coronary artery bypass grafting compared to percutaneous coronary intervention: insights from the Australasian Society of Cardiac and Thoracic Surgeons (ASCTS) and the Melbourne Interventional Group (MIG) Registries. Heart Lung Circ. 2009;18(3):184-90. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 19268632].
Yan HB, Song L, Liu R, et al. Comparison of safety and efficacy between fondaparinux and nadroparin in non-ST elevation acute coronary syndromes. Chin Med J (Engl). 2011;124(6):879-86. Exclude - no active comparator. [pmid: 21518596].
Yasue H, Ogawa H, Tanaka H, et al. Effects of aspirin and trapidil on cardiovascular events after acute myocardial infarction. Japanese Antiplatelets Myocardial Infarction Study (JAMIS) Investigators. Am J Cardiol. 1999;83(9):1308-13. Exclude - no active comparator. [pmid: 10235086].
Yeh RW, Baron SJ, Healy JL, et al. Anticoagulation with the direct thrombin inhibitor argatroban in patients presenting with acute coronary syndromes. Catheter Cardiovasc Interv. 2009;74(2):359-64. Exclude - no active comparator. [pmid: 19213062].
Yip HK, Wu CJ, Chang HW, et al. Comparison of primary angioplasty and conservative treatment on short- and long-term outcome in octogenarian or older patients with acute myocardial infarction. Jpn Heart J. 2002;43(5):463-74. Exclude - no active comparator. [pmid: 12452304].
Young JJ, Kereiakes DJ. Abciximab: cost-effective survival advantage in clinical trials and clinical practice. Am Heart J. 2000;140(6 Suppl):S148-53. Exclude - no outcomes of interest. [pmid: 11100009].
Young JJ, Kereiakes DJ, Grines CL. Low-molecular-weight heparin therapy in percutaneous coronary intervention: the NICE 1 and NICE 4 trials. National Investigators Collaborating on Enoxaparin Investigators. J Invasive Cardiol. Suppl E. 2000;12:E14-8. discussion E25-8. Exclude - not a Clinical Study. [pmid: 11156724].
Yu HT, Kim KJ, Bang WD, et al. Gender-based differences in the management and prognosis of acute coronary syndrome in Korea. Yonsei Med J. 2011;52(4):562-8. Exclude - no active comparator. [pmid: 21623596].
Yu KH, Ku YC, Lin SL. Drug interaction between clopidogrel and proton pump inhibitors. Acta Cardiol Sin. 2010;26(1):1-6. Exclude - not a Clinical Study.
Yun KH, Shin IS, Shin SN, et al. Effect of previous statin therapy in patients with acute coronary syndrome and percutaneous coronary intervention. Korean Circ J. 2011;41(8):458-63. Exclude - no active comparator. [pmid: 21949530].
Yusuf S. Design, baseline characteristics, and preliminary clinical results of the Organization to Assess Strategies for Ischemic Syndromes-2 (OASIS-2) trial. Am J Cardiol. 1999;84(5A):20M-25M. Exclude - no active comparator. [pmid: 10505539].
Zahn R, Schweppe F, Zeymer U, et al. Reperfusion therapy for acute ST-elevation and non ST-elevation myocardial infarction: what can be achieved in daily clinical practice in unselected patients at an interventional center?. Acute Card Care. 2009;11(2):92-8. Exclude - no active comparator. [pmid: 19391052].
Zalewski J, Nycz K, Przewlocki T, et al. Conservative strategy in patients with non-ST-segment elevation acute coronary syndromes. Postepy Kardiol Interwencyjnej. 2010;6(4):147-153. Exclude - no active comparator.
Zapata GO, Lasave LI, Kozak F, et al. Culprit-only or multivessel percutaneous coronary stenting in patients with non-ST-segment elevation acute coronary syndromes: one-year follow-up. J Interv Cardiol. 2009;22(4):329-35. Exclude - no active comparator. [pmid: 19515083].
Zeymer U, Bauer T, Juenger C, et al. Efficacy of combination therapy with aspirin, an ACE-inhibitor and a statin in secondary prevention in patients after acute myocardial infarction treated with a beta-blocker. Arguments for a polypill. Eur Heart J. 2011;32:420. Exclude - no active comparator.
Zeymer U, Junger C, Zahn R, et al. Effects of a secondary prevention combination therapy with an aspirin, an ACE inhibitor and a statin on 1-year mortality of patients with acute myocardial infarction treated with a beta-blocker. Support for a polypill approach. Curr Med Res Opin. 2011;27(8):1563-70. Exclude - no active comparator. [pmid: 21682553].
Zeymer U, Norrbacka K, Paget MA, et al. Practice patterns and quality of life in acute coronary syndrome patients in 2008-2009: Baseline results for Germany from the antiplatelet treatment observational registry II (APTOR II). Value Health. 2010;13(7):A366. Exclude - no active comparator.
Zeymer U, Uebis R, Vogt A, et al. Randomized comparison of percutaneous transluminal coronary angioplasty and medical therapy in stable survivors of acute myocardial infarction with single vessel disease: a study of the Arbeitsgemeinschaft Leitende Kardiologische Krankenhausarzte. Circulation. 2003;108(11):1324-8. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 12939210].
Zeymer U, Zahn R, Hochadel M, et al. Incications and complications of invasive diagnostic procedures and percutaneous coronary interventions in the year 2003. Results of the quality control registry of the Arbeitsgemeinschaft Leitende Kardiologische Krankenhausarzte (ALKK). Z Kardiol. 2005;94(6):392-8. Exclude - no active comparator. [pmid: 15940439].
Zhang D, Cai X, Shen W, et al. Intracoronary stent implantation under intracoronary ultrasound guidance with aspirin and ticlopidine therapy. Chin Med J (Engl). 2001;114(3):262-5. Exclude - population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 11780310].
Zhang LJ, Chen YD, Song XT, et al. Antithrombotic and antiplatelet therapies in relation to risk stratification in patients with non-ST elevation acute coronary syndrome: insights from the Sino-Global Registry of Acute Coronary Events. Chin Med J (Engl). 2009;122(5):502-8. Exclude - no active comparator. [pmid: 19323898].
Zhao XQ, Theroux P, Snapinn SM, et al. Intracoronary thrombus and platelet glycoprotein IIb/IIIa receptor blockade with tirofiban in unstable angina or non-Q-wave myocardial infarction. Angiographic results from the PRISM-PLUS trial (Platelet receptor inhibition for ischemic syndrome management in patients limited by unstable signs and symptoms). PRISM-PLUS Investigators. Circulation. 1999;100(15):1609-15. Exclude -no outcomes of interest. [pmid: 10517731].
Zhu B, Zhao Z, McCollam P, et al. Factors associated with clopidogrel use, adherence, and persistence in patients with acute coronary syndromes undergoing percutaneous coronary intervention. Curr Med Res Opin. 2011;27(3):633-41. Exclude - no active comparator. [pmid: 21241206].
Zibaeenezhad MJ, Mowla A, Sorbi MH. Warfarin and aspirin versus aspirin alone in patients with acute myocardial infarction: a pilot study. Angiology. 2004;55(1):17-20. Exclude -population not UA/NSTEMI (only STEMI, or cannot separate data). [pmid: 14759085].
Zubaid M, Penn IM, Buller CE, et al. Antiplatelet therapy alone is safe and effective after coronary stenting: observations of a transition in practice. Can J Cardiol. 1997;13(4):335-40. Exclude - no active comparator. [pmid: 9141964].
Zubaid M, Rashed WA, Husain M, et al. A registry of acute myocardial infarction in Kuwait: Patient characteristics and practice patterns. Can J Cardiol. 2004;20(8):783-7. Exclude - no active comparator. [pmid: 15229759].