# List of Included Studies

Abuzahra M, Pillai M, Caldera A, et al. Comparison of higher clopidogrel loading and maintenance dose to standard dose on platelet function and outcomes after percutaneous coronary intervention using drug-eluting stents. Am J Cardiol. 2008;102(4):401-3. [pmid: 18678295].
Ajani AE, Waksman R, Gruberg L, et al. Acute procedural complications and in-hospital events after percutaneous coronary interventions: eptifibatide versus abciximab. Cardiovasc Radiat Med. 2003;4(1):12-7. [pmid: 12892767].
Alexander D, Ou FS, Roe MT, et al. Use of and inhospital outcomes after early clopidogrel therapy in patients not undergoing an early invasive strategy for treatment of non-ST-segment elevation myocardial infarction: results from Can Rapid risk stratification of Unstable angina patients Suppress ADverse outcomes with Early implementation of the American College of Cardiology/American Heart Association guidelines (CRUSADE). Am Heart J. 2008;156(3):606-12. [pmid: 18760147].
Ambrosio G, Steinhubl S, Gresele P, et al. Impact of chronic antiplatelet therapy before hospitalization on ischemic and bleeding events in invasively managed patients with acute coronary syndromes: the ACUITY trial. Eur J Cardiovasc Prev Rehabil. 2011;18(1):121-8. [pmid: 20523219].
Angkasuwapala K, Ratanasumawong K, Ngarmukos T, et al. Effect of un-fractionated heparin and low molecular weight heparin on hospital mortality in patients with non ST elevation acute coronary syndrome (ACS). J Med Assoc Thai. Suppl 1. 2007;90:109-14. [pmid: 18431893].
Anonymous. Inhibition of platelet glycoprotein IIb/IIIa with eptifibatide in patients with acute coronary syndromes. The PURSUIT Trial Investigators. Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy. N Engl J Med. 1998;339(7):436-43. [pmid: 9705684].
Anonymous. Randomised placebo-controlled and balloon-angioplasty-controlled trial to assess safety of coronary stenting with use of platelet glycoprotein-IIb/IIIa blockade. Lancet. 1998;352(9122):87-92. [pmid: 9672272].
Anonymous. A comparison of aspirin plus tirofiban with aspirin plus heparin for unstable angina. Platelet Receptor Inhibition in Ischemic Syndrome Management (PRISM) Study Investigators. N Engl J Med. 1998;338(21):1498-505. [pmid: 9599104].
Anonymous. Inhibition of the platelet glycoprotein IIb/IIIa receptor with tirofiban in unstable angina and non-Q-wave myocardial infarction. Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) Study Investigators. N Engl J Med. 1998;338(21):1488-97. [pmid: 9599103].
Anonymous. Novel dosing regimen of eptifibatide in planned coronary stent implantation (ESPRIT): a randomised, placebo-controlled trial. The ESPRIT Investigators. Lancet. 2000;356(9247):2037-44. [pmid: 11145489].
Anonymous. The SYNERGY trial: study design and rationale. Am Heart J. 2002;143(6):952-60. [pmid: 12075248].
Antman EM. TIMI 11B. Enoxaparin versus unfractionated heparin for unstable angina or non-Q-wave myocardial infarction: a double-blind, placebo-controlled, parallel-group, multicenter trial. Rationale, study design, and methods. Thrombolysis in Myocardial Infarction (TIMI) 11B Trial Investigators. Am Heart J. 1998;135(6 Pt 3 Su):S353-60. [pmid: 9628449].
Antman EM, McCabe CH, Braunwald E. Bivalirudin as a replacement for unfractionated heparin in unstable angina/non-ST-elevation myocardial infarction: observations from the TIMI 8 trial. The Thrombolysis in Myocardial Infarction. Am Heart J. 2002;143(2):229-34. [pmid: 11835024].
Antman EM, McCabe CH, Gurfinkel EP, et al. Enoxaparin prevents death and cardiac ischemic events in unstable angina/non-Q-wave myocardial infarction. Results of the thrombolysis in myocardial infarction (TIMI) 11B trial. Circulation. 1999;100(15):1593-601. [pmid: 10517729].
Antman EM, Wiviott SD, Murphy SA, et al. Early and late benefits of prasugrel in patients with acute coronary syndromes undergoing percutaneous coronary intervention: a TRITON-TIMI 38 (TRial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet InhibitioN with Prasugrel-Thrombolysis In Myocardial Infarction) analysis. J Am Coll Cardiol. 2008;51(21):2028-33. [pmid: 18498956].
Aoki J, Lansky AJ, Mehran R, et al. Early stent thrombosis in patients with acute coronary syndromes treated with drug-eluting and bare metal stents: the Acute Catheterization and Urgent Intervention Triage Strategy trial. Circulation. 2009;119(5):687-98. [pmid: 19171852].
Aronow HD, Califf RM, Harrington RA, et al. Relation between aspirin dose, all-cause mortality, and bleeding in patients with recent cerebrovascular or coronary ischemic events (from the BRAVO Trial). Am J Cardiol. 2008;102(10):1285-90. [pmid: 18993142].
Aronow HD, Steinhubl SR, Brennan DM, et al. Bleeding risk associated with 1 year of dual antiplatelet therapy after percutaneous coronary intervention: Insights from the Clopidogrel for the Reduction of Events During Observation (CREDO) trial. Am Heart J. 2009;157(2):369-74. [pmid: 19185647].
Banerjee S, Weideman RA, Weideman MW, et al. Effect of concomitant use of clopidogrel and proton pump inhibitors after percutaneous coronary intervention. Am J Cardiol. 2011;107(6):871-8. [pmid: 21247527].
Barada K, Karrowni W, Abdallah M, et al. Upper gastrointestinal bleeding in patients with acute coronary syndromes: clinical predictors and prophylactic role of proton pump inhibitors. J Clin Gastroenterol. 2008;42(4):368-72. [pmid: 18277903].
Bauer T, Mollmann H, Weidinger F, et al. Use of platelet glycoprotein IIb/IIIa inhibitors in diabetics undergoing PCI for non-ST-segment elevation acute coronary syndromes: impact of clinical status and procedural characteristics. Clin Res Cardiol. 2010;99(6):375-83. [pmid: 20186546].
Becker RC, Bassand JP, Budaj A, et al. Bleeding complications with the P2Y12 receptor antagonists clopidogrel and ticagrelor in the PLATelet inhibition and patient Outcomes (PLATO) trial. Eur Heart J. 2011;32(23):2933-44. [pmid: 22090660].
Berger JS, Slater JN, Sherman W, et al. Impact of platelet glycoprotein IIb/IIIa inhibitor therapy on in-hospital outcomes and long-term survival following percutaneous coronary rotational atherectomy. J Thromb Thrombolysis. 2005;19(1):47-54. [pmid: 15976967].
Berger PB, Best PJ, Topol EJ, et al. The relation of renal function to ischemic and bleeding outcomes with 2 different glycoprotein IIb/IIIa inhibitors: the do Tirofiban and ReoPro Give Similar Efficacy Outcome (TARGET) trial. Am Heart J. 2005;149(5):869-75. [pmid: 15894970].
Berglund U, Richter A. Clopidogrel treatment before percutaneous coronary intervention reduces adverse cardiac events. J Invasive Cardiol. 2002;14(5):243-6. [pmid: 11983944].
Bernardi V, Szarfer J, Summay G, et al. Long-term versus short-term clopidogrel therapy in patients undergoing coronary stenting (from the Randomized Argentine Clopidogrel Stent [RACS] trial). Am J Cardiol. 2007;99(3):349-52. [pmid: 17261396].
Bertel O, Ramsay D, Wettstein T, et al. Intravenous enoxaparin versus unfractionated heparin in unselected patients undergoing percutaneous coronary interventions: the Zurich enoxaparin versus unfractionated heparin in PCI study (ZEUS). EuroIntervention. 2010;6(3):407-12. [pmid: 20884422].
Best PJ, Steinhubl SR, Berger PB, et al. The efficacy and safety of short- and long-term dual antiplatelet therapy in patients with mild or moderate chronic kidney disease: results from the Clopidogrel for the Reduction of Events During Observation (CREDO) trial. Am Heart J. 2008;155(4):687-93. [pmid: 18371477].
Bhatt DL, Cryer BL, Contant CF, et al. Clopidogrel with or without omeprazole in coronary artery disease. N Engl J Med. 2010;363(20):1909-17. [pmid: 20925534].
Bhatt DL, Lee BI, Casterella PJ, et al. Safety of concomitant therapy with eptifibatide and enoxaparin in patients undergoing percutaneous coronary intervention: results of the Coronary Revascularization Using Integrilin and Single bolus Enoxaparin Study. J Am Coll Cardiol. 2003;41(1):20-5. [pmid: 12570939].
Bhattacharya R, Pani A, Dutta D, et al. Randomised controlled trial evaluating the role of tirofiban in high-risk non-ST elevation acute coronary syndromes: an East Indian perspective. Singapore Med J. 2010;51(7):558-64. [pmid: 20730395].
Bhurke SM, Martin BC, Li C, et al. Effect of the Clopidogrel-Proton Pump Inhibitor Drug Interaction on Adverse Cardiovascular Events in Patients with Acute Coronary Syndrome. Pharmacotherapy. 2012. [pmid: 22744772].
Blazing MA, De Lemos JA, Dyke CK, et al. The A-to-Z Trial: Methods and rationale for a single trial investigating combined use of low-molecular-weight heparin with the glycoprotein IIb/IIIa inhibitor tirofiban and defining the efficacy of early aggressive simvastatin therapy. Am Heart J. 2001;142(2):211-7. [pmid: 11479456].
Blazing MA, de Lemos JA, White HD, et al. Safety and efficacy of enoxaparin vs unfractionated heparin in patients with non-ST-segment elevation acute coronary syndromes who receive tirofiban and aspirin: a randomized controlled trial. JAMA. 2004;292(1):55-64. [pmid: 15238591].
Bonde L, Sorensen R, Fosbol EL, et al. Increased mortality associated with low use of clopidogrel in patients with heart failure and acute myocardial infarction not undergoing percutaneous coronary intervention: a nationwide study. J Am Coll Cardiol. 2010;55(13):1300-7. [pmid: 20338489].
Bonello L, Lemesle G, De Labriolle A, et al. Impact of a 600-mg loading dose of clopidogrel on 30-day outcome in unselected patients undergoing percutaneous coronary intervention. Am J Cardiol. 2008;102(10):1318-22. [pmid: 18993148].
Brener SJ, Ellis SG, Schneider J, et al. Abciximab-facilitated percutaneous coronary intervention and long-term survival--a prospective single-center registry. Eur Heart J. 2003;24(7):630-8. [pmid: 12657221].
Brener SJ, Steinhubl SR, Berger PB, et al. Prolonged dual antiplatelet therapy after percutaneous coronary intervention reduces ischemic events without affecting the need for repeat revascularization: insights from the CREDO trial. J Invasive Cardiol. 2007;19(7):287-90. [pmid: 17620671].
Brieger D, Van de Werf F, Avezum A, et al. Interactions between heparins, glycoprotein IIb/IIIa antagonists, and coronary intervention. The Global Registry of Acute Coronary Events (GRACE). Am Heart J. 2007;153(6):960-9. [pmid: 17540196].
Brosa M, Rubio-Terres C, Farr I, et al. Cost-effectiveness analysis of enoxaparin versus unfractionated heparin in the secondary prevention of acute coronary syndrome. Pharmacoeconomics. 2002;20(14):979-87. [pmid: 12403638].
Brown R, Armstrong P. Cost effectiveness in Canada of eptifibatide treatment for acute coronary syndrome patients using PURSUIT subgroup analysis. Can J Cardiol. 2003;19(2):161-6. [pmid: 12601441].
Budaj A, Eikelboom JW, Mehta SR, et al. Improving clinical outcomes by reducing bleeding in patients with non-ST-elevation acute coronary syndromes. Eur Heart J. 2009;30(6):655-61. [pmid: 18713759].
Budaj A, Yusuf S, Mehta SR, et al. Benefit of clopidogrel in patients with acute coronary syndromes without ST-segment elevation in various risk groups. Circulation. 2002;106(13):1622-6. [pmid: 12270853].
Buresly K, Eisenberg MJ, Zhang X, et al. Bleeding complications associated with combinations of aspirin, thienopyridine derivatives, and warfarin in elderly patients following acute myocardial infarction. Arch Intern Med. 2005;165(7):784-9. [pmid: 15824298].
Burgess BC, Hanna-Moussa S, Ramasamy K, et al. Abciximab or eptifibatide in percutaneous coronary intervention: In-hospital outcomes and costs and six-month results. Int J Angiol. 2002;11(4):221-224.
Butler MJ, Eccleston D, Clark DJ, et al. The effect of intended duration of clopidogrel use on early and late mortality and major adverse cardiac events in patients with drug-eluting stents. Am Heart J. 2009;157(5):899-907. [pmid: 19376319].
Caixeta A, Dangas GD, Mehran R, et al. Incidence and clinical consequences of acquired thrombocytopenia after antithrombotic therapies in patients with acute coronary syndromes: results from the Acute Catheterization and Urgent Intervention Triage Strategy (ACUITY) trial. Am Heart J. 2011;161(2):298-306 e1. [pmid: 21315212].
Cannon CP, Harrington RA, James S, et al. Comparison of ticagrelor with clopidogrel in patients with a planned invasive strategy for acute coronary syndromes (PLATO): a randomised double-blind study. Lancet. 2010;375(9711):283-93. [pmid: 20079528].
Cannon CP, Husted S, Harrington RA, et al. Safety, tolerability, and initial efficacy of AZD6140, the first reversible oral adenosine diphosphate receptor antagonist, compared with clopidogrel, in patients with non-ST-segment elevation acute coronary syndrome: primary results of the DISPERSE-2 trial. J Am Coll Cardiol. 2007;50(19):1844-51. [pmid: 17980250].
Chan AW, Moliterno DJ, Berger PB, et al. Triple antiplatelet therapy during percutaneous coronary intervention is associated with improved outcomes including one-year survival: results from the Do Tirofiban and ReoProGive Similar Efficacy Outcome Trial (TARGET). J Am Coll Cardiol. 2003;42(7):1188-95. [pmid: 14522478].
Chang WC, Harrington RA, Simoons ML, et al. Does eptifibatide confer a greater benefit to patients with unstable angina than with non-ST segment elevation myocardial infarction? Insights from the PURSUIT Trial. Eur Heart J. 2002;23(14):1102-11. [pmid: 12090748].
Charlot M, Ahlehoff O, Norgaard ML, et al. Proton-pump inhibitors are associated with increased cardiovascular risk independent of clopidogrel use: a nationwide cohort study. Ann Intern Med. 2010;153(6):378-86. [pmid: 20855802].
Charlot M, Grove EL, Hansen PR, et al. Proton pump inhibitor use and risk of adverse cardiovascular events in aspirin treated patients with first time myocardial infarction: nationwide propensity score matched study. BMJ. 2011;342:d2690. [pmid: 21562004].
Charlot M, Nielsen LH, Lindhardsen J, et al. Clopidogrel discontinuation after myocardial infarction and risk of thrombosis: a nationwide cohort study. Eur Heart J. 2012. [pmid: 22798561].
Chen JL, Chen J, Qiao SB, et al. A randomized comparative study of using enoxaparin instead of unfractionated heparin in the intervention treatment of coronary heart disease. Chin Med J (Engl). 2006;119(5):355-9. [pmid: 16542576].
Cheng CI, Chen CP, Kuan PL, et al. The causes and outcomes of inadequate implementation of existing guidelines for antiplatelet treatment in patients with acute coronary syndrome: the experience from Taiwan Acute Coronary Syndrome Descriptive Registry (T-ACCORD Registry). Clin Cardiol. 2010;33(6):E40-8. [pmid: 20552592].
Chew DP, Huang Z, Pieper KS, et al. Patients with non-ST-elevation acute coronary syndromes undergoing coronary artery bypass grafting in the modern era of antithrombotic therapy. Am Heart J. 2008;155(2):239-44. [pmid: 18215592].
Chin CT, Roe MT, Fox KA, et al. Study design and rationale of a comparison of prasugrel and clopidogrel in medically managed patients with unstable angina/non-ST-segment elevation myocardial infarction: the TaRgeted platelet Inhibition to cLarify the Optimal strateGy to medicallY manage Acute Coronary Syndromes (TRILOGY ACS) trial. Am Heart J. 2010;160(1):16-22 e1. [pmid: 20598967].
Chitose T, Hokimoto S, Oshima S, et al. Clinical Outcomes Following Coronary Stenting in Japanese Patients Treated With and Without Proton Pump Inhibitor. Circ J. 2011. [pmid: 22130313].
Chu WW, Kuchulakanti PK, Wang B, et al. Bivalirudin versus unfractionated heparin in patients undergoing percutaneous coronary intervention after acute myocardial infarction. Cardiovasc Revasc Med. 2006;7(3):132-5. [pmid: 16945819].
Cohen M, Blaber R, Demers C, et al. The Essence Trial: Efficacy and Safety of Subcutaneous Enoxaparin in Unstable Angina and Non-Q-Wave MI: A Double-Blind, Randomized, Parallel-Group, Multicenter Study Comparing Enoxaparin and Intravenous Unfractionated Heparin: Methods and Design. J Thromb Thrombolysis. 1997;4(2):271-274. [pmid: 10639269].
Cohen M, Demers C, Gurfinkel EP, et al. A comparison of low-molecular-weight heparin with unfractionated heparin for unstable coronary artery disease. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q-Wave Coronary Events Study Group. N Engl J Med. 1997;337(7):447-52. [pmid: 9250846].
Cohen M, Demers C, Gurfinkel EP, et al. Low-molecular-weight heparins in non-ST-segment elevation ischemia: the ESSENCE trial. Efficacy and Safety of Subcutaneous Enoxaparin versus intravenous unfractionated heparin, in non-Q-wave Coronary Events. Am J Cardiol. 1998;82(5B):19L-24L. [pmid: 9737476].
Cohen M, Levine GN, Pieper KS, et al. Enoxaparin 0.3 mg/kg IV supplement for patients transitioning to PCI after subcutaneous enoxaparin therapy for NSTE ACS: a subgroup analysis from the SYNERGY trial. Catheter Cardiovasc Interv. 2010;75(6):928-35. [pmid: 20432399].
Cohen M, Mahaffey KW, Pieper K, et al. A subgroup analysis of the impact of prerandomization antithrombin therapy on outcomes in the SYNERGY trial: enoxaparin versus unfractionated heparin in non-ST-segment elevation acute coronary syndromes. J Am Coll Cardiol. 2006;48(7):1346-54. [pmid: 17010793].
Cohen M, Theroux P, Borzak S, et al. Randomized double-blind safety study of enoxaparin versus unfractionated heparin in patients with non-ST-segment elevation acute coronary syndromes treated with tirofiban and aspirin: the ACUTE II study. The Antithrombotic Combination Using Tirofiban and Enoxaparin. Am Heart J. 2002;144(3):470-7. [pmid: 12228784].
Cortese B, Micheli A, Picchi A, et al. Safety and efficacy of a prolonged bivalirudin infusion after urgent and complex percutaneous coronary interventions: a descriptive study. Coron Artery Dis. 2009;20(5):348-53. [pmid: 19543084].
Cuisset T, Frere C, Quilici J, et al. Benefit of a 600-mg loading dose of clopidogrel on platelet reactivity and clinical outcomes in patients with non-ST-segment elevation acute coronary syndrome undergoing coronary stenting. J Am Coll Cardiol. 2006;48(7):1339-45. [pmid: 17010792].
Dabbous OH, Anderson FA Jr., Gore JM, et al. Outcomes with the use of glycoprotein IIb/IIIa inhibitors in non-ST-segment elevation acute coronary syndromes. Heart. 2008;94(2):159-65. [pmid: 17575335].
Danzi GB, Sesana M, Capuano C, et al. Downstream administration of a high-dose tirofiban bolus in high-risk patients with unstable angina undergoing early percutaneous coronary intervention. Int J Cardiol. 2006;107(2):241-6. [pmid: 16412804].
Davlouros PA, Arseniou A, Hahalis G, et al. Timing of clopidogrel loading before percutaneous coronary intervention in clopidogrel-naive patients with stable or unstable angina: a comparison of two strategies. Am Heart J. 2009;158(4):585-91. [pmid: 19781418].
de Lemos JA, Blazing MA, Wiviott SD, et al. Enoxaparin versus unfractionated heparin in patients treated with tirofiban, aspirin and an early conservative initial management strategy: results from the A phase of the A-to-Z trial. Eur Heart J. 2004;25(19):1688-94. [pmid: 15451146].
De Servi S, Mariani M, Vandoni P, et al. Use of glycoprotein IIb/IIIa inhibitors in invasively-treated patients with non-ST elevation acute coronary syndrome. J Cardiovasc Med (Hagerstown). 2006;7(3):159-65. [pmid: 16645379].
Di Sciascio G, Patti G, Pasceri V, et al. Clopidogrel reloading in patients undergoing percutaneous coronary intervention on chronic clopidogrel therapy: results of the ARMYDA-4 RELOAD (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) randomized trial. Eur Heart J. 2010;31(11):1337-43. [pmid: 20363764].
Di Sciascio G, Patti G, Pasceri V, et al. Effectiveness of in-laboratory high-dose clopidogrel loading versus routine pre-load in patients undergoing percutaneous coronary intervention: results of the ARMYDA-5 PRELOAD (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) randomized trial. J Am Coll Cardiol. 2010;56(7):550-7. [pmid: 20688209].
Durand E, Hamm CW, Macaya CM, et al. A randomised controlled trial of upstream administration of eptifibatide in patients presenting non-ST segment elevation acute coronary syndrome treated with an invasive strategy. EuroIntervention. 2007;3(2):228-34. [pmid: 19758942].
Evanchan J, Donnally MR, Binkley P, et al. Recurrence of acute myocardial infarction in patients discharged on clopidogrel and a proton pump inhibitor after stent placement for acute myocardial infarction. Clin Cardiol. 2010;33(3):168-71. [pmid: 20235209].
Feit F, Manoukian SV, Ebrahimi R, et al. Safety and efficacy of bivalirudin monotherapy in patients with diabetes mellitus and acute coronary syndromes: a report from the ACUITY (Acute Catheterization and Urgent Intervention Triage Strategy) trial. J Am Coll Cardiol. 2008;51(17):1645-52. [pmid: 18436116].
Ferguson JJ. Antithrombin therapy, antiplatelet therapy and percutaneous coronary intervention: Rationale and design of the SYNERGY trial. European Heart Journal, Supplement. 2002;4(5):E2-E9.
Ferguson JJ, Califf RM, Antman EM, et al. Enoxaparin vs unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndromes managed with an intended early invasive strategy: primary results of the SYNERGY randomized trial. JAMA. 2004;292(1):45-54. [pmid: 15238590].
Fitchett DH, Langer A, Armstrong PW, et al. Randomized evaluation of the efficacy of enoxaparin versus unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndromes receiving the glycoprotein IIb/IIIa inhibitor eptifibatide. Long-term results of the Integrilin and Enoxaparin Randomized Assessment of Acute Coronary Syndrome Treatment (INTERACT) trial. Am Heart J. 2006;151(2):373-9. [pmid: 16442903].
Fosbol EL, Wang TY, Li S, et al. Safety and effectiveness of antithrombotic strategies in older adult patients with atrial fibrillation and non-ST elevation myocardial infarction. Am Heart J. 2012;163(4):720-8. [pmid: 22520540].
Fox KA, Antman EM, Cohen M, et al. Comparison of enoxaparin versus unfractionated heparin in patients with unstable angina pectoris/non-ST-segment elevation acute myocardial infarction having subsequent percutaneous coronary intervention. Am J Cardiol. 2002;90(5):477-82. [pmid: 12208405].
Fox KA, Bassand JP, Mehta SR, et al. Influence of renal function on the efficacy and safety of fondaparinux relative to enoxaparin in non ST-segment elevation acute coronary syndromes. Ann Intern Med. 2007;147(5):304-10. [pmid: 17785485].
Fox KA, Mehta SR, Peters R, et al. Benefits and risks of the combination of clopidogrel and aspirin in patients undergoing surgical revascularization for non-ST-elevation acute coronary syndrome: the Clopidogrel in Unstable angina to prevent Recurrent ischemic Events (CURE) Trial. Circulation. 2004;110(10):1202-8. [pmid: 15313956].
Fung AY, Saw J, Starovoytov A, et al. Abbreviated infusion of eptifibatide after successful coronary intervention The BRIEF-PCI (Brief Infusion of Eptifibatide Following Percutaneous Coronary Intervention) randomized trial. J Am Coll Cardiol. 2009;53(10):837-45. [pmid: 19264239].
Galassi AR, Russo G, Nicosia A, et al. Usefulness of platelet glycoprotein IIb/IIIa inhibitors in coronary stenting for reconstruction of complex lesions: procedural and 30 day outcome. Cardiologia. 1999;44(7):639-45. [pmid: 10476589].
Galasso G, Piscione F, Furbatto F, et al. Abciximab in elderly with acute coronary syndrome invasively treated: effect on outcome. Int J Cardiol. 2008;130(3):380-5. [pmid: 18590933].
Gao QP, Sun Y, Sun YX, et al. Early use of omeprazole benefits patients with acute myocardial infarction. J Thromb Thrombolysis. 2009;28(3):282-7. [pmid: 18830566].
Gaspar A, Ribeiro S, Nabais S, et al. Proton pump inhibitors in patients treated with aspirin and clopidogrel after acute coronary syndrome. Rev Port Cardiol. 2010;29(10):1511-20. [pmid: 21265493].
Gibson CM, Morrow DA, Murphy SA, et al. A randomized trial to evaluate the relative protection against post-percutaneous coronary intervention microvascular dysfunction, ischemia, and inflammation among antiplatelet and antithrombotic agents: the PROTECT-TIMI-30 trial. J Am Coll Cardiol. 2006;47(12):2364-73. [pmid: 16781360].
Giugliano RP, Newby LK, Harrington RA, et al. The early glycoprotein IIb/IIIa inhibition in non-ST-segment elevation acute coronary syndrome (EARLY ACS) trial: a randomized placebo-controlled trial evaluating the clinical benefits of early front-loaded eptifibatide in the treatment of patients with non-ST-segment elevation acute coronary syndrome--study design and rationale. Am Heart J. 2005;149(6):994-1002. [pmid: 15976780].
Giugliano RP, White JA, Bode C, et al. Early versus delayed, provisional eptifibatide in acute coronary syndromes. N Engl J Med. 2009;360(21):2176-90. [pmid: 19332455].
Goodman S. Enoxaparin and glycoprotein IIb/IIIa inhibition in non-ST-elevation acute coronary syndrome: insights from the INTERACT trial. Am Heart J. 2005;149(4 Suppl):S73-80. [pmid: 16124951].
Goodman SG, Bozovich GE, Tan M, et al. The greatest benefit of enoxaparin over unfractionated heparin in acute coronary syndromes is achieved in patients presenting with ST-segment changes: the Enoxaparin in Non-Q-Wave Coronary Events (ESSENCE) Electrocardiogram Core Laboratory Substudy. Am Heart J. 2006;151(4):791-7. [pmid: 16569535].
Goodman SG, Clare R, Pieper KS, et al. Association of Proton Pump Inhibitor Use on Cardiovascular Outcomes with Clopidogrel and Ticagrelor: Insights from PLATO. Circulation. 2012. [pmid: 22261200].
Goodman SG, Cohen M, Bigonzi F, et al. Randomized trial of low molecular weight heparin (enoxaparin) versus unfractionated heparin for unstable coronary artery disease: one-year results of the ESSENCE Study. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q Wave Coronary Events. J Am Coll Cardiol. 2000;36(3):693-8. [pmid: 10987586].
Goodman SG, Fitchett D, Armstrong PW, et al. Randomized evaluation of the safety and efficacy of enoxaparin versus unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndromes receiving the glycoprotein IIb/IIIa inhibitor eptifibatide. Circulation. 2003;107(2):238-44. [pmid: 12538422].
Gore JM, Spencer FA, Goldberg RJ, et al. Use of heparins in Non-ST-elevation acute coronary syndromes. Am J Med. 2007;120(1):63-71. [pmid: 17208081].
Goto K, Lansky AJ, Fahy M, et al. Predictors of outcomes in medically treated patients with acute coronary syndromes after angiographic triage: an Acute Catheterization And Urgent Intervention Triage Strategy (ACUITY) substudy. Circulation. 2010;121(7):853-62. [pmid: 20142447].
Gowda MS, Vacek JL, Lakkireddy DJ, et al. Differential benefits and outcomes of tirofiban vs abciximab for acute coronary syndromes in current clinical practice. Angiology. 2003;54(2):211-8. [pmid: 12678197].
Gunasekara AP, Walters DL, Aroney CN. Comparison of abciximab with “high-dose” tirofiban in patients undergoing percutaneous coronary intervention. Int J Cardiol. 2006;109(1):16-20. [pmid: 16014315].
Gupta E, Bansal D, Sotos J, et al. Risk of adverse clinical outcomes with concomitant use of clopidogrel and proton pump inhibitors following percutaneous coronary intervention. Dig Dis Sci. 2010;55(7):1964-8. [pmid: 19731021].
Gwon HC, Hahn JY, Park KW, et al. Six-month versus 12-month dual antiplatelet therapy after implantation of drug-eluting stents: the Efficacy of Xience/Promus Versus Cypher to Reduce Late Loss After Stenting (EXCELLENT) randomized, multicenter study. Circulation. 2012;125(3):505-13. [pmid: 22179532].
Harjai KJ, Shenoy C, Orshaw P, et al. Dual antiplatelet therapy for more than 12 months after percutaneous coronary intervention: insights from the Guthrie PCI Registry. Heart. 2009;95(19):1579-86. [pmid: 19549619].
Harjai KJ, Shenoy C, Orshaw P, et al. Clinical outcomes in patients with the concomitant use of clopidogrel and proton pump inhibitors after percutaneous coronary intervention: an analysis from the Guthrie Health Off-Label Stent (GHOST) investigators. Circ Cardiovasc Interv. 2011;4(2):162-70. [pmid: 21386091].
Harjai KJ, Shenoy C, Orshaw P, et al. Low-dose versus high-dose aspirin after percutaneous coronary intervention: analysis from the guthrie health off-label StenT (GHOST) registry. J Interv Cardiol. 2011;24(4):307-14. [pmid: 21790788].
Harrington RA. Design and methodology of the PURSUIT trial: evaluating eptifibatide for acute ischemic coronary syndromes. Platelet Glycoprotein IIb-IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy. Am J Cardiol. 1997;80(4A):34B-38B. [pmid: 9291244].
Hasdai D, Holmes DR Jr., Criger DA, et al. Age and outcome after acute coronary syndromes without persistent ST-segment elevation. Am Heart J. 2000;139(5):858-66. [pmid: 10783220].
Held C, Asenblad N, Bassand JP, et al. Ticagrelor versus clopidogrel in patients with acute coronary syndromes undergoing coronary artery bypass surgery: results from the PLATO (Platelet Inhibition and Patient Outcomes) trial. J Am Coll Cardiol. 2011;57(6):672-84. [pmid: 21194870].
Ho PM, Fihn SD, Wang L, et al. Clopidogrel and long-term outcomes after stent implantation for acute coronary syndrome. Am Heart J. 2007;154(5):846-51. [pmid: 17967588].
Ho PM, Maddox TM, Wang L, et al. Risk of adverse outcomes associated with concomitant use of clopidogrel and proton pump inhibitors following acute coronary syndrome. JAMA. 2009;301(9):937-44. [pmid: 19258584].
Hsiao FY, Mullins CD, Wen YW, et al. Relationship between cardiovascular outcomes and proton pump inhibitor use in patients receiving dual antiplatelet therapy after acute coronary syndrome. Pharmacoepidemiol Drug Saf. 2011;20(10):1043-9. [pmid: 21823195].
Husted S, James S, Becker RC, et al. Ticagrelor versus clopidogrel in elderly patients with acute coronary syndromes: a substudy from the Prospective Randomized PLATelet Inhibition and Patient Outcomes (PLATO) trial. Circ Cardiovasc Qual Outcomes. 2012;5(5):680-8. [pmid: 22991347].
Huynh T, Piazza N, DiBattiste PM, et al. Analysis of bleeding complications associated with glycoprotein IIb/IIIa receptors blockade in patients with high-risk acute coronary syndromes: insights from the PRISM-PLUS study. Int J Cardiol. 2005;100(1):73-8. [pmid: 15820288].
Huynh T, Theroux P, Snapinn S, et al. Effect of platelet glycoprotein IIb/IIIa receptor blockade with tirofiban on adverse cardiac events in women with unstable angina/non-ST-elevation myocardial infarction (PRISM-PLUS Study). Am Heart J. 2003;146(4):668-73. [pmid: 14564321].
Iijima R, Ndrepepa G, Mehilli J, et al. Profile of bleeding and ischaemic complications with bivalirudin and unfractionated heparin after percutaneous coronary intervention. Eur Heart J. 2009;30(3):290-6. [pmid: 19147609].
Iijima R, Ndrepepa G, Mehilli J, et al. Effect of abciximab on clinical and angiographic restenosis in patients with non-ST-segment elevation acute coronary syndromes. Am J Cardiol. 2008;101(9):1226-31. [pmid: 18435948].
Iijima R, Ndrepepa G, Mehilli J, et al. Troponin level and efficacy of abciximab in patients with acute coronary syndromes undergoing early intervention after clopidogrel pretreatment. Clin Res Cardiol. 2008;97(3):160-8. [pmid: 18046527].
Islam MA, Blankenship JC, Balog C, et al. Effect of abciximab on angiographic complications during percutaneous coronary stenting in the Evaluation of Platelet IIb/IIIa Inhibition in Stenting Trial (EPISTENT). Am J Cardiol. 2002;90(9):916-21. [pmid: 12398954].
Ivandic BT, Kurz K, Keck F, et al. Tirofiban optimizes platelet inhibition for immediate percutaneous coronary intervention in high-risk acute coronary syndromes. Thromb Haemost. 2008;100(4):648-54. [pmid: 18841288].
Iversen AZ, Galatius S, Pedersen S, et al. Impact of abciximab in elderly patients with high-risk acute coronary syndrome undergoing percutaneous coronary intervention: an observational registry study. Drugs Aging. 2011;28(5):369-78. [pmid: 21542659].
Iversen AZ, Pedersen SH, Joens C, et al. Impact of abciximab in diabetic patients with acute coronary syndrome who undergo percutaneous coronary intervention: results from a high-volume, single-center registry. J Invasive Cardiol. 2011;23(1):21-6. [pmid: 21183766].
James S, Akerblom A, Cannon CP, et al. Comparison of ticagrelor, the first reversible oral P2Y(12) receptor antagonist, with clopidogrel in patients with acute coronary syndromes: Rationale, design, and baseline characteristics of the PLATelet inhibition and patient Outcomes (PLATO) trial. Am Heart J. 2009;157(4):599-605. [pmid: 19332184].
James S, Angiolillo DJ, Cornel JH, et al. Ticagrelor vs. clopidogrel in patients with acute coronary syndromes and diabetes: a substudy from the PLATelet inhibition and patient Outcomes (PLATO) trial. Eur Heart J. 2010;31(24):3006-16. [pmid: 20802246].
James S, Budaj A, Aylward P, et al. Ticagrelor versus clopidogrel in acute coronary syndromes in relation to renal function: results from the Platelet Inhibition and Patient Outcomes (PLATO) trial. Circulation. 2010;122(11):1056-67. [pmid: 20805430].
James SK, Roe MT, Cannon CP, et al. Ticagrelor versus clopidogrel in patients with acute coronary syndromes intended for non-invasive management: substudy from prospective randomised PLATelet inhibition and patient Outcomes (PLATO) trial. BMJ. 2011;342:d3527. [pmid: 21685437].
Jang SW, Rho TH, Kim DB, et al. Optimal antithrombotic strategy in patients with atrial fibrillation after coronary stent implantation. Korean Circ J. 2011;41(10):578-582. [pmid: 22125556].
Januzzi JL, Chae CU, Sabatine MS, et al. Elevation in serum troponin I predicts the benefit of tirofiban. J Thromb Thrombolysis. 2001;11(3):211-5. [pmid: 11577259].
Januzzi JL, Hahn SS, Chae CU, et al. Effects of tirofiban plus heparin versus heparin alone on troponin I levels in patients with acute coronary syndromes. Am J Cardiol. 2000;86(7):713-7. [pmid: 11018188].
Januzzi JL Jr., Snapinn SM, DiBattiste PM, et al. Benefits and safety of tirofiban among acute coronary syndrome patients with mild to moderate renal insufficiency: results from the Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) trial. Circulation. 2002;105(20):2361-6. [pmid: 12021221].
Jolly SS, Faxon DP, Fox KA, et al. Efficacy and safety of fondaparinux versus enoxaparin in patients with acute coronary syndromes treated with glycoprotein IIb/IIIa inhibitors or thienopyridines: results from the OASIS 5 (Fifth Organization to Assess Strategies in Ischemic Syndromes) trial. J Am Coll Cardiol. 2009;54(5):468-76. [pmid: 19628124].
Jolly SS, Pogue J, Haladyn K, et al. Effects of aspirin dose on ischaemic events and bleeding after percutaneous coronary intervention: insights from the PCI-CURE study. Eur Heart J. 2009;30(8):900-7. [pmid: 18819961].
Joyner CD, Peters RJ, Afzal R, et al. Fondaparinux compared to enoxaparin in patients with acute coronary syndromes without ST-segment elevation: outcomes and treatment effect across different levels of risk. Am Heart J. 2009;157(3):502-8. [pmid: 19249421].
Juurlink DN, Gomes T, Ko DT, et al. A population-based study of the drug interaction between proton pump inhibitors and clopidogrel. CMAJ. 2009;180(7):713-8. [pmid: 19176635].
Karha J, Gurm HS, Rajagopal V, et al. Use of platelet glycoprotein IIb/IIIa inhibitors in saphenous vein graft percutaneous coronary intervention and clinical outcomes. Am J Cardiol. 2006;98(7):906-10. [pmid: 16996871].
Karjalainen PP, Porela P, Ylitalo A, et al. Safety and efficacy of combined antiplatelet-warfarin therapy after coronary stenting. Eur Heart J. 2007;28(6):726-32. [pmid: 17267456].
Kastrati A, Mehilli J, Neumann FJ, et al. Abciximab in patients with acute coronary syndromes undergoing percutaneous coronary intervention after clopidogrel pretreatment: the ISAR-REACT 2 randomized trial. JAMA. 2006;295(13):1531-8. [pmid: 16533938].
Kastrati A, Neumann FJ, Mehilli J, et al. Bivalirudin versus unfractionated heparin during percutaneous coronary intervention. N Engl J Med. 2008;359(7):688-96. [pmid: 18703471].
Kastrati A, Neumann FJ, Schulz S, et al. Abciximab and heparin versus bivalirudin for non-ST-elevation myocardial infarction. N Engl J Med. 2011;365(21):1980-9. [pmid: 22077909].
Keltai M, Tonelli M, Mann JF, et al. Renal function and outcomes in acute coronary syndrome: impact of clopidogrel. Eur J Cardiovasc Prev Rehabil. 2007;14(2):312-8. [pmid: 17446813].
Kim JH, Jeong MH, Rhew JY, et al. Long-term clinical outcomes of platelet glycoprotein IIb/IIIa inhibitor combined with low molecular weight heparin in patients with acute coronary syndrome. Circ J. 2005;69(2):159-64. [pmid: 15671606].
Kirtane AJ, Parise H, Mehran R, et al. Comparison of catheterization laboratory initiated abciximab and eptifibatide during percutaneous coronary intervention in acute coronary syndromes (an ACUITY substudy). Am J Cardiol. 2010;106(2):180-6. [pmid: 20599000].
Kleiman NS, Lincoff AM, Flaker GC, et al. Early percutaneous coronary intervention, platelet inhibition with eptifibatide, and clinical outcomes in patients with acute coronary syndromes. PURSUIT Investigators. Circulation. 2000;101(7):751-7. [pmid: 10683348].
Konstantino Y, Iakobishvili Z, Porter A, et al. Aspirin, warfarin and a thienopyridine for acute coronary syndromes. Cardiology. 2006;105(2):80-5. [pmid: 16286733].
Korovesis S, Karvouni E, Karabinos I, et al. Comparison of enoxaparin and unfractionated heparin in coronary angioplasty. Hellenic J Cardiol. 2005;46(1):46-51. [pmid: 15807395].
Kovar D, Canto JG, Rogers WJ. Safety and effectiveness of combined low molecular weight heparin and glycoprotein IIb/IIIa inhibitors. Am J Cardiol. 2002;90(9):911-5. [pmid: 12398953].
Kreutz RP, Stanek EJ, Aubert R, et al. Impact of proton pump inhibitors on the effectiveness of clopidogrel after coronary stent placement: the clopidogrel Medco outcomes study. Pharmacotherapy. 2010;30(8):787-96. [pmid: 20653354].
Kumar D, Dangas G, Mehran R, et al. Comparison of Bivalirudin versus Bivalirudin plus glycoprotein IIb/IIIa inhibitor versus heparin plus glycoprotein IIb/IIIa inhibitor in patients with acute coronary syndromes having percutaneous intervention for narrowed saphenous vein aorto-coronary grafts (the ACUITY trial investigators). Am J Cardiol. 2010;106(7):941-5. [pmid: 20854954].
Labinaz M, Kaul P, Harrington RA, et al. Six-month outcomes of percutaneous coronary balloon angioplasty in acute coronary syndromes: Results from the PURSUIT trial. Can J Cardiol. 2004;20(8):773-8. [pmid: 15229770].
Labinaz M, Madan M, O'Shea JO, et al. Comparison of one-year outcomes following coronary artery stenting in diabetic versus nondiabetic patients (from the Enhanced Suppression of the Platelet IIb/IIIa Receptor With Integrilin Therapy [ESPRIT] Trial). Am J Cardiol. 2002;90(6):585-90. [pmid: 12231081].
Lahtela H, Karjalainen PP, Niemela M, et al. Are glycoprotein inhibitors safe during percutaneous coronary intervention in patients on chronic warfarin treatment?. Thromb Haemost. 2009;102(6):1227-33. [pmid: 19967155].
Lamberts M, Gislason GH, Olesen JB, et al. Oral anticoagulation and antiplatelets in atrial fibrillation patients after myocardial infarction and coronary intervention. J Am Coll Cardiol. 2013;62(11):981-9. [pmid: 23747760].
Lansky AJ, Mehran R, Cristea E, et al. Impact of gender and antithrombin strategy on early and late clinical outcomes in patients with non-ST-elevation acute coronary syndromes (from the ACUITY trial). Am J Cardiol. 2009;103(9):1196-203. [pmid: 19406258].
LaPointe NM, Chen AY, Alexander KP, et al. Enoxaparin dosing and associated risk of in-hospital bleeding and death in patients with non ST-segment elevation acute coronary syndromes. Arch Intern Med. 2007;167(14):1539-44. [pmid: 17646609].
Lemesle G, Bonello L, De Labriolle A, et al. Impact of bivalirudin use on outcomes in nonagenarians undergoing percutaneous coronary intervention. J Interv Cardiol. 2009;22(1):61-7. [pmid: 19281522].
Lemesle G, De Labriolle A, Bonello L, et al. Impact of bivalirudin on in-hospital bleeding and six-month outcomes in octogenarians undergoing percutaneous coronary intervention. Catheter Cardiovasc Interv. 2009;74(3):428-35. [pmid: 19360860].
Lenderink T, Boersma E, Ruzyllo W, et al. Bleeding events with abciximab in acute coronary syndromes without early revascularization: An analysis of GUSTO IV-ACS. Am Heart J. 2004;147(5):865-73. [pmid: 15131544].
Leoncini M, Toso A, Maioli M, et al. Effects of tirofiban plus clopidogrel versus clopidogrel plus provisional abciximab on biomarkers of myocardial necrosis in patients with non-ST-elevation acute coronary syndromes treated with early aggressive approach. Results of the CLOpidogrel, upstream TIrofiban, in cath Lab Downstream Abciximab (CLOTILDA) study. Am Heart J. 2005;150(3):401. [pmid: 16169315].
Lewis BS, Mehta SR, Fox KA, et al. Benefit of clopidogrel according to timing of percutaneous coronary intervention in patients with acute coronary syndromes: further results from the Clopidogrel in Unstable angina to prevent Recurrent Events (CURE) study. Am Heart J. 2005;150(6):1177-84. [pmid: 16338255].
Li YJ, Rha SW, Chen KY, et al. Low molecular weight heparin versus unfractionated heparin in patients with acute non-ST-segment elevation myocardial infarction undergoing percutaneous coronary intervention with drug-eluting stents. J Cardiol. 2012;(59):22-29. [pmid: 22079855].
Lim MJ, Spencer FA, Gore JM, et al. Impact of combined pharmacologic treatment with clopidogrel and a statin on outcomes of patients with non-ST-segment elevation acute coronary syndromes: perspectives from a large multinational registry. Eur Heart J. 2005;26(11):1063-9. [pmid: 15716281].
Lin YL, Chen LL, Luo YK, et al. Benefit of standard versus low-dose tirofiban for percutaneous coronary intervention in very elderly patients with high-risk acute coronary syndrome. Acta Pharmacol Sin. 2009;30(5):553-8. [pmid: 19417734].
Lincoff AM, Harrington RA, Califf RM, et al. Management of patients with acute coronary syndromes in the United States by platelet glycoprotein IIb/IIIa inhibition. Insights from the platelet glycoprotein IIb/IIIa in unstable angina: receptor suppression using integrilin therapy (PURSUIT) trial. Circulation. 2000;102(10):1093-100. [pmid: 10973836].
Lincoff AM, Steinhubl SR, Manoukian SV, et al. Influence of timing of clopidogrel treatment on the efficacy and safety of bivalirudin in patients with non-ST-segment elevation acute coronary syndromes undergoing percutaneous coronary intervention: an analysis of the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. JACC Cardiovasc Interv. 2008;1(6):639-48. [pmid: 19463378].
Liu T, Xie Y, Zhou YJ, et al. Effects of upstream tirofiban versus downstream tirofiban on myocardial damage and 180-day clinical outcomes in high-risk acute coronary syndromes patients undergoing percutaneous coronary interventions. Chin Med J (Engl). 2009;122(15):1732-7. [pmid: 19781316].
Lopes RD, Alexander KP, Manoukian SV, et al. Advanced age, antithrombotic strategy, and bleeding in non-ST-segment elevation acute coronary syndromes: results from the ACUITY (Acute Catheterization and Urgent Intervention Triage Strategy) trial. J Am Coll Cardiol. 2009;53(12):1021-30. [pmid: 19298914].
Lopes RD, Alexander KP, Marcucci G, et al. Outcomes in elderly patients with acute coronary syndromes randomized to enoxaparin vs. unfractionated heparin: results from the SYNERGY trial. Eur Heart J. 2008;29(15):1827-33. [pmid: 18519426].
Lopes RD, Starr A, Pieper CF, et al. Warfarin use and outcomes in patients with atrial fibrillation complicating acute coronary syndromes. Am J Med. 2010;123(2):134-40. [pmid: 20103022].
Maegdefessel L, Schlitt A, Faerber J, et al. Anticoagulant and/or antiplatelet treatment in patients with atrial fibrillation after percutaneous coronary intervention. A single-center experience. Med Klin (Munich). 2008;103(9):628-32. [pmid: 18813885].
Mahaffey KW, Wojdyla DM, Carroll K, et al. Ticagrelor compared with clopidogrel by geographic region in the Platelet Inhibition and Patient Outcomes (PLATO) trial. Circulation. 2011;124(5):544-54. [pmid: 21709065].
Malhotra S, Bhargava VK, Grover A, et al. A randomized trial to compare the efficacy, safety, cost and platelet aggregation effects of enoxaparin and unfractionated heparin (the ESCAPEU trial). Int J Clin Pharmacol Ther. 2001;39(3):110-5. [pmid: 11396750].
Manoukian SV, Feit F, Mehran R, et al. Impact of major bleeding on 30-day mortality and clinical outcomes in patients with acute coronary syndromes: an analysis from the ACUITY Trial. J Am Coll Cardiol. 2007;49(12):1362-8. [pmid: 17394970].
Mark DB, Cowper PA, Berkowitz SD, et al. Economic assessment of low-molecular-weight heparin (enoxaparin) versus unfractionated heparin in acute coronary syndrome patients: results from the ESSENCE randomized trial. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q wave Coronary Events [unstable angina or non-Q-wave myocardial infarction]. Circulation. 1998;97(17):1702-7. [pmid: 9591764].
Mehilli J, Ndrepepa G, Kastrati A, et al. Sex and effect of abciximab in patients with acute coronary syndromes treated with percutaneous coronary interventions: results from Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment 2 trial. Am Heart J. 2007;154(1):158 e1-7. [pmid: 17584569].
Mehran R, Nikolsky E, Lansky AJ, et al. Impact of chronic kidney disease on early (30-day) and late (1-year) outcomes of patients with acute coronary syndromes treated with alternative antithrombotic treatment strategies: an ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) substudy. JACC Cardiovasc Interv. 2009;2(8):748-57. [pmid: 19695543].
Mehta SR, Bassand JP, Chrolavicius S, et al. Dose comparisons of clopidogrel and aspirin in acute coronary syndromes. N Engl J Med. 2010;363(10):930-42. [pmid: 20818903].
Mehta SR, Bassand JP, Chrolavicius S, et al. Design and rationale of CURRENT-OASIS 7: a randomized, 2 × 2 factorial trial evaluating optimal dosing strategies for clopidogrel and aspirin in patients with ST and non-ST-elevation acute coronary syndromes managed with an early invasive strategy. Am Heart J. 2008;156(6):1080-1088 e1. [pmid: 19033002].
Mehta SR, Boden WE, Eikelboom JW, et al. Antithrombotic therapy with fondaparinux in relation to interventional management strategy in patients with ST- and non-ST-segment elevation acute coronary syndromes: an individual patient-level combined analysis of the Fifth and Sixth Organization to Assess Strategies in Ischemic Syndromes (OASIS 5 and 6) randomized trials. Circulation. 2008;118(20):2038-46. [pmid: 18955665].
Mehta SR, Granger CB, Eikelboom JW, et al. Efficacy and safety of fondaparinux versus enoxaparin in patients with acute coronary syndromes undergoing percutaneous coronary intervention: results from the OASIS-5 trial. J Am Coll Cardiol. 2007;50(18):1742-51. [pmid: 17964037].
Mehta SR, Steg PG, Granger CB, et al. Randomized, blinded trial comparing fondaparinux with unfractionated heparin in patients undergoing contemporary percutaneous coronary intervention: Arixtra Study in Percutaneous Coronary Intervention: a Randomized Evaluation (ASPIRE) Pilot Trial. Circulation. 2005;111(11):1390-7. [pmid: 15781750].
Mehta SR, Tanguay JF, Eikelboom JW, et al. Double-dose versus standard-dose clopidogrel and high-dose versus low-dose aspirin in individuals undergoing percutaneous coronary intervention for acute coronary syndromes (CURRENT-OASIS 7): a randomised factorial trial. Lancet. 2010;376(9748):1233-43. [pmid: 20817281].
Mehta SR, Yusuf S, Granger CB, et al. Design and rationale of the MICHELANGELO Organization to Assess Strategies in Acute Ischemic Syndromes (OASIS)-5 trial program evaluating fondaparinux, a synthetic factor Xa inhibitor, in patients with non-ST-segment elevation acute coronary syndromes. Am Heart J. 2005;150(6):1107. [pmid: 16338245].
Mehta SR, Yusuf S, Peters RJ, et al. Effects of pretreatment with clopidogrel and aspirin followed by long-term therapy in patients undergoing percutaneous coronary intervention: the PCI-CURE study. Lancet. 2001;358(9281):527-33. [pmid: 11520521].
Melloni C, James SK, White JA, et al. Safety and efficacy of adjusted-dose eptifibatide in patients with acute coronary syndromes and reduced renal function. Am Heart J. 2011;162(5):884-892 e1. [pmid: 22093205].
Merlini PA, Rossi M, Menozzi A, et al. Thrombocytopenia caused by abciximab or tirofiban and its association with clinical outcome in patients undergoing coronary stenting. Circulation. 2004;109(18):2203-6. [pmid: 15117843].
Miller CD, Blomkalns AL, Gersh BJ, et al. Safety and efficacy of bivalirudin in high-risk patients admitted through the emergency department. Acad Emerg Med. 2009;16(8):717-25. [pmid: 19673711].
Moliterno DJ. A randomized two-by-two comparison of high-dose bolus tirofiban versus abciximab and unfractionated heparin versus bivalirudin during percutaneous coronary revascularization and stent placement: the tirofiban evaluation of novel dosing versus abciximab with clopidogrel and inhibition of thrombin (TENACITY) study trial. Catheter Cardiovasc Interv. 2011;77(7):1001-9. [pmid: 21598351].
Moliterno DJ, Topol EJ. A direct comparison of tirofiban and abciximab during percutaneous coronary revascularization and stent placement: rationale and design of the TARGET study. Am Heart J. 2000;140(5):722-6. [pmid: 11054616].
Moliterno DJ, Yakubov SJ, DiBattiste PM, et al. Outcomes at 6 months for the direct comparison of tirofiban and abciximab during percutaneous coronary revascularisation with stent placement: the TARGET follow-up study. Lancet. 2002;360(9330):355-60. [pmid: 12241774].
Momtahen M, Abdi S, Javadzadeh F, et al. Platelet GP IIb/IIIa receptor inhibition by Eptifibatide in non ST-elevation MI-acute coronary syndrome. Iran Cardiovasc Res J. 2009;3(2):86-90.
Montalescot G, Sideris G, Meuleman C, et al. A randomized comparison of high clopidogrel loading doses in patients with non-ST-segment elevation acute coronary syndromes: the ALBION (Assessment of the Best Loading Dose of Clopidogrel to Blunt Platelet Activation, Inflammation and Ongoing Necrosis) trial. J Am Coll Cardiol. 2006;48(5):931-8. [pmid: 16949482].
Morrow DA, Sabatine MS, Antman EM, et al. Usefulness of tirofiban among patients treated without percutaneous coronary intervention (TIMI high risk patients in PRISM-PLUS). Am J Cardiol. 2004;94(6):774-6. [pmid: 15374786].
Morrow DA, Wiviott SD, White HD, et al. Effect of the novel thienopyridine prasugrel compared with clopidogrel on spontaneous and procedural myocardial infarction in the Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition with Prasugrel-Thrombolysis in Myocardial Infarction 38: an application of the classification system from the universal definition of myocardial infarction. Circulation. 2009;119(21):2758-64. [pmid: 19451347].
Mozes G, Sullivan TM, Torres-Russotto DR, et al. Carotid endarterectomy in SAPPHIRE-eligible high-risk patients: implications for selecting patients for carotid angioplasty and stenting. J Vasc Surg. 2004;39(5):958-65. discussion 965-6. [pmid: 15111844].
Mukherjee D, Topol EJ, Bertrand ME, et al. Mortality at 1 year for the direct comparison of tirofiban and abciximab during percutaneous coronary revascularization: do tirofiban and ReoPro give similar efficacy outcomes at trial 1-year follow-up. Eur Heart J. 2005;26(23):2524-8. [pmid: 16107485].
Murphy SA, Antman EM, Wiviott SD, et al. Reduction in recurrent cardiovascular events with prasugrel compared with clopidogrel in patients with acute coronary syndromes from the TRITON-TIMI 38 trial. Eur Heart J. 2008;29(20):2473-9. [pmid: 18682445].
Ndrepepa G, Kastrati A, Mehilli J, et al. One-year clinical outcomes with abciximab vs. placebo in patients with non-ST-segment elevation acute coronary syndromes undergoing percutaneous coronary intervention after pre-treatment with clopidogrel: results of the ISAR-REACT 2 randomized trial. Eur Heart J. 2008;29(4):455-61. [pmid: 18158289].
Ndrepepa G, Kastrati A, Mehilli J, et al. Age-dependent effect of abciximab in patients with acute coronary syndromes treated with percutaneous coronary interventions. Circulation. 2006;114(19):2040-6. [pmid: 17060377].
Ng FH, Tunggal P, Chu WM, et al. Esomeprazole Compared With Famotidine in the Prevention of Upper Gastrointestinal Bleeding in Patients With Acute Coronary Syndrome or Myocardial Infarction. Am J Gastroenterol. 2011. [pmid: 22108447].
Ng FH, Wong SY, Lam KF, et al. Gastrointestinal bleeding in patients receiving a combination of aspirin, clopidogrel, and enoxaparin in acute coronary syndrome. Am J Gastroenterol. 2008;103(4):865-71. [pmid: 18177451].
Nguyen MC, Lim YL, Walton A, et al. Combining warfarin and antiplatelet therapy after coronary stenting in the Global Registry of Acute Coronary Events: is it safe and effective to use just one antiplatelet agent?. Eur Heart J. 2007;28(14):1717-22. [pmid: 17562671].
O'Donoghue M, Antman EM, Braunwald E, et al. The efficacy and safety of prasugrel with and without a glycoprotein IIb/IIIa inhibitor in patients with acute coronary syndromes undergoing percutaneous intervention: a TRITON-TIMI 38 (Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition With Prasugrel-Thrombolysis In Myocardial Infarction 38) analysis. J Am Coll Cardiol. 2009;54(8):678-85. [pmid: 19679245].
O'Donoghue ML, Braunwald E, Antman EM, et al. Pharmacodynamic effect and clinical efficacy of clopidogrel and prasugrel with or without a proton-pump inhibitor: an analysis of two randomised trials. Lancet. 2009;374(9694):989-97. [pmid: 19726078].
Okmen E, Cakmak M, Tartan Z, et al. Effects of glycoprotein IIb/IIIa inhibition on clinical stabilization parameters in patients with unstable angina and non-Q-wave myocardial infarction. Heart Vessels. 2003;18(3):117-22. [pmid: 12955426].
Ortolani P, Marino M, Marzocchi A, et al. One-year clinical outcome in patients with acute coronary syndrome treated with concomitant use of clopidogrel and proton pump inhibitors: results from a regional cohort study. J Cardiovasc Med (Hagerstown). 2011. [pmid: 21252697].
O'Shea JC, Hafley GE, Greenberg S, et al. Platelet glycoprotein IIb/IIIa integrin blockade with eptifibatide in coronary stent intervention: the ESPRIT trial: a randomized controlled trial. JAMA. 2001;285(19):2468-73. [pmid: 11368699].
Ottervanger JP, Armstrong P, Barnathan ES, et al. Long-term results after the glycoprotein IIb/IIIa inhibitor abciximab in unstable angina: one-year survival in the GUSTO IV-ACS (Global Use of Strategies To Open Occluded Coronary Arteries IV--Acute Coronary Syndrome) Trial. Circulation. 2003;107(3):437-42. [pmid: 12551868].
Ozkan M, Sag C, Yokusoglu M, et al. The effect of tirofiban and clopidogrel pretreatment on outcome of old saphenous vein graft stenting in patients with acute coronary syndromes. Tohoku J Exp Med. 2005;206(1):7-13. [pmid: 15802870].
Parodi G, Migliorini A, Valenti R, et al. Comparison of bivalirudin and unfractionated heparin plus protamine in patients with coronary heart disease undergoing percutaneous coronary intervention (from the Antithrombotic Regimens aNd Outcome [ARNO] trial). Am J Cardiol. 2010;105(8):1053-9. [pmid: 20381652].
Patti G, Colonna G, Pasceri V, et al. Randomized trial of high loading dose of clopidogrel for reduction of periprocedural myocardial infarction in patients undergoing coronary intervention: results from the ARMYDA-2 (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) study. Circulation. 2005;111(16):2099-106. [pmid: 15750189].
Patti G, Pasceri V, D'Antonio L, et al. Comparison of Safety and Efficacy of Bivalirudin Versus Unfractionated Heparin in High-Risk Patients Undergoing Percutaneous Coronary Intervention (from the Anti-Thrombotic Strategy for Reduction of Myocardial Damage During Angioplasty-Bivalirudin vs Heparin Study). Am J Cardiol. 2012. [pmid: 22583760].
Pekdemir H, Cin VG, Camsari A, et al. A comparison of 1-month and 6-month clopidogrel therapy on clinical and angiographic outcome after stent implantation. Heart Vessels. 2003;18(3):123-9. [pmid: 12955427].
Persson J, Lindback J, Hofman-Bang C, et al. Efficacy and safety of clopidogrel after PCI with stenting in patients on oral anticoagulants with acute coronary syndrome. EuroIntervention. 2011;6(9):1046-1052. [pmid: 21518675].
Peters RJ, Mehta SR, Fox KA, et al. Effects of aspirin dose when used alone or in combination with clopidogrel in patients with acute coronary syndromes: observations from the Clopidogrel in Unstable angina to prevent Recurrent Events (CURE) study. Circulation. 2003;108(14):1682-7. [pmid: 14504182].
Petersen JL, Mahaffey KW, Becker RC, et al. Coordinated series of studies to evaluate characteristics and mechanisms of acute coronary syndromes in high-risk patients randomly assigned to enoxaparin or unfractionated heparin: design and rationale of the SYNERGY Library. Am Heart J. 2004;148(2):269-76. [pmid: 15308996].
Peterson ED, Pollack CV Jr., Roe MT, et al. Early use of glycoprotein IIb/IIIa inhibitors in non-ST-elevation acute myocardial infarction: observations from the National Registry of Myocardial Infarction 4. J Am Coll Cardiol. 2003;42(1):45-53. [pmid: 12849658].
Pinto DS, Stone GW, Shi C, et al. Economic evaluation of bivalirudin with or without glycoprotein IIb/IIIa inhibition versus heparin with routine glycoprotein IIb/IIIa inhibition for early invasive management of acute coronary syndromes. J Am Coll Cardiol. 2008;52(22):1758-68. [pmid: 19022155].
Price DJ, Campbell PG, Sutton AG, et al. Selective use of abciximab in coronary stenting: overall outcomes can still be equivalent to those in the EPISTENT treatment group. Int J Cardiovasc Intervent. 2001;4(1):15-20. [pmid: 12431335].
Price MJ, Berger PB, Teirstein PS, et al. Standard- vs high-dose clopidogrel based on platelet function testing after percutaneous coronary intervention: the GRAVITAS randomized trial. JAMA. 2011;305(11):1097-105. [pmid: 21406646].
Pride YB, Wiviott SD, Buros JL, et al. Effect of prasugrel versus clopidogrel on outcomes among patients with acute coronary syndrome undergoing percutaneous coronary intervention without stent implantation: a TRial to assess Improvement in Therapeutic Outcomes by optimizing platelet inhibitioN with prasugrel (TRITON)-Thrombolysis in Myocardial Infarction (TIMI) 38 substudy. Am Heart J. 2009;158(3):e21-6. [pmid: 19699846].
Puma JA, Banko LT, Pieper KS, et al. Clinical characteristics predict benefits from eptifibatide therapy during coronary stenting: insights from the Enhanced Suppression of the Platelet IIb/IIIa Receptor With Integrilin Therapy (ESPRIT) trial. J Am Coll Cardiol. 2006;47(4):715-8. [pmid: 16487833].
Puymirat E, Aissaoui N, Coste P, et al. Comparison of efficacy and safety of a standard versus a loading dose of clopidogrel for acute myocardial infarction in patients >/= 75 years of age (from the FAST-MI registry). Am J Cardiol. 2011;108(6):755-9. [pmid: 21726837].
Quinn MJ, Aronow HD, Califf RM, et al. Aspirin dose and six-month outcome after an acute coronary syndrome. J Am Coll Cardiol. 2004;43(6):972-8. [pmid: 15028352].
Rajagopal V, Lincoff AM, Cohen DJ, et al. Outcomes of patients with acute coronary syndromes who are treated with bivalirudin during percutaneous coronary intervention: an analysis from the Randomized Evaluation in PCI Linking Angiomax to Reduced Clinical Events (REPLACE-2) trial. Am Heart J. 2006;152(1):149-54. [pmid: 16824845].
Rasoul S, Ottervanger JP, de Boer MJ, et al. A comparison of dual vs. triple antiplatelet therapy in patients with non-ST-segment elevation acute coronary syndrome: results of the ELISA-2 trial. Eur Heart J. 2006;27(12):1401-7. [pmid: 16682384].
Rassen JA, Choudhry NK, Avorn J, et al. Cardiovascular outcomes and mortality in patients using clopidogrel with proton pump inhibitors after percutaneous coronary intervention or acute coronary syndrome. Circulation. 2009;120(23):2322-9. [pmid: 19933932].
Ray WA, Murray KT, Griffin MR, et al. Outcomes with concurrent use of clopidogrel and proton-pump inhibitors: a cohort study. Ann Intern Med. 2010;152(6):337-45. [pmid: 20231564].
Ren YH, Zhao M, Chen YD, et al. Omeprazole affects clopidogrel efficacy but not ischemic events in patients with acute coronary syndrome undergoing elective percutaneous coronary intervention. Chin Med J (Engl). 2011;124(6):856-61. [pmid: 21518592].
Roe M, Armstrong P, Fox K. Prasugrel versus Clopidogrel for Acute Coronary Syndromes without Revascularization. NEJM. 2012. e-pub Aug. 26, 2012. 2012.
Roe MT, Christenson RH, Ohman EM, et al. A randomized, placebo-controlled trial of early eptifibatide for non-ST-segment elevation acute coronary syndromes. Am Heart J. 2003;146(6):993-8. [pmid: 14660990].
Roffi M, Moliterno DJ, Meier B, et al. Impact of different platelet glycoprotein IIb/IIIa receptor inhibitors among diabetic patients undergoing percutaneous coronary intervention: : Do Tirofiban and ReoPro Give Similar Efficacy Outcomes Trial (TARGET) 1-year follow-up. Circulation. 2002;105(23):2730-6. [pmid: 12057986].
Ronner E, Boersma E, Akkerhuis KM, et al. Patients with acute coronary syndromes without persistent ST elevation undergoing percutaneous coronary intervention benefit most from early intervention with protection by a glycoprotein IIb/IIIa receptor blocker. Eur Heart J. 2002;23(3):239-46. [pmid: 11792139].
Rossini R, Capodanno D, Musumeci G, et al. Safety of clopidogrel and proton pump inhibitors in patients undergoing drug-eluting stent implantation. Coron Artery Dis. 2011;22(3):199-205. [pmid: 21358542].
Rossini R, Musumeci G, Lettieri C, et al. Long-term outcomes in patients undergoing coronary stenting on dual oral antiplatelet treatment requiring oral anticoagulant therapy. Am J Cardiol. 2008;102(12):1618-23. [pmid: 19064015].
Roy P, Bonello L, Torguson R, et al. Temporal relation between Clopidogrel cessation and stent thrombosis after drug-eluting stent implantation. Am J Cardiol. 2009;103(6):801-5. [pmid: 19268735].
Ruiz-Nodar JM, Marin F, Hurtado JA, et al. Anticoagulant and antiplatelet therapy use in 426 patients with atrial fibrillation undergoing percutaneous coronary intervention and stent implantation implications for bleeding risk and prognosis. J Am Coll Cardiol. 2008;51(8):818-25. [pmid: 18294566].
Ruiz-Nodar JM, Marin F, Roldan V, et al. Should We Recommend Oral Anticoagulation Therapy in Patients With Atrial Fibrillation Undergoing Coronary Artery Stenting With a High HAS-BLED Bleeding Risk Score?. Circ Cardiovasc Interv. 2012;5(4):459-66. [pmid: 22787018].
Sarafoff N, Sibbing D, Sonntag U, et al. Risk of drug-eluting stent thrombosis in patients receiving proton pump inhibitors. Thromb Haemost. 2010;104(3):626-32. [pmid: 20664905].
Schiariti M, Saladini A, Cuturello D, et al. Long-term efficacy of high-dose tirofiban versus double-bolus eptifibatide in patients undergoing percutaneous coronary intervention. J Cardiovasc Med (Hagerstown). 2011;12(1):29-36. [pmid: 20639765].
Schiariti M, Saladini A, Missiroli B, et al. Safety of downstream high-dose tirofiban bolus among 1578 patients undergoing percutaneous coronary intervention: the Sant'ANna TIrofiban Safety study. J Cardiovasc Med (Hagerstown). 2010;11(4):250-9. [pmid: 19952776].
Schiele F, Meneveau N, Seronde MF, et al. Routine use of fondaparinux in acute coronary syndromes: a 2-year multicenter experience. Am Heart J. 2010;159(2):190-8. [pmid: 20152216].
Schmidt M, Johansen MB, Robertson DJ, et al. Concomitant use of clopidogrel and proton pump inhibitors is not associated with major adverse cardiovascular events following coronary stent implantation. Aliment Pharmacol Ther. 2012;35(1):165-74. [pmid: 22050009].
Schulz S, Mehilli J, Ndrepepa G, et al. Bivalirudin vs. unfractionated heparin during percutaneous coronary interventions in patients with stable and unstable angina pectoris: 1-year results of the ISAR-REACT 3 trial. Eur Heart J. 2010;31(5):582-7. [pmid: 20150324].
Schulz S, Mehilli J, Neumann FJ, et al. ISAR-REACT 3A: a study of reduced dose of unfractionated heparin in biomarker negative patients undergoing percutaneous coronary intervention. Eur Heart J. 2010;31(20):2482-91. [pmid: 20805113].
Schulz S, Schuster T, Mehilli J, et al. Stent thrombosis after drug-eluting stent implantation: incidence, timing, and relation to discontinuation of clopidogrel therapy over a 4-year period. Eur Heart J. 2009;30(22):2714-21. [pmid: 19596658].
Schweiger MJ, Changezi HU, Naglieri-Prescod D, et al. Open-label, sequential comparison of eptifibatide with abciximab for patients undergoing percutaneous coronary intervention. Clin Ther. 2003;25(1):225-34. [pmid: 12637122].
Sculpher MJ, Lozano-Ortega G, Sambrook J, et al. Fondaparinux versus Enoxaparin in non-ST-elevation acute coronary syndromes: short-term cost and long-term cost-effectiveness using data from the Fifth Organization to Assess Strategies in Acute Ischemic Syndromes Investigators (OASIS-5) trial. Am Heart J. 2009;157(5):845-52. [pmid: 19376310].
Sibbald M, Yan AT, Huang W, et al. Association between smoking, outcomes, and early clopidogrel use in patients with acute coronary syndrome: insights from the Global Registry of Acute Coronary Events. Am Heart J. 2010;160(5):855-61. [pmid: 21095272].
Simon T, Steg PG, Gilard M, et al. Clinical events as a function of proton pump inhibitor use, clopidogrel use, and cytochrome P450 2C19 genotype in a large nationwide cohort of acute myocardial infarction: results from the French Registry of Acute ST-Elevation and Non-ST-Elevation Myocardial Infarction (FAST-MI) registry. Circulation. 2011;123(5):474-82. [pmid: 21262992].
Simoons ML. Effect of glycoprotein IIb/IIIa receptor blocker abciximab on outcome in patients with acute coronary syndromes without early coronary revascularisation: the GUSTO IV-ACS randomised trial. Lancet. 2001;357(9272):1915-24. [pmid: 11425411].
Singh KP, Roe MT, Peterson ED, et al. Low-molecular-weight heparin compared with unfractionated heparin for patients with non-ST-segment elevation acute coronary syndromes treated with glycoprotein IIb/IIIa inhibitors: results from the CRUSADE initiative. J Thromb Thrombolysis. 2006;21(3):211-20. [pmid: 16683212].
So D, Cook EF, Le May M, et al. Association of aspirin dosage to clinical outcomes after percutaneous coronary intervention: observations from the Ottawa Heart Institute PCI Registry. J Invasive Cardiol. 2009;21(3):121-7. [pmid: 19258643].
Song Y. Evaluation on the safety and efficacy of tirofiban in the treatment of acute coronary syndrome. J Huazhong Univ Sci Technolog Med Sci. 2007;27(2):142-4. [pmid: 17497280].
Spinler SA, Inverso SM, Cohen M, et al. Safety and efficacy of unfractionated heparin versus enoxaparin in patients who are obese and patients with severe renal impairment: analysis from the ESSENCE and TIMI 11B studies. Am Heart J. 2003;146(1):33-41. [pmid: 12851605].
Srichai MB, Jaber WA, Prior DL, et al. Evaluating the benefits of glycoprotein IIb/IIIa inhibitors in heart failure at baseline in acute coronary syndromes. Am Heart J. 2004;147(1):84-90. [pmid: 14691424].
Steg PG, Jolly SS, Mehta SR, et al. Low-dose vs standard-dose unfractionated heparin for percutaneous coronary intervention in acute coronary syndromes treated with fondaparinux: the FUTURA/OASIS-8 randomized trial. JAMA. 2010;304(12):1339-49. [pmid: 20805623].
Steg PG, Mehta S, Jolly S, et al. Fondaparinux with UnfracTionated heparin dUring Revascularization in Acute coronary syndromes (FUTURA/OASIS 8): a randomized trial of intravenous unfractionated heparin during percutaneous coronary intervention in patients with non-ST-segment elevation acute coronary syndromes initially treated with fondaparinux. Am Heart J. 2010;160(6):1029-34. 1034 e1. [pmid: 21146654].
Steinhubl SR, Berger PB, Mann JT 3rd, et al. Early and sustained dual oral antiplatelet therapy following percutaneous coronary intervention: a randomized controlled trial. JAMA. 2002;288(19):2411-20. [pmid: 12435254].
Stenestrand U, Lindback J, Wallentin L. Anticoagulation therapy in atrial fibrillation in combination with acute myocardial infarction influences long-term outcome: a prospective cohort study from the Register of Information and Knowledge About Swedish Heart Intensive Care Admissions (RIKS-HIA). Circulation. 2005;112(21):3225-31. [pmid: 16301355].
Stockl KM, Le L, Zakharyan A, et al. Risk of rehospitalization for patients using clopidogrel with a proton pump inhibitor. Arch Intern Med. 2010;170(8):704-10. [pmid: 20421557].
Stone GW, Bertrand M, Colombo A, et al. Acute Catheterization and Urgent Intervention Triage strategY (ACUITY) trial: study design and rationale. Am Heart J. 2004;148(5):764-75. [pmid: 15523305].
Stone GW, Bertrand ME, Moses JW, et al. Routine upstream initiation vs deferred selective use of glycoprotein IIb/IIIa inhibitors in acute coronary syndromes: the ACUITY Timing trial. JAMA. 2007;297(6):591-602. [pmid: 17299194].
Stone GW, McLaurin BT, Cox DA, et al. Bivalirudin for patients with acute coronary syndromes. N Engl J Med. 2006;355(21):2203-16. [pmid: 17124018].
Stone GW, Moliterno DJ, Bertrand M, et al. Impact of clinical syndrome acuity on the differential response to 2 glycoprotein IIb/IIIa inhibitors in patients undergoing coronary stenting: the TARGET Trial. Circulation. 2002;105(20):2347-54. [pmid: 12021219].
Stone GW, Ware JH, Bertrand ME, et al. Antithrombotic strategies in patients with acute coronary syndromes undergoing early invasive management: one-year results from the ACUITY trial. JAMA. 2007;298(21):2497-506. [pmid: 18056903].
Stone GW, White HD, Ohman EM, et al. Bivalirudin in patients with acute coronary syndromes undergoing percutaneous coronary intervention: a subgroup analysis from the Acute Catheterization and Urgent Intervention Triage strategy (ACUITY) trial. Lancet. 2007;369(9565):907-19. [pmid: 17368152].
Storey RF, Becker RC, Harrington RA, et al. Characterization of dyspnoea in PLATO study patients treated with ticagrelor or clopidogrel and its association with clinical outcomes. Eur Heart J. 2011;32(23):2945-53. [pmid: 21804104].
Suleiman M, Gruberg L, Hammerman H, et al. Comparison of two platelet glycoprotein IIb/IIIa inhibitors, eptifibatide and abciximab: outcomes, complications and thrombocytopenia during percutaneous coronary intervention. J Invasive Cardiol. 2003;15(6):319-23. [pmid: 12777670].
Szuk T, Gyongyosi M, Homorodi N, et al. Effect of timing of clopidogrel administration on 30-day clinical outcomes: 300-mg loading dose immediately after coronary stenting versus pretreatment 6 to 24 hours before stenting in a large unselected patient cohort. Am Heart J. 2007;153(2):289-95. [pmid: 17239691].
Tentzeris I, Jarai R, Farhan S, et al. Impact of concomitant treatment with proton pump inhibitors and clopidogrel on clinical outcome in patients after coronary stent implantation. Thromb Haemost. 2010;104(6):1211-8. [pmid: 20941464].
Theroux P, Alexander J Jr., Pharand C, et al. Glycoprotein IIb/IIIa receptor blockade improves outcomes in diabetic patients presenting with unstable angina/non-ST-elevation myocardial infarction: results from the Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) study. Circulation. 2000;102(20):2466-72. [pmid: 11076818].
Topol EJ, Moliterno DJ, Herrmann HC, et al. Comparison of two platelet glycoprotein IIb/IIIa inhibitors, tirofiban and abciximab, for the prevention of ischemic events with percutaneous coronary revascularization. N Engl J Med. 2001;344(25):1888-94. [pmid: 11419425].
Tricoci P, Peterson ED, Chen AY, et al. Timing of glycoprotein IIb/IIIa inhibitor use and outcomes among patients with non-ST-segment elevation myocardial infarction undergoing percutaneous coronary intervention (results from CRUSADE). Am J Cardiol. 2007;99(10):1389-93. [pmid: 17493466].
Tsai YW, Wen YW, Huang WF, et al. Cardiovascular and gastrointestinal events of three antiplatelet therapies: clopidogrel, clopidogrel plus proton-pump inhibitors, and aspirin plus proton-pump inhibitors in patients with previous gastrointestinal bleeding. J Gastroenterol. 2011;46(1):39-45. [pmid: 20811753].
Valgimigli M, Campo G, Monti M, et al. Short-Versus Long-term Duration of Dual Antiplatelet Therapy After Coronary Stenting: A Randomized Multicentre Trial. Circulation. 2012. [pmid: 22438530].
Valgimigli M, Campo G, Tebaldi M, et al. Randomized, double-blind comparison of effects of abiciximab bolus only vs. on-label regimen on ex vivo inhibition of platelet aggregation in responders to clopidogrel undergoing coronary stenting. J Thromb Haemost. 2010;8(9):1903-11. [pmid: 20586923].
Valkhoff VE, t Jong GW, Van Soest EM, et al. Risk of recurrent myocardial infarction with the concomitant use of clopidogrel and proton pump inhibitors. Aliment Pharmacol Ther. 2011;33(1):77-88. [pmid: 21083580].
van Boxel OS, van Oijen MG, Hagenaars MP, et al. Cardiovascular and gastrointestinal outcomes in clopidogrel users on proton pump inhibitors: results of a large Dutch cohort study. Am J Gastroenterol. 2010;105(11):2430-6. quiz 2437. [pmid: 20736935].
van den Brand MJ, Simoons ML, de Boer MJ, et al. Antiplatelet therapy in therapy-resistant unstable angina. A pilot study with REO PRO (c7E3). Eur Heart J. Suppl L. 1995;16:36-42. [pmid: 8869017].
van't Hof AW, de Vries ST, Dambrink JH, et al. A comparison of two invasive strategies in patients with non-ST elevation acute coronary syndromes: results of the Early or Late Intervention in unStable Angina (ELISA) pilot study. 2b/3a upstream therapy and acute coronary syndromes. Eur Heart J. 2003;24(15):1401-5. [pmid: 12909068].
Velianou JL, Mathew V, Wilson SH, et al. Effect of abciximab on late adverse events in patients with diabetes mellitus undergoing stent implantation. Am J Cardiol. 2000;86(10):1063-8. [pmid: 11074200].
Wallentin L, Becker RC, Budaj A, et al. Ticagrelor versus clopidogrel in patients with acute coronary syndromes. N Engl J Med. 2009;361(11):1045-57. [pmid: 19717846].
Wang C, Kereiakes DJ, Bae JP, et al. Clopidogrel loading doses and outcomes of patients undergoing percutaneous coronary intervention for acute coronary syndromes. J Invasive Cardiol. 2007;19(10):431-6. [pmid: 17906345].
Wang TY, White JA, Tricoci P, et al. Upstream clopidogrel use and the efficacy and safety of early eptifibatide treatment in patients with acute coronary syndrome: an analysis from the Early Glycoprotein IIb/IIIa Inhibition in Patients with Non-ST-Segment Elevation Acute Coronary Syndrome (EARLY ACS) trial. Circulation. 2011;123(7):722-30. [pmid: 21300952].
White HD, Chew DP, Hoekstra JW, et al. Safety and efficacy of switching from either unfractionated heparin or enoxaparin to bivalirudin in patients with non-ST-segment elevation acute coronary syndromes managed with an invasive strategy: results from the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. J Am Coll Cardiol. 2008;51(18):1734-41. [pmid: 18452778].
White HD, Kleiman NS, Mahaffey KW, et al. Efficacy and safety of enoxaparin compared with unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndrome undergoing percutaneous coronary intervention in the Superior Yield of the New Strategy of Enoxaparin, Revascularization and Glycoprotein IIb/IIIa Inhibitors (SYNERGY) trial. Am Heart J. 2006;152(6):1042-50. [pmid: 17161049].
White HD, Ohman EM, Lincoff AM, et al. Safety and efficacy of bivalirudin with and without glycoprotein IIb/IIIa inhibitors in patients with acute coronary syndromes undergoing percutaneous coronary intervention 1-year results from the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. J Am Coll Cardiol. 2008;52(10):807-14. [pmid: 18755342].
Wiviott SD, Antman EM, Gibson CM, et al. Evaluation of prasugrel compared with clopidogrel in patients with acute coronary syndromes: design and rationale for the TRial to assess Improvement in Therapeutic Outcomes by optimizing platelet InhibitioN with prasugrel Thrombolysis In Myocardial Infarction 38 (TRITON-TIMI 38). Am Heart J. 2006;152(4):627-35. [pmid: 16996826].
Wiviott SD, Braunwald E, Angiolillo DJ, et al. Greater clinical benefit of more intensive oral antiplatelet therapy with prasugrel in patients with diabetes mellitus in the trial to assess improvement in therapeutic outcomes by optimizing platelet inhibition with prasugrel-Thrombolysis in Myocardial Infarction 38. Circulation. 2008;118(16):1626-36. [pmid: 18757948].
Wiviott SD, Braunwald E, McCabe CH, et al. Intensive oral antiplatelet therapy for reduction of ischaemic events including stent thrombosis in patients with acute coronary syndromes treated with percutaneous coronary intervention and stenting in the TRITON-TIMI 38 trial: a subanalysis of a randomised trial. Lancet. 2008;371(9621):1353-63. [pmid: 18377975].
Wiviott SD, Braunwald E, McCabe CH, et al. Prasugrel versus clopidogrel in patients with acute coronary syndromes. N Engl J Med. 2007;357(20):2001-15. [pmid: 17982182].
Wiviott SD, Desai N, Murphy SA, et al. Efficacy and safety of intensive antiplatelet therapy with prasugrel from TRITON-TIMI 38 in a core clinical cohort defined by worldwide regulatory agencies. Am J Cardiol. 2011;108(7):905-11. [pmid: 21816379].
Wolfram R, Leborgne L, Cheneau E, et al. Comparison of effectiveness and safety of three different antithrombotic regimens (bivalirudin, eptifibatide, and heparin) in preventing myocardial ischemia during percutaneous coronary intervention. Am J Cardiol. 2003;92(9):1080-3. [pmid: 14583359].
Wu CY, Chan FK, Wu MS, et al. Histamine2-receptor antagonists are an alternative to proton pump inhibitor in patients receiving clopidogrel. Gastroenterology. 2010;139(4):1165-71. [pmid: 20600012].
Yan Z, Zhou Y, Zhao Y, et al. Efficacy and safety of tirofiban in high-risk patients with non-ST-segment elevation acute coronary syndromes. Clin Cardiol. 2009;32(9):E40-4. [pmid: 19645039].
Yong G, Rankin J, Ferguson L, et al. Randomized trial comparing 600- with 300-mg loading dose of clopidogrel in patients with non-ST elevation acute coronary syndrome undergoing percutaneous coronary intervention: results of the Platelet Responsiveness to Aspirin and Clopidogrel and Troponin Increment after Coronary intervention in Acute coronary Lesions (PRACTICAL) Trial. Am Heart J. 2009;157(1):60 e1-9. [pmid: 19081397].
Yusuf S, Mehta SR, Chrolavicius S, et al. Comparison of fondaparinux and enoxaparin in acute coronary syndromes. N Engl J Med. 2006;354(14):1464-76. [pmid: 16537663].
Yusuf S, Mehta SR, Zhao F, et al. Early and late effects of clopidogrel in patients with acute coronary syndromes. Circulation. 2003;107(7):966-72. [pmid: 12600908].
Yusuf S, Zhao F, Mehta SR, et al. Effects of clopidogrel in addition to aspirin in patients with acute coronary syndromes without ST-segment elevation. N Engl J Med. 2001;345(7):494-502. [pmid: 11519503].
Zairis MN, Tsiaousis GZ, Patsourakos NG, et al. The impact of treatment with omeprazole on the effectiveness of clopidogrel drug therapy during the first year after successful coronary stenting. Can J Cardiol. 2010;26(2):e54-7. [pmid: 20151060].
Zeymer U, Gitt AK, Zahn R, et al. Clopidogrel in addition to aspirin reduces one-year major adverse cardiac and cerebrovascular events in unselected patients with non-ST segment elevation myocardial infarction. Acute Card Care. 2008;10(1):43-8. [pmid: 17924233].

## Study Groupings Table

Table C-1 presents a key to the 302 primary and companion articles included in this report, organized alphabetically by study designation (if applicable). A full reference list follows the table.

Table C-1 Primary articles and companion articles

Study Designation | Primary Article(s) | Companion Article(s)
A to Z Trial | Blazing, 2004^1^ | Blazing, 2001^2^ de Lemos,2004^3^
ACUITY (Acute Catheterization and Urgent Intervention Triage Strategy Trial) ACUITY TIMING | Stone, 2006^4^ Stone, 2007^5^ | Ambrosio, 2011^6^ Aoki, 2009^7^ Caixeta, 2011^8^ Feit, 2008^9^ Goto, 2010^10^ Kumar, 2010^11^ Kirtane, 2010^12^ Lansky, 2009^13^ Lincoff, 2008^14^ Lopes, 2009^15^ Manoukian, 2007^16^ Mehran, 2009^17^ Miller, 2009^18^ Pinto, 2008^19^ Stone, 2004^20^ Stone, 2007^21^ Stone, 2007^22^ White, 2008^23^ White, 2008^24^
ACUTE II | Cohen, 2002^25^ | None
ALBION (Assessment of the Best Loading Dose of Clopidogrel to Blunt Platelet Activation, Inflammation and Ongoing Necrosis Trial) | Montalescot, 2006^26^ | None
ARMYDA-2 (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) | Patti, 2005^27^ | None
ARMYDA-4 RELOAD (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) | Di Sciascio, 2010^28^ | None
ARMYDA-5 PRELOAD (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) | Di Sciascio, 2010^29^ | None
ARMYDA-7 BIVALVE (Anti-Thrombotic Strategy for Reduction of Myocardial Damage During Angioplasty – Bivalirudin vs Heparin) | Patti, 2012^30^ | None
ARNO (Antithrombotic Regimens aNd Outcome trial) | Parodi, 2010^31^ | None
ASPIRE pilot trial (Arixtra Study in Percutaneous Coronary Intervention: a Randomized Evaluation) | Mehta, 2005^32^ | None
BRAVO (Blockage of the Glycoprotein IIb/IIIa Receptor to Avoid Vascular Occlusion) | Aronow, 2008^33^ | None
BRIEF-PCI (Brief Infusion of Eptifibatide Following Percutaneous Coronary Intervention) | Fung, 2009^34^ | None
Clopidogrel Medco Outcomes Study | Kreutz, 2010^35^ | None
CLOTILDA (CLOpidogrel, upstream TIrofiban, in cath Lab Downstream Abciximab study) | Leoncini, 2005^36^ | None
COGENT (Clopidogrel and the Optimization of Gastrointestinal Events Trial) | Bhatt, 2010^37^ | None
CREDO (Clopidogrel for the Reduction of Events During Observation Trial) | Steinhubl, 2002^38^ | Aronow, 2009^39^ Best, 2008^40^ Brener, 2007^41^
CRUISE (Coronary Revascularization Using Integrilin and Single Bolus Enoxaparin Study) | Bhatt, 2003^42^ | None
CRUSADE (Can Rapid risk stratification of Unstable angina patients Suppress Adverse outcomes with Early implementation of the ACC/AHA guidelines) | Alexander, 2008^43^ Fosbol, 2012^44^ LaPointe, 2007^45^ Singh, 2006^46^ Tricoci, 2007^47^ | None
CURE (Clopidogrel in Unstable Angina to Prevent Recurrent Events Trial) | Yusuf, 2001^48^ | Budaj, 2002^49^ Fox, 2004^50^ Jolly, 2009^51^ Keltai, 2007^52^ Lewis, 2005^53^ Peters, 2003^54^ Mehta, 2001^55^ Moliterno, 2002^56^ Yusuf, 2003^57^
CURRENT-OASIS 7 (Clopidogrel and Aspirin Optimal Dose Usage to Reduce Recurrent Events – Seventh Organization to Assess Strategies in Ischemic Syndromes) | Mehta, 2010^58^ | Mehta, 2008^59^ Mehta, 2010^60^
DISPERSE-2 | Cannon, 2007^61^ | None
EARLY ACS | Giugliano, 2009^62^ | Giugliano, 2005^63^ Melloni, 2011^64^ Wang, 2011^65^
EARLY Pilot Trial (Eptifibatide for Acute Coronary Syndromes – Rapid Versus Late Administration for Therapeutic Yield) | Roe, 2003^66^ | None
ELISA Pilot Study (Early or Late Intervention in unstable Angina) | van't Hof, 2003^67^ | None
ELISA-2 (Early or Late Intervention in unstable Angina 2) | Rasoul, 2006^68^ | None
EPISTENT (Evaluation of Platelet IIb/IIIa Inhibition in Stenting Trial) | Islam, 2002^69^ | Anonymous, 1998^70^ Price, 2001^71^
ESCAPEU (Efficacy, Safety, Cost, and Platelet Aggregation Effects of Enoxaparin and Unfractionated Heparin) | Malhotra, 2001^72^ | None
ESPRIT (Enhanced Suppression of the Platelet IIb/IIIa Receptor with Integrilin Therapy) | Anonymous, 2000^73^ | Labinaz, 2002^74^ O'Shea, 2001^75^ Puma, 2006^76^
ESSENCE (Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q-Wave Coronary Events Trial) | Cohen, 1997^77^ | Brosa, 2002^78^ Cohen, 1997^79^ Cohen, 1998^80^ Fox, 2002^81^ Goodman, 2000^82^ Goodman, 2006^83^ Mark, 1998^84^ Spinler, 2003^85,a^
EXCELLENT (Efficacy of Xience/Promus Versus Cypher to Reduce Late Loss After Stenting) | Gwon, 2012^86^ | None
FABOLUS SYNCHRO (Facilitation through Abciximab By drOpping Infusion Line in patients Undergoing coronary Stenting. SYNergy with Clopidogrel at High loading dOse Regimen) | Valgimigli, 2010^87^ | None
FAST-MI Registry (French Registry of Acute ST-Elevation or Non-ST-Elevation Myocardial Infarction) | Puymirat, 2011^88^ Simon, 2011^89^ | None
FUTURA/OASIS 8 Randomized Trial (Fondaparinux Trial With Unfractionated Heprin During Revascularization in Acute Coronary Syndromes) | Steg, 2010^90^ | Steg, 2010^91^
GHOST Guthrie Health Off-Label Stent) | Harjai, 2011^92^ Harjai, 2011^93^ | None
GRACE (Global Registry of Acute Coronary Events) | Brieger, 2007^94^ Dabbous, 2008^95^ Gore, 2007^96^ Lim, 2005^97^ Nguyen, 2007^98^ Sibbald, 2010^99^ | None
GRAVITAS (Gauging Responsiveness with A Verify Now assay – Impact on Thrombosis And Safety) | Price, 2011^100^ | None
GUSTO IIb (Global Use of Strategies to open Occluded coronary Arteries | Quinn, 2004^101,a^ | None
GUSTO IV-ACS (Global Use of Strategies To Open Occluded Coronary Arteries IV – Acute Coronary Syndrome Trial) | Simoons, 2001^102^ | Lenderink, 2004^103^ Ottervanger, 2003^104^
INTERACT (Integrilin and Enoxaparin Randomized Assessment of Acute Coronary Syndrome Treatment) | Goodman, 2003^105^ | Fitchett, 2006^106^ Goodman, 2005^107^
ISAR-REACT 2 Randomized Trial (Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment 2) | Kastrati, 2006^108^ | Iijima, 2008^109^ Iijima, 2008^110^ Mehilli, 2007^111^ Ndrepepa, 2008^112^ Ndrepepa, 2006^113^
ISAR-REACT 3 (Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment 3 Trial) | Kastrati, 2008^114^ | Iijima, 2009^115^ Schulz, 2010^116^ Schulz, 2010^117^
ISAR-REACT 4 (Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment 4 Trial) | Kastrati, 2011^118^ | None
KAMIR (Korea Acute Myocardial Infarction Registry) | Li, 2012^119^ | None
KICS (Kumamoto Intervention Conference Study) | Chitose, 2011^120^ | None
NRMI3 (National Registry of Myocardial Infarction 3) | Kovar, 2002^121^ | None
NRMI4 (National Registry of Myocardial Infarction 4) | Peterson, 2003^122^ | None
OASIS-5 (Fifth Organization to Assess Strategies in Acute Ischemic Syndromes) | Yusuf, 2006^123^ | Budaj, 2009^124^ Fox, 2007^125^ Jolly, 2009^126^ Joyner, 2009^127^ Mehta, 2005^128^ Mehta, 2008^129^ Mehta, 2007^130^ Sculpher, 2009^131^
Ottawa Heart Institute PCI Registry | So, 2009^132^ | None
PARAGON-A (Platelet IIb/IIIa Antagonist for the Reduction of Acute Coronary Syndrome Events in a Global Organization Network A) | Lopes, 2010^133,a^ | None
PLATO (Platelet Inhibition and Patient Outcomes) | Wallentin, 2009^134^ James, 2011^135^ | Cannon, 2010^136^ Becker, 2011^137^ Goodman, 2012^138^ Held, 2011^139^ Husted, 2012^140^ James, 2010^141^ James, 2010^142^ James, 2009^143^ Mahaffey, 2011^144^ Storey, 2011^145^
PRACTICAL Platelet Responsiveness to Aspirin and Clopidogrel and Troponin Increment after Coronary intervention in Acute coronary Lesions) | Yong, 2009^146^ | None
PRACTICE (Prospective RAndomised placebo Controlled trial to assess the role of BP IIb/IIIa blockade by integrilin in patients with troponin Increase and nonpersistent ST segment elevation acute Coronary syndrome study) | Durand, 2007^147^ | None
PRISM (Platelet Receptor Inhibition in Ischemic Syndrome Management) | Anonymous, 1998^148^ | None
PRISM-PLUS (Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms) | Anonymous, 1998^149^ | Huynh, 2003^150^ Huynh, 2005^151^ Januzzi, 2000^152^ Januzzi, 2001^153^ Januzzi, 2002^154^ Morrow, 2004^155^ Mozes, 2004^156^ Theroux, 2000^157^
PRODIGY (PROlonging Dual antiplatelet treatment after Grading stent-induced Intimal hyperplasia studY) | Valgimigli, 2012^158^ | None
PROTECT-TIMI-30 (Randomized Trial to Evaluate the Relative PROTECTion against Post-PCI Microvascular Dysfunction and Post-PCI Ischemia among Anti-Platelet and Anti-Thrombotic Agents-Thrombolysus In Myocardial Infarction-30) | Gibson, 2006^159^ | None
PURSUIT (Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy Trial) | Anonymous, 1998^160^ | Brown, 2003^161^ Chang, 2002^162^ Harrington, 1997^163^ Hasdai, 2000^164^ Kleiman, 2000^165^ Labinaz, 2004^166^ Lincoff, 2000^167^ Lopes, 2010^133,a^ Quinn, 2004^101,a^ Ronner, 2002^168^ Srichai, 2004^169^
RACS (Randomized Argentine Clopidogrel Stent Trial) | Bernardi, 2007^170^ | None
REPLACE-2 (Randomized Evaluation in PCI Linking Angiomax to Reduced Clinical Events Trial) | Rajagopal, 2006^171^ | None
RIKS-HIA (Register of Information and Knowledge About Swedish Heart Intensive Care Admissions) | Stenestrand, 2005^172^ | None
ROSAI-2 (Registro Osservazionale Angina Instabile) | De Servi, 2006^173^ | None
SANTISS (Sant'ANna TIrofiban Safety Study) | Schiariti, 2011^174^ | Schiariti, 2010^175^
SYNERGY (Superior Yield of the New Strategy of Enoxaparin, Revascularization and Glycoprotein IIb/IIIa Inhibitors Trial) | Ferguson, 2004^176^ | Anonymous, 2002^177^ Chew, 2008^178^ Cohen, 2006^179^ Cohen, 2010^180^ Ferguson, 2002^181^ Lopes, 2008^182^ Lopes, 2010^133,a^ Petersen, 2004^183^ White, 2006^184^
T-ACCORD Registry (Taiwan Acute CORonary Syndrome Descriptive Registry) | Cheng, 2010^185^ | None
TARGET (Do Tirofiban and ReoPro Give Similar Efficacy Outcomes Trial) | Topol, 2001^186^ | Berger, 2005^187^ Chan, 2003^188^ Merlini, 2004^189^ Moliterno, 2000^190^ Mukherjee, 2005^191^ Roffi, 2002^192^ Stone, 2002^193^
TENACITY (Tirofiban Evaluation of Novel Dosing versus Abciximab with Clopidogrel and Inhibition of Thrombin Study Trial) | Moliterno, 2011^194^ | None
TIMI 8 (Thrombolysis in Myocardial Infarction) | Antman, 2002^195^ | None
TIMI 11B (Thrombolysis In Myocardial Infarction) | Antman, 1999^196^ | Antman, 1998^197^ Spinler, 2003^85,a^
TRILOGY-ACS (Targeted Platelet Inhibition to Clarify the Optimal Strategy to Medically Manage Acute Coronary Syndromes) | Roe, 2012^198^ | Chin, 2010^199^
TRITON-TIMI 38 (Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition with Prasugrel – Thrombolysis in Myocardial Infarction) | Wiviott, 2007^200^ | Antman, 2008^201^ Morrow, 2009^202^ Murphy, 2008^203^ O'Donoghue,2009^204^ O'Donoghue,2009^205^ Pride, 2009^206^ Wiviott, 2006^207^ Wiviott, 2008^208^ Wiviott, 2008^209^ Wiviott, 2011^210^
ZEUS (Zurich Enoxaparin versus Unfractionated heparin in PCI Study) | Bertel, 2010^211^ | None
None indicated | Abuzahra, 2008^212^ | None
None indicated | Ajani, 2003^213^ | None
None indicated | Angkasuwapala, 2007^214^ | None
None indicated | Banerjee, 2011^215^ | None
None indicated | Barada, 2008^216^ | None
None indicated | Bauer, 2010^217^ | None
None indicated | Berger, 2005^218^ | None
None indicated | Berglund, 2002^219^ | None
None indicated | Bhattacharya, 2010^220^ | None
None indicated | Bhurke, 2012^221^ | None
None indicated | Bonde, 2010^222^ | None
None indicated | Bonello, 2008^223^ | None
None indicated | Brener, 2003^224^ | None
None indicated | Buresly, 2005^225^ | None
None indicated | Burgess, 2002^226^ | None
None indicated | Butler, 2009^227^ | None
None indicated | Charlot, 2010^228^ | None
None indicated | Charlot, 2011^229^ | None
None indicated | Charlot, 2012^230^ | None
None indicated | Chen, 2006^231^ | None
None indicated | Chu, 2006^232^ | None
None indicated | Cortese, 2009^233^ | None
None indicated | Cuisset, 2006^234^ | None
None indicated | Danzi, 2006^235^ | None
None indicated | Daviouros, 2009^236^ | None
None indicated | Evanchan, 2010^237^ | None
None indicated | Galassi, 1999^238^ | None
None indicated | Galasso, 2008^239^ | None
None indicated | Gao, 2009^240^ | None
None indicated | Gaspar, 2010^241^ | None
None indicated | Gowda, 2003^242^ | None
None indicated | Gunasekara, 2006^243^ | None
None indicated | Gupta, 2010^244^ | None
None indicated | Harjai, 2009^245^ | None
None indicated | Ho, 2007^246^ | None
None indicated | Ho, 2009^247^ | None
None indicated | Hsaio, 2011^248^ | None
None indicated | Ivandic, 2008^249^ | None
None indicated | Iversen, 2011^250^ | None
None indicated | Iversen, 2011^251^ | None
None indicated | Jang, 2011^252^ | None
None indicated | Juurlink, 2009^253^ | None
None indicated | Karha, 2006^254^ | None
None indicated | Karjalainen, 2007^255^ | None
None indicated | Kim, 2005^256^ | None
None indicated | Konstantino, 2006^257^ | None
None indicated | Korovesis, 2005^258^ | None
None indicated | Lahtela, 2009^259^ | None
None indicated | Lamberts, 2013^260^ | None
None indicated | Lemesle, 2009^261^ | None
None indicated | Lemesle, 2009^262^ | None
None indicated | Lin, 2009^263^ | None
None indicated | Liu, 2009^264^ | None
None indicated | Maegdefessel,2008^265^ | None
None indicated | Momtahen, 2009^266^ | None
None indicated | Ng, 2011^267^ | None
None indicated | Ng, 2008^268^ | None
None indicated | Okmen, 2003^269^ | None
None indicated | Ortolani, 2011^270^ | None
None indicated | Ozkan, 2005^271^ | None
None indicated | Pekdemir, 2003^272^ | None
None indicated | Persson, 2011^273^ | None
None indicated | Rassen, 2009^274^ | None
None indicated | Ray, 2010^275^ | None
None indicated | Ren, 2011^276^ | None
None indicated | Rossini, 2011^277^ | None
None indicated | Rossini, 2008^278^ | None
None indicated | Roy, 2009^279^ | None
None indicated | Ruiz-Nodar, 2008^280^ | None
None indicated | Ruiz-Nodar, 2012^281^ | None
None indicated | Sarafoff, 2010^282^ | None
None indicated | Schiele, 2010^283^ | None
None indicated | Schmidt, 2012^284^ | None
None indicated | Schulz, 2009^285^ | None
None indicated | Schweiger, 2003^286^ | None
None indicated | Song, 2007^287^ | None
None indicated | Stockl, 2010^288^ | None
None indicated | Suleiman, 2003^289^ | None
None indicated | Szuk, 2007^290^ | None
None indicated | Tentzeris, 2010^291^ | None
None indicated | Tsai, 2011^292^ | None
None indicated | Valkhoff, 2011^293^ | None
None indicated | van Boxel, 2010^294^ | None
None indicated | van den Brand, 1995^295^ | None
None indicated | Velianou, 2000^296^ | None
None indicated | Wang, 2007^297^ | None
None indicated | Wolfram, 2003^298^ | None
None indicated | Wu, 2010^299^ | None
None indicated | Yan, 2009^300^ | None
None indicated | Zairis, 2010^301^ | None
None indicated | Zeymer, 2008^302^ | None

a Article reported data from multiple separate trials.

### References for Study Groupings

1 Blazing MA, de Lemos JA, White HD, et al. Safety and efficacy of enoxaparin vs unfractionated heparin in patients with non-ST-segment elevation acute coronary syndromes who receive tirofiban and aspirin: a randomized controlled trial. JAMA. 2004;292(1):55-64. [pmid: 15238591].
2 Blazing MA, De Lemos JA, Dyke CK, et al. The A-to-Z Trial: Methods and rationale for a single trial investigating combined use of low-molecular-weight heparin with the glycoprotein IIb/IIIa inhibitor tirofiban and defining the efficacy of early aggressive simvastatin therapy. Am Heart J. 2001;142(2):211-7. [pmid: 11479456].
3 de Lemos JA, Blazing MA, Wiviott SD, et al. Enoxaparin versus unfractionated heparin in patients treated with tirofiban, aspirin and an early conservative initial management strategy: results from the A phase of the A-to-Z trial. Eur Heart J. 2004;25(19):1688-94. [pmid: 15451146].
4 Stone GW, McLaurin BT, Cox DA, et al. Bivalirudin for patients with acute coronary syndromes. N Engl J Med. 2006;355(21):2203-16. [pmid: 17124018].
5 Stone GW, Bertrand ME, Moses JW, et al. Routine upstream initiation vs deferred selective use of glycoprotein IIb/IIIa inhibitors in acute coronary syndromes: the ACUITY Timing trial. JAMA. 2007;297(6):591-602. [pmid: 17299194].
6 Ambrosio G, Steinhubl S, Gresele P, et al. Impact of chronic antiplatelet therapy before hospitalization on ischemic and bleeding events in invasively managed patients with acute coronary syndromes: the ACUITY trial. Eur J Cardiovasc Prev Rehabil. 2011;18(1):121-8. [pmid: 20523219].
7 Aoki J, Lansky AJ, Mehran R, et al. Early stent thrombosis in patients with acute coronary syndromes treated with drug-eluting and bare metal stents: the Acute Catheterization and Urgent Intervention Triage Strategy trial. Circulation. 2009;119(5):687-98. [pmid: 19171852].
8 Caixeta A, Dangas GD, Mehran R, et al. Incidence and clinical consequences of acquired thrombocytopenia after antithrombotic therapies in patients with acute coronary syndromes: results from the Acute Catheterization and Urgent Intervention Triage Strategy (ACUITY) trial. Am Heart J. 2011;161(2):298-306 e1. [pmid: 21315212].
9 Feit F, Manoukian SV, Ebrahimi R, et al. Safety and efficacy of bivalirudin monotherapy in patients with diabetes mellitus and acute coronary syndromes: a report from the ACUITY (Acute Catheterization and Urgent Intervention Triage Strategy) trial. J Am Coll Cardiol. 2008;51(17):1645-52. [pmid: 18436116].
10 Goto K, Lansky AJ, Fahy M, et al. Predictors of outcomes in medically treated patients with acute coronary syndromes after angiographic triage: an Acute Catheterization And Urgent Intervention Triage Strategy (ACUITY) substudy. Circulation. 2010;121(7):853-62. [pmid: 20142447].
11 Kumar D, Dangas G, Mehran R, et al. Comparison of Bivalirudin versus Bivalirudin plus glycoprotein IIb/IIIa inhibitor versus heparin plus glycoprotein IIb/IIIa inhibitor in patients with acute coronary syndromes having percutaneous intervention for narrowed saphenous vein aorto-coronary grafts (the ACUITY trial investigators). Am J Cardiol. 2010;106(7):941-5. [pmid: 20854954].
12 Kirtane AJ, Parise H, Mehran R, et al. Comparison of catheterization laboratory initiated abciximab and eptifibatide during percutaneous coronary intervention in acute coronary syndromes (an ACUITY substudy). Am J Cardiol. 2010;106(2):180-6. [pmid: 20599000].
13 Lansky AJ, Mehran R, Cristea E, et al. Impact of gender and antithrombin strategy on early and late clinical outcomes in patients with non-ST-elevation acute coronary syndromes (from the ACUITY trial). Am J Cardiol. 2009;103(9):1196-203. [pmid: 19406258].
14 Lincoff AM, Steinhubl SR, Manoukian SV, et al. Influence of timing of clopidogrel treatment on the efficacy and safety of bivalirudin in patients with non-ST-segment elevation acute coronary syndromes undergoing percutaneous coronary intervention: an analysis of the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. JACC Cardiovasc Interv. 2008;1(6):639-48. [pmid: 19463378].
15 Lopes RD, Alexander KP, Manoukian SV, et al. Advanced age, antithrombotic strategy, and bleeding in non-ST-segment elevation acute coronary syndromes: results from the ACUITY (Acute Catheterization and Urgent Intervention Triage Strategy) trial. J Am Coll Cardiol. 2009;53(12):1021-30. [pmid: 19298914].
16 Manoukian SV, Feit F, Mehran R, et al. Impact of major bleeding on 30-day mortality and clinical outcomes in patients with acute coronary syndromes: an analysis from the ACUITY Trial. J Am Coll Cardiol. 2007;49(12):1362-8. [pmid: 17394970].
17 Mehran R, Nikolsky E, Lansky AJ, et al. Impact of chronic kidney disease on early (30-day) and late (1-year) outcomes of patients with acute coronary syndromes treated with alternative antithrombotic treatment strategies: an ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) substudy. JACC Cardiovasc Interv. 2009;2(8):748-57. [pmid: 19695543].
18 Miller CD, Blomkalns AL, Gersh BJ, et al. Safety and efficacy of bivalirudin in high-risk patients admitted through the emergency department. Acad Emerg Med. 2009;16(8):717-25. [pmid: 19673711].
19 Pinto DS, Stone GW, Shi C, et al. Economic evaluation of bivalirudin with or without glycoprotein IIb/IIIa inhibition versus heparin with routine glycoprotein IIb/IIIa inhibition for early invasive management of acute coronary syndromes. J Am Coll Cardiol. 2008;52(22):1758-68. [pmid: 19022155].
20 Stone GW, Bertrand M, Colombo A, et al. Acute Catheterization and Urgent Intervention Triage strategY (ACUITY) trial: study design and rationale. Am Heart J. 2004;148(5):764-75. [pmid: 15523305].
21 Stone GW, Ware JH, Bertrand ME, et al. Antithrombotic strategies in patients with acute coronary syndromes undergoing early invasive management: one-year results from the ACUITY trial. JAMA. 2007;298(21):2497-506. [pmid: 18056903].
22 Stone GW, White HD, Ohman EM, et al. Bivalirudin in patients with acute coronary syndromes undergoing percutaneous coronary intervention: a subgroup analysis from the Acute Catheterization and Urgent Intervention Triage strategy (ACUITY) trial. Lancet. 2007;369(9565):907-19. [pmid: 17368152].
23 White HD, Ohman EM, Lincoff AM, et al. Safety and efficacy of bivalirudin with and without glycoprotein IIb/IIIa inhibitors in patients with acute coronary syndromes undergoing percutaneous coronary intervention 1-year results from the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. J Am Coll Cardiol. 2008;52(10):807-14. [pmid: 18755342].
24 White HD, Chew DP, Hoekstra JW, et al. Safety and efficacy of switching from either unfractionated heparin or enoxaparin to bivalirudin in patients with non-ST-segment elevation acute coronary syndromes managed with an invasive strategy: results from the ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) trial. J Am Coll Cardiol. 2008;51(18):1734-41. [pmid: 18452778].
25 Cohen M, Theroux P, Borzak S, et al. Randomized double-blind safety study of enoxaparin versus unfractionated heparin in patients with non-ST-segment elevation acute coronary syndromes treated with tirofiban and aspirin: the ACUTE II study. The Antithrombotic Combination Using Tirofiban and Enoxaparin. Am Heart J. 2002;144(3):470-7. [pmid: 12228784].
26 Montalescot G, Sideris G, Meuleman C, et al. A randomized comparison of high clopidogrel loading doses in patients with non-ST-segment elevation acute coronary syndromes: the ALBION (Assessment of the Best Loading Dose of Clopidogrel to Blunt Platelet Activation, Inflammation and Ongoing Necrosis) trial. J Am Coll Cardiol. 2006;48(5):931-8. [pmid: 16949482].
27 Patti G, Colonna G, Pasceri V, et al. Randomized trial of high loading dose of clopidogrel for reduction of periprocedural myocardial infarction in patients undergoing coronary intervention: results from the ARMYDA-2 (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) study. Circulation. 2005;111(16):2099-106. [pmid: 15750189].
28 Di Sciascio G, Patti G, Pasceri V, et al. Clopidogrel reloading in patients undergoing percutaneous coronary intervention on chronic clopidogrel therapy: results of the ARMYDA-4 RELOAD (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) randomized trial. Eur Heart J. 2010;31(11):1337-43. [pmid: 20363764].
29 Di Sciascio G, Patti G, Pasceri V, et al. Effectiveness of in-laboratory high-dose clopidogrel loading versus routine pre-load in patients undergoing percutaneous coronary intervention: results of the ARMYDA-5 PRELOAD (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) randomized trial. J Am Coll Cardiol. 2010;56(7):550-7. [pmid: 20688209].
30 Patti G, Pasceri V, D'Antonio L, et al. Comparison of Safety and Efficacy of Bivalirudin Versus Unfractionated Heparin in High-Risk Patients Undergoing Percutaneous Coronary Intervention (from the Anti-Thrombotic Strategy for Reduction of Myocardial Damage During Angioplasty-Bivalirudin vs Heparin Study). Am J Cardiol. 2012. [pmid: 22583760].
31 Parodi G, Migliorini A, Valenti R, et al. Comparison of bivalirudin and unfractionated heparin plus protamine in patients with coronary heart disease undergoing percutaneous coronary intervention (from the Antithrombotic Regimens aNd Outcome [ARNO] trial). Am J Cardiol. 2010;105(8):1053-9. [pmid: 20381652].
32 Mehta SR, Steg PG, Granger CB, et al. Randomized, blinded trial comparing fondaparinux with unfractionated heparin in patients undergoing contemporary percutaneous coronary intervention: Arixtra Study in Percutaneous Coronary Intervention: a Randomized Evaluation (ASPIRE) Pilot Trial. Circulation. 2005;111(11):1390-7. [pmid: 15781750].
33 Aronow HD, Califf RM, Harrington RA, et al. Relation between aspirin dose, all-cause mortality, and bleeding in patients with recent cerebrovascular or coronary ischemic events (from the BRAVO Trial). Am J Cardiol. 2008;102(10):1285-90. [pmid: 18993142].
34 Fung AY, Saw J, Starovoytov A, et al. Abbreviated infusion of eptifibatide after successful coronary intervention The BRIEF-PCI (Brief Infusion of Eptifibatide Following Percutaneous Coronary Intervention) randomized trial. J Am Coll Cardiol. 2009;53(10):837-45. [pmid: 19264239].
35 Kreutz RP, Stanek EJ, Aubert R, et al. Impact of proton pump inhibitors on the effectiveness of clopidogrel after coronary stent placement: the clopidogrel Medco outcomes study. Pharmacotherapy. 2010;30(8):787-96. [pmid: 20653354].
36 Leoncini M, Toso A, Maioli M, et al. Effects of tirofiban plus clopidogrel versus clopidogrel plus provisional abciximab on biomarkers of myocardial necrosis in patients with non-ST-elevation acute coronary syndromes treated with early aggressive approach. Results of the CLOpidogrel, upstream TIrofiban, in cath Lab Downstream Abciximab (CLOTILDA) study. Am Heart J. 2005;150(3):401. [pmid: 16169315].
37 Bhatt DL, Cryer BL, Contant CF, et al. Clopidogrel with or without omeprazole in coronary artery disease. N Engl J Med. 2010;363(20):1909-17. [pmid: 20925534].
38 Steinhubl SR, Berger PB, Mann JT 3rd, et al. Early and sustained dual oral antiplatelet therapy following percutaneous coronary intervention: a randomized controlled trial. JAMA. 2002;288(19):2411-20. [pmid: 12435254].
39 Aronow HD, Steinhubl SR, Brennan DM, et al. Bleeding risk associated with 1 year of dual antiplatelet therapy after percutaneous coronary intervention: Insights from the Clopidogrel for the Reduction of Events During Observation (CREDO) trial. Am Heart J. 2009;157(2):369-74. [pmid: 19185647].
40 Best PJ, Steinhubl SR, Berger PB, et al. The efficacy and safety of short- and long-term dual antiplatelet therapy in patients with mild or moderate chronic kidney disease: results from the Clopidogrel for the Reduction of Events During Observation (CREDO) trial. Am Heart J. 2008;155(4):687-93. [pmid: 18371477].
41 Brener SJ, Steinhubl SR, Berger PB, et al. Prolonged dual antiplatelet therapy after percutaneous coronary intervention reduces ischemic events without affecting the need for repeat revascularization: insights from the CREDO trial. J Invasive Cardiol. 2007;19(7):287-90. [pmid: 17620671].
42 Bhatt DL, Lee BI, Casterella PJ, et al. Safety of concomitant therapy with eptifibatide and enoxaparin in patients undergoing percutaneous coronary intervention: results of the Coronary Revascularization Using Integrilin and Single bolus Enoxaparin Study. J Am Coll Cardiol. 2003;41(1):20-5. [pmid: 12570939].
43 Alexander D, Ou FS, Roe MT, et al. Use of and inhospital outcomes after early clopidogrel therapy in patients not undergoing an early invasive strategy for treatment of non-ST-segment elevation myocardial infarction: results from Can Rapid risk stratification of Unstable angina patients Suppress ADverse outcomes with Early implementation of the American College of Cardiology/American Heart Association guidelines (CRUSADE). Am Heart J. 2008;156(3):606-12. [pmid: 18760147].
44 Fosbol EL, Wang TY, Li S, et al. Safety and effectiveness of antithrombotic strategies in older adult patients with atrial fibrillation and non-ST elevation myocardial infarction. Am Heart J. 2012;163(4):720-8. [pmid: 22520540].
45 LaPointe NM, Chen AY, Alexander KP, et al. Enoxaparin dosing and associated risk of in-hospital bleeding and death in patients with non ST-segment elevation acute coronary syndromes. Arch Intern Med. 2007;167(14):1539-44. [pmid: 17646609].
46 Singh KP, Roe MT, Peterson ED, et al. Low-molecular-weight heparin compared with unfractionated heparin for patients with non-ST-segment elevation acute coronary syndromes treated with glycoprotein IIb/IIIa inhibitors: results from the CRUSADE initiative. J Thromb Thrombolysis. 2006;21(3):211-20. [pmid: 16683212].
47 Tricoci P, Peterson ED, Chen AY, et al. Timing of glycoprotein IIb/IIIa inhibitor use and outcomes among patients with non-ST-segment elevation myocardial infarction undergoing percutaneous coronary intervention (results from CRUSADE). Am J Cardiol. 2007;99(10):1389-93. [pmid: 17493466].
48 Yusuf S, Zhao F, Mehta SR, et al. Effects of clopidogrel in addition to aspirin in patients with acute coronary syndromes without ST-segment elevation. N Engl J Med. 2001;345(7):494-502. [pmid: 11519503].
49 Budaj A, Yusuf S, Mehta SR, et al. Benefit of clopidogrel in patients with acute coronary syndromes without ST-segment elevation in various risk groups. Circulation. 2002;106(13):1622-6. [pmid: 12270853].
50 Fox KA, Mehta SR, Peters R, et al. Benefits and risks of the combination of clopidogrel and aspirin in patients undergoing surgical revascularization for non-ST-elevation acute coronary syndrome: the Clopidogrel in Unstable angina to prevent Recurrent ischemic Events (CURE) Trial. Circulation. 2004;110(10):1202-8. [pmid: 15313956].
51 Jolly SS, Pogue J, Haladyn K, et al. Effects of aspirin dose on ischaemic events and bleeding after percutaneous coronary intervention: insights from the PCI-CURE study. Eur Heart J. 2009;30(8):900-7. [pmid: 18819961].
52 Keltai M, Tonelli M, Mann JF, et al. Renal function and outcomes in acute coronary syndrome: impact of clopidogrel. Eur J Cardiovasc Prev Rehabil. 2007;14(2):312-8. [pmid: 17446813].
53 Lewis BS, Mehta SR, Fox KA, et al. Benefit of clopidogrel according to timing of percutaneous coronary intervention in patients with acute coronary syndromes: further results from the Clopidogrel in Unstable angina to prevent Recurrent Events (CURE) study. Am Heart J. 2005;150(6):1177-84. [pmid: 16338255].
54 Peters RJ, Mehta SR, Fox KA, et al. Effects of aspirin dose when used alone or in combination with clopidogrel in patients with acute coronary syndromes: observations from the Clopidogrel in Unstable angina to prevent Recurrent Events (CURE) study. Circulation. 2003;108(14):1682-7. [pmid: 14504182].
55 Mehta SR, Yusuf S, Peters RJ, et al. Effects of pretreatment with clopidogrel and aspirin followed by long-term therapy in patients undergoing percutaneous coronary intervention: the PCI-CURE study. Lancet. 2001;358(9281):527-33. [pmid: 11520521].
56 Moliterno DJ, Yakubov SJ, DiBattiste PM, et al. Outcomes at 6 months for the direct comparison of tirofiban and abciximab during percutaneous coronary revascularisation with stent placement: the TARGET follow-up study. Lancet. 2002;360(9330):355-60. [pmid: 12241774].
57 Yusuf S, Mehta SR, Zhao F, et al. Early and late effects of clopidogrel in patients with acute coronary syndromes. Circulation. 2003;107(7):966-72. [pmid: 12600908].
58 Mehta SR, Bassand JP, Chrolavicius S, et al. Dose comparisons of clopidogrel and aspirin in acute coronary syndromes. N Engl J Med. 2010;363(10):930-42. [pmid: 20818903].
59 Mehta SR, Bassand JP, Chrolavicius S, et al. Design and rationale of CURRENT-OASIS 7: a randomized, 2 × 2 factorial trial evaluating optimal dosing strategies for clopidogrel and aspirin in patients with ST and non-ST-elevation acute coronary syndromes managed with an early invasive strategy. Am Heart J. 2008;156(6):1080-8 e1. [pmid: 19033002].
60 Mehta SR, Tanguay JF, Eikelboom JW, et al. Double-dose versus standard-dose clopidogrel and high-dose versus low-dose aspirin in individuals undergoing percutaneous coronary intervention for acute coronary syndromes (CURRENT-OASIS 7): a randomised factorial trial. Lancet. 2010;376(9748):1233-43. [pmid: 20817281].
61 Cannon CP, Husted S, Harrington RA, et al. Safety, tolerability, and initial efficacy of AZD6140, the first reversible oral adenosine diphosphate receptor antagonist, compared with clopidogrel, in patients with non-ST-segment elevation acute coronary syndrome: primary results of the DISPERSE-2 trial. J Am Coll Cardiol. 2007;50(19):1844-51. [pmid: 17980250].
62 Giugliano RP, White JA, Bode C, et al. Early versus delayed, provisional eptifibatide in acute coronary syndromes. N Engl J Med. 2009;360(21):2176-90. [pmid: 19332455].
63 Giugliano RP, Newby LK, Harrington RA, et al. The early glycoprotein IIb/IIIa inhibition in non-ST-segment elevation acute coronary syndrome (EARLY ACS) trial: a randomized placebo-controlled trial evaluating the clinical benefits of early front-loaded eptifibatide in the treatment of patients with non-ST-segment elevation acute coronary syndrome--study design and rationale. Am Heart J. 2005;149(6):994-1002. [pmid: 15976780].
64 Melloni C, James SK, White JA, et al. Safety and efficacy of adjusted-dose eptifibatide in patients with acute coronary syndromes and reduced renal function. Am Heart J. 2011;162(5):884-92 e1. [pmid: 22093205].
65 Wang TY, White JA, Tricoci P, et al. Upstream clopidogrel use and the efficacy and safety of early eptifibatide treatment in patients with acute coronary syndrome: an analysis from the Early Glycoprotein IIb/IIIa Inhibition in Patients with Non-ST-Segment Elevation Acute Coronary Syndrome (EARLY ACS) trial. Circulation. 2011;123(7):722-30. [pmid: 21300952].
66 Roe MT, Christenson RH, Ohman EM, et al. A randomized, placebo-controlled trial of early eptifibatide for non-ST-segment elevation acute coronary syndromes. Am Heart J. 2003;146(6):993-8. [pmid: 14660990].
67 van't Hof AW, de Vries ST, Dambrink JH, et al. A comparison of two invasive strategies in patients with non-ST elevation acute coronary syndromes: results of the Early or Late Intervention in unStable Angina (ELISA) pilot study. 2b/3a upstream therapy and acute coronary syndromes. Eur Heart J. 2003;24(15):1401-5. [pmid: 12909068].
68 Rasoul S, Ottervanger JP, de Boer MJ, et al. A comparison of dual vs. triple antiplatelet therapy in patients with non-ST-segment elevation acute coronary syndrome: results of the ELISA-2 trial. Eur Heart J. 2006;27(12):1401-7. [pmid: 16682384].
69 Islam MA, Blankenship JC, Balog C, et al. Effect of abciximab on angiographic complications during percutaneous coronary stenting in the Evaluation of Platelet IIb/IIIa Inhibition in Stenting Trial (EPISTENT). Am J Cardiol. 2002;90(9):916-21. [pmid: 12398954].
70 Anonymous. Randomised placebo-controlled and balloon-angioplasty-controlled trial to assess safety of coronary stenting with use of platelet glycoprotein-IIb/IIIa blockade. Lancet. 1998;352(9122):87-92. [pmid: 9672272].
71 Price DJ, Campbell PG, Sutton AG, et al. Selective use of abciximab in coronary stenting: overall outcomes can still be equivalent to those in the EPISTENT treatment group. Int J Cardiovasc Intervent. 2001;4(1):15-20. [pmid: 12431335].
72 Malhotra S, Bhargava VK, Grover A, et al. A randomized trial to compare the efficacy, safety, cost and platelet aggregation effects of enoxaparin and unfractionated heparin (the ESCAPEU trial). Int J Clin Pharmacol Ther. 2001;39(3):110-5. [pmid: 11396750].
73 Anonymous. Novel dosing regimen of eptifibatide in planned coronary stent implantation (ESPRIT): a randomised, placebo-controlled trial. The ESPRIT Investigators. Lancet. 2000;356(9247):2037-44. [pmid: 11145489].
74 Labinaz M, Madan M, O'Shea JO, et al. Comparison of one-year outcomes following coronary artery stenting in diabetic versus nondiabetic patients (from the Enhanced Suppression of the Platelet IIb/IIIa Receptor With Integrilin Therapy [ESPRIT] Trial). Am J Cardiol. 2002;90(6):585-90. [pmid: 12231081].
75 O'Shea JC, Hafley GE, Greenberg S, et al. Platelet glycoprotein IIb/IIIa integrin blockade with eptifibatide in coronary stent intervention: the ESPRIT trial: a randomized controlled trial. JAMA. 2001;285(19):2468-73. [pmid: 11368699].
76 Puma JA, Banko LT, Pieper KS, et al. Clinical characteristics predict benefits from eptifibatide therapy during coronary stenting: insights from the Enhanced Suppression of the Platelet IIb/IIIa Receptor With Integrilin Therapy (ESPRIT) trial. J Am Coll Cardiol. 2006;47(4):715-8. [pmid: 16487833].
77 Cohen M, Demers C, Gurfinkel EP, et al. A comparison of low-molecular-weight heparin with unfractionated heparin for unstable coronary artery disease. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q-Wave Coronary Events Study Group. N Engl J Med. 1997;337(7):447-52. [pmid: 9250846].
78 Brosa M, Rubio-Terres C, Farr I, et al. Cost-effectiveness analysis of enoxaparin versus unfractionated heparin in the secondary prevention of acute coronary syndrome. Pharmacoeconomics. 2002;20(14):979-87. [pmid: 12403638].
79 Cohen M, Blaber R, Demers C, et al. The Essence Trial: Efficacy and Safety of Subcutaneous Enoxaparin in Unstable Angina and Non-Q-Wave MI: A Double-Blind, Randomized, Parallel-Group, Multicenter Study Comparing Enoxaparin and Intravenous Unfractionated Heparin: Methods and Design. J Thromb Thrombolysis. 1997;4(2):271-4. [pmid: 10639269].
80 Cohen M, Demers C, Gurfinkel EP, et al. Low-molecular-weight heparins in non-ST-segment elevation ischemia: the ESSENCE trial. Efficacy and Safety of Subcutaneous Enoxaparin versus intravenous unfractionated heparin, in non-Q-wave Coronary Events. Am J Cardiol. 1998;82(5B):19L-24L. [pmid: 9737476].
81 Fox KA, Antman EM, Cohen M, et al. Comparison of enoxaparin versus unfractionated heparin in patients with unstable angina pectoris/non-ST-segment elevation acute myocardial infarction having subsequent percutaneous coronary intervention. Am J Cardiol. 2002;90(5):477-82. [pmid: 12208405].
82 Goodman SG, Cohen M, Bigonzi F, et al. Randomized trial of low molecular weight heparin (enoxaparin) versus unfractionated heparin for unstable coronary artery disease: one-year results of the ESSENCE Study. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q Wave Coronary Events. J Am Coll Cardiol. 2000;36(3):693-8. [pmid: 10987586].
83 Goodman SG, Bozovich GE, Tan M, et al. The greatest benefit of enoxaparin over unfractionated heparin in acute coronary syndromes is achieved in patients presenting with ST-segment changes: the Enoxaparin in Non-Q-Wave Coronary Events (ESSENCE) Electrocardiogram Core Laboratory Substudy. Am Heart J. 2006;151(4):791-7. [pmid: 16569535].
84 Mark DB, Cowper PA, Berkowitz SD, et al. Economic assessment of low-molecular-weight heparin (enoxaparin) versus unfractionated heparin in acute coronary syndrome patients: results from the ESSENCE randomized trial. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q wave Coronary Events [unstable angina or non-Q-wave myocardial infarction]. Circulation. 1998;97(17):1702-7. [pmid: 9591764].
85 Spinler SA, Inverso SM, Cohen M, et al. Safety and efficacy of unfractionated heparin versus enoxaparin in patients who are obese and patients with severe renal impairment: analysis from the ESSENCE and TIMI 11B studies. Am Heart J. 2003;146(1):33-41. [pmid: 12851605].
86 Gwon HC, Hahn JY, Park KW, et al. Six-month versus 12-month dual antiplatelet therapy after implantation of drug-eluting stents: the Efficacy of Xience/Promus Versus Cypher to Reduce Late Loss After Stenting (EXCELLENT) randomized, multicenter study. Circulation. 2012;125(3):505-13. [pmid: 22179532].
87 Valgimigli M, Campo G, Tebaldi M, et al. Randomized, double-blind comparison of effects of abiciximab bolus only vs. on-label regimen on ex vivo inhibition of platelet aggregation in responders to clopidogrel undergoing coronary stenting. J Thromb Haemost. 2010;8(9):1903-11. [pmid: 20586923].
88 Puymirat E, Aissaoui N, Coste P, et al. Comparison of efficacy and safety of a standard versus a loading dose of clopidogrel for acute myocardial infarction in patients >/= 75 years of age (from the FAST-MI registry). Am J Cardiol. 2011;108(6):755-9. [pmid: 21726837].
89 Simon T, Steg PG, Gilard M, et al. Clinical events as a function of proton pump inhibitor use, clopidogrel use, and cytochrome P450 2C19 genotype in a large nationwide cohort of acute myocardial infarction: results from the French Registry of Acute ST-Elevation and Non-ST-Elevation Myocardial Infarction (FAST-MI) registry. Circulation. 2011;123(5):474-82. [pmid: 21262992].
90 Steg PG, Jolly SS, Mehta SR, et al. Low-dose vs standard-dose unfractionated heparin for percutaneous coronary intervention in acute coronary syndromes treated with fondaparinux: the FUTURA/OASIS-8 randomized trial. JAMA. 2010;304(12):1339-49. [pmid: 20805623].
91 Steg PG, Mehta S, Jolly S, et al. Fondaparinux with UnfracTionated heparin dUring Revascularization in Acute coronary syndromes (FUTURA/OASIS 8): a randomized trial of intravenous unfractionated heparin during percutaneous coronary intervention in patients with non-ST-segment elevation acute coronary syndromes initially treated with fondaparinux. Am Heart J. 2010;160(6):1029-34. 34 e1. [pmid: 21146654].
92 Harjai KJ, Shenoy C, Orshaw P, et al. Low-dose versus high-dose aspirin after percutaneous coronary intervention: analysis from the guthrie health off-label StenT (GHOST) registry. J Interv Cardiol. 2011;24(4):307-14. [pmid: 21790788].
93 Harjai KJ, Shenoy C, Orshaw P, et al. Clinical outcomes in patients with the concomitant use of clopidogrel and proton pump inhibitors after percutaneous coronary intervention: an analysis from the Guthrie Health Off-Label Stent (GHOST) investigators. Circ Cardiovasc Interv. 2011;4(2):162-70. [pmid: 21386091].
94 Brieger D, Van de Werf F, Avezum A, et al. Interactions between heparins, glycoprotein IIb/IIIa antagonists, and coronary intervention. The Global Registry of Acute Coronary Events (GRACE). Am Heart J. 2007;153(6):960-9. [pmid: 17540196].
95 Dabbous OH, Anderson FA Jr., Gore JM, et al. Outcomes with the use of glycoprotein IIb/IIIa inhibitors in non-ST-segment elevation acute coronary syndromes. Heart. 2008;94(2):159-65. [pmid: 17575335].
96 Gore JM, Spencer FA, Goldberg RJ, et al. Use of heparins in Non-ST-elevation acute coronary syndromes. Am J Med. 2007;120(1):63-71. [pmid: 17208081].
97 Lim MJ, Spencer FA, Gore JM, et al. Impact of combined pharmacologic treatment with clopidogrel and a statin on outcomes of patients with non-ST-segment elevation acute coronary syndromes: perspectives from a large multinational registry. Eur Heart J. 2005;26(11):1063-9. [pmid: 15716281].
98 Nguyen MC, Lim YL, Walton A, et al. Combining warfarin and antiplatelet therapy after coronary stenting in the Global Registry of Acute Coronary Events: is it safe and effective to use just one antiplatelet agent?. Eur Heart J. 2007;28(14):1717-22. [pmid: 17562671].
99 Sibbald M, Yan AT, Huang W, et al. Association between smoking, outcomes, and early clopidogrel use in patients with acute coronary syndrome: insights from the Global Registry of Acute Coronary Events. Am Heart J. 2010;160(5):855-61. [pmid: 21095272].
100 Price MJ, Berger PB, Teirstein PS, et al. Standard- vs high-dose clopidogrel based on platelet function testing after percutaneous coronary intervention: the GRAVITAS randomized trial. JAMA. 2011;305(11):1097-105. [pmid: 21406646].
101 Quinn MJ, Aronow HD, Califf RM, et al. Aspirin dose and six-month outcome after an acute coronary syndrome. J Am Coll Cardiol. 2004;43(6):972-8. [pmid: 15028352].
102 Simoons ML. Effect of glycoprotein IIb/IIIa receptor blocker abciximab on outcome in patients with acute coronary syndromes without early coronary revascularisation: the GUSTO IV-ACS randomised trial. Lancet. 2001;357(9272):1915-24. [pmid: 11425411].
103 Lenderink T, Boersma E, Ruzyllo W, et al. Bleeding events with abciximab in acute coronary syndromes without early revascularization: An analysis of GUSTO IV-ACS. Am Heart J. 2004;147(5):865-73. [pmid: 15131544].
104 Ottervanger JP, Armstrong P, Barnathan ES, et al. Long-term results after the glycoprotein IIb/IIIa inhibitor abciximab in unstable angina: one-year survival in the GUSTO IV-ACS (Global Use of Strategies To Open Occluded Coronary Arteries IV--Acute Coronary Syndrome) Trial. Circulation. 2003;107(3):437-42. [pmid: 12551868].
105 Goodman SG, Fitchett D, Armstrong PW, et al. Randomized evaluation of the safety and efficacy of enoxaparin versus unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndromes receiving the glycoprotein IIb/IIIa inhibitor eptifibatide. Circulation. 2003;107(2):238-44. [pmid: 12538422].
106 Fitchett DH, Langer A, Armstrong PW, et al. Randomized evaluation of the efficacy of enoxaparin versus unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndromes receiving the glycoprotein IIb/IIIa inhibitor eptifibatide. Long-term results of the Integrilin and Enoxaparin Randomized Assessment of Acute Coronary Syndrome Treatment (INTERACT) trial. Am Heart J. 2006;151(2):373-9. [pmid: 16442903].
107 Goodman S. Enoxaparin and glycoprotein IIb/IIIa inhibition in non-ST-elevation acute coronary syndrome: insights from the INTERACT trial. Am Heart J. 2005;149(4 Suppl):S73-80. [pmid: 16124951].
108 Kastrati A, Mehilli J, Neumann FJ, et al. Abciximab in patients with acute coronary syndromes undergoing percutaneous coronary intervention after clopidogrel pretreatment: the ISAR-REACT 2 randomized trial. JAMA. 2006;295(13):1531-8. [pmid: 16533938].
109 Iijima R, Ndrepepa G, Mehilli J, et al. Effect of abciximab on clinical and angiographic restenosis in patients with non-ST-segment elevation acute coronary syndromes. Am J Cardiol. 2008;101(9):1226-31. [pmid: 18435948].
110 Iijima R, Ndrepepa G, Mehilli J, et al. Troponin level and efficacy of abciximab in patients with acute coronary syndromes undergoing early intervention after clopidogrel pretreatment. Clin Res Cardiol. 2008;97(3):160-8. [pmid: 18046527].
111 Mehilli J, Ndrepepa G, Kastrati A, et al. Sex and effect of abciximab in patients with acute coronary syndromes treated with percutaneous coronary interventions: results from Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment 2 trial. Am Heart J. 2007;154(1):158 e1-7. [pmid: 17584569].
112 Ndrepepa G, Kastrati A, Mehilli J, et al. One-year clinical outcomes with abciximab vs. placebo in patients with non-ST-segment elevation acute coronary syndromes undergoing percutaneous coronary intervention after pre-treatment with clopidogrel: results of the ISAR-REACT 2 randomized trial. Eur Heart J. 2008;29(4):455-61. [pmid: 18158289].
113 Ndrepepa G, Kastrati A, Mehilli J, et al. Age-dependent effect of abciximab in patients with acute coronary syndromes treated with percutaneous coronary interventions. Circulation. 2006;114(19):2040-6. [pmid: 17060377].
114 Kastrati A, Neumann FJ, Mehilli J, et al. Bivalirudin versus unfractionated heparin during percutaneous coronary intervention. N Engl J Med. 2008;359(7):688-96. [pmid: 18703471].
115 Iijima R, Ndrepepa G, Mehilli J, et al. Profile of bleeding and ischaemic complications with bivalirudin and unfractionated heparin after percutaneous coronary intervention. Eur Heart J. 2009;30(3):290-6. [pmid: 19147609].
116 Schulz S, Mehilli J, Neumann FJ, et al. ISAR-REACT 3A: a study of reduced dose of unfractionated heparin in biomarker negative patients undergoing percutaneous coronary intervention. Eur Heart J. 2010;31(20):2482-91. [pmid: 20805113].
117 Schulz S, Mehilli J, Ndrepepa G, et al. Bivalirudin vs. unfractionated heparin during percutaneous coronary interventions in patients with stable and unstable angina pectoris: 1-year results of the ISAR-REACT 3 trial. Eur Heart J. 2010;31(5):582-7. [pmid: 20150324].
118 Kastrati A, Neumann FJ, Schulz S, et al. Abciximab and heparin versus bivalirudin for non-ST-elevation myocardial infarction. N Engl J Med. 2011;365(21):1980-9. [pmid: 22077909].
119 Li YJ, Rha SW, Chen KY, et al. Low molecular weight heparin versus unfractionated heparin in patients with acute non-ST-segment elevation myocardial infarction undergoing percutaneous coronary intervention with drug-eluting stents. J Cardiol. 2012;(59):22-9. [pmid: 22079855].
120 Chitose T, Hokimoto S, Oshima S, et al. Clinical Outcomes Following Coronary Stenting in Japanese Patients Treated With and Without Proton Pump Inhibitor. Circ J. 2011. [pmid: 22130313].
121 Kovar D, Canto JG, Rogers WJ. Safety and effectiveness of combined low molecular weight heparin and glycoprotein IIb/IIIa inhibitors. Am J Cardiol. 2002;90(9):911-5. [pmid: 12398953].
122 Peterson ED, Pollack CV Jr., Roe MT, et al. Early use of glycoprotein IIb/IIIa inhibitors in non-ST-elevation acute myocardial infarction: observations from the National Registry of Myocardial Infarction 4. J Am Coll Cardiol. 2003;42(1):45-53. [pmid: 12849658].
123 Yusuf S, Mehta SR, Chrolavicius S, et al. Comparison of fondaparinux and enoxaparin in acute coronary syndromes. N Engl J Med. 2006;354(14):1464-76. [pmid: 16537663].
124 Budaj A, Eikelboom JW, Mehta SR, et al. Improving clinical outcomes by reducing bleeding in patients with non-ST-elevation acute coronary syndromes. Eur Heart J. 2009;30(6):655-61. [pmid: 18713759].
125 Fox KA, Bassand JP, Mehta SR, et al. Influence of renal function on the efficacy and safety of fondaparinux relative to enoxaparin in non ST-segment elevation acute coronary syndromes. Ann Intern Med. 2007;147(5):304-10. [pmid: 17785485].
126 Jolly SS, Faxon DP, Fox KA, et al. Efficacy and safety of fondaparinux versus enoxaparin in patients with acute coronary syndromes treated with glycoprotein IIb/IIIa inhibitors or thienopyridines: results from the OASIS 5 (Fifth Organization to Assess Strategies in Ischemic Syndromes) trial. J Am Coll Cardiol. 2009;54(5):468-76. [pmid: 19628124].
127 Joyner CD, Peters RJ, Afzal R, et al. Fondaparinux compared to enoxaparin in patients with acute coronary syndromes without ST-segment elevation: outcomes and treatment effect across different levels of risk. Am Heart J. 2009;157(3):502-8. [pmid: 19249421].
128 Mehta SR, Yusuf S, Granger CB, et al. Design and rationale of the MICHELANGELO Organization to Assess Strategies in Acute Ischemic Syndromes (OASIS)-5 trial program evaluating fondaparinux, a synthetic factor Xa inhibitor, in patients with non-ST-segment elevation acute coronary syndromes. Am Heart J. 2005;150(6):1107. [pmid: 16338245].
129 Mehta SR, Boden WE, Eikelboom JW, et al. Antithrombotic therapy with fondaparinux in relation to interventional management strategy in patients with ST- and non-ST-segment elevation acute coronary syndromes: an individual patient-level combined analysis of the Fifth and Sixth Organization to Assess Strategies in Ischemic Syndromes (OASIS 5 and 6) randomized trials. Circulation. 2008;118(20):2038-46. [pmid: 18955665].
130 Mehta SR, Granger CB, Eikelboom JW, et al. Efficacy and safety of fondaparinux versus enoxaparin in patients with acute coronary syndromes undergoing percutaneous coronary intervention: results from the OASIS-5 trial. J Am Coll Cardiol. 2007;50(18):1742-51. [pmid: 17964037].
131 Sculpher MJ, Lozano-Ortega G, Sambrook J, et al. Fondaparinux versus Enoxaparin in non-ST-elevation acute coronary syndromes: short-term cost and long-term cost-effectiveness using data from the Fifth Organization to Assess Strategies in Acute Ischemic Syndromes Investigators (OASIS-5) trial. Am Heart J. 2009;157(5):845-52. [pmid: 19376310].
132 So D, Cook EF, Le May M, et al. Association of aspirin dosage to clinical outcomes after percutaneous coronary intervention: observations from the Ottawa Heart Institute PCI Registry. J Invasive Cardiol. 2009;21(3):121-7. [pmid: 19258643].
133 Lopes RD, Starr A, Pieper CF, et al. Warfarin use and outcomes in patients with atrial fibrillation complicating acute coronary syndromes. Am J Med. 2010;123(2):134-40. [pmid: 20103022].
134 Wallentin L, Becker RC, Budaj A, et al. Ticagrelor versus clopidogrel in patients with acute coronary syndromes. N Engl J Med. 2009;361(11):1045-57. [pmid: 19717846].
135 James SK, Roe MT, Cannon CP, et al. Ticagrelor versus clopidogrel in patients with acute coronary syndromes intended for non-invasive management: substudy from prospective randomised PLATelet inhibition and patient Outcomes (PLATO) trial. BMJ. 2011;342:d3527. [pmid: 21685437].
136 Cannon CP, Harrington RA, James S, et al. Comparison of ticagrelor with clopidogrel in patients with a planned invasive strategy for acute coronary syndromes (PLATO): a randomised double-blind study. Lancet. 2010;375(9711):283-93. [pmid: 20079528].
137 Becker RC, Bassand JP, Budaj A, et al. Bleeding complications with the P2Y12 receptor antagonists clopidogrel and ticagrelor in the PLATelet inhibition and patient Outcomes (PLATO) trial. Eur Heart J. 2011;32(23):2933-44. [pmid: 22090660].
138 Goodman SG, Clare R, Pieper KS, et al. Association of Proton Pump Inhibitor Use on Cardiovascular Outcomes with Clopidogrel and Ticagrelor: Insights from PLATO. Circulation. 2012. [pmid: 22261200].
139 Held C, Asenblad N, Bassand JP, et al. Ticagrelor versus clopidogrel in patients with acute coronary syndromes undergoing coronary artery bypass surgery: results from the PLATO (Platelet Inhibition and Patient Outcomes) trial. J Am Coll Cardiol. 2011;57(6):672-84. [pmid: 21194870].
140 Husted S, James S, Becker RC, et al. Ticagrelor versus clopidogrel in elderly patients with acute coronary syndromes: a substudy from the Prospective Randomized PLATelet Inhibition and Patient Outcomes (PLATO) trial. Circ Cardiovasc Qual Outcomes. 2012;5(5):680-8. [pmid: 22991347].
141 James S, Budaj A, Aylward P, et al. Ticagrelor versus clopidogrel in acute coronary syndromes in relation to renal function: results from the Platelet Inhibition and Patient Outcomes (PLATO) trial. Circulation. 2010;122(11):1056-67. [pmid: 20805430].
142 James S, Angiolillo DJ, Cornel JH, et al. Ticagrelor vs. clopidogrel in patients with acute coronary syndromes and diabetes: a substudy from the PLATelet inhibition and patient Outcomes (PLATO) trial. Eur Heart J. 2010;31(24):3006-16. [pmid: 20802246].
143 James S, Akerblom A, Cannon CP, et al. Comparison of ticagrelor, the first reversible oral P2Y(12) receptor antagonist, with clopidogrel in patients with acute coronary syndromes: Rationale, design, and baseline characteristics of the PLATelet inhibition and patient Outcomes (PLATO) trial. Am Heart J. 2009;157(4):599-605. [pmid: 19332184].
144 Mahaffey KW, Wojdyla DM, Carroll K, et al. Ticagrelor compared with clopidogrel by geographic region in the Platelet Inhibition and Patient Outcomes (PLATO) trial. Circulation. 2011;124(5):544-54. [pmid: 21709065].
145 Storey RF, Becker RC, Harrington RA, et al. Characterization of dyspnoea in PLATO study patients treated with ticagrelor or clopidogrel and its association with clinical outcomes. Eur Heart J. 2011;32(23):2945-53. [pmid: 21804104].
146 Yong G, Rankin J, Ferguson L, et al. Randomized trial comparing 600- with 300-mg loading dose of clopidogrel in patients with non-ST elevation acute coronary syndrome undergoing percutaneous coronary intervention: results of the Platelet Responsiveness to Aspirin and Clopidogrel and Troponin Increment after Coronary intervention in Acute coronary Lesions (PRACTICAL) Trial. Am Heart J. 2009;157(1):60 e1-9. [pmid: 19081397].
147 Durand E, Hamm CW, Macaya CM, et al. A randomised controlled trial of upstream administration of eptifibatide in patients presenting non-ST segment elevation acute coronary syndrome treated with an invasive strategy. EuroIntervention. 2007;3(2):228-34. [pmid: 19758942].
148 Anonymous. A comparison of aspirin plus tirofiban with aspirin plus heparin for unstable angina. Platelet Receptor Inhibition in Ischemic Syndrome Management (PRISM) Study Investigators. N Engl J Med. 1998;338(21):1498-505. [pmid: 9599104].
149 Anonymous. Inhibition of the platelet glycoprotein IIb/IIIa receptor with tirofiban in unstable angina and non-Q-wave myocardial infarction. Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) Study Investigators. N Engl J Med. 1998;338(21):1488-97. [pmid: 9599103].
150 Huynh T, Theroux P, Snapinn S, et al. Effect of platelet glycoprotein IIb/IIIa receptor blockade with tirofiban on adverse cardiac events in women with unstable angina/non-ST-elevation myocardial infarction (PRISM-PLUS Study). Am Heart J. 2003;146(4):668-73. [pmid: 14564321].
151 Huynh T, Piazza N, DiBattiste PM, et al. Analysis of bleeding complications associated with glycoprotein IIb/IIIa receptors blockade in patients with high-risk acute coronary syndromes: insights from the PRISM-PLUS study. Int J Cardiol. 2005;100(1):73-8. [pmid: 15820288].
152 Januzzi JL, Hahn SS, Chae CU, et al. Effects of tirofiban plus heparin versus heparin alone on troponin I levels in patients with acute coronary syndromes. Am J Cardiol. 2000;86(7):713-7. [pmid: 11018188].
153 Januzzi JL, Chae CU, Sabatine MS, et al. Elevation in serum troponin I predicts the benefit of tirofiban. J Thromb Thrombolysis. 2001;11(3):211-5. [pmid: 11577259].
154 Januzzi JL Jr., Snapinn SM, DiBattiste PM, et al. Benefits and safety of tirofiban among acute coronary syndrome patients with mild to moderate renal insufficiency: results from the Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) trial. Circulation. 2002;105(20):2361-6. [pmid: 12021221].
155 Morrow DA, Sabatine MS, Antman EM, et al. Usefulness of tirofiban among patients treated without percutaneous coronary intervention (TIMI high risk patients in PRISM-PLUS). Am J Cardiol. 2004;94(6):774-6. [pmid: 15374786].
156 Mozes G, Sullivan TM, Torres-Russotto DR, et al. Carotid endarterectomy in SAPPHIRE-eligible high-risk patients: implications for selecting patients for carotid angioplasty and stenting. J Vasc Surg. 2004;39(5):958-65. discussion 65-6. [pmid: 15111844].
157 Theroux P, Alexander J Jr., Pharand C, et al. Glycoprotein IIb/IIIa receptor blockade improves outcomes in diabetic patients presenting with unstable angina/non-ST-elevation myocardial infarction: results from the Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) study. Circulation. 2000;102(20):2466-72. [pmid: 11076818].
158 Valgimigli M, Campo G, Monti M, et al. Short- Versus Long-term Duration of Dual Antiplatelet Therapy After Coronary Stenting: A Randomized Multicentre Trial. Circulation. 2012. [pmid: 22438530].
159 Gibson CM, Morrow DA, Murphy SA, et al. A randomized trial to evaluate the relative protection against post-percutaneous coronary intervention microvascular dysfunction, ischemia, and inflammation among antiplatelet and antithrombotic agents: the PROTECT-TIMI-30 trial. J Am Coll Cardiol. 2006;47(12):2364-73. [pmid: 16781360].
160 Anonymous. Inhibition of platelet glycoprotein IIb/IIIa with eptifibatide in patients with acute coronary syndromes. The PURSUIT Trial Investigators. Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy. N Engl J Med. 1998;339(7):436-43. [pmid: 9705684].
161 Brown R, Armstrong P. Cost effectiveness in Canada of eptifibatide treatment for acute coronary syndrome patients using PURSUIT subgroup analysis. Can J Cardiol. 2003;19(2):161-6. [pmid: 12601441].
162 Chang WC, Harrington RA, Simoons ML, et al. Does eptifibatide confer a greater benefit to patients with unstable angina than with non-ST segment elevation myocardial infarction? Insights from the PURSUIT Trial. Eur Heart J. 2002;23(14):1102-11. [pmid: 12090748].
163 Harrington RA. Design and methodology of the PURSUIT trial: evaluating eptifibatide for acute ischemic coronary syndromes. Platelet Glycoprotein IIb-IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy. Am J Cardiol. 1997;80(4A):34B-8B. [pmid: 9291244].
164 Hasdai D, Holmes DR Jr., Criger DA, et al. Age and outcome after acute coronary syndromes without persistent ST-segment elevation. Am Heart J. 2000;139(5):858-66. [pmid: 10783220].
165 Kleiman NS, Lincoff AM, Flaker GC, et al. Early percutaneous coronary intervention, platelet inhibition with eptifibatide, and clinical outcomes in patients with acute coronary syndromes. PURSUIT Investigators. Circulation. 2000;101(7):751-7. [pmid: 10683348].
166 Labinaz M, Kaul P, Harrington RA, et al. Six-month outcomes of percutaneous coronary balloon angioplasty in acute coronary syndromes: Results from the PURSUIT trial. Can J Cardiol. 2004;20(8):773-8. [pmid: 15229770].
167 Lincoff AM, Harrington RA, Califf RM, et al. Management of patients with acute coronary syndromes in the United States by platelet glycoprotein IIb/IIIa inhibition. Insights from the platelet glycoprotein IIb/IIIa in unstable angina: receptor suppression using integrilin therapy (PURSUIT) trial. Circulation. 2000;102(10):1093-100. [pmid: 10973836].
168 Ronner E, Boersma E, Akkerhuis KM, et al. Patients with acute coronary syndromes without persistent ST elevation undergoing percutaneous coronary intervention benefit most from early intervention with protection by a glycoprotein IIb/IIIa receptor blocker. Eur Heart J. 2002;23(3):239-46. [pmid: 11792139].
169 Srichai MB, Jaber WA, Prior DL, et al. Evaluating the benefits of glycoprotein IIb/IIIa inhibitors in heart failure at baseline in acute coronary syndromes. Am Heart J. 2004;147(1):84-90. [pmid: 14691424].
170 Bernardi V, Szarfer J, Summay G, et al. Long-term versus short-term clopidogrel therapy in patients undergoing coronary stenting (from the Randomized Argentine Clopidogrel Stent [RACS] trial). Am J Cardiol. 2007;99(3):349-52. [pmid: 17261396].
171 Rajagopal V, Lincoff AM, Cohen DJ, et al. Outcomes of patients with acute coronary syndromes who are treated with bivalirudin during percutaneous coronary intervention: an analysis from the Randomized Evaluation in PCI Linking Angiomax to Reduced Clinical Events (REPLACE-2) trial. Am Heart J. 2006;152(1):149-54. [pmid: 16824845].
172 Stenestrand U, Lindback J, Wallentin L. Anticoagulation therapy in atrial fibrillation in combination with acute myocardial infarction influences long-term outcome: a prospective cohort study from the Register of Information and Knowledge About Swedish Heart Intensive Care Admissions (RIKS-HIA). Circulation. 2005;112(21):3225-31. [pmid: 16301355].
173 De Servi S, Mariani M, Vandoni P, et al. Use of glycoprotein IIb/IIIa inhibitors in invasively-treated patients with non-ST elevation acute coronary syndrome. J Cardiovasc Med (Hagerstown). 2006;7(3):159-65. [pmid: 16645379].
174 Schiariti M, Saladini A, Cuturello D, et al. Long-term efficacy of high-dose tirofiban versus double-bolus eptifibatide in patients undergoing percutaneous coronary intervention. J Cardiovasc Med (Hagerstown). 2011;12(1):29-36. [pmid: 20639765].
175 Schiariti M, Saladini A, Missiroli B, et al. Safety of downstream high-dose tirofiban bolus among 1578 patients undergoing percutaneous coronary intervention: the Sant'ANna TIrofiban Safety study. J Cardiovasc Med (Hagerstown). 2010;11(4):250-9. [pmid: 19952776].
176 Ferguson JJ, Califf RM, Antman EM, et al. Enoxaparin vs unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndromes managed with an intended early invasive strategy: primary results of the SYNERGY randomized trial. JAMA. 2004;292(1):45-54. [pmid: 15238590].
177 Anonymous. The SYNERGY trial: study design and rationale. Am Heart J. 2002;143(6):952-60. [pmid: 12075248].
178 Chew DP, Huang Z, Pieper KS, et al. Patients with non-ST-elevation acute coronary syndromes undergoing coronary artery bypass grafting in the modern era of antithrombotic therapy. Am Heart J. 2008;155(2):239-44. [pmid: 18215592].
179 Cohen M, Mahaffey KW, Pieper K, et al. A subgroup analysis of the impact of prerandomization antithrombin therapy on outcomes in the SYNERGY trial: enoxaparin versus unfractionated heparin in non-ST-segment elevation acute coronary syndromes. J Am Coll Cardiol. 2006;48(7):1346-54. [pmid: 17010793].
180 Cohen M, Levine GN, Pieper KS, et al. Enoxaparin 0.3 mg/kg IV supplement for patients transitioning to PCI after subcutaneous enoxaparin therapy for NSTE ACS: a subgroup analysis from the SYNERGY trial. Catheter Cardiovasc Interv. 2010;75(6):928-35. [pmid: 20432399].
181 Ferguson JJ. Antithrombin therapy, antiplatelet therapy and percutaneous coronary intervention: Rationale and design of the SYNERGY trial. European Heart Journal, Supplement. 2002;4(5):E2-E9.
182 Lopes RD, Alexander KP, Marcucci G, et al. Outcomes in elderly patients with acute coronary syndromes randomized to enoxaparin vs. unfractionated heparin: results from the SYNERGY trial. Eur Heart J. 2008;29(15):1827-33. [pmid: 18519426].
183 Petersen JL, Mahaffey KW, Becker RC, et al. Coordinated series of studies to evaluate characteristics and mechanisms of acute coronary syndromes in high-risk patients randomly assigned to enoxaparin or unfractionated heparin: design and rationale of the SYNERGY Library. Am Heart J. 2004;148(2):269-76. [pmid: 15308996].
184 White HD, Kleiman NS, Mahaffey KW, et al. Efficacy and safety of enoxaparin compared with unfractionated heparin in high-risk patients with non-ST-segment elevation acute coronary syndrome undergoing percutaneous coronary intervention in the Superior Yield of the New Strategy of Enoxaparin, Revascularization and Glycoprotein IIb/IIIa Inhibitors (SYNERGY) trial. Am Heart J. 2006;152(6):1042-50. [pmid: 17161049].
185 Cheng CI, Chen CP, Kuan PL, et al. The causes and outcomes of inadequate implementation of existing guidelines for antiplatelet treatment in patients with acute coronary syndrome: the experience from Taiwan Acute Coronary Syndrome Descriptive Registry (T-ACCORD Registry). Clin Cardiol. 2010;33(6):E40-8. [pmid: 20552592].
186 Topol EJ, Moliterno DJ, Herrmann HC, et al. Comparison of two platelet glycoprotein IIb/IIIa inhibitors, tirofiban and abciximab, for the prevention of ischemic events with percutaneous coronary revascularization. N Engl J Med. 2001;344(25):1888-94. [pmid: 11419425].
187 Berger PB, Best PJ, Topol EJ, et al. The relation of renal function to ischemic and bleeding outcomes with 2 different glycoprotein IIb/IIIa inhibitors: the do Tirofiban and ReoPro Give Similar Efficacy Outcome (TARGET) trial. Am Heart J. 2005;149(5):869-75. [pmid: 15894970].
188 Chan AW, Moliterno DJ, Berger PB, et al. Triple antiplatelet therapy during percutaneous coronary intervention is associated with improved outcomes including one-year survival: results from the Do Tirofiban and ReoProGive Similar Efficacy Outcome Trial (TARGET). J Am Coll Cardiol. 2003;42(7):1188-95. [pmid: 14522478].
189 Merlini PA, Rossi M, Menozzi A, et al. Thrombocytopenia caused by abciximab or tirofiban and its association with clinical outcome in patients undergoing coronary stenting. Circulation. 2004;109(18):2203-6. [pmid: 15117843].
190 Moliterno DJ, Topol EJ. A direct comparison of tirofiban and abciximab during percutaneous coronary revascularization and stent placement: rationale and design of the TARGET study. Am Heart J. 2000;140(5):722-6. [pmid: 11054616].
191 Mukherjee D, Topol EJ, Bertrand ME, et al. Mortality at 1 year for the direct comparison of tirofiban and abciximab during percutaneous coronary revascularization: do tirofiban and ReoPro give similar efficacy outcomes at trial 1-year follow-up. Eur Heart J. 2005;26(23):2524-8. [pmid: 16107485].
192 Roffi M, Moliterno DJ, Meier B, et al. Impact of different platelet glycoprotein IIb/IIIa receptor inhibitors among diabetic patients undergoing percutaneous coronary intervention: : Do Tirofiban and ReoPro Give Similar Efficacy Outcomes Trial (TARGET) 1-year follow-up. Circulation. 2002;105(23):2730-6. [pmid: 12057986].
193 Stone GW, Moliterno DJ, Bertrand M, et al. Impact of clinical syndrome acuity on the differential response to 2 glycoprotein IIb/IIIa inhibitors in patients undergoing coronary stenting: the TARGET Trial. Circulation. 2002;105(20):2347-54. [pmid: 12021219].
194 Moliterno DJ. A randomized two-by-two comparison of high-dose bolus tirofiban versus abciximab and unfractionated heparin versus bivalirudin during percutaneous coronary revascularization and stent placement: the tirofiban evaluation of novel dosing versus abciximab with clopidogrel and inhibition of thrombin (TENACITY) study trial. Catheter Cardiovasc Interv. 2011;77(7):1001-9. [pmid: 21598351].
195 Antman EM, McCabe CH, Braunwald E. Bivalirudin as a replacement for unfractionated heparin in unstable angina/non-ST-elevation myocardial infarction: observations from the TIMI 8 trial. The Thrombolysis in Myocardial Infarction. Am Heart J. 2002;143(2):229-34. [pmid: 11835024].
196 Antman EM, McCabe CH, Gurfinkel EP, et al. Enoxaparin prevents death and cardiac ischemic events in unstable angina/non-Q-wave myocardial infarction. Results of the thrombolysis in myocardial infarction (TIMI) 11B trial. Circulation. 1999;100(15):1593-601. [pmid: 10517729].
197 Antman EM. TIMI 11B. Enoxaparin versus unfractionated heparin for unstable angina or non-Q-wave myocardial infarction: a double-blind, placebo-controlled, parallel-group, multicenter trial. Rationale, study design, and methods. Thrombolysis in Myocardial Infarction (TIMI) 11B Trial Investigators. Am Heart J. 1998;135(6 Pt 3 Su):S353-60. [pmid: 9628449].
198 Roe M, Armstrong P, Fox K. Prasugrel versus Clopidogrel for Acute Coronary Syndromes without Revascularization. NEJM. 2012. e-pub Aug. 26, 2012. 2012.
199 Chin CT, Roe MT, Fox KA, et al. Study design and rationale of a comparison of prasugrel and clopidogrel in medically managed patients with unstable angina/non-ST-segment elevation myocardial infarction: the TaRgeted platelet Inhibition to cLarify the Optimal strateGy to medicallY manage Acute Coronary Syndromes (TRILOGY ACS) trial. Am Heart J. 2010;160(1):16-22 e1. [pmid: 20598967].
200 Wiviott SD, Braunwald E, McCabe CH, et al. Prasugrel versus clopidogrel in patients with acute coronary syndromes. N Engl J Med. 2007;357(20):2001-15. [pmid: 17982182].
201 Antman EM, Wiviott SD, Murphy SA, et al. Early and late benefits of prasugrel in patients with acute coronary syndromes undergoing percutaneous coronary intervention: a TRITON-TIMI 38 (TRial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet InhibitioN with Prasugrel-Thrombolysis In Myocardial Infarction) analysis. J Am Coll Cardiol. 2008;51(21):2028-33. [pmid: 18498956].
202 Morrow DA, Wiviott SD, White HD, et al. Effect of the novel thienopyridine prasugrel compared with clopidogrel on spontaneous and procedural myocardial infarction in the Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition with Prasugrel-Thrombolysis in Myocardial Infarction 38: an application of the classification system from the universal definition of myocardial infarction. Circulation. 2009;119(21):2758-64. [pmid: 19451347].
203 Murphy SA, Antman EM, Wiviott SD, et al. Reduction in recurrent cardiovascular events with prasugrel compared with clopidogrel in patients with acute coronary syndromes from the TRITON-TIMI 38 trial. Eur Heart J. 2008;29(20):2473-9. [pmid: 18682445].
204 O'Donoghue M, Antman EM, Braunwald E, et al. The efficacy and safety of prasugrel with and without a glycoprotein IIb/IIIa inhibitor in patients with acute coronary syndromes undergoing percutaneous intervention: a TRITON-TIMI 38 (Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition With Prasugrel-Thrombolysis In Myocardial Infarction 38) analysis. J Am Coll Cardiol. 2009;54(8):678-85. [pmid: 19679245].
205 O'Donoghue ML, Braunwald E, Antman EM, et al. Pharmacodynamic effect and clinical efficacy of clopidogrel and prasugrel with or without a proton-pump inhibitor: an analysis of two randomised trials. Lancet. 2009;374(9694):989-97. [pmid: 19726078].
206 Pride YB, Wiviott SD, Buros JL, et al. Effect of prasugrel versus clopidogrel on outcomes among patients with acute coronary syndrome undergoing percutaneous coronary intervention without stent implantation: a TRial to assess Improvement in Therapeutic Outcomes by optimizing platelet inhibitioN with prasugrel (TRITON)-Thrombolysis in Myocardial Infarction (TIMI) 38 substudy. Am Heart J. 2009;158(3):e21-6. [pmid: 19699846].
207 Wiviott SD, Antman EM, Gibson CM, et al. Evaluation of prasugrel compared with clopidogrel in patients with acute coronary syndromes: design and rationale for the TRial to assess Improvement in Therapeutic Outcomes by optimizing platelet InhibitioN with prasugrel Thrombolysis In Myocardial Infarction 38 (TRITON-TIMI 38). Am Heart J. 2006;152(4):627-35. [pmid: 16996826].
208 Wiviott SD, Braunwald E, Angiolillo DJ, et al. Greater clinical benefit of more intensive oral antiplatelet therapy with prasugrel in patients with diabetes mellitus in the trial to assess improvement in therapeutic outcomes by optimizing platelet inhibition with prasugrel-Thrombolysis in Myocardial Infarction 38. Circulation. 2008;118(16):1626-36. [pmid: 18757948].
209 Wiviott SD, Braunwald E, McCabe CH, et al. Intensive oral antiplatelet therapy for reduction of ischaemic events including stent thrombosis in patients with acute coronary syndromes treated with percutaneous coronary intervention and stenting in the TRITON-TIMI 38 trial: a subanalysis of a randomised trial. Lancet. 2008;371(9621):1353-63. [pmid: 18377975].
210 Wiviott SD, Desai N, Murphy SA, et al. Efficacy and safety of intensive antiplatelet therapy with prasugrel from TRITON-TIMI 38 in a core clinical cohort defined by worldwide regulatory agencies. Am J Cardiol. 2011;108(7):905-11. [pmid: 21816379].
211 Bertel O, Ramsay D, Wettstein T, et al. Intravenous enoxaparin versus unfractionated heparin in unselected patients undergoing percutaneous coronary interventions: the Zurich enoxaparin versus unfractionated heparin in PCI study (ZEUS). EuroIntervention. 2010;6(3):407-12. [pmid: 20884422].
212 Abuzahra M, Pillai M, Caldera A, et al. Comparison of higher clopidogrel loading and maintenance dose to standard dose on platelet function and outcomes after percutaneous coronary intervention using drug-eluting stents. Am J Cardiol. 2008;102(4):401-3. [pmid: 18678295].
213 Ajani AE, Waksman R, Gruberg L, et al. Acute procedural complications and in-hospital events after percutaneous coronary interventions: eptifibatide versus abciximab. Cardiovasc Radiat Med. 2003;4(1):12-7. [pmid: 12892767].
214 Angkasuwapala K, Ratanasumawong K, Ngarmukos T, et al. Effect of un-fractionated heparin and low molecular weight heparin on hospital mortality in patients with non ST elevation acute coronary syndrome (ACS). J Med Assoc Thai. Suppl 1. 2007;90:109-14. [pmid: 18431893].
215 Banerjee S, Weideman RA, Weideman MW, et al. Effect of concomitant use of clopidogrel and proton pump inhibitors after percutaneous coronary intervention. Am J Cardiol. 2011;107(6):871-8. [pmid: 21247527].
216 Barada K, Karrowni W, Abdallah M, et al. Upper gastrointestinal bleeding in patients with acute coronary syndromes: clinical predictors and prophylactic role of proton pump inhibitors. J Clin Gastroenterol. 2008;42(4):368-72. [pmid: 18277903].
217 Bauer T, Mollmann H, Weidinger F, et al. Use of platelet glycoprotein IIb/IIIa inhibitors in diabetics undergoing PCI for non-ST-segment elevation acute coronary syndromes: impact of clinical status and procedural characteristics. Clin Res Cardiol. 2010;99(6):375-83. [pmid: 20186546].
218 Berger JS, Slater JN, Sherman W, et al. Impact of platelet glycoprotein IIb/IIIa inhibitor therapy on in-hospital outcomes and long-term survival following percutaneous coronary rotational atherectomy. J Thromb Thrombolysis. 2005;19(1):47-54. [pmid: 15976967].
219 Berglund U, Richter A. Clopidogrel treatment before percutaneous coronary intervention reduces adverse cardiac events. J Invasive Cardiol. 2002;14(5):243-6. [pmid: 11983944].
220 Bhattacharya R, Pani A, Dutta D, et al. Randomised controlled trial evaluating the role of tirofiban in high-risk non-ST elevation acute coronary syndromes: an East Indian perspective. Singapore Med J. 2010;51(7):558-64. [pmid: 20730395].
221 Bhurke SM, Martin BC, Li C, et al. Effect of the Clopidogrel-Proton Pump Inhibitor Drug Interaction on Adverse Cardiovascular Events in Patients with Acute Coronary Syndrome. Pharmacotherapy. 2012. [pmid: 22744772].
222 Bonde L, Sorensen R, Fosbol EL, et al. Increased mortality associated with low use of clopidogrel in patients with heart failure and acute myocardial infarction not undergoing percutaneous coronary intervention: a nationwide study. J Am Coll Cardiol. 2010;55(13):1300-7. [pmid: 20338489].
223 Bonello L, Lemesle G, De Labriolle A, et al. Impact of a 600-mg loading dose of clopidogrel on 30-day outcome in unselected patients undergoing percutaneous coronary intervention. Am J Cardiol. 2008;102(10):1318-22. [pmid: 18993148].
224 Brener SJ, Ellis SG, Schneider J, et al. Abciximab-facilitated percutaneous coronary intervention and long-term survival--a prospective single-center registry. Eur Heart J. 2003;24(7):630-8. [pmid: 12657221].
225 Buresly K, Eisenberg MJ, Zhang X, et al. Bleeding complications associated with combinations of aspirin, thienopyridine derivatives, and warfarin in elderly patients following acute myocardial infarction. Arch Intern Med. 2005;165(7):784-9. [pmid: 15824298].
226 Burgess BC, Hanna-Moussa S, Ramasamy K, et al. Abciximab or eptifibatide in percutaneous coronary intervention: In-hospital outcomes and costs and six-month results. Int J Angiol. 2002;11(4):221-4.
227 Butler MJ, Eccleston D, Clark DJ, et al. The effect of intended duration of clopidogrel use on early and late mortality and major adverse cardiac events in patients with drug-eluting stents. Am Heart J. 2009;157(5):899-907. [pmid: 19376319].
228 Charlot M, Ahlehoff O, Norgaard ML, et al. Proton-pump inhibitors are associated with increased cardiovascular risk independent of clopidogrel use: a nationwide cohort study. Ann Intern Med. 2010;153(6):378-86. [pmid: 20855802].
229 Charlot M, Grove EL, Hansen PR, et al. Proton pump inhibitor use and risk of adverse cardiovascular events in aspirin treated patients with first time myocardial infarction: nationwide propensity score matched study. BMJ. 2011;342:d2690. [pmid: 21562004].
230 Charlot M, Nielsen LH, Lindhardsen J, et al. Clopidogrel discontinuation after myocardial infarction and risk of thrombosis: a nationwide cohort study. Eur Heart J. 2012. [pmid: 22798561].
231 Chen JL, Chen J, Qiao SB, et al. A randomized comparative study of using enoxaparin instead of unfractionated heparin in the intervention treatment of coronary heart disease. Chin Med J (Engl). 2006;119(5):355-9. [pmid: 16542576].
232 Chu WW, Kuchulakanti PK, Wang B, et al. Bivalirudin versus unfractionated heparin in patients undergoing percutaneous coronary intervention after acute myocardial infarction. Cardiovasc Revasc Med. 2006;7(3):132-5. [pmid: 16945819].
233 Cortese B, Micheli A, Picchi A, et al. Safety and efficacy of a prolonged bivalirudin infusion after urgent and complex percutaneous coronary interventions: a descriptive study. Coron Artery Dis. 2009;20(5):348-53. [pmid: 19543084].
234 Cuisset T, Frere C, Quilici J, et al. Benefit of a 600-mg loading dose of clopidogrel on platelet reactivity and clinical outcomes in patients with non-ST-segment elevation acute coronary syndrome undergoing coronary stenting. J Am Coll Cardiol. 2006;48(7):1339-45. [pmid: 17010792].
235 Danzi GB, Sesana M, Capuano C, et al. Downstream administration of a high-dose tirofiban bolus in high-risk patients with unstable angina undergoing early percutaneous coronary intervention. Int J Cardiol. 2006;107(2):241-6. [pmid: 16412804].
236 Davlouros PA, Arseniou A, Hahalis G, et al. Timing of clopidogrel loading before percutaneous coronary intervention in clopidogrel-naive patients with stable or unstable angina: a comparison of two strategies. Am Heart J. 2009;158(4):585-91. [pmid: 19781418].
237 Evanchan J, Donnally MR, Binkley P, et al. Recurrence of acute myocardial infarction in patients discharged on clopidogrel and a proton pump inhibitor after stent placement for acute myocardial infarction. Clin Cardiol. 2010;33(3):168-71. [pmid: 20235209].
238 Galassi AR, Russo G, Nicosia A, et al. Usefulness of platelet glycoprotein IIb/IIIa inhibitors in coronary stenting for reconstruction of complex lesions: procedural and 30 day outcome. Cardiologia. 1999;44(7):639-45. [pmid: 10476589].
239 Galasso G, Piscione F, Furbatto F, et al. Abciximab in elderly with acute coronary syndrome invasively treated: effect on outcome. Int J Cardiol. 2008;130(3):380-5. [pmid: 18590933].
240 Gao QP, Sun Y, Sun YX, et al. Early use of omeprazole benefits patients with acute myocardial infarction. J Thromb Thrombolysis. 2009;28(3):282-7. [pmid: 18830566].
241 Gaspar A, Ribeiro S, Nabais S, et al. Proton pump inhibitors in patients treated with aspirin and clopidogrel after acute coronary syndrome. Rev Port Cardiol. 2010;29(10):1511-20. [pmid: 21265493].
242 Gowda MS, Vacek JL, Lakkireddy DJ, et al. Differential benefits and outcomes of tirofiban vs abciximab for acute coronary syndromes in current clinical practice. Angiology. 2003;54(2):211-8. [pmid: 12678197].
243 Gunasekara AP, Walters DL, Aroney CN. Comparison of abciximab with “high-dose” tirofiban in patients undergoing percutaneous coronary intervention. Int J Cardiol. 2006;109(1):16-20. [pmid: 16014315].
244 Gupta E, Bansal D, Sotos J, et al. Risk of adverse clinical outcomes with concomitant use of clopidogrel and proton pump inhibitors following percutaneous coronary intervention. Dig Dis Sci. 2010;55(7):1964-8. [pmid: 19731021].
245 Harjai KJ, Shenoy C, Orshaw P, et al. Dual antiplatelet therapy for more than 12 months after percutaneous coronary intervention: insights from the Guthrie PCI Registry. Heart. 2009;95(19):1579-86. [pmid: 19549619].
246 Ho PM, Fihn SD, Wang L, et al. Clopidogrel and long-term outcomes after stent implantation for acute coronary syndrome. Am Heart J. 2007;154(5):846-51. [pmid: 17967588].
247 Ho PM, Maddox TM, Wang L, et al. Risk of adverse outcomes associated with concomitant use of clopidogrel and proton pump inhibitors following acute coronary syndrome. JAMA. 2009;301(9):937-44. [pmid: 19258584].
248 Hsiao FY, Mullins CD, Wen YW, et al. Relationship between cardiovascular outcomes and proton pump inhibitor use in patients receiving dual antiplatelet therapy after acute coronary syndrome. Pharmacoepidemiol Drug Saf. 2011;20(10):1043-9. [pmid: 21823195].
249 Ivandic BT, Kurz K, Keck F, et al. Tirofiban optimizes platelet inhibition for immediate percutaneous coronary intervention in high-risk acute coronary syndromes. Thromb Haemost. 2008;100(4):648-54. [pmid: 18841288].
250 Iversen AZ, Galatius S, Pedersen S, et al. Impact of abciximab in elderly patients with high-risk acute coronary syndrome undergoing percutaneous coronary intervention: an observational registry study. Drugs Aging. 2011;28(5):369-78. [pmid: 21542659].
251 Iversen AZ, Pedersen SH, Joens C, et al. Impact of abciximab in diabetic patients with acute coronary syndrome who undergo percutaneous coronary intervention: results from a high-volume, single-center registry. J Invasive Cardiol. 2011;23(1):21-6. [pmid: 21183766].
252 Jang SW, Rho TH, Kim DB, et al. Optimal antithrombotic strategy in patients with atrial fibrillation after coronary stent implantation. Korean Circ J. 2011;41(10):578-82. [pmid: 22125556].
253 Juurlink DN, Gomes T, Ko DT, et al. A population-based study of the drug interaction between proton pump inhibitors and clopidogrel. CMAJ. 2009;180(7):713-8. [pmid: 19176635].
254 Karha J, Gurm HS, Rajagopal V, et al. Use of platelet glycoprotein IIb/IIIa inhibitors in saphenous vein graft percutaneous coronary intervention and clinical outcomes. Am J Cardiol. 2006;98(7):906-10. [pmid: 16996871].
255 Karjalainen PP, Porela P, Ylitalo A, et al. Safety and efficacy of combined antiplatelet-warfarin therapy after coronary stenting. Eur Heart J. 2007;28(6):726-32. [pmid: 17267456].
256 Kim JH, Jeong MH, Rhew JY, et al. Long-term clinical outcomes of platelet glycoprotein IIb/IIIa inhibitor combined with low molecular weight heparin in patients with acute coronary syndrome. Circ J. 2005;69(2):159-64. [pmid: 15671606].
257 Konstantino Y, Iakobishvili Z, Porter A, et al. Aspirin, warfarin and a thienopyridine for acute coronary syndromes. Cardiology. 2006;105(2):80-5. [pmid: 16286733].
258 Korovesis S, Karvouni E, Karabinos I, et al. Comparison of enoxaparin and unfractionated heparin in coronary angioplasty. Hellenic J Cardiol. 2005;46(1):46-51. [pmid: 15807395].
259 Lahtela H, Karjalainen PP, Niemela M, et al. Are glycoprotein inhibitors safe during percutaneous coronary intervention in patients on chronic warfarin treatment?. Thromb Haemost. 2009;102(6):1227-33. [pmid: 19967155].
260 Lamberts M, Gislason GH, Olesen JB, et al. Oral anticoagulation and antiplatelets in atrial fibrillation patients after myocardial infarction and coronary intervention. J Am Coll Cardiol. 2013;62(11):981-9. [pmid: 23747760].
261 Lemesle G, Bonello L, De Labriolle A, et al. Impact of bivalirudin use on outcomes in nonagenarians undergoing percutaneous coronary intervention. J Interv Cardiol. 2009;22(1):61-7. [pmid: 19281522].
262 Lemesle G, De Labriolle A, Bonello L, et al. Impact of bivalirudin on in-hospital bleeding and six-month outcomes in octogenarians undergoing percutaneous coronary intervention. Catheter Cardiovasc Interv. 2009;74(3):428-35. [pmid: 19360860].
263 Lin YL, Chen LL, Luo YK, et al. Benefit of standard versus low-dose tirofiban for percutaneous coronary intervention in very elderly patients with high-risk acute coronary syndrome. Acta Pharmacol Sin. 2009;30(5):553-8. [pmid: 19417734].
264 Liu T, Xie Y, Zhou YJ, et al. Effects of upstream tirofiban versus downstream tirofiban on myocardial damage and 180-day clinical outcomes in high-risk acute coronary syndromes patients undergoing percutaneous coronary interventions. Chin Med J (Engl). 2009;122(15):1732-7. [pmid: 19781316].
265 Maegdefessel L, Schlitt A, Faerber J, et al. Anticoagulant and/or antiplatelet treatment in patients with atrial fibrillation after percutaneous coronary intervention. A single-center experience. Med Klin (Munich). 2008;103(9):628-32. [pmid: 18813885].
266 Momtahen M, Abdi S, Javadzadeh F, et al. Platelet GP IIb/IIIa receptor inhibition by Eptifibatide in non ST-elevation MI-acute coronary syndrome. Iran Cardiovasc Res J. 2009;3(2):86-90.
267 Ng FH, Tunggal P, Chu WM, et al. Esomeprazole Compared With Famotidine in the Prevention of Upper Gastrointestinal Bleeding in Patients With Acute Coronary Syndrome or Myocardial Infarction. Am J Gastroenterol. 2011. [pmid: 22108447].
268 Ng FH, Wong SY, Lam KF, et al. Gastrointestinal bleeding in patients receiving a combination of aspirin, clopidogrel, and enoxaparin in acute coronary syndrome. Am J Gastroenterol. 2008;103(4):865-71. [pmid: 18177451].
269 Okmen E, Cakmak M, Tartan Z, et al. Effects of glycoprotein IIb/IIIa inhibition on clinical stabilization parameters in patients with unstable angina and non-Q-wave myocardial infarction. Heart Vessels. 2003;18(3):117-22. [pmid: 12955426].
270 Ortolani P, Marino M, Marzocchi A, et al. One-year clinical outcome in patients with acute coronary syndrome treated with concomitant use of clopidogrel and proton pump inhibitors: results from a regional cohort study. J Cardiovasc Med (Hagerstown). 2011. [pmid: 21252697].
271 Ozkan M, Sag C, Yokusoglu M, et al. The effect of tirofiban and clopidogrel pretreatment on outcome of old saphenous vein graft stenting in patients with acute coronary syndromes. Tohoku J Exp Med. 2005;206(1):7-13. [pmid: 15802870].
272 Pekdemir H, Cin VG, Camsari A, et al. A comparison of 1-month and 6-month clopidogrel therapy on clinical and angiographic outcome after stent implantation. Heart Vessels. 2003;18(3):123-9. [pmid: 12955427].
273 Persson J, Lindback J, Hofman-Bang C, et al. Efficacy and safety of clopidogrel after PCI with stenting in patients on oral anticoagulants with acute coronary syndrome. EuroIntervention. 2011;6(9):1046-52. [pmid: 21518675].
274 Rassen JA, Choudhry NK, Avorn J, et al. Cardiovascular outcomes and mortality in patients using clopidogrel with proton pump inhibitors after percutaneous coronary intervention or acute coronary syndrome. Circulation. 2009;120(23):2322-9. [pmid: 19933932].
275 Ray WA, Murray KT, Griffin MR, et al. Outcomes with concurrent use of clopidogrel and proton-pump inhibitors: a cohort study. Ann Intern Med. 2010;152(6):337-45. [pmid: 20231564].
276 Ren YH, Zhao M, Chen YD, et al. Omeprazole affects clopidogrel efficacy but not ischemic events in patients with acute coronary syndrome undergoing elective percutaneous coronary intervention. Chin Med J (Engl). 2011;124(6):856-61. [pmid: 21518592].
277 Rossini R, Capodanno D, Musumeci G, et al. Safety of clopidogrel and proton pump inhibitors in patients undergoing drug-eluting stent implantation. Coron Artery Dis. 2011;22(3):199-205. [pmid: 21358542].
278 Rossini R, Musumeci G, Lettieri C, et al. Long-term outcomes in patients undergoing coronary stenting on dual oral antiplatelet treatment requiring oral anticoagulant therapy. Am J Cardiol. 2008;102(12):1618-23. [pmid: 19064015].
279 Roy P, Bonello L, Torguson R, et al. Temporal relation between Clopidogrel cessation and stent thrombosis after drug-eluting stent implantation. Am J Cardiol. 2009;103(6):801-5. [pmid: 19268735].
280 Ruiz-Nodar JM, Marin F, Hurtado JA, et al. Anticoagulant and antiplatelet therapy use in 426 patients with atrial fibrillation undergoing percutaneous coronary intervention and stent implantation implications for bleeding risk and prognosis. J Am Coll Cardiol. 2008;51(8):818-25. [pmid: 18294566].
281 Ruiz-Nodar JM, Marin F, Roldan V, et al. Should We Recommend Oral Anticoagulation Therapy in Patients With Atrial Fibrillation Undergoing Coronary Artery Stenting With a High HAS-BLED Bleeding Risk Score?. Circ Cardiovasc Interv. 2012;5(4):459-66. [pmid: 22787018].
282 Sarafoff N, Sibbing D, Sonntag U, et al. Risk of drug-eluting stent thrombosis in patients receiving proton pump inhibitors. Thromb Haemost. 2010;104(3):626-32. [pmid: 20664905].
283 Schiele F, Meneveau N, Seronde MF, et al. Routine use of fondaparinux in acute coronary syndromes: a 2-year multicenter experience. Am Heart J. 2010;159(2):190-8. [pmid: 20152216].
284 Schmidt M, Johansen MB, Robertson DJ, et al. Concomitant use of clopidogrel and proton pump inhibitors is not associated with major adverse cardiovascular events following coronary stent implantation. Aliment Pharmacol Ther. 2012;35(1):165-74. [pmid: 22050009].
285 Schulz S, Schuster T, Mehilli J, et al. Stent thrombosis after drug-eluting stent implantation: incidence, timing, and relation to discontinuation of clopidogrel therapy over a 4-year period. Eur Heart J. 2009;30(22):2714-21. [pmid: 19596658].
286 Schweiger MJ, Changezi HU, Naglieri-Prescod D, et al. Open-label, sequential comparison of eptifibatide with abciximab for patients undergoing percutaneous coronary intervention. Clin Ther. 2003;25(1):225-34. [pmid: 12637122].
287 Song Y. Evaluation on the safety and efficacy of tirofiban in the treatment of acute coronary syndrome. J Huazhong Univ Sci Technolog Med Sci. 2007;27(2):142-4. [pmid: 17497280].
288 Stockl KM, Le L, Zakharyan A, et al. Risk of rehospitalization for patients using clopidogrel with a proton pump inhibitor. Arch Intern Med. 2010;170(8):704-10. [pmid: 20421557].
289 Suleiman M, Gruberg L, Hammerman H, et al. Comparison of two platelet glycoprotein IIb/IIIa inhibitors, eptifibatide and abciximab: outcomes, complications and thrombocytopenia during percutaneous coronary intervention. J Invasive Cardiol. 2003;15(6):319-23. [pmid: 12777670].
290 Szuk T, Gyongyosi M, Homorodi N, et al. Effect of timing of clopidogrel administration on 30-day clinical outcomes: 300-mg loading dose immediately after coronary stenting versus pretreatment 6 to 24 hours before stenting in a large unselected patient cohort. Am Heart J. 2007;153(2):289-95. [pmid: 17239691].
291 Tentzeris I, Jarai R, Farhan S, et al. Impact of concomitant treatment with proton pump inhibitors and clopidogrel on clinical outcome in patients after coronary stent implantation. Thromb Haemost. 2010;104(6):1211-8. [pmid: 20941464].
292 Tsai YW, Wen YW, Huang WF, et al. Cardiovascular and gastrointestinal events of three antiplatelet therapies: clopidogrel, clopidogrel plus proton-pump inhibitors, and aspirin plus proton-pump inhibitors in patients with previous gastrointestinal bleeding. J Gastroenterol. 2011;46(1):39-45. [pmid: 20811753].
293 Valkhoff VE, t Jong GW, Van Soest EM, et al. Risk of recurrent myocardial infarction with the concomitant use of clopidogrel and proton pump inhibitors. Aliment Pharmacol Ther. 2011;33(1):77-88. [pmid: 21083580].
294 van Boxel OS, van Oijen MG, Hagenaars MP, et al. Cardiovascular and gastrointestinal outcomes in clopidogrel users on proton pump inhibitors: results of a large Dutch cohort study. Am J Gastroenterol. 2010;105(11):2430-6. quiz 7. [pmid: 20736935].
295 van den Brand MJ, Simoons ML, de Boer MJ, et al. Antiplatelet therapy in therapy-resistant unstable angina. A pilot study with REO PRO (c7E3). Eur Heart J. Suppl L. 1995;16:36-42. [pmid: 8869017].
296 Velianou JL, Mathew V, Wilson SH, et al. Effect of abciximab on late adverse events in patients with diabetes mellitus undergoing stent implantation. Am J Cardiol. 2000;86(10):1063-8. [pmid: 11074200].
297 Wang C, Kereiakes DJ, Bae JP, et al. Clopidogrel loading doses and outcomes of patients undergoing percutaneous coronary intervention for acute coronary syndromes. J Invasive Cardiol. 2007;19(10):431-6. [pmid: 17906345].
298 Wolfram R, Leborgne L, Cheneau E, et al. Comparison of effectiveness and safety of three different antithrombotic regimens (bivalirudin, eptifibatide, and heparin) in preventing myocardial ischemia during percutaneous coronary intervention. Am J Cardiol. 2003;92(9):1080-3. [pmid: 14583359].
299 Wu CY, Chan FK, Wu MS, et al. Histamine2-receptor antagonists are an alternative to proton pump inhibitor in patients receiving clopidogrel. Gastroenterology. 2010;139(4):1165-71. [pmid: 20600012].
300 Yan Z, Zhou Y, Zhao Y, et al. Efficacy and safety of tirofiban in high-risk patients with non-ST-segment elevation acute coronary syndromes. Clin Cardiol. 2009;32(9):E40-4. [pmid: 19645039].
301 Zairis MN, Tsiaousis GZ, Patsourakos NG, et al. The impact of treatment with omeprazole on the effectiveness of clopidogrel drug therapy during the first year after successful coronary stenting. Can J Cardiol. 2010;26(2):e54-7. [pmid: 20151060].
302 Zeymer U, Gitt AK, Zahn R, et al. Clopidogrel in addition to aspirin reduces one-year major adverse cardiac and cerebrovascular events in unselected patients with non-ST segment elevation myocardial infarction. Acute Card Care. 2008;10(1):43-8. [pmid: 17924233].