# Data Abstraction Elements

I. Study Characteristics
  - Author Last Name and Year
  - Study Name and Acronym
  - Additional Articles Used in This Abstraction
  - Key Question (s) (check all that apply)
    ○ KQ 1a, KQ 1b, KQ 1c, KQ 2a, KQ 2b, KQ 2c, KQ 3a, KQ 3b, KQ 3c, KQ 3d
  - Study Dates
    ○ Date enrollment started (MM/YYYY)
    ○ Date enrollment ended (MM/YYYY)
    ○ Length of Followup (months or years)
  - Study Type
    ○ RCT
    ○ Observational (prospective or retrospective)
  - Enrollment Approach
    ○ Check all that apply
      ■ Consecutive patients
      ■ Convenience sample (not explicitly consecutive)
      ■ Other (specify)
      ■ Not reported/unclear
    ○ Number eligible for study
    ○ Number randomized/enrolled
    ○ Number completing follow-up
    ○ Number included in primary outcome analysis
  - Study Sites
    ○ Single Center
    ○ Multicenter
    ○ Not reported/Unclear
  - Number of Sites
  - Geographical Location (select all applicable geographic regions
    ○ US, Canada, UK, Europe, S. America, C. America, Asia, Africa, Australia/NZ, Not reported/Unclear, Other (specify)
  - Funding Source (check all that apply)
    ○ Government, Private Foundation, Non-profit, Industry, Not reported, Other (specify)
  - Setting (check all that apply)
    ○ Academic centers, Community hospitals, Outpatient, VA, Not reported/Unclear, Other (specify)
  - Study Inclusion and Exclusion Criteria
    ○ Copy and paste inclusion/exclusion criteria as reported in the article
  - Clinical Presentation of Population Studied
    ○ UA/NSTEMI only
    ○ Mixed Population
  - Comments
II. Baseline Characteristics
  - Number of Subjects
    ○ Total, Tx 1, Tx 2, Tx 3, Tx 4
      ■ N
        - Total
        - Female
        - Male
      ■ %
        - Female
        - Male
  - Total Population – Age in Years
    ○ Total, Tx 1, Tx 2, Tx 3, Tx 4
      ■ Mean
      ■ SD
      ■ Median
      ■ IQR
  - Ethnicity
    ○ Total, Tx 1, Tx 2, Tx 3, Tx 4
      ■ Hispanic or Latino (N, %)
      ■ Not Hispanic or Latino (N, %)
  - Race
    ○ Total, Tx 1, Tx 2, Tx 3, Tx 4
      ■ Black/African American (N, %)
      ■ American Indian or Alaska Native (N, %)
      ■ Asian (N, %)
      ■ Native Hawaiian or other Pacific Islander (N, %)
      ■ White (N, %)
      ■ Multiracial (N, %)
      ■ Other (specify) (N, %)
  - Baseline Characteristics
    ○ Total, Tx 1, Tx 2, Tx 3, Tx 4
      ■ Diabetes (N, %)
      ■ Hypertension (N, %)
      ■ Hyperlipidemia (N, %)
      ■ Prior MI (N, %)
      ■ Prior PCI (N, %)
      ■ Prior CABG (N, %)
      ■ Heart Failure (N, %)
      ■ CKD/Renal Insufficiency (N, %)
      ■ Smoking/Tobacco Use (N, %)
      ■ Known PAD (N, %)
      ■ Prior Stroke (N, %)
      ■ Obesity (N, %)
      ■ Other (Specify) (N, %)
      ■ Weight
        - Result (Mean, Median)
        - Variability (Standard deviation, Standard error, 95% CI, IQR)
      ■ BMI
        - Result (Mean, Median)
        - Variability (Standard deviation, Standard error, 95% CI, IQR)
  - Presentation
    ○ Total, Tx 1, Tx 2, Tx 3, Tx 4
      ■ UA only (N, %)
      ■ NSTEMI only (N, %)
      ■ UA/NSTEMI (N, %)
      ■ STEMI only (N, %)
      ■ ACS (N, %)
      ■ Stable CAD (N, %)
  - Comments
III. Intervention Characteristics
  - Treatment Strategy (check all that apply
    ○ Early Invasive, Initial Conservative, Post-Discharge, Unclear/Not Specified
  - Intervention Characteristics
    ○ Tx 1, Tx 2, Tx 3, Tx 4
      ■ Specify Treatment – Clopidogrel, Prasugrel, Ticagrelor, Bivalirudin, Fondaparinux, Aspirin, Abciximab, Eptifibatide, Tirofiban, Enoxaparin, Unfractionated Heparin, Warfarin, Dabigatran, Rivaroxaban, Apixaban, Pantoprazole, Omeprazole, Lansoprazole, Rabeprazole, Esomeprazole, Dual Therapy (specify), Triple Therapy (specify), Placebo, Other (specify)
      ■ Intervention
        - Admission, In-Lab, In-Hospital, Discharge, Unknown
        - Loading Dose
        - Maintenance Dose
        - Timing
        - Duration of Treatment
      ■ Co-Interventions (check all that apply)
        - Clopidogrel, Prasugrel, Ticagrelor, Bivalirudin, Fondaparinux, Aspirin, Abciximab, Eptifibatide, Tirofiban, Enoxaparin, Unfractionated Heparin, Warfarin, Dabigatran, Rivaroxaban, Apixaban, Pantoprazole, Omeprazole, Lansoprazole, Rabeprazole, Esomeprazole, Placebo/Control, Other (specify), Glycoprotein IIB/IIA inhibitors, Low molecular weight heparins, Proton pump inhibitors
      ■ Description of Co-Intervention (dose, frequency, duration, administration)
      ■ Hours from Admission to Angiography
        - Result (Mean, Median)
        - Variability (IQR, 95% CI, Standard deviation, Standard error)
      ■ Hours from Antithrombotic Study Drug to Angiography
        - Result (Mean, Median)
        - Variability (IQR, 95% CI, Standard deviation, Standard error)
      ■ Hours from Antithrombotic Study Drug to PCI
        - Result (Mean, Median)
        - Variability (IQR, 95% CI, Standard deviation, Standard error)
      ■ Treatment Given
        - Medical Therapy
        - PCI
        - CABG
  - Intervention Description
  - Describe the Concomitant Medical Therapy/Optimal Medical Therapy from this study
  - PCI Characteristics
    ○ Tx 1, Tx 2, Tx 3, Tx 4
      ■ Lesions Treated (mean per patient)
        - Mean
        - Standard Deviation
        - Standard Error
      ■ Access Site – Radial (list %)
      ■ Access Site – Femoral (list %)
      ■ Interventional Approach – Balloon (N, %)
      ■ Interventional Approach – Atherectomy (N, %)
      ■ Stents – patient receiving stents
        - N and/or %
        - Type of Stent
          ○ Bare Metal
          ○ Drug-Eluting
          ○ Closed-Cell
          ○ Open-Cell
      ■ Stents Used (mean per patient)
        - Mean
        - Standard Deviation
        - Standard Error
  - PCI Intervention Description
IV. Individual Outcomes
  - Primary or Secondary Outcome
    ○ Primary/Secondary/ Unclear
  - Select Outcome
    ○ Total Mortality, Cardiovascular mortality, Nonfatal myocardial infarction, Stroke (any kind), Revascularization, Rehospitalization, Length of hospital stay, Stent thrombosis, Resource utilization (e.g. emergency dept. visits), Major bleeding, Minor bleeding, Quality of life, Adverse drug reactions, Contrast nephropathy, Radiation, Other 1, 2, 3, 4 (specify)
  - Describe Outcome
  - Table 1, Table 2, Table 3, Table 4, Table 5
    ○ Specify the Treatment Strategy
      ■ Early Invasive, Initial Conservative, Post-Discharge, Not Specified
    ○ Timing of Outcome
      ■ Baseline
      ■ Short term ≤ 30 days
        - In-hospital – before cath
        - In-hospital – during PCI
        - 30 days
        - Other (specify)
      ■ Intermediate term >30 days and ≤ 1 year
        - 6 weeks
        - 6 months
        - 1 year
        - Other (specify)
      ■ Long term > 1 year
        - 2 years
        - 3 years
        - 4 years
        - 5 years
        - Other (specify)
    ○ Adjustment(s) of outcome data (check all that apply)
      ■ Results are not adjusted, Age, Sex, Race/ethnicity, Comorbidity(ies) (specify), Body Weight/BMI, Risk factors (smoking), Other (specify all)
    ○ Group (Tx 1, Tx 2, Tx 3, Tx 4)
      ■ Clopidogrel
      ■ Prasugrel
      ■ Ticagrelor
      ■ Bivalirudin
      ■ Fondaparinux
      ■ Aspirin
      ■ Abciximab
      ■ Eptifibatide
      ■ Tirofiban
      ■ Enoxaparin
      ■ Unfractionated Heparin
      ■ Warfarin
      ■ Dabigatran
      ■ Rivaroxaban
      ■ Apixaban
      ■ Pantoprazole
      ■ Omeprazole
      ■ Lansoprazole
      ■ Rabeprazole
      ■ Esomeprazole
      ■ Dual Therapy (specify)
      ■ Triple Therapy (specify)
      ■ Placebo, Other (specify)
    ○ N for Analysis
    ○ Result
      ■ Mean
      ■ Median
      ■ Number Patients w/Outcome
      ■ % Patients w/Outcome
      ■ Relative Risk (RR)
      ■ Relative Hazard (HR)
      ■ Odds Ratio (OR)
      ■ Risk difference
      ■ Other (specify)
    ○ Variability
      ■ Standard Error (SE)
      ■ Standard Deviation (SD)
      ■ Other (specify)
    ○ Confidence Interval (CI) or Interquartile Range (IQR)
      ■ LL (25% if IQR)
      ■ UL (75% if IQR)
    ○ P-value between tx groups
    ○ Reference group (for comparison between tx groups)
  - Comments
V. Composite Outcomes
  - Label the composite outcome reported on this form
    ○ Composite #1/ Composite #2/ Composite #3/ Composite #4
  - Primary or Secondary Outcome
    ○ Primary/Secondary/ Unclear
  - Indicate components that make up this composite outcome (Check all that apply)
    ○ Total Mortality, Cardiovascular mortality, Nonfatal myocardial infarction, Stroke (any kind), Revascularization, Rehospitalization, Length of hospital stay, Stent thrombosis, Resource utilization (e.g. Emergency Dept. visits), Major bleeding, Minor bleeding, Quality of life, Adverse drug reactions, Contrast nephropathy, Radiation, Other 1, 2, 3, 4 (specify)
  - Table 1, Table 2, Table 3, Table 4, Table 5
    ○ Specify the Treatment Strategy
      ■ Early Invasive, Initial Conservative, Post-Discharge, Not Specified
    ○ Timing of Outcome
      ■ Baseline
      ■ Short term ≤ 30 days
        - In-hospital – before cath
        - In-hospital – during PCI
        - 30 days
        - Other (specify)
      ■ Intermediate term >30 days and ≤ 1 year
        - 6 weeks
        - 6 months
        - 1 year
        - Other (specify)
      ■ Long term > 1 year
        - 2 years
        - 3 years
        - 4 years
        - 5 years
        - Other (specify)
    ○ Adjustment(s) of outcome data (check all that apply)
      ■ Results are not adjusted, Age, Sex, Race/ethnicity, Comorbidity(ies) (specify), Body Weight/BMI, Risk factors (smoking), Other (specify all)
    ○ Group (Tx 1, Tx 2, Tx 3, Tx 4)
      ■ Clopidogrel
      ■ Prasugrel
      ■ Ticagrelor
      ■ Bivalirudin
      ■ Fondaparinux
      ■ Aspirin
      ■ Abciximab
      ■ Eptifibatide
      ■ Tirofiban
      ■ Enoxaparin
      ■ Unfractionated Heparin
      ■ Warfarin
      ■ Dabigatran
      ■ Rivaroxaban
      ■ Apixaban
      ■ Pantoprazole
      ■ Omeprazole
      ■ Lansoprazole
      ■ Rabeprazole
      ■ Esomeprazole
      ■ Dual Therapy (specify)
      ■ Triple Therapy (specify)
      ■ Placebo, Other (specify)
    ○ N for Analysis
    ○ Result
      ■ Mean
      ■ Median
      ■ Number Patients w/Outcome
      ■ % Patients w/Outcome
      ■ Relative Risk (RR)
      ■ Relative Hazard (HR)
      ■ Odds Ratio (OR)
      ■ Risk difference
      ■ Other (specify)
    ○ Variability
      ■ Standard Error (SE)
      ■ Standard Deviation (SD)
      ■ Other (specify)
    ○ Confidence Interval (CI) or Interquartile Range (IQR)
      ■ LL (25% if IQR)
      ■ UL (75% if IQR)
    ○ P-value between tx groups
    ○ Reference group (for comparison between tx groups)
  - Comments
VI. Quality
  - Was this study randomized? (Yes/No)
    ○ If yes:
      ■ Were study subjects randomized? (Yes/No/Unclear)
      ■ Was the randomization process described? (Yes/No/Unclear)
      ■ Was the outcome assessor blinded to study assignment? (Yes/No/Unclear)
      ■ Were patients blinded to study intervention? (Yes/No/Unclear)
      ■ Were results adjusted for clustering? (Yes/No/Unclear)
      ■ Were measures of outcomes based on validated procedures or instruments? (Yes/No/Unclear)
      ■ Conducted an intent to treat analysis? (Yes/No/Unclear)
      ■ Were all outcomes reported (i.e. was there evidence of selective outcome reporting)? (Yes/No/Unclear)
      ■ Were incomplete data adequately addressed (i.e. no systematic differences between groups in withdrawals/loss to follow-up AND no high drop-out or loss to follow-up rate [>30%])? (Yes/No/Unclear)
      ■ Was there adequate power (either based on pre-study or post-hoc power calculations [80% power for primary outcome])? (Yes/No/Unclear)
      ■ Were systematic differences observed in baseline characteristics and prognostic factors across the groups compared? (Yes/No/Unclear)
      ■ Were comparable groups maintained? (Includes crossovers, adherence, and contamination. Consider issues of crossover [e.g. from one intervention to another], adherence [major differences in adherence to the interventions being compared], contamination [e.g. some members of control group get intervention], or other systematic difference in care that was provided.) (Yes/No/Unclear)
      ■ Was there absence of potential important conflict-of-interest? (Focus on financial conflicts with for-profit capacities; government or non-profit funding = ‘yes’) (Yes/No/Unclear)
      ■ Overall Study Rating (Good/Fair/Poor) – Please give reasons for a rating of Fair or Poor
        - A “Good” study has the least bias, and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
        - A “Fair” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
        - A “Poor” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.
    ○ If no:
      ■ Basic Design
        - Is the study design prospective, retrospective, or mixed? (Prospective/Mixed/Retrospective/Cannot determine)
      ■ Selection Bias
        - Inclusion/Exclusion Criteria
          ○ Are the inclusion/exclusion criteria clearly stated (does not require the reader to infer)? (Yes/Partially/No)
          ○ Did the study apply inclusion/exclusion criteria uniformly to all comparison groups? (Yes/Partially/No/NA
        - Recruitment
          ○ Did the strategy for recruiting participants into the study differ across study groups? (Yes/No/Cannot determine/NA)
        - Baseline characteristics similar or appropriate adjusted analysis
          ○ Are key characteristics of study participants similar between intervention and control group? If not similar, did the analysis appropriately adjust for important differences? (Yes – similar or appropriate adjusted analysis/Partially – only some characteristics described or some characteristics not clearly described; analysis adjust for some/No – important baseline differences; unadjusted analysis/Insufficient reporting to be able to determine)
        - Comparison Group
          ○ Is the selection of the comparison group appropriate? (Yes/No/Cannot determine/NA)
      ■ Performance Bias
        - Intervention implementation
          ○ What is the level of detail in describing the intervention or exposure? (High – very clear, all PI-required details provided/Medium – somewhat clear, majority of PI-required details provided/Low – unclear, many PI-required details missing)
        - Concurrent/concomitant interventions
          ○ Did researches isolate the impact from a concurrent intervention or unintended exposure that might bias the results, e.g., through multivariate analysis, stratification, or subgroup analysis? (Yes/Partially/Not described)
      ■ Attrition Bias
        - Equality of length of follow-up for participants
          ○ In cohort studies, is the length of follow-up different between groups? (Yes/No or cannot determine/Not applicable)
        - Completeness of follow-up
          ○ Was there a high rate of differential or overall attrition? (Yes/No/Cannot determine)
        - Attrition affecting participant composition
          ○ Did attrition result in a difference in group characteristics between baseline and follow-up? (Yes/No/Cannot determine)
        - Any attempt to balance
          ○ Any attempt to balance the allocation between groups (e.g. through stratification, matching, propensity scores)? (Yes/No/Cannot determine)
        - Intention-to-treat analysis
          ○ Is the analysis conducted on an intention-to-treat (ITT) basis, that is, the intervention allocation status rather than the actual intervention received? (Yes/No/Cannot determine/NA)
      ■ Detection Bias
        - Source of information re: outcomes
          ○ Are procedural outcomes (e.g. stent thrombosis) assessed using valid and reliable measures and implemented consistently across all study participants? (Yes/No/Cannot determine)
          ○ Are event outcomes (e.g. mortality, MI, CVA, revascularization) assessed using valid and reliable measures and implemented consistently across all study participants? (Yes/No/Cannot determine)
          ○ Are patient-reported outcomes (e.g. quality of life) assessed using valid and reliable measure and implemented consistently across all study participants? (Yes/No/Cannot determine)
      ■ Reporting Bias
        - Are any important primary outcomes missing from the results? (Yes/No/Cannot determine/Primary outcomes no pre-specified)
      ■ Other risk of bias issues
        - Are the statistical methods used to assess the primary outcomes appropriate to the data? (Yes/Partially/No/Cannot determine)
        - Power and sample size
          ○ Did the authors report conducting a power analysis or some other basis for determining the adequacy of study group sizes for the primary outcome(s) being abstracted? (Yes/No/NA)
      ■ Overall rating of the study
        - Good/Low risk of Bias (good quality study with clear description)
        - Fair/Moderate risk of Bias (fair quality study; some bias but not enough to invalidate results)
        - Poor/High risk of Bias (low quality study; significant bias that may invalidate results)
      ■ A “Good/Low Risk of Bias” study has the least bias, and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses recruitment and eligibility criteria that minimizes selection bias; has a low attrition rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results. These studies will meet the majority of items in each domain.
      ■ A “Fair/Moderate Risk of Bias” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid. These studies will meet the majority of items in most but not all domains.
      ■ A “Poor/High Risk of Bias” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.
VII. Applicability
  - Did this study have any limitations that would affect its applicability? (Yes/No)
    ○ If Yes:
      ■ Population (P)
        - Study did not report participants' baseline characteristics.
        - Study did not report participant' comorbid conditions.
        - Participant diagnosis and identification for eligibility screening before random allocation was not appropriate/Cohort selection was not appropriate.
        - Study eligibility criteria were poorly described or not appropriate.
        - Study exclusion criteria were poorly described or not appropriate.
        - Study selectively recruited participants who demonstrated a history of favorable or unfavorable response to drug or other interventions for the condition.
      ■ Intervention (I)
        - Study interventions (active arm) were not similar to interventions used in routine clinical practice.
        - Study's cointerventions did not adequately reflect routine clinical practice (e.g., use of medical therapy for secondary prevention – antiplatelet agents, HTN/DM/lipid control).
        - Study prohibited interventions that are routinely used in clinical practice.
        - Diagnostic or therapeutic advances have been made in routine practice since the study was conducted.
      ■ Comparator (C)
        - Comparator(s) not well described.
        - Use of substandard alternative therapy (e.g., standard of treatment not from current practice).
      ■ Outcomes (O)
        - Study did not use a clinically relevant surrogate outcome where applicable.
        - Study centers and/or clinicians were not selected on the basis of their skill or experience.
        - Study excluded participants at elevated risk of intervention complications.
        - Composite outcomes that mix outcomes of different significance.
      ■ Timing (T)
        - Duration of participant followup was inadequate.
      ■ Setting (S)
        - Study conducted solely outside the US.
        - Study was conducted only at a single site.
      ■ Comments
    ○ If No:
      ■ Comments