# Exact Search Strings

## PubMed^®^ Search Strategy (July 19, 2012)

Table A-1 PubMed search strategy

Set # | Terms
1 | ACS[tw] OR acute coronary syndrome[MeSH Terms] OR (acute[tw] AND coronary[tw] AND syndrome[tw]) OR “acute coronary syndrome”[tw] OR non-st[tw] OR nstemi[tw] OR n-stemi[tw] OR non-stemi[tw] OR nonstemi[tw] OR nsteacs[tw] OR angina, unstable[MeSH Terms] OR (angina[tw] AND unstable[tw]) OR “unstable angina”[tw] OR (preinfarction[tw] AND angina[tw]) OR “preinfarction angina”[tw] OR myocardial infarction[mesh] OR “myocardial infarction”[tw] OR “heart attack”[tw]
2 | platelet aggregation inhibitors[MeSH Terms] OR (platelet[tw] AND aggregation[tw] AND inhibitors[tw]) OR (antiplatelet[tw] AND agent*[tw]) OR “platelet aggregation inhibitors”[Pharmacological Action] OR Purinergic P2Y Receptor Antagonists[Pharmacological Action] OR purinergic p2y receptor antagonists[MeSH Terms] OR (purinergic[tw] AND p2y[tw] AND receptor[tw] AND antagonists[tw]) OR “ADP receptor antagonist”[tw] OR “ADP receptor antagonists”[tw] OR aspirin[mesh] OR aspirin[tw] OR clopidogrel[supplementary concept] OR clopidogrel[tw] OR plavix[tw] OR prasugrel[supplementary concept] OR prasugrel[tw] OR effient[tw] OR ticagrelor[supplementary concept] OR ticagrelor[tw] OR brilinta[tw]
3 | factor xa[mesh] OR “factor xa inhibitor”[tw] OR “factor xa inhibitors”[tw] OR rivaroxaban[Supplementary Concept] OR rivaroxaban[tw] OR xarelto[tw] OR bivalirudin[Supplementary Concept] OR bivalirudin[tw] OR angiomax[tw] OR apixaban[Supplementary Concept] OR eliquis[tw] OR apixaban[tw] OR “2-(3-carbamimidoylbenzyl)-3-(4-(1-oxypyridin-4-yl)benzoylamino)butyric acid methyl ester”[Supplementary Concept] OR “2-(3-carbamimidoylbenzyl)-3-(4-(1-oxypyridin-4-yl)benzoylamino)butyric acid methyl ester”[tw] OR otamixaban[tw] OR “YM 60828”[Supplementary Concept] OR “YM 60828”[tw] OR “ym466”[tw]
4 | heparin[MeSH] OR heparin[tw] OR (low[tw] AND molecular[tw] AND weight[tw] AND heparin[tw]) OR (unfractionated[tw] AND heparin[tw]) OR fondaparinux[Supplementary Concept] OR fondaparinux[tw] OR arixtra[tw] OR Dalteparin[tw] OR fragmin[tw] OR Enoxaparin[tw] OR lovenox[tw] OR Nadroparin[tw] OR fraxiparine[tw]
5 | Vitamin K/antagonists and inhibitors[mesh] OR “vitamin k antagonist”[tw] OR “vitamin k antagonists”[tw] OR warfarin[mesh] OR warfarin[tw] OR Coumadin[tw] OR VKA[tw] OR coumarol[tw] OR dicoumarol[tw] OR coumarin[tw] OR dicoumarin[tw]
6 | antithrombins[mesh] OR antithrombins[pharmacological action] OR “direct thrombin inhibitor”[tw] OR “direct thrombin inhibitors”[tw] OR “N-((2-(((4-(aminoiminomethyl)phenyl)amino)methyl)-1-methyl-1H-benzimidazol-5-yl)carbonyl)-N-2-pyridinyl-beta-alanine”[Supplementary Concept] OR “N-((2-(((4-(aminoiminomethyl)phenyl)amino)methyl)-1-methyl-1H-benzimidazol-5-yl)carbonyl)-N-2-pyridinyl-beta-alanine”[tw] OR dabigatran[tw] OR pradaxa[tw]
7 | “Glycoprotein IIb/IIIa inhibitor”[tw] OR “GP IIb/IIIa inhibitor”[tw] OR “Glycoprotein IIb/IIIa inhibitors”[tw] OR “GP IIb/IIIa inhibitors”[tw] OR abciximab[Supplementary Concept] OR abciximab[tw] OR reopro[tw] OR eptifibatide[Supplementary Concept] OR eptifibatide[tw] OR integrilin[tw] OR tirofiban[Supplementary Concept] OR tirofiban[tw] OR aggrastat[tw]
8 | Proton Pump Inhibitors[Mesh] OR Proton Pump Inhibitors[Pharmacological Action] OR Proton Pumps/antagonists and inhibitors[Mesh] OR omeprazole[MeSH] OR omeprazole[tw] OR esomeprazole[tw] OR lansoprazole[Supplementary Concept] OR lansoprazole[tw] OR pantoprazole[Supplementary Concept] OR pantoprazole[tw] OR rabeprazole[Supplementary Concept] OR rabeprazole[tw] OR dexlansoprazole[tw] OR “omeprazole, sodium bicarbonate drug combination”[Supplementary Concept] OR zegerid[tw] OR nexium[tw] OR aciphex[tw] OR protonix[tw] OR prevacid[tw] OR kapidex[tw] OR prilosec[tw]
9 | “Angioplasty, Balloon, Coronary”[Mesh] OR (Percutaneous[tw] AND Transluminal[tw] AND Coronary[tw] AND Angioplasty[tw]) OR “percutaneous transluminal coronary angioplasty”[tw] OR angioplasty[mesh] OR angioplasty[tw] OR PTCA[tw] OR PCI[tw] OR (percutaneous[tw] AND coronary[tw] AND intervention[tw]) OR ((coronary[tw] OR heart[mesh] OR heart[tw]) AND (stents[mesh] OR stent[tw] OR stents[tw] OR stenting[tw] OR stented[tw]))
10 | 1 AND (2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9)
12 | randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw]
13 | 10 AND 12
14 | 13 NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[MeSH] NOT humans[MeSH]) Limits: English, 1995 - Present

## Embase^®^ Search Strategy (July 19, 2012)

Platform: Embase.com

Table A-2 Embase search strategy

Set # | Terms
1 | ACS:ab,ti OR (acute:ab,ti AND coronary:ab,ti AND syndrome:ab,ti) OR non-st:ab,ti OR nstemi:ab,ti OR n-stemi:ab,ti OR non-stemi:ab,ti OR nonstemi:ab,ti OR nsteacs:ab,ti OR ‘unstable angina pectoris’/exp OR (unstable:ab,ti AND angina:ab,ti) OR (preinfarction:ab,ti AND angina:ab,ti) OR ‘heart infarction’/exp OR “myocardial infarction”:ab,ti OR “heart attack”:ab,ti
2 | ‘antithrombocytic agent’/exp OR ‘purinergic receptor blocking agent’/exp OR ‘acetylsalicylic acid’/exp OR ‘adenosine receptor blocking agent’/exp OR ‘clopidogrel’/exp OR ‘prasugrel’/exp OR ‘ticagrelor’/exp OR (platelet:ab,ti AND aggregation:ab,ti AND inhibitors:ab,ti) OR (antiplatelet:ab,ti OR antiplatelets:ab,ti) OR (purinergic:ab,ti AND p2y:ab,ti AND receptor:ab,ti AND antagonists:ab,ti) OR “ADP receptor antagonist”:ab,ti OR “ADP receptor antagonists”:ab,ti OR aspirin:ab,ti OR clopidogrel:ab,ti OR plavix:ab,ti OR prasugrel:ab,ti OR effient:ab,ti OR ticagrelor:ab,ti OR brilinta:ab,ti
3 | ‘blood clotting factor 10a’/exp OR ‘rivaroxaban’/exp OR ‘hirulog’/exp OR ‘apixaban’/exp OR ‘(n (4 ((1 acetimidoyl 4 piperidyl)oxy)phenyl) n ((7 amidino 2 naphthyl)methyl)sulfamoyl)acetic acid’/exp OR ‘otamixaban’/exp OR “factor xa inhibitor”:ab,ti OR “factor xa inhibitors”:ab,ti OR rivaroxaban:ab,ti OR xarelto:ab,ti OR bivalirudin:ab,ti OR angiomax:ab,ti OR eliquis:ab,ti OR apixaban:ab,ti OR “2-(3-carbamimidoylbenzyl)-3-(4-(1-oxypyridin-4-yl)benzoylamino)butyric acid methyl ester”:ab,ti OR otamixaban:ab,ti OR “YM 60828”:ab,ti OR “ym466”:ab,ti
4 | ‘heparin’/exp OR ‘fondaparinux’/exp OR ‘dalteparin’/exp OR ‘enoxaparin’/exp OR ‘nadroparin’/exp OR ‘low molecular weight heparin’/exp OR heparin:ab,ti OR (low:ab,ti AND molecular:ab,ti AND weight:ab,ti AND heparin:ab,ti) OR (unfractionated:ab,ti AND heparin:ab,ti) OR fondaparinux:ab,ti OR arixtra:ab,ti OR Dalteparin:ab,ti OR fragmin:ab,ti OR Enoxaparin:ab,ti OR lovenox:ab,ti OR Nadroparin:ab,ti OR fraxiparine:ab,ti
5 | ‘antivitamin K’/exp OR ‘warfarin’/exp OR ‘coumarin’/exp OR “vitamin k antagonist”:ab,ti OR “vitamin k antagonists”:ab,ti OR warfarin:ab,ti OR Coumadin:ab,ti OR VKA:ab,ti OR coumarol:ab,ti OR dicoumarol:ab,ti OR coumarin:ab,ti OR dicoumarin:ab,ti
6 | ‘antithrombin’/exp OR ‘dabigatran’/exp OR “direct thrombin inhibitor”:ab,ti OR “direct thrombin inhibitors”:ab,ti OR “N-((2-(((4-(aminoiminomethyl)phenyl)amino)methyl)-1-methyl-1H-benzimidazol-5-yl)carbonyl)-N-2-pyridinyl-beta-alanine”:ab,ti OR dabigatran:ab,ti OR pradaxa:ab,ti
7 | ‘abciximab’/exp OR ‘eptifibatide’/exp OR ‘tirofiban’/exp OR “Glycoprotein IIb/IIIa inhibitor”:ab,ti OR “GP IIb/IIIa inhibitor”:ab,ti OR “Glycoprotein IIb/IIIa inhibitors”:ab,ti OR “GP IIb/IIIa inhibitors”:ab,ti OR abciximab:ab,ti OR reopro:ab,ti OR eptifibatide:ab,ti OR integrilin:ab,ti OR tirofiban:ab,ti OR aggrastat:ab,ti
8 | ‘proton pump inhibitor’/exp OR omeprazole:ab,ti OR esomeprazole:ab,ti OR lansoprazole:ab,ti OR pantoprazole:ab,ti OR rabeprazole:ab,ti OR dexlansoprazole:ab,ti OR zegerid:ab,ti OR nexium:ab,ti OR aciphex:ab,ti OR protonix:ab,ti OR prevacid:ab,ti OR kapidex:ab,ti OR prilosec:ab,ti
9 | ‘transluminal coronary angioplasty’/exp OR ‘percutaneous coronary intervention’/exp OR (Percutaneous:ab,ti AND Transluminal:ab,ti AND Coronary:ab,ti AND Angioplasty:ab,ti) OR “percutaneous transluminal coronary angioplasty”:ab,ti OR ‘angioplasty’/exp OR angioplasty:ab,ti OR PTCA:ab,ti OR PCI:ab,ti OR (percutaneous:ab,ti AND coronary:ab,ti AND intervention:ab,ti) OR ((coronary:ab,ti OR ‘heart’/exp OR heart:ab,ti) AND (‘stent’/exp OR stent:ab,ti OR stents:ab,ti OR stenting:ab,ti OR stented:ab,ti))
10 | 1 AND (2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9)
12 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti
13 | 10 AND 12
14 | 13 AND [embase]/lim NOT [medline]/lim
14 | 13 NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) Limits: English, Human, 1995 - Present

## Cochrane Search Strategy (July 19, 2012)

Platform: Wiley

Databases searched: Cochrane Central Registry of Controlled Trials and Cochrane Database of Systematic Reviews

Table A-3 Cochrane search strategy

Set # | Terms
1 | “heart diseases”[MeSH Terms] OR “myocardium”[MeSH Terms] OR “cardiovascular diseases”[MeSH Terms] OR angina, unstable[MeSH Terms] OR “heart”[MeSH Terms] OR myocardial infarction[mesh] OR acute coronary syndrome[MeSH Terms] OR (acute:ti,ab AND coronary:ti,ab AND syndrome:ti,ab) OR “acute coronary syndrome”:ti,ab OR non-st:ti,ab OR nstemi:ti,ab OR n-stemi:ti,ab OR non-stemi:ti,ab OR nonstemi:ti,ab OR nsteacs:ti,ab OR (angina:ti,ab AND unstable:ti,ab) OR “unstable angina”:ti,ab OR (preinfarction:ti,ab AND angina:ti,ab) OR “preinfarction angina”:ti,ab OR (“cardiovascular”:ti,ab AND “diseases”:ti,ab) OR OR (“heart”:ti,ab AND “diseases”:ti,ab) OR “heart”:ti,ab OR “coronary”:ti,ab OR cardiovas*:ti,ab OR cardiac*:ti,ab OR “myocardium”:ti,ab OR “myocardial”:ti,ab OR ACS:ti,ab
2 | (platelet:ti,ab AND aggregation:ti,ab AND inhibitors:ti,ab) OR (antiplatelet:ti,ab AND agent*:ti,ab) OR (purinergic:ti,ab AND p2y:ti,ab AND receptor:ti,ab AND antagonists:ti,ab) OR “ADP receptor antagonist”:ti,ab OR “ADP receptor antagonists”:ti,ab OR aspirin:ti,ab OR clopidogrel:ti,ab OR plavix:ti,ab OR prasugrel:ti,ab OR effient:ti,ab OR ticagrelor:ti,ab OR brilinta:ti,ab OR “factor xa inhibitor”:ti,ab OR “factor xa inhibitors”:ti,ab OR rivaroxaban:ti,ab OR xarelto:ti,ab OR bivalirudin:ti,ab OR angiomax:ti,ab OR eliquis:ti,ab OR apixaban:ti,ab OR “2-(3-carbamimidoylbenzyl)-3-(4-(1-oxypyridin-4-yl)benzoylamino)butyric acid methyl ester”:ti,ab OR otamixaban:ti,ab OR “YM 60828”:ti,ab OR “ym466”:ti,ab OR heparin:ti,ab OR (low:ti,ab AND molecular:ti,ab AND weight:ti,ab AND heparin:ti,ab) OR (unfractionated:ti,ab AND heparin:ti,ab) OR fondaparinux:ti,ab OR arixtra:ti,ab OR Dalteparin:ti,ab OR fragmin:ti,ab OR Enoxaparin:ti,ab OR lovenox:ti,ab OR Nadroparin:ti,ab OR fraxiparine:ti,ab OR “vitamin k antagonist”:ti,ab OR “vitamin k antagonists”:ti,ab OR warfarin:ti,ab OR Coumadin:ti,ab OR VKA:ti,ab OR coumarol:ti,ab OR dicoumarol:ti,ab OR coumarin:ti,ab OR dicoumarin:ti,ab OR “direct thrombin inhibitor”:ti,ab OR “direct thrombin inhibitors”:ti,ab OR “N-((2-(((4-(aminoiminomethyl)phenyl)amino)methyl)-1-methyl-1H-benzimidazol-5-yl)carbonyl)-N-2-pyridinyl-beta-alanine”:ti,ab OR dabigatran:ti,ab OR pradaxa:ti,ab OR “Glycoprotein IIb/IIIa inhibitor”:ti,ab OR “GP IIb/IIIa inhibitor”:ti,ab OR “Glycoprotein IIb/IIIa inhibitors”:ti,ab OR “GP IIb/IIIa inhibitors”:ti,ab OR abciximab:ti,ab OR reopro:ti,ab OR eptifibatide:ti,ab OR integrilin:ti,ab OR tirofiban:ti,ab OR aggrastat:ti,ab OR omeprazole:ti,ab OR esomeprazole:ti,ab OR lansoprazole:ti,ab OR pantoprazole:ti,ab OR rabeprazole:ti,ab OR dexlansoprazole:ti,ab OR zegerid:ti,ab OR nexium:ti,ab OR aciphex:ti,ab OR protonix:ti,ab OR prevacid:ti,ab OR kapidex:ti,ab OR prilosec:ti,ab OR (Percutaneous:ti,ab AND Transluminal:ti,ab AND Coronary:ti,ab AND Angioplasty:ti,ab) OR “percutaneous transluminal coronary angioplasty”:ti,ab OR angioplasty:ti,ab OR PTCA:ti,ab OR PCI:ti,ab OR (percutaneous:ti,ab AND coronary:ti,ab AND intervention:ti,ab) OR ((coronary:ti,ab OR heart:ti,ab) AND (stent:ti,ab OR stents:ti,ab OR stenting:ti,ab OR stented:ti,ab)) OR MeSH descriptor Myocardial Infarction OR MeSH descriptor Angina, Unstable OR MeSH descriptor Acute Coronary Syndrome OR MeSH descriptor Aspirin OR MeSH descriptor Purinergic P2Y Receptor Antagonists OR MeSH descriptor Platelet Aggregation Inhibitors OR MeSH descriptor Factor Xa OR MeSH descriptor Heparin OR MeSH descriptor Vitamin K with qualifier: AI OR MeSH descriptor Warfarin OR MeSH descriptor Antithrombins OR MeSH descriptor Proton Pump Inhibitors OR MeSH descriptor Proton Pumps with qualifier: AI OR MeSH descriptor Omeprazole OR MeSH descriptor Heart OR MeSH descriptor Angioplasty OR MeSH descriptor Stents OR MeSH descriptor Angioplasty, Balloon, Coronary
3 | 1 AND 2 Each MeSH descriptor was searched separately and then combined with OR
4 | 3, Limits: English, 2005-, Systematic Reviews

## Gray Literature Searches

### ClinicalTrials.gov (Final Search Date August 20, 2012)

| Terms
Condition | acute coronary syndrome OR non-st OR nstemi OR n-stemi OR non-stemi OR nonstemi OR nsteacs OR unstable angina OR preinfarction angina
First received | From 01/01/1995

Total number of results: 630

### WHO International Clinical Trials Registry Platform Search Portal (Final Search Date March 7, 2012)

Terms: acute coronary syndrome OR non-st OR nstemi OR n-stemi OR non-stemi OR nonstemi OR nsteacs OR unstable angina OR preinfarction angina

Total number of results: 623

### ProQuest COS Conference Papers Index (Final Search Date February 15, 2012)

Set # | Terms
1 | all(acs OR “acute coronary syndrome” OR non-st OR nstemi OR n-stemi OR non-stemi OR nonstemi OR nsteacs OR (unstable AND angina) OR (preinfarction AND angina) OR “myocardial infarction” OR “heart attack” )
2 | all ((platelet AND aggregation AND inhibitor*) OR (antiplatelet AND agent*) OR (purinergic AND p2y AND receptor AND antagonists) OR “ADP receptor antagonist” OR “ADP receptor antagonists” OR aspirin OR clopidogrel OR plavix OR prasugrel OR effient OR ticagrelor OR brilinta OR “factor xa” OR rivaroxaban OR xarelto OR bivalirudin OR angiomax OR apixaban OR eliquis OR otamixaban OR “YM 60828” OR ym466 OR heparin OR fondaparinux OR arixtra OR Dalteparin OR fragmin OR Enoxaparin OR lovenox OR Nadroparin OR fraxiparine OR (“Vitamin K” AND antagonist*) OR warfarin OR Coumadin OR VKA OR coumarol OR dicoumarol OR coumarin OR dicoumarin OR antithrombins OR “direct thrombin inhibitor” OR “direct thrombin inhibitors” OR dabigatran OR pradaxa OR (Glycoprotein AND inhibitor*) OR (GP AND inhibitor*) OR abciximab OR reopro OR eptifibatide OR integrilin OR tirofiban OR aggrastat OR “Proton Pump Inhibitors” OR “Proton Pump Inhibitor” OR omeprazole OR esomeprazole OR lansoprazole OR pantoprazole OR rabeprazole OR dexlansoprazole OR zegerid OR nexium OR aciphex OR protonix OR prevacid OR kapidex OR prilosec OR Angioplasty OR PTCA OR PCI OR (percutaneous AND coronary AND intervention) OR ((coronary OR heart) AND (stent OR stents OR stenting OR stented)) )
3 | 1 and 2

Total number of results: 1467