# Abbreviations

ACS: acute coronary syndrome
AHRQ: Agency for Healthcare Research and Quality
ASA: aspirin
BMS: bare metal stent
CI: confidence interval
CV: cardiovascular
DAPT: dual antiplatelet therapy
DES: drug-eluting stent
GI: gastrointestinal
GPI: glycoprotein IIb/IIIa inhibitor
HR: hazard ratio
IV: intravenous
KQ: Key Question
MI: myocardial infarction
mo: month/months
NSTEMI: non-ST elevation myocardial infarction
OR: odds ratio
PCI: percutaneous coronary intervention
PPI: proton pump inhibitor
RCT: randomized controlled trial
RR: risk ratio
SOE: strength of evidence
STEMI: ST elevation myocardial infarction
TEP: Technical Expert Panel
UA: unstable angina
UFH: unfractionated heparin
wk: week/weeks
yr: year/years