# Results

Our literature search yielded 11,869 citations (11,866 from electronic databases and 3 from hand-searching; no submission information packages were received; Figure 2). Of these, 901 articles were reviewed in full text. After full text review, 60 unique studies (reported in 65 publications8,11,31-93) were judged to have met the inclusion criteria for at least one of the Key Questions (44 RCTs; 10 NRCSs; and 6 single-group cohorts). The most common reasons for exclusion of articles were related to study design (e.g., we excluded uncontrolled case series and NRCSs not meeting the sample size cutoffs) and language of publication. See Appendix B for a list of the excluded studies with the reason for exclusion. Data extraction forms and summary tables for all included studies are available online on the Systematic Review Data Repository (http://srdr.ahrq.gov/).

Figure 2 Literature flow diagram

AE = adverse event; CINAHL = Cumulative Index to Nursing and Allied Health Literature; KQ = Key Question; NRCS = non-randomized comparative trial; RCT = randomized controlled trial; SIP = scientific information packet

Note: Some publications reported data from the same study. Detailed reasons for exclusion of studies reviewed in full text but not considered further are presented in Appendix B.

Figure 2 is a literature flow diagram. A total of 65 publications were included, out of 11866 abstracts screened.

## Key Question 1

How do various preoperative OMBP strategies compare between them and versus a control with respect to their effectiveness for preventing surgical or postsurgical complications?

a. For elective right colon surgery?
b. For elective left colon surgery?
c. For elective rectal surgery?

Forty-four RCTs (Table 1) and ten NRCSs met criteria for Key Question 1. Twenty-seven studies compared OMBP versus enema or no preparation (20 RCTs; 7 NRCSs); 25 compared alternative active OMBP strategies (23 RCTs and 2 NRCSs); two studies compared inpatient versus outpatient preparation (1 RCT and 1 NRCS).

Table 1 Bowel preparation strategies in included RCTs

Author, Year [PMID] | OMBP (per arm) | Enema Used (per arm) | Oral Antibiotics Used (per arm) | Parenteral Antibiotics Used (per arm)
Comparisons of OMBP vs. Enema or no Preparation
Hughes, 1972^55^ [4621021] | bisacodyl/no OMBP | yes/no | unclear/unclear | yes/yes
Burke, 1994^39^ [8044619] | Na picosulphate/no OMBP | no/no | no/no | yes/yes
Santos, 1994^76^ [7827905] | mineral oil, agar, phenolphthalein + mannitol/ no OMBP | yes/no | no/no | yes/yes
Miettinen, 2000^67^ [10826429] | PEG/no OMBP | no/no | no/no | yes/yes
Zmora, 2003^92,93^ [12616120] | PEG/no OMBP | selective/selective | yes/yes | yes/yes
Bucher, 2005^38^ [15786427] | PEG/no OMBP | no/selective | no/no | yes/yes
Fa-Si-Oen, 2005^49^ [15981065] | PEG/no OMBP | no/no | no/no | yes/yes
Platell, 2006^73^ [16491463] | PEG/no OMBP | no/yes | no/no | yes/yes
Contant, 2007^44,85,86^ [18156032] | PEG or NaP/no OMBP | no/no | no/no | yes/yes
Ali, 2007^31^ [not indexed] | WGI with saline/non OMBP | no/no | unclear/unclear | unclear/unclear
Jung, 2007^57,58^ [17514668] | PEG or NaP/no OMBP | no/no | yes/yes | yes/yes
Pena-Soria, 2008^8,72^ [18820977] | PEG/no OMBP | yes/no | no/no | yes/yes
Bretagnol, 2010^36^ [21037443]^*^ | senna/no OMBP | yes/no | no/no | yes/yes
Scabini, 2010^78^ [20433721] | PEG/no OMBP | selective/selective | no/no | yes/yes
Watanabe, 2010^87^ [20799286] | MgCitrate/no OMBP | yes/no | no/no | yes/yes
Bertani, 2011^35^ [21689356] | PEG/no OMBP | yes/yes | no/no | yes/yes
Khan, 2011^59^ [not indexed] | Na picosulphate/no OMBP | no/no | no/no | yes/yes
Sasaki, 2012^77^ [22976604] | PEG + Na picosulfate/no OMBP | no/no | no/no | yes/yes
Tahirkheli, 2013^81^ [not indexed] | WGI with saline/no OMBP | no/no | yes/no | yes/yes
Comparisons of Alternative OMBP Strategies in Adults
Matheson, 1978^66^ [359083] | MgSulphate/nutritional | yes/yes | yes/yes | no/no
Chung, 1979^43^ [365010] | MgCitrate/WGI with Ringer's | yes/no | no/no | yes/yes
Christensen, 1981^42^ [7318622] | WGI with NaCl, NaHCO_3_, KCl/sodium salt solution | no/yes | no/no | yes/yes
Morris, 1983^68^ [6190888] | senna/mannitol | no/no | no/no | yes/yes
Beck, 1985^34^ [4017808] | senna + MgCitrate/PEG+bisacodyl | yes/no | no/no | yes/yes
Fleites, 1985^50^ [3901374] | PEG/bisacodyl + MgCitrate | unclear/unclear | yes/yes | yes/yes
Panton, 1985^71^ [3887955] | castor oil or MgSulfate/WGI with Ringer's | unclear/yes | no/no | yes/yes
Beck, 1986^11^ [3095080] | PEG/mannitol | no/no | no/no | yes/yes
Dueholm, 1987^46^ [3552504] | PEG/WGI with NaCl solution | no/no | no/no | yes/yes
Wolff, 1988^88^ [3132910] | WGI with PEG/NaP | no/yes | yes/yes | yes/yes [for a subset of patients]
Soballe, 1989^80^ [2499830] | PEG/bisacodyl + MgCitrate | no/yes | yes/yes | no/no
Beck, 1991^33^ [2021332] | PEG/senna + MgCitrate | no/yes | no/no | yes/yes
Wolters, 1994^89^ [8205446] | PEG/WGI with Ringer's/bisacodyl + NaP | no/no/no | no/no/no | no/no/no
Grundel, 1997^52^ [9369111] | PEG/PEG+bisacodyl+NaP | no/no | no/no | yes/yes
Oliveira, 1997^70^ [9152189] | PEG/NaP | no/no | yes/yes | no/no
Makino, 1998^65^ [9496494] | senna + MgCitrate/PEG + senna | yes/no | yes/yes | no/no
Valverde, 1999^83^ [10323423] | PEG/senna | yes/yes | no/no | yes/yes
Yoshioka, 2000^90^ [10720834] | Na picosulphate/NaP | no/no | no/no | no/no
Koussidis, 2001^62^ [11841079] | WGI with Ringer's/gastrografin | no/no | unclear/unclear | yes/yes
Reddy, 2007^75^ [17443852] | Na picosulphate + MgCitrate/Na picosulphate + MgCitrate/Na picosulphate + MgCitrate/ nutritional | no/no/no/no | no/yes/yes/yes | no/no/no/no
Horvat, 2010^54^ [20517667] | PEG + senna/nutritional/nutritional | no/no/no | unclear/unclear/ unclear | unclear/unclear/ unclear
Comparison of Inpatient vs. Outpatient OMBP
Frazee, 1992^51^ [1740065] | PEG/PEG | yes/yes | yes/yes | yes/yes
Comparisons of Alternative OMBP Strategies in Children
Chattopadhyay, 2004^41^ [14752676] | PEG/WGI with NaCl + KCl | no/no | no/no | yes/yes
Sinha, 2007^79^ [17394002] | WGI with PEG/WGI with NaCl solution/WGI with Ringer's | no/no/no | no/no/no | yes/yes/yes

OMBP = oral mechanical bowel preparation; PMID = PubMed identification number; PEG = polyethylene glycol; WGI = whole gut irrigation

* Retracted study.

Note: A possible duplicate study is not included in the table.37

One RCT comparing OMBP versus no OMBP has been retracted,^f^ and was not included in the main analyses.78,94 In extensive sensitivity analyses, inclusion of the retracted study did not impact appreciably impact results or conclusions. One RCT was considered to at least partially overlap with another larger trial and was excluded from main analyses. Two RCTs that enrolled exclusively children are discussed separately. Among studies enrolling adults, one compared the same OMBP regimen in the inpatient versus outpatient setting, and is also described separately.

f The retraction notice stated: “large portions of text … have been duplicated from another article previously published in Annals of Surgery”. In fact, the text (but not the numerical data) in the two publications is identical (despite being conducted by different research teams based in different countries), raising concerns about the truthfulness of reporting in the second study.

We classified the remaining 39 RCTs into two mutually exclusive groups: trials comparing OMBP versus no OMBP (with or without enema) – active versus inactive comparison; and trials comparing alternative active OMBP strategies – active versus active comparison. Studies belonging to the latter group were conducted in earlier years (median year of enrollment start = 1986), followed by studies investigating the omission of OMBP (median year of enrollment start = 2001). Figure 3 depicts this temporal pattern.

Figure 3 Enrollment periods for RCTs comparing OMBP versus no OMBP and alternative OMBP strategies

Note: The information in the figure includes only RCTs conducted in adult or mixed populations (i.e. studies exclusively enrolling children are not shown). Studies of inpatient vs. outpatient OMBP are also not shown. Horizontal lines denote the trial enrollment period (from enrollment start to end). Black lines denote trials comparing OMBP versus no OMBP; solid gray lines denote trials comparing alternative active OMBP preparations, and dashed gray lines denote nutritional preparation methods (prebiotics or symbiotics, with or without OMBP. Studies are plotted by year of enrollment start and then by year of publication. For studies not reporting the enrollment period we used the year of publication as the last year of enrollment and assumed a trial duration of one year.

Figure 3 depicts the enrollment periods for RCTs comparing OMBP versus no OMBP and alternative OMBP strategies. The information in the figure includes only RCTs conducted in adult patients. Horizontal lines denote the trial enrollment period (from enrollment start to end). Black lines denote trials comparing OMBP versus no OMBP; solid gray lines denote trials comparing alternative active OMBP preparations, and dashed gray lines denote nutritional preparation methods (prebiotics or symbiotics, with or without OMBP. Studies are plotted by year of enrollment start and then by year of publication. For studies not reporting the enrollment period we used the year of publication as the last year of enrollment and assumed a trial duration of one year. In general, studies comparing active OMBP strategies were initiated and completed before the mid-1990s; trials of OMBP versus enema or no preparation were mostly conducted in later years.

The two groups of studies also differed with respect to the type, duration, and intensity of preparation, as well as the administered cointerventions (Table 2). For example, OMBP by whole gut irrigation with electrolyte solutions other than polyethylene glycol (PEG) was a comparator in seven OMBP-treated arms in older studies, but in only two OMBP-treated arms in more recent studies (both of which were conducted in Pakistan). (Whole gut irrigation is often done through a nasogastric tube, and is more invasive than oral administration; PEG is one of the most commonly used solutions nowadays.) Most importantly, perioperative intravenous or intramuscular antibiotics were used in almost all studies comparing OMBP versus no OMBP (one study provided unclear information) but only in 26 of the 46 OMBP-treated arms in trials comparing alternative active OMBP preparations. The total duration of patient preparation for surgery also declined over time (Figure 4), indicating that older studies may have used more aggressive preoperative preparation strategies. Indeed, dietary modification of several days duration, repeated enemas, and multiday OMBP regimens were more often or even exclusively used in the older studies (Group 2).

Table 2 Study design aspects and OMBP methods used in included RCTs

Study Characteristics | | Trials Comparing OMBP vs. no OMBP(18 Trials With 18 OMBP-Treated Arms) | Trials Comparing Alternative Active OMBP Strategies (21 Trials With 46 OMBP-Treated Arms)
Study design and surgical technique | Median year starting enrollment | 2001 | 1986
Study design and surgical technique | Median number of included patients | 178 | 92
Study design and surgical technique | Reported performing a power calculation | 8 (44%) | 5 (24%)
Study design and surgical technique | Study conducted in the U.S. | 0 (0%) | 6 (29%)
Study design and surgical technique | At least some patients treated with laparoscopic surgery | 5 (33%) | 2 (10%)
OMBP strategy (in OMBP-treated groups) | PEG | 7 (39%) | 10 (22%)
OMBP strategy (in OMBP-treated groups) | Laxatives or cathartics | 5 (28%) | 16 (35%)
OMBP strategy (in OMBP-treated groups) | PEG + laxatives/cathartics | 1 (6%) | 3 (7%)
OMBP strategy (in OMBP-treated groups) | Hyperosmotic sodium solutions | 0 (0%) | 3 (7%)
OMBP strategy (in OMBP-treated groups) | Whole gut irrigation with electrolyte solution (non-PEG) | 2 (11%) | 7 (15%)
OMBP strategy (in OMBP-treated groups) | Dietary modifications (symbiotics/prebiotics) | 0 (0%) | 4 (9%)
OMBP strategy (in OMBP-treated groups) | Mixed/other | 3 (17%) | 3 (7%)
Planned administration through NG tube (in OMBP-treated groups) | | 2 (0%) | 8 (17%)
Cointerventions (in OMBP-treated groups) | IV antibiotics | 17 (94%) | 26 (57%)
Cointerventions (in OMBP-treated groups) | Oral antibiotics | 3 (17%) | 15 (33%)
Cointerventions (in OMBP-treated groups) | Enema | 6 (33%) | 12 (26%)

IV = intravenous; NG = nasogastric; OMBP = oral mechanical bowel preparation; PEG = polyethylene glycol

Note: Limited to studies of adult patients. Percentages have been rounded to the nearest integer.

Figure 4 Change in the duration of surgical preparation over time

Note: Limited to RCTs conducted in adult patients. Each dot represents an OMBP-treated arm. Markers have been jittered to make all OMBP-treated groups visible. A smoothed gray line is plotted to help visualize the association.

Figure 4 depicts the change in the duration of surgical preparation over time among RCTs conducted in adult patients. Each dot represents an OMBP-treated arm. Markers have been jittered to make all OMBP-treated groups visible. A smoothed line is plotted to help visualize the association. The figure show a decline from relatively long preparation regimens (3-4 days) to regimens with a duration of approximately one day.

Further, studies conducted in recent years tended to be better designed, with more studies reporting the conduct of a prospective power calculation (8 of 18 vs. 4 of 20). Reporting of randomization methods and allocation concealment was also generally better in recent studies.

Because of the aforementioned differences between studies of OMBP versus no OMBP and studies of active versus active OMBP comparisons with respect to design, interventions, and cointerventions, we review the findings separately by group.

## Ability To Evaluate the Effects of OMBP Separately by Anatomic Location

For Key Question 1 we planned to perform a detailed subgroup analysis of the effects of OMBP according to the anatomic location of the surgical procedures performed. However, of the 43 included RCTs, two enrolled exclusively patients undergoing colonic surgery and another enrolled exclusively patients undergoing rectal surgery. The remaining studies (n=40) enrolled mixed populations of patients undergoing both colon and rectal surgery, or did not provide details regarding anatomic location. Using information provided by the corresponding authors of studies included in this report (directly to us or to the authors of a recent Cochrane report), we were able to identify the anatomic location (colon versus rectum) only for the outcome of anastomotic leakage, and only for the comparison of OMBP versus enema or no preparation. These results are presented below.

## Comparisons of OMBP Versus No OMBP

Twenty RCTs and seven NRCSs compared OMBP versus no use of mechanical preparation. One RCT was reported in two papers, but it was not possible to deduce whether the two publications were in disjoint or overlapping sets of patients.^g^ To avoid double-counting, we did not use information from the publication reporting the smallest number of participants (50 patients).37 Even if said publications describe disjoint groups of patients, it is unlikely that excluding the smaller group changes our results or conclusions (only four clinical events were reported in that group—3 wound abscesses and 1 anastomotic leakage). We excluded from the main analysis a RCT described in a paper that was retracted because its text duplicated large portions from a previously published paper reporting the results of a different study, leaving a total of 18 RCTs and seven NRCSs.

g We contacted the corresponding author of these two publications to obtain additional information, however we have received no response as of September 24, 2013.

All but two studies enrolled adult patients (or did not provide relevant information). Two RCTs explicitly reported that the study population consisted of both adults and children, but did not report results stratified by age group.76 Because children are probably the minority of the study sample, and for consistency with previous work, we included these studies together with studies enrolling exclusively adults.1 In sensitivity analyses, we assessed the robustness of our results to their removal from the dataset.

Common indications for surgery were colorectal cancer and diverticular disease; seven studies explicitly reported excluding patients with inflammatory bowel disease and three studies enrolled exclusively patients with colorectal cancer. Details on the surgical approach (e.g., operation types, anastomosis methods, open versus surgical surgery) were generally incompletely reported.

### Direct Comparisons of OMBP Versus No OMBP in RCTs

In our main analyses, 18 RCTs reported comparisons of OMBP strategies versus strategies omitting OMBP. In six studies all participants in OMBP-treated groups received enemas. In one study enemas were administered only to patients with rectal cancer, and 11 studies did not administer enemas in the OMBP-treated groups. In their comparator groups, two studies used enemas for all participants, two studies administered enemas to patients undergoing rectal surgery, and 14 studies did not use any enema. In our main analyses, following previous work, we examined separately the comparisons of OMBP (with or without enema) versus enema, and OMBP versus no enema.

Studies used a variety of OMBP regimens: seven studies used PEG, five studies used other laxatives or cathartics, and six studies used other methods. Almost all studies reported using intravenous antibiotics in the perioperative period (1 study provided unclear information) and three studies reported also using oral antibiotics.

The majority of RCTs were considered to be at moderate risk of bias. Overall, based on the number of items considered indicative of low risk, eight studies were considered to be at high risk of bias, nine to be at moderate risk of bias, and one to be at low risk of bias. Additional details on risk of bias of individual studies are provided in the relevant section, below.

Table 3 presents a summary of the results of our main analysis for outcomes where meta-analysis was possible. The following sections present detailed results for each outcome of interest, followed by the results of sensitivity analyses. Throughout this section, odds ratio (OR) values lower than 1 indicate benefit (i.e., decreased incidence of complications) in OMBP treated patients, as compared to controls. Analyses are stratified by use of enema in the control group (i.e., OMBP versus enema and OMBP versus no preparation); combined analyses of all studies (OMBP versus no OMBP) are also presented in forest plots.

Table 3 Summary of meta-analysis results for the comparison of OMBP versus enema or no preparation

Outcome | Comparison | N Studies (N Events/N Patients, per Group) | OR (95% CrI) | Between-Study Variance (95% CrI) [log-odds ratio scale]
All-cause mortality | OMBP ± enema vs. enema/no prep | 14 (45/2,550 vs. 44/2,544) | 1.17 (0.67 to 2.67) | 0.12 (0.00 to 1.99)
All-cause mortality | OMBP ± enema vs. no prep | 10 (38/2,024 vs. 40/2,014) | 1.09 (0.57 to 2.99) | 0.17 (0.00 to 2.61)
All-cause mortality | OMBP ± enema vs. enema | 4 (7/526 vs. 4/530) | 1.99 (0.27 to 18.45) | 0.82 (0.00 to 3.76)
Anastomotic leakage | OMBP ± enema vs. enema/no prep | 16 (126/2,702 vs. 124/2,680) | 1.08 (0.79 to 1.63) | 0.08 (0.00 to 0.72)
Anastomotic leakage | OMBP ± enema vs. no prep | 12 (102/2,176 vs. 103/2,150) | 1.06 (0.73 to 1.73) | 0.09 (0.00 to 0.95)
Anastomotic leakage | OMBP ± enema vs. enema | 4 (24/526 vs. 21/530) | 1.24 (0.38 to 4.72) | 0.61 (0.00 to 3.59)
Wound Infection | OMBP ± enema vs. enema/no prep | 16 (266/2,612 vs. 239/2,603) | 1.19 (0.93 to 1.63) | 0.04 (0.00 to 0.41)
Wound Infection | OMBP ± enema vs. no prep | 12 (218/2,086 vs. 190/2,073) | 1.27 (0.95 to 1.88) | 0.05 (0.00 to 0.50)
Wound Infection | OMBP ± enema vs. enema | 4 (48/526 vs. 49/530) | 1.04 (0.37 to 3.34) | 0.52 (0.00 to 3.46)
Peritonitis/ intra-abdominal abscess | OMBP ± enema vs. enema/no prep | 14 (51/2,381 vs. 70/2,362) | 0.84 (0.50 to 1.66) | 0.25 (0.00 to 1.77)
Peritonitis/ intra-abdominal abscess | OMBP ± enema vs. no prep | 10 (45/1,855 vs. 64/1,832) | 0.84 (0.45 to 2.00) | 0.38 (0.00 to 2.74)
Peritonitis/ intra-abdominal abscess | OMBP ± enema vs. enema | 4 (6/526 vs. 6/530) | 0.99 (0.21 to 4.68) | 0.42 (0.00 to 3.51)
Reoperation | OMBP ± enema vs. enema/no prep | 8 (124/1,967 vs. 119/1,945) | 1.14 (0.57 to 2.65) | 0.38 (0.00 to 3.23)
Reoperation | OMBP ± enema vs. no prep | 6 (117/1,742 vs. 111/1,723) | 1.15 (0.73 to 2.50) | 0.09 (0.00 to 1.82)
Reoperation | OMBP ± enema vs. enema | 2 (7/225 vs. 8/222) | 0.50 (0.03 to 6.12) | 2.49 (0.27 to 3.93)
SSI | OMBP ± enema vs. enema/no prep | 7 (206/1,279 vs. 197/1,230) | 1.19 (0.56 to 2.63) | 0.64 (0.11 to 2.91)
SSI | OMBP ± enema vs. no prep | 5 (173/1,087 vs. 171/1,040) | 1.10 (0.41 to 3.05) | 0.76 (0.10 to 3.39)
SSI | OMBP ± enema vs. enema | 2 (33/192 vs. 26/190) | 1.50 (0.24 to 10.42) | 1.20 (0.02 to 3.79)

CrI = credible interval; no prep = no OMBP and no enema; OMBP = oral mechanical bowel preparation (with or without enema); OR = odds ratio; SSI = surgical site infection.

Note: OR values lower than 1 indicate that events are less common among OMBP-treated groups (i.e., that OMBP is beneficial).

#### All-Cause Mortality

##### OMBP Versus No Preparation

Ten RCTs comparing OMBP versus no preparation reported information on all cause mortality; eight of these reported the occurrence of at least one death. Study sizes ranged from 97 to 1354. Death was relatively rare (78 events in total across all nine studies). The summary OR for all-cause mortality for OMBP versus no preparation was 1.09 (95% CrI 0.57 to 2.99). However, the estimate was imprecise, reflecting the relatively small number of patients contributing information to the meta-analysis and the small number of observed events. There was little evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.17 (95 CrI, 0 to 2.61). Figure 5 presents the meta-analysis results, along with study-specific event rates.

Figure 5 All-cause mortality meta-analysis results for studies comparing OMBP (with or without enema) versus no preparation or enema

CI = confidence interval; CrI = credible interval; NA = not applicable; OMBP = oral mechanical bowel preparation; OR = odds ratio

Note: The solid squares (and horizontal lines) indicate the point estimate of the OR (and the corresponding 95% CI) for individual studies; the diamonds (and horizontal lines) indicate the summary estimate of the OR (and corresponding 95% central CrI). The numbers of events and the sample size of each treatment group are shown to the right of the plot. The dashed line indicates an OR of 1.

Figure 5 depicts the results of a meta-analysis of all-cause mortality for studies comparing OMBP (with or without enema) versus enema or no preparation. The summary OR comparing OMBP versus no OMBP was 1.17 (0.67, 2.67). The summary OR comparing OMBP versus no preparation was 1.09 (0.57, 2.99). The summary OR for OMBP versus enema was 1.99 (0.27, 18.45).

##### OMBP Versus Enema

Four RCTs comparing OMBP versus enema reported information on all-cause mortality (2 studies employed a strategy of selective enema use in patients undergoing elective colorectal surgery). Two of the four studies reported the occurrence of at least one outcome event. Studies were small (minimum = 153; maximum = 380) and reported a small number of outcome events (11 events total). The summary OR for all-cause mortality for OMBP versus enema was 1.99 (95% CrI 0.27 to 18.45). However, the estimate was very imprecise, reflecting the relatively small number of patients contributing information to the meta-analysis and the small number of observed events. There was some evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.82 (95 CrI, 0 to 3.76). Figure 5 presents the meta-analysis results, along with study-specific event rates.

#### Cause-Specific Mortality

##### OMBP Versus No Preparation

Only two studies comparing OMBP versus no preparation reported information on mortality, stratified by cause of death.8,55 The causes investigated included death due to chest infections, peritonitis, pulmonary embolism, and anastomotic leakage. Each study reported information on different causes of death. None of the comparisons were statistically significant and study-specific estimates of effect were very imprecise. Thus, no clinically meaningful conclusions could be reached.

##### OMBP Versus Enema

Only two studies comparing OMBP versus enema reported information on mortality, stratified by cause of death.73,93 The causes investigated included death due to infectious causes, anastomotic leakage, and cardiovascular causes (further stratified into deaths due to congestive heart failure, cardiac arrest, and acute myocardial infarction). Each study reported information on different causes of death. None of the comparisons were statistically significant and study-specific estimates of effect were very imprecise. Therefore, no clinically meaningful conclusions could be reached.

#### Anastomotic Leakage

##### OMBP Versus No Preparation

Twelve RCTs comparing OMBP versus no preparation reported information on anastomotic leakage; all studies reported the occurrence of at least one outcome event. Study sample size ranged from 79 to 1354. The total number of outcome events across all 12 studies was 205, i.e., events were relatively rare. The summary OR for anastomotic leakage in OMBP-treated patients versus controls was 1.06 (95% CrI 0.73 to 1.73). However, the estimate was somewhat imprecise, reflecting the relatively small number of patients contributing information to the meta-analysis and the small number of observed events. There was little evidence of between-study heterogeneity but there was uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.09 (95 CrI, 0 to 0.95). Figure 6 presents the meta-analysis results, along with study-specific event rates.

Figure 6 Anastomotic leakage meta-analysis results for studies comparing OMBP (with or without enema) versus no preparation or enema

CI = confidence interval; CrI = credible interval; NA = not available (could not be estimated); OMBP = oral mechanical bowel preparation; OR = odds ratio

Note: The solid squares (and horizontal lines) indicate the point estimate of the OR (and the corresponding 95% CI) for individual studies; the diamonds (and horizontal lines) indicate the summary estimate of the OR (and the corresponding 95% central CrI). The numbers of events and the sample size of each treatment group are shown to the right of the plot. The dashed line indicates an OR of 1.

Figure 6 depicts the results of a meta-analysis of anastomotic leakage for studies comparing OMBP (with or without enema) versus enema or no preparation. The summary OR comparing OMBP versus no OMBP was 1.08 (0.79, 1.63). The summary OR comparing OMBP versus no preparation was 1.06 (0.73, 1.73). The summary OR for OMBP versus enema was 1.24 (0.38, 4.72)

##### OMBP Versus Enema

Four RCTs comparing OMBP versus enema reported information on anastomotic leakage (2 studies employed a strategy of selective enema use in patients undergoing elective colorectal surgery); all studies reported the occurrence of at least one outcome event. Studies were small (minimum = 153; maximum = 380) and reported a small number of outcome events (45 events total). The summary OR for all-cause mortality in OMBP-treated patients versus controls was 1.24 (95% CrI 0.38 to 4.72). This estimate was imprecise, reflecting the relatively small number of patients contributing information to the meta-analysis and the small number of observed events. There was some evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.61 (95 CrI, 0 to 3.59). Figure 6 presents the meta-analysis results, along with study-specific event rates.

#### Wound Infection

##### OMBP Versus No Preparation

Twelve RCTs comparing OMBP versus no preparation reported information on wound infection; eleven studies reported the occurrence of at least one outcome event in either arm. Studies had varying sample sizes (minimum = 42; maximum = 1354) and reported a total of 388 outcome events. The summary OR for wound infection was 1.27 (95% CrI 0.95 to 1.88). There was little evidence of between-study heterogeneity but there was uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.05 (95 CrI, 0 to 0.5). Figure 7 presents the meta-analysis results, along with study-specific event rates.

Figure 7 Wound infection meta-analysis results for studies comparing OMBP (with or without enema) versus no preparation or enema

CI = confidence interval; CrI = credible interval; NA = not available (could not be estimated); OMBP = oral mechanical bowel preparation; OR = odds ratio

Note: The solid squares (and horizontal lines) indicate the point estimate of the OR (and the corresponding 95% CI) for individual studies; the diamonds (and horizontal lines) indicate the summary estimate of the OR (and the corresponding 95% central CrI). The numbers of events and the sample size of each treatment group are shown to the right of the plot. The dashed line indicates an OR of 1.

Figure 7 depicts the results of a meta-analysis of wound infection Results for studies comparing OMBP (with or without enema) versus enema or no preparation. The summary OR comparing OMBP versus no OMBP was 1.19 (0.93, 1.63). The summary OR comparing OMBP versus no preparation was 1.27 (0.95, 1.88). The summary OR for OMBP versus enema was 1.04 (0.37, 3.34).

##### OMBP Versus Enema

Four RCTs comparing OMBP versus enema reported information on wound infection (2 studies employed a strategy of selective enema use in patients undergoing elective colorectal surgery); all studies reported the occurrence of at least one outcome event. Studies were small (minimum sample size= 153; maximum = 380) and reported a total of 97 outcome events. The summary OR for wound infection was 1.04 (95% CrI 0.37 to 3.34). There was some evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.52 (95 CrI, 0 to 3.46). Figure 7 presents the meta-analysis results, along with study-specific event rates.

#### Peritonitis or Intra-Abdominal Abscess

##### OMBP Versus No Preparation

Ten RCTs comparing OMBP versus no preparation reported information on peritonitis or intra-abdominal abscess development; all studies reported the occurrence of at least one outcome event. Studies had varying sample sizes (minimum = 42; maximum = 1354) and reported a small number of outcome events (109 events total). The summary OR for peritonitis or intra-abdominal abscess development was 0.84 (95% CrI 0.45 to 2.00). However, the estimate was somewhat imprecise, reflecting the relatively small number of patients contributing information to the meta-analysis and the small number of observed events. There was some evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.38 (95 CrI, 0 to 2.74). Figure 8 presents the meta-analysis results, along with study-specific event rates.

Figure 8 Peritonitis/intra-abdominal abscess meta-analysis results for studies comparing OMBP (with or without enema) versus no preparation or enema

CI = confidence interval; CrI = credible interval; NA = not available (could not be estimated); OMBP = oral mechanical bowel preparation; OR = odds ratio

Note: The solid squares (and horizontal lines) indicate the point estimate of the OR (and the corresponding 95% CI) for individual studies; the diamonds (and horizontal lines) indicate the summary estimate of the OR (and the corresponding 95% central CrI). The numbers of events and the sample size of each treatment group are shown to the right of the plot. The dashed line indicates an OR of 1.

Figure 8 depicts the results of a meta-analysis of peritonitis/ intra-abdominal abscess for studies comparing OMBP (with or without enema) versus enema or no preparation. The summary OR comparing OMBP versus no OMBP was 0.84 (0.50, 1.66). The summary OR comparing OMBP versus no preparation was 0.84 (0.45, 2.00). The summary OR for OMBP versus enema was 0.99 (0.21, 4.68).

##### OMBP Versus Enema

Four RCTs comparing OMBP versus enema reported information on peritonitis or intra-abdominal abscess development (2 studies employed a strategy of selective enema use in patients undergoing elective colorectal surgery); seven studies reported the occurrence of at least one outcome event. Studies were small (minimum = 153; maximum = 380) and reported a small number of outcome events (12 events total). The summary OR for peritonitis or intra-abdominal abscess development, comparing OMBP-treated patients versus controls was 0.99 (95% CrI 0.21 to 4.68). There was some evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.42 (95 CrI, 0 to 3.51). Figure 8 presents the meta-analysis results, along with study-specific event rates.

#### Reoperation

##### OMBP Versus No Preparation

Six RCTs comparing OMBP versus no preparation reported information on reoperation; all studies reported the occurrence of at least one outcome event. Studies had varying sample sizes (minimum = 149; maximum = 1354) and reported a total of 228 events. The summary OR for reoperation was 1.15 (95% CrI 0.73 to 2.50). There was little evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.09 (95 CrI, 0 to 1.82). Figure 9 presents the meta-analysis results, along with study-specific event rates.

Figure 9 Reoperation meta-analysis results for studies comparing OMBP (with or without enema) versus no preparation or enema

CI = confidence interval; CrI = credible interval; NA = not available (could not be estimated); OMBP = oral mechanical bowel preparation; OR = odds ratio

Note: The solid squares (and horizontal lines) indicate the point estimate of the OR (and the corresponding 95% CI) for individual studies; the diamonds (and horizontal lines) indicate the summary estimate of the OR (and the corresponding 95% central CrI). The numbers of events and the sample size of each treatment group are shown to the right of the plot. The dashed line indicates an OR of 1.

Figure 9 depicts the results of a meta-analysis of reoperation for studies comparing OMBP (with or without enema) versus enema or no preparation.The summary OR comparing OMBP versus no OMBP was 1.14 (0.57, 2.65). The summary OR comparing OMBP versus no preparation was 1.15 (0.73, 2.50). The summary OR for OMBP versus enema was 0.50 (0.03, 6.12).

##### OMBP Versus Enema

Two RCTs comparing OMBP versus enema reported information on reoperation; both studies reported the occurrence of at least one outcome event. Studies were relatively small (sample sizes were 154 and 294) and reported a small number of outcome events (15 events total). The summary OR for reoperation was 0.50 (95% CrI 0.03 to 6.12). However, the estimate was extremely imprecise, reflecting the small number of patients contributing information to the meta-analysis, the very small number of observed events. There was little evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 2.49 (95 CrI, 0.27 to 3.93). Figure 9 presents the meta-analysis results, along with study-specific event rates.

#### Surgical Site Infections

##### OMBP Versus No Preparation

Five RCTs comparing OMBP versus no preparation reported information on infectious complications classified as surgical site infections; all studies reported the occurrence of at least one outcome event. Studies had varying sample sizes (minimum = 129; maximum = 1343) and reported a total of 344 events. The summary OR for SSI, comparing OMBP-treated patients versus controls was 1.10 (95% CrI 0.41 to 3.05). However, the estimate was somewhat imprecise, reflecting the relatively small number of studies contributing information to the meta-analysis. There was some evidence of between-study heterogeneity but there was substantial uncertainty for this parameter: the posterior distribution of the between-study variance of the log-OR had a median of 0.76 (95 CrI, 0.10 to 3.39). Figure 10 presents the meta-analysis results, along with study-specific event rates.

Figure 10 Surgical site infection meta-analysis results for studies comparing OMBP (with or without enema) versus no preparation or enema

CI = confidence interval; CrI = credible interval; NA = not available (could not be estimated); OMBP = oral mechanical bowel preparation; OR = odds ratio

Note: The solid squares (and horizontal lines) indicate the point estimate of the OR (and the corresponding 95% CI) for individual studies; the diamonds (and horizontal lines) indicate the summary estimate of the OR (and the corresponding 95% central CrI). The numbers of events and the sample size of each treatment group are shown to the right of the plot. The dashed line indicates an OR of 1.

Figure 10 depicts the results of the meta-analysis of surgical site infection for studies comparing OMBP (with or without enema) versus enema or no preparation. The summary OR comparing OMBP versus no OMBP was 1.19 (0.56, 2.63). The summary OR comparing OMBP versus no preparation was 1.10 (0.41, 3.05). The summary OR for OMBP versus enema was 1.50 (0.24, 10.42).

##### OMBP Versus Enema

Two RCTs comparing OMBP versus enema reported information on surgical site infections. Studies were small (sample sizes of 153 and 229) and reported a small number of outcome events (59 events total). The summary OR for surgical site infections was 1.50 (95% CrI 0.24 to 10.42). However, the estimate was very imprecise, reflecting the relatively small number of patients contributing information to the meta-analysis, the small number of observed events, and the presence of substantial between-study heterogeneity: the posterior distribution of the between-study variance of the log-OR had a median of 1.20 (95 CrI, 0 to 3.79). Figure 10 presents the meta-analysis results, along with study-specific event rates.

#### Venous Thromboembolism (Deep Venous Thrombosis and Pulmonary Embolism)

##### OMBP Versus No Preparation

Three studies comparing OMBP versus no preparation reported information on venous thromboembolic outcomes (1 study reported information on pulmonary embolism, 1 study on venous thrombosis, and 1 on both outcomes). None of the comparisons were statistically significant, and study-specific estimates of effect were very imprecise. Thus, no clinically meaningful conclusions could be reached.

##### OMBP Versus Enema

No studies comparing OMBP versus enema reported information on venous thromboembolic outcomes.

#### Length of Hospital Stay

##### OMBP Versus No Preparation

Nine studies comparing OMBP versus no preparation reported information on mean or median length of hospital stay (6 studies on total and 3 studies on postoperative length of stay), but did not report information to enable statistical testing. The difference in mean or median length of stay between groups ranged from -5 days to 4.4 days and was positive in four studies, negative in two studies, and (reported as) exactly zero in two studies (positive values indicate longer average length of stay for patients in the OMBP-treated group). Statistical comparisons of the duration of stay were possible only in five of the studies (3 reporting on total length of stay and 2 reporting on postoperative stay); differences were statistically non-significant in one study (longer total duration in the OMBP-treated group).

##### OMBP Versus Enema

Three studies comparing OMBP versus enema reported information on mean or median total length of hospital stay (no studies reported information separately for the pre- and postoperative periods), but did not report information to enable statistical testing. The difference in mean or median length of stay ranged from 0.1 days to 0.9 days (and was positive in all studies).

#### Patient Satisfaction and Quality of Life

No studies reported information on patient satisfaction and quality of life using appropriate measurement scales. However, several studies assessed patient-relevant symptoms (e.g., nausea, discomfort, malaise, etc.) using ordinal scales. Findings from these studies have been summarized in Key Question 2.

#### Other Outcomes

No studies provided information on other prespecified effectiveness outcomes for this Key Question (unplanned ostomies, failed attempts to restore bowel continuity, readmissions after surgery, additional interventional procedures (other than surgery); admission to intensive care unit, admission to nursing care).

### Sensitivity Analyses

For mortality, anastomotic leakage, and wound infection we reanalyzed the available data after (1) excluding two studies76,81 that included both adults and children (and did not report results separately by age group); (2) excluding one study55 that was unclearly reported and had been presented as a conference paper published in a peer-reviewed journal (this study was also excluded from a recent Cochrane review on OMBP); (3) including the one study78 that has been retracted; (4) excluding studies using selective enema strategies in their control groups38,93 (in main analyses, we included studies using enemas for patients undergoing rectal surgery only together with studies using enema on all patients, because we reasoned that this is the subgroup of patients most likely to experience any effects from enema use). The complete results of these sensitivity analyses are presented in Appendix C. These analyses produced results that were consistent with our main analyses (presented above).

We also examined whether our results were robust to the choice of alternative analysis methods. Appendix D presents sensitivity analyses for Bayesian pairwise meta-analyses with respect to the choice of alternative prior distributions for the between-studies variance parameter. Appendix E presents results of frequentist (non-Bayesian) analyses for all outcomes and all comparisons presented in the preceding section. Overall, none of these analyses produced results that were qualitatively different from those our main analyses (presented above).

### Risk of Bias Assessment for Individual Studies

Information on trial design needed to assess the risk of bias of individual studies was not fully reported. For example, among the 18 RCTs comparing OMBP versus no OMBP, information on randomized sequence generation and allocation concealment was deemed “unclear” in eight and 10 studies, respectively. In addition, blinding of patients, care providers, and outcome assessors was unclear in 14, 10, and 12 of the studies, respectively. In contrast, information on withdrawals and dropouts was better reported. Of the studies reporting relevant information, only two reported a dropout rate of more than 10 percent (both only in their no-OMBP trial groups) and no study had evidence of differential dropout (defined as a greater than 10 percent difference in the dropout rate between treatment groups). Overall, based on the number of items considered indicative of Low risk, eight studies were considered to be at high risk of bias, nine to be at intermediate risk of bias, and one to be at low risk of bias. As always, aggregated risk of bias assessments need to be interpreted with caution, given our inability to fully distinguish inappropriate study design from poor reporting and lack of context-specific evidence that the risk items we assessed are indeed associated with bias.

### Association of Anatomic Location and Study Characteristics (Including Risk of Bias Items) With OMBP Effectiveness

We investigated whether the effect of OMBP varied by anatomic location (colon versus rectum), year of publication, or items related to study risk of bias (specifically, randomized sequence generation and allocation concealment).

#### Anatomic Location

Using published data and information obtained though author contact, separate analyses by anatomic location were possible for the outcome of anastomotic leakage (data were insufficient for other outcomes). There was limited evidence of effect modification by anatomic location; however, summary estimates were imprecise and evidence was available only from 10 studies (11 publications) that used heterogeneous subgroup definitions. The OR for anastomotic leakage comparing OMBP versus enema or no preparation was 1.01 (95% CrI, 0.57 to 2.13) for colon surgery (9 studies); and 0.91 (95% CrI, 0.42 to 2.45) for rectal surgery (7 studies; 6 studies provided information for both subgroups).

#### Year of Study Publication

In meta-regression analyses comparing OMBP versus enema or no preparation (Table 4) over year of publication, the 95% CrI of the relative OR included the null value; however, CrIs were wide, indicating substantial uncertainty regarding changes in treatment effectiveness over time. Thus, definitive conclusions about the presence of temporal trends could not be drawn.

Table 4 Meta-regression results for studies comparing OMBP (with or without enema) versus enema or no preparation

Potential Modifier | Outcome | rOR (95% CrI)
Year of publication (per decade) | All-cause mortality | 0.79 (0.38 to 1.55)
Year of publication (per decade) | Anastomotic leakage | 0.80 (0.41 to 1.65)
Year of publication (per decade) | Wound infection | 1.00 (0.73 to 1.41)
ROB for randomized sequence generation (low vs. moderate/high/unclear) | All-cause mortality | 0.35 (0.08 to 1.52)
ROB for randomized sequence generation (low vs. moderate/high/unclear) | Anastomotic leakage | 0.71 (0.36 to 1.50)
ROB for randomized sequence generation (low vs. moderate/high/unclear) | Wound infection | 0.91 (0.51 to 1.73)
ROB for allocation concealment (low vs. moderate/high/unclear) | All-cause mortality | 0.90 (0.24 to 3.88)
ROB for allocation concealment (low vs. moderate/high/unclear) | Anastomotic leakage | 0.45 (0.23 to 0.85)
ROB for allocation concealment (low vs. moderate/high/unclear) | Wound infection | 0.64 (0.38 to 1.08)

CrI = credible interval; ROB = risk of bias; rOR = relative odds ratio; SSI = surgical site infection

Note: Results suggestive of an association are highlighted in bold type.

#### Risk of Bias Items

In meta-regression analyses comparing OMBP versus enema or no preparation over randomized sequence generation (Table 4), the 95% CrI of the relative OR included the null value for all key outcomes with 10 or more available studies. However, CrIs were wide, indicating substantial uncertainty regarding differences across studies.

For allocation concealment the OR comparing OMBP versus enema or no preparation was lower in trials considered at low risk of bias compared to trials at higher or unclear risk. Specifically, trials with adequate allocation concealment methods suggested that OMBP has a protective effect (i.e., OR <1); whereas trials with inadequate or unclear allocation concealment methods had a summary effect in the opposite direction (i.e., OR>1) (Table 4). Clearly, appropriate (and well-reported) procedures of allocation concealment are preferable in any clinical trial. However, we caution against interpreting our result as “proof” for the presence of bias because the reporting of allocation concealment was incomplete in the reviewed studies, other study characteristics that may be associated with allocation concealment methods (and reporting) could not be accounted for in the analysis, the association was observed only for one of the outcomes of interest (and in one of several regression analyses), and the relative OR was extreme and fairly imprecise. Of note, in the low risk of bias subgroup of studies the CrI of the OR comparing OMBP versus enema or no preparation for anastomotic leakage included the null value; OR = 0.81 (95% CrI, 0.56 to 1.19). These findings in conjunction with the wide credible intervals observed in the overall meta-analysis support the need for more research.

Other risk of bias items were poorly reported and did not show adequate variation across studies; for this reason they were not considered in meta-regression analyses.

### Direct Comparisons of OMBP Versus No OMBP in NRCSs

Seven NRCSs reported information on the comparison of OMBP versus omission of preparation. Because of heterogeneity in patient selection and outcomes reported, differences in study design, and concerns regarding risk for residual confounding we did not perform meta-analysis.

One study74 reported an experimental^h^ nonrandomized comparison of OMBP (165 patients, all treated with sodium phosphate) versus no preparation (164 patients) in patients undergoing elective colorectal surgery in a single center. Assignment to treatments was based on patients' identification numbers, offering some protection from confounding bias. The study found no statistically significant difference between the two groups for the outcomes of all-cause mortality, wound dehiscence, wound infection, anastomotic leakage, thrombophlebitis, or the need for repeat laparotomy. Events were more common in the OMBP group for all outcomes except anastomotic leakage and thrombophlebitis. For all outcomes, estimates of effect were very imprecise and no between-group difference was statistically significant. The study was considered to be at moderate risk of bias because of lack of randomization, allocation concealment, or blinding of care providers and outcome assessors.

h Experimental indicates that the investigators had control over treatment assignment (i.e., patients did not self-select into treatments). However, treatment assignment was deterministic (based on patient's identification numbers).

Another study53 reported an observational comparison of anastomotic leakage rates among patients treated at a single center before (1997–2002) and after (2002–2006) the implementation of a policy of omitting OMBP (in the first period patients were treated with bisacodyl and sodium phosphate). The authors noted that another change in treatment policy occurred during the study period: a replacement of ibuprofen by celecoxib (for the years between 2003 and 2004). The rates of anastomotic leakage were 3.5 percent (7 of 203 patients) versus 1.7 percent (3 of 180 patients) during the period of OMBP plus celecoxib and no OMBP no celecoxib preparation (P = 0.35). Results for the other treatment periods were not reported and the study was considered to be at high risk of bias because historical comparisons were unadjusted for potential confounding factors (particularly those that vary over time).

The third study63 reported results from an observational analysis of 2263 patients undergoing nonemergent colectomy in 24 hospitals participating in the Michigan Surgical Quality Collaborative Colectomy project. A total of 1685 patients received OMBP (oral cathartics with or without enema; in 684 patients combined with oral antibiotics and in 1001 without), and 578 did not; the study outcome was the development of Clostridium difficile infection. The adjusted OR comparing OMBP-treated versus not treated patients was 0.96 (95% CI 0.50 to 1.83) and was not-statistically significant. Among patients who received OMBP, the use of oral antibiotics was associated with a statistically nonsignificant reduction in the odds of Clostridium difficile infection (OR = 0.60; 95% CI 0.29 to 1.23). The study was considered to be at high risk of bias because of concerns about residual confounding (factors that differed between treated groups at baseline, and other potential confounders, may not have been included in the multivariable analysis because of the variable selection method employed).

The fourth study60 also used data from the Michigan Surgical Quality Collaborative Colectomy project to compare OMBP with oral antibiotics versus no OMBP (with or without oral antibiotics); patients receiving OMBP without oral antibiotics were excluded. Using propensity score methods, 957 treated patients were matched with an equal number of untreated patients (1:1 matching). In matched-pair analyses, OMBP with oral antibiotics was associated with a lower incidence proportion of organ space (1.57% versus 3.13%; P=0.024), superficial (2.93% versus 5.96%%; P=0.001), and overall surgical site infections (5.02% versus 9.72%; P<0.001), but not deep incisional infections (0.73% in both groups; P=0.99). The study was deemed to be at moderate risk of bias; even though matching was performed for a fair amount of variables some important variables were not considered (e.g., the type of surgical operation or its anatomic location). In addition, because of the design of the study, the effect of OMBP could not be identified from that of oral antibiotics.

The fifth study40 reported results from an observational retrospective analysis of data from the Veterans Affairs Surgical Quality Improvement Program, using the Veterans Affairs Surgical Care Improvement Project and Pharmacy Benefits Management data to evaluate the impact of OMBP on surgical site infections within 30 days of elective colorectal surgery. The study included a total of 9940 patients (1978 received no preparation; 723 received oral antibiotics only; 3839 receive OMBP only; and 3400 received OMBP and oral antibiotics). OMBP strategies included polyethylene glycol, sodium phosphate, and magnesium citrate. In multivariable analyses (including 6070 patients), using the no preparation as the baseline, the OR for surgical site infection was 0.33 (95% CI 0.21 to 0.50); 0.99 (95% CI 0.80 to 1.22); and 0.43 (95% CI 0.34 to 0.55), for patients receiving oral antibiotics, OMBP without antibiotics, and OMBP plus oral antibiotics, respectively. The study was considered to be at moderate risk of bias because of concerns regarding residual confounding (a limited number of covariates were controlled in the analysis).

The sixth study82 also used results from the Veterans Affairs Surgical Quality Improvement Program to evaluate the impact of OMBP for colorectal surgery on length of stay and readmission within 30 days of the operation. The study included a total of 8180 patients (1412 received no preparation; 3193 received OMBP alone; and 3575 received oral antibiotic preparation, with or without OMBP; the later group was not further stratified by OMBP use). In analyses adjusted for indication for surgery, age, procedure type, ostomy, American Society of Anesthesiologists class, and wound class, use of OMBP (without oral antibiotics) was associated with reduced length of stay; the number of hospitalization days was approximately 3.5% lower compared to no preparation; P=0.023. Use of oral antibiotic preparation (with or without OMBP) was also associated with reduced length of stay; the number of hospitalization days was 11% lower compared to no preparation; P<0.001. In analyses of readmission within 30 days, adjusted for the same variables as the analyses of length of stay, oral antibiotic preparation (with or without OMBP) was associated with reduced odds of readmission (OR=0.81; 95% CI, 0.68 to 0.97). In contrast, OMBP alone was not associated statistically significantly with the odds of readmission (OR=0.96; 95% CI, 0.81 to 1.15). The study was considered to be at moderate risk of bias because of concerns regarding residual confounding.

The seventh study69 reported results using clinical audit data from the West of Scotland Colorectal Cancer Managed Clinical Network, and death records from the Scottish Cancer Registry and General Register Office of Scotland. The study included a total of 1730 patients (1460 received OMBP and 270 did not). In multivariable analyses, the OR for mortality comparing OMBP-treated versus non-treated patients was 0.85 (95% CI 0.67 to 1.10); P = 0.22; at a mean followup of 3.5 years. In unadjusted analyses of 30-day postsurgical outcomes, there was no statistically significant difference between groups for anastomotic leakage, intra-abdominal abscess, fistula, would infection, deep venous thrombosis, pulmonary embolism, chest infection, or a composite of any postoperative complication. The study was considered to be at moderate risk of bias on the basis of concerns about residual confounding and because some of the comparisons between treatment groups were not adjusted for potential confounders.

Overall, the NRCSs reported results consistent with those of RCTs and did not demonstrate significant differences between OMBP and no-OMBP strategies. However, studies were at substantial risk of bias, mostly due to confounding factors that had not been adequately controlled in the design or analysis of these investigations.

### Network Meta-Analysis

To further explore the available data on the effectiveness of OMBP, as compared to enema or no preparation, we analyzed the data presented in the previous section using Bayesian network meta-analysis of the 18 RCTs comparing OMBP versus enema or no preparation. The underlying model respects the randomization procedure within each study and allows us to borrow strength across different direct comparisons when estimating between-study heterogeneity. See the Methods section for additional information on the network structure and details of the statistical analysis.

### Comparative Effectiveness of OMBP, Enema, and No Preparation

Our main analysis used 3-node network structure (topology) comparing OMBP (with or without enema) versus enema alone and versus no preparation. Figure 11 presents the structure of the network. Estimates of the comparative effectiveness of enema versus no preparation can only be obtained via indirect comparisons (because no trials directly comparing these two interventions were included in our analyses), and are not shown.

Figure 11 Three-node network structure

No prep = no OMBP and no enema; OMBP = oral mechanical bowel preparation

Note: Structure for the 3-node network meta-analysis comparing OMBP +/- enema vs. enema alone vs. no preparation. Nodes indicate the treatments compared. Connecting lines depict direct comparisons and are labeled with the total number of available studies (not all studies contributed data for all outcomes).

Figure 11 depicts the 3-node network structure. The network includes 3 notes: OMBP with or without enema; enema; no preparation. Direct comparisons were available between OMBP with or without enema versus no preparation, and OMBP with or without enema versus enema.

Table 5 summarizes the results of this analysis, for all the possible pairwise comparisons, for outcomes where enough studies were available. Generally, results are consistent with those of the direct comparisons reported in the preceding section: 95% credible intervals do not exclude the null value for any outcome.

Table 5 Summary estimates from the three-node network meta-analysis

Outcome | Comparison | OR (95% CrI)
All-cause mortality | OMBP ± enema vs. no prep | 1.08 (0.56 to 3.02)
All-cause mortality | OMBP ± enema vs. enema | 1.88 (0.40 to 10.56)
Anastomotic leakage | OMBP ± enema vs. no prep | 1.07 (0.73 to 1.73)
Anastomotic leakage | OMBP ± enema vs. enema | 1.20 (0.57 to 2.61)
Wound infection | OMBP ± enema vs. no prep | 1.27 (0.94 to 1.91)
Wound infection | OMBP ± enema vs. enema | 1.00 (0.59 to 1.76)
Peritonitis/intra-abdominal abscess | OMBP ± enema vs. no prep | 0.82 (0.46 to 1.82)
Peritonitis/intra-abdominal abscess | OMBP ± enema vs. enema | 0.99 (0.24 to 4.07)

CrI = credible interval; no prep = no OMBP and no enema; OMBP = oral mechanical bowel preparation; OR = odds ratio

Note: OR values lower than 1 indicate that events are less common among treatment groups receiving the first listed treatment for each comparison. Results based on indirect comparisons were imprecise and are not shown.

#### Rank Probabilities

Using the network structure presented in Figure 11 we estimated the probability of a given treatment to be the best (i.e., to be associated with the lowest incidence of harmful events, rank = 1), second best (rank = 2), or last (rank = 3) with respect to each of four key outcomes of interest: all-cause mortality, anastomotic leakage, wound infection, and peritonitis or intra-abdominal abscess (Figure 12). The rank probabilities take into account the difference in the point estimates of the treatment effects and the uncertainty around them. However, they do not readily convey the difference in the treatment effects and they have to be interpreted with caution. Overall, across outcomes, no one intervention appears to be uniformly better or worse than the others.

Figure 12 Ranking of treatments based on the 3-node network meta-analysis

No prep = no OMBP and no enema; OMBP = oral mechanical bowel preparation

Each panel depicts the estimated probability that a given treatment is the best (rank = 1), second best (rank = 2), or last (rank = 3), for each of the outcomes of interest. Probabilities across ranks (within a treatment) and probabilities of the same rank (across treatments) sum to 1.

Figure 12 depicts the ranking of treatments based on the 3-node network meta-analysis. Each panel depicts the estimated probability that a given treatment is the best (rank = 1), second best (rank = 2), or last (rank = 3), for each of the outcomes of interest. Probabilities across ranks (within a treatment) and probabilities of the same rank (across treatments) sum to 1. There is no clearly dominant treatment.

#### Probability of Differences Above Threshold Values

We also estimated the probability that the true OR comparing pairs of interventions was above or below some threshold. These results are summarized in Table 6. Note the substantial uncertainty around summary estimates: although very extreme OR values (i.e., below 0.5 and above 3) are quite unlikely for all outcomes, values less than 0.8 or greater than 1.25, corresponding to a decrease of 20 percent or an increase of 25 percent in the odds of an event, are not unlikely for almost all outcomes.

Table 6 Probability that the treatment effect is smaller (or larger) than various cut-off values, for each outcome of interest

Outcome | Comparison | Probability That the OR is Smaller Than (or Exceeds) a Threshold Value
Outcome | Comparison | <0.2 | <0.333 | <0.5 | <0.667 | <0.80 | <0.91 | >1 | >1.10 | >1.25 | >1.5 | >2 | >3 | >5
All-cause mortality | OMBP vs.no prep | 0 | 0 | 0.01 | 0.07 | 0.17 | 0.3 | 0.59 | 0.48 | 0.34 | 0.2 | 0.08 | 0.03 | 0.01
All-cause mortality | OMBP vs. enema | 0.01 | 0.02 | 0.04 | 0.08 | 0.13 | 0.16 | 0.8 | 0.77 | 0.71 | 0.62 | 0.47 | 0.27 | 0.11
Anastomotic leakage | OMBP vs.no preparation | 0 | 0 | 0 | 0.01 | 0.07 | 0.2 | 0.63 | 0.44 | 0.22 | 0.07 | 0.01 | 0 | 0
Anastomotic leakage | OMBP vs. enema | 0 | 0 | 0.01 | 0.06 | 0.14 | 0.22 | 0.69 | 0.59 | 0.45 | 0.27 | 0.09 | 0.01 | 0
Wound infection | OMBP vs.no prep | 0 | 0 | 0 | 0 | 0 | 0.02 | 0.94 | 0.82 | 0.54 | 0.18 | 0.02 | 0 | 0
Wound infection | OMBP vs. enema | 0 | 0 | 0.01 | 0.06 | 0.19 | 0.35 | 0.5 | 0.36 | 0.2 | 0.07 | 0.01 | 0 | 0
Peritornitis/ intra-abdominal abscess | OMBP vs.no prep | 0 | 0 | 0.05 | 0.24 | 0.46 | 0.62 | 0.28 | 0.2 | 0.12 | 0.06 | 0.02 | 0 | 0
Peritornitis/ intra-abdominal abscess | OMBP vs. enema | 0.01 | 0.06 | 0.16 | 0.28 | 0.38 | 0.45 | 0.49 | 0.44 | 0.37 | 0.27 | 0.16 | 0.06 | 0.01

No prep = no OMBP and no enema; OMBP = oral mechanical bowel preparation; OR =odds ratio

Note: “0” should be interpreted as very low probability (because the probability cannot be exactly zero).

#### Analysis of a Structural Variant of the Network

Appendix F presents the results of structural sensitivity analysis for the network meta-analysis. Appendix Figure F1 shows the topology of the structural variant of the network. Overall, the results of this sensitivity analysis (Appendix Table F1) are consistent with those based on the 3-node network model (Table 5): although there is even greater uncertainty regarding the comparative effectiveness of the available interventions than under the previous two models. This is particularly true for rare outcomes (e.g., mortality) and for comparisons without head to head data. Therefore the analysis did not lead to definitive conclusions regarding the effect of adding enema to OMBP.

## Comparisons of Alternative Active OMBP Strategies

For the reasons outlined in the beginning of the Results chapter, studies comparing alternative active OMBP strategies were considered separately from those reporting on comparisons between OMBP and no OMBP strategies.

Twenty-three RCTs and two NRCSs provided information on comparisons among active OMBP strategies for adult patients undergoing elective colorectal surgery. We first examine the findings of RCTs, followed by the findings of NRCSs.

### RCTs Comparing Alternative OMBP Strategies

Twenty-one of the 23 RCTs enrolled primarily adult patients and two enrolled exclusively children. The most common indications for surgery were colorectal cancer and diverticular disease. Two studies enrolled only patients diagnosed with cancer. Eight studies excluded patients with inflammatory bowel disease. Details on the surgical approach (e.g., operation types, anastomosis methods, open versus laparoscopic surgery) were generally not reported. Information on the breakdown of surgical sites into right colon, left colon and rectum was generally not reported. Most studies enrolled mixed populations of patients undergoing colon and rectal surgery, but none reported outcome data separately by anatomic location. One study enrolled exclusively patients undergoing left colon or rectal surgery. No study enrolled exclusively patients undergoing rectal surgery.

We grouped OMBP strategies in the active versus active studies into seven grand categories to facilitate synthesis and presentation, as described in the Methods section: PEG, hyperosmotic sodium solutions, other laxatives or cathartics, PEG and laxatives/cathartics, whole gut irrigation, mixed/other, and dietary interventions. The most common comparisons were between PEG- versus whole-gut-irrigation-based OMBP (examined in 5 RCTs) and PEG-based versus laxative/cathartic-based OMBP (6 RCTs). Note that we were lenient in the grouping of OMBP interventions in the seven categories, and that the actual interventions in RCTs that are grouped in the same category can be quite diverse.

The majority of RCTs (19 out of 23) had two treatment groups; three had three groups and one had four groups, for a total of 51 active OMBP groups and 34 possible pairwise contrasts. Studies compared diverse OMBP strategies: of the 51 groups, 12 received PEG solutions, 16 laxatives or cathartics (mainly, senna or bisacodyl), three hyperosmotic sodium solutions, three a combination of PEG with laxatives or cathartics, 10 whole gut irrigation with electrolyte solutions other than PEG (typically Ringer's lactate or normal saline), three combinations of these strategies or other OMBP drugs, and four nutritional interventions (prebiotics or symbiotics).

Many items necessary for detailed assessment of all risk of bias were unreported in most studies. Overall, based on the number of items considered indicative of low risk, 10 studies were considered to be at high risk of bias, 12 to be at intermediate risk of bias, and one to be at low risk of bias. Details on the risk of bias are given at the end of this subsection.

#### Summary of Findings From RCTs Comparing Active OMBP Strategies

We did not perform meta-analysis of findings from head-to-head (active versus active) studies of OMBP strategies, because of extensive diversity of the employed OMBP strategies, the heterogeneity in the assessed outcomes, and, of concerns regarding selective outcome reporting (and other risk of bias dimensions). Instead, we summarize the information extracted from studies in a series of graphs (Figure 13). The underlying data, together with additional extracted information are accessible online (at http://srdr.ahrq.gov/).

Figure 13 Summary of findings from studies comparing alternative active OMBP strategies

Note: Comparisons of alternative active OMBP strategies. Please consult the main text of the report for details on how this graph should be interpreted. The panel for extra-abdominal infections depicts more than one datapoint per study.

Figure 13 provides a visual summary of findings from studies comparing alternative active OMBP Strategies. outcomes were assessed or reported in sufficient detail in a minority of the conducted studies, perhaps with the exception of wound infection. Where two or more studies provided information for the same outcome (e.g., wound infection) no conclusions could be reached regarding the comparative effectiveness of interventions. Some of the outcomes of interest to this review, such as surgical site infections, pulmonary embolism, and venous thrombosis were not reported in any study. The majority of the available studies were small, and probably underpowered to detect modest or small effect sizes, let alone relatively rare harms.

We use the first page of Figure 13 as an example. Each panel summarizes information on one outcome. The left upper panel shows information on overall mortality. Each outcome panel is a matrix of cells that represent contrasts between the strategies listed in the rows versus the strategies in the columns. Markers are plotted in a cell if an actual study compared the respective strategies. Marker color and shape is a key to whether the outcome was reported, and if so, to the direction and significance of the treatment effects:

- Gray ‘x’ markers denote that a study did not assess the predefined outcome, or if it did assess it, it did not report sufficient data for a meta-analysis.
- Gray hollow markers denote that the effects in the first (row) versus the second (column) strategy were statistically not significant (P-value ≥0.05).
  ○ Gray hollow circles stand for studies where effects trend in favor of the row versus the column strategy.
  ○ Gray hollow triangles stand for studies where there is no effect (e.g., equal number of events in each arm).
  ○ Gray hollow squares stand for studies where effects trend in favor of the column versus the row strategy.
- Black hollow markers denote that the effects were statistically significant at the P <0.05. The corresponding marker shapes (as for nonsignificant findings) denote the direction of the effects.

Consider the top left panel in the first page of Figure 13. For the outcome of all-cause mortality, a single grey ‘x’ marker in the cell at the intersection of hyperosmotic sodium solution-based strategy (4^th^ column) and laxatives/cathartics (2^nd^ row) indicates that a single study compared these two OMBP strategies, but this study reported no analyzable results on all-cause mortality. Also, whole gut irrigation (WGI) was associated with reduced incidence of death compared to laxatives/cathartics, but the difference was not statistically significant at the 0.05 level.

Figure 13 allows us to make the following observations:

Only 13 out of the 28 cells (comparisons) have some empirical information, i.e., have at least one study (one marker). This density of observed versus possible comparisons is somewhat optimistic: we have been quite lenient in categorizing the individual active OMBP comparisons into the seven conceptual categories represented by rows and columns in each panel. If we used a more granular categorization, the matrix would be larger, and there would be fewer studies in each of the cell. Further, we have also been lenient in the categorization of outcomes. For example, we operationalized peritonitis (lower right panel in the first page in Figure 14) as a clinical diagnosis defined by the study authors as a condition (local or generalized) that warrants repeat surgery, or deep infection or abscess.

Figure 14 Summary of findings from studies comparing alternative active OMBP strategies (results reported as binary outcomes)

Note: Comparisons of alternative active OMBP strategies. Please consult the main text of the report for details on how this graph should be interpreted.

Figure 14 provides a visual summary of findings from studies comparing alternative active OMBP strategies for studies reporting harms as binary outcomes.

Outcomes are assessed or reported in sufficient detail in a minority of the conducted studies, perhaps with the exception of wound infection in Figure 13. Where two or more studies provided information for the same outcome (e.g., wound infection) no conclusions could be reached regarding the comparative effectiveness of interventions. Some of the outcomes of interest to this review, such as pulmonary embolism, and venous thrombosis were not reported in any study.

Visually, most markers in each panel are grey x's, and just a handful are hollow (grey or black). The empirical evidence that is available to a literature-based review is but a small fraction of what could have been available. This represents a lost opportunity. If the observed outcomes are missing at random (e.g., by design) or completely at random, the missingness is ignorable, and represents loss of precision in the estimates we get from these studies. If, however, information is censored for systematic reasons (e.g., because of selective outcome reporting95,96), then summaries of the published literature are likely misleading. We have no solid indications of outcome reporting bias in this set of studies. As discussed in the risk of bias subsection, however, one is left with the impression that a lot in their design, conduct and analysis could be done better.

The majority of the available studies are small, and probably underpowered to detect modest or small effect sizes, let alone relatively rare harms. Across all 106 analyzable results (outcome/comparison combinations) two were statistically significant –visually, in the three Figures the gray hollow markers far outnumber the black ones. This proportion (2%) is less than the 5% that would be expected by chance if the null hypothesis of no association were true. Because the true distribution of effects in this body of literature is unknown, and because these analyses are not independent (per study, they are in the same patients), one cannot simply infer that all identified statistically significant findings are false. Nevertheless, this observation may suggest that studies were underpowered to detect modest treatment differences or that very few, if any, genuine differences exist among active OMBP strategies in the included studies.

#### Assessment of Risk of Bias for RCTs Comparing Alternative Active OMBP Strategies

Studies did not allow detailed assessment of the risk of bias for several important aspects of study design. For example, information on the randomized sequence generation and allocation concealment was deemed unclear in 14 and 19 of the 23 RCTs, respectively. Similarly, blinding of patients, physicians, and outcome assessors were deemed unclear in 19, 16, and 12 of the RCTs. In contrast, information on withdrawals and dropouts was generally well reported. Of the studies reporting relevant information, only three reported a dropout rate of more than 10% (two in both arms; one only in a single arm) and only one study had evidence of differential dropout (defined as a more than 10% difference in the dropout rate between arms). As shown in Figure 14, only few studies provided information on each of the outcomes of interest, raising some concerns about selective outcome reporting. Overall, based on the number of items considered indicative of low risk, ten studies were considered to be at high risk of bias, 12 to be at intermediate risk of bias, and 1 to be at low risk of bias. As always, aggregated risk of bias assessments need to be interpreted with caution, given our inability to fully distinguish inappropriate study design from poor reporting and lack of context-specific evidence that the risk items we assessed are indeed associated with bias.

### RCTs of Alternative Active OMBP Strategies in Children

Two studies, both conducted in India, compared alternative active OMBP strategies in children undergoing colorectal surgery (a minority of children underwent procedures for indications other than colorectal surgery in both studies). Both studies were considered to be at high risk of bias and provided limited information on the generation of the randomized sequence and allocation concealment.

The first study41 enrolled 54 children and compared whole gut irrigation with normal saline with added potassium (26 patients) versus PEG (28 patients). Four patients developed a wound infection in the whole-gut irrigation group and three in the PEG group; the difference was not statistically significant (P = 0.699).

The second study 79enrolled 126 children and compared whole gut irrigation with a NaCl solution (40 patients), PEG (55 patients), and Ringer's lactate (31 patients). Wound infections developed in two, three, and two patients in the NaCl, PEG, and Ringer's lactate treatment groups, respectively; the difference between groups was not statistically significant (P > 0.99).

### NRCSs Comparing Active OMBP Strategies

Only two NRCSs reported information on the comparison of alternative active OMBP strategies. The first study56 was a secondary analysis of a previously completed multicenter RCT of alternative antibiotic treatments (comparing ertapenem versus cefotetan) for patients undergoing elective colorectal surgery. Inclusion in the parent trial required patients to have undergone bowel preparation with PEG or sodium phosphate. Patients were followed up for SSI development for a period of 4 weeks. Of a total of 670 evaluable patients, 303 had OMBP with PEG and 367 with sodium phosphate. The overall rate of SSI was lower among patients who received sodium phosphate as compared with those who received PEG, however the difference was not statistically significant in multivariable analysis (OR = 0.69, 95% CI 0.46 to 1.02; P = 0.07). The study also reported a subgroup analysis by resection subtype, comparing PEG versus sodium phosphate among patients who underwent resection of the rectum versus those who underwent other colorectal surgical procedures. The magnitude and direction of effects was similar in both groups [using data in the paper, we calculated the unadjusted OR to be 0.59 (95% CI 0.42 to 0.83) and 0.67 (95% CI 0.46 to 0.99), for patients undergoing and not undergoing rectal resection, respectively]. The test for interaction between resection type and preparation regimen was not statistically significant (P = 0.64). The study was considered to be at intermediate risk of bias, mainly due to concerns about confounding bias (some of the reported analyses were unadjusted).

The second study32 was a retrospective cohort comparing three groups: mannitol with ceftriaxone (150 patients), mannitol with ceftriaxone plus metronidazole (160 patients), and traditional preparation with purgatives and enemas, combined with neomycin and metronidazole (140 patients). Of note, 110 of the 140 patients in the traditional preparation group were not treated concurrently with the patients receiving mannitol (i.e., they were historical controls). A comparison across all three groups found statistically significant differences for the outcomes of peritonitis requiring reoperation and a composite outcome of all infectious complications (P = 0.008 and P < 0.001, respectively). Differences were not statistically significant for other outcomes assessed, including wound infection, intra-abdominal abscess necessitating reoperation, anastomotic insufficiency, death due to peritonitis, or all cause mortality. For all outcomes, event rates were higher in the traditional preparation group and lower in the two mannitol study groups. The study was considered to be at high risk of bias, on the basis of concerns regarding confounding bias (all comparisons between groups were unadjusted and patients in the traditional preparation group were not treated concurrently with those in the mannitol groups).

## Comparisons of Inpatient Versus Outpatient OMBP

One RCT and one NRCS compared inpatient versus outpatient use of OMBP. The RCT51 compared inpatient versus outpatient preparation using of PEG in 100 patients undergoing elective colorectal surgery (51 inpatient versus 49 outpatient). Overall, the study was considered to be at high risk of bias and provided limited information regarding blinding and allocation concealment. Two patients in each group developed a wound infection; the difference between groups was not statistically significant (P > 0.99). Information was not provided regarding the treatment received by patients experiencing two additional outcome events (1 intra-abdominal abscess and 1 enterocutaneous fistula). However, the difference between the two groups for these outcomes was also nonsignificant (P > 0.99).

The NRCS64 retrospectively compared inpatient versus outpatient use of PEG in 319 patients who underwent colectomy with primary anastomosis (174 inpatient vs. 145 outpatient). The study was considered to be at high risk of bias because of concerns regarding confounding bias (all comparisons were unadjusted). One death was observed in each study group (P > 0.99). Three patients who received inpatient OMBP and where discharged to a rehabilitation facility, no patients in the outpatient group required care in such a facility (P = 0.25). Length of hospitalization was 10.7^i^ days in the inpatient group and 9 days in the outpatient group and the difference was not statistically significant (which the authors reported to be statistically nonsignificant).

i The number was reported as 107 (rather than 10.7), but based on the statistical analysis results reported in the study and the range of values (6-41 days) 10.7 appears to be the most likely correct value.

## Key Question 2a

How does the use of OMBP, with or without cointerventions (e.g., antibiotics, rectal enema), compare with no OMBP or with OMBP plus different cointerventions with respect to presurgical and postsurgical adverse events?

- What are the comparative adverse events of the various OMBP strategies?

In this section we summarize the evidence on the following predefined potential adverse events of OMBP: nausea, vomiting, dehydration, electrolyte imbalance, kidney damage, emergency admissions prior to surgery, cancelled, delayed, or rescheduled surgeries, allergic reactions, and seizures. Based on preliminary literature searches and discussions with TEP members, we expected that evidence on these outcomes would be sparse in comparative studies (both randomized and nonrandomized). We therefore also considered evidence from noncomparative (single group) cohort studies where all patients received OMBP.

The organization of the subsequent sections follows that of Key Question 1: we first discuss comparative studies of OMBP versus enema or no preparation, followed by comparative and noncomparative (single group) studies of alternative active OMBP strategies. The risk of bias assessment of comparative studies has already been presented in the section pertaining to Key Question 1. Thus, in the risk of bias subsection we provide assessments only for single-group cohorts.

## Comparisons of OMBP Versus No OMBP

### RCTs Comparing OMBP Versus No Preparation

Of the 18 RCTs included in main analyses comparing OMBP with or without enema versus enema alone or no preparation, only two provided information pertaining to the prespecified adverse events (one for nausea and one for renal failure).

#### Nausea

In one study35 patients were asked to rate their degree of nausea using a 1-to-5 ordinal scale (higher values indicated more severe symptoms). Of 233 randomized patients, 185 (95 OMBP-treated and 90 controls) replied to the questionnaire. The frequency of nonresponse to the questionnaire was not significantly different among OMBP-treated and untreated patients (P = 0.40). Nausea (the cut off on the scale was not reported) was reported by nine OMBP-treated patients and eight controls (P = 0.77).

#### Renal Failure

One study36 comparing OMBP versus no preparation reported that three of 89 patients receiving OMBP versus one of 89 patients receiving no preparation experienced acute renal failure (P = 0.62).

### Comparisons of OMBP Versus No OMBP in NRCSs

None of the seven NRCSs comparing OMBP versus no preparation reported information on the prespecified adverse events.

## Comparisons of Alternative Active OMBP Strategies

### RCTs Comparing Alternative OMBP Strategies in Adults

As discussed in the corresponding section of Key Question 1, studies of alternative active OMBP strategies used very diverse OMBP strategies, assessed heterogeneous outcomes, and, raised concerns of selective outcome reporting (and other risk of bias dimensions). Regarding the assessment of adverse events, studies utilized a diverse set of symptom scales to measure severity of patient reported adverse events (nausea, vomiting, fatigue, bloating, cramping, etc.). In most studies adverse event definitions were not clearly described, making it impossible to consistently compare outcomes across studies. Only a single study70 provided a copy of the questionnaire that was administered to patients; no study described whether the validity of the questionnaires had been formally assessed.

For these reasons, we have used the same approach as in Key Question 1 and summarize findings using scatterplots that map the comparisons reported and the direction and statistical significance of effects (Figures 14 and 15). The underlying data, together with additional extracted information are accessible online (at http://srdr.ahrq.gov/).

Figure 15 Summary of findings from studies comparing alternative active OMBP strategies (results reported as continuous outcomes)

Note: Comparisons of alternative active OMBP strategies. Please consult the main text of the report for details on how this graph should be interpreted.

Figure 15 provides a visual summary of findings from studies comparing alternative active OMBP strategies for studies reporting harms as continuous outcomes.

Based on Figures 14 and 15 we make the following observations, which are in accordance with the corresponding descriptions in Key Question 1:

Only 13 out of the 28 cells (comparisons) have some empirical information (13 for binary outcomes; 10 for continuous outcomes), i.e., have at least one study (one marker) provided evidence about them. We have been quite lenient in categorizing the individual active OMBP comparisons into the seven conceptual categories represented by rows and columns in each panel; were we to use a more granular categorization, the matrix would be larger, and there would be fewer studies in each of the cell.

Outcomes are assessed or reported in sufficient detail in a minority of the conducted studies. Most reported data fall into the outcome category other patient-reported adverse events (Figure 14, first page, lower left panel), which is indicative of the nonstandardized reporting. Where two or more studies provided information for the same outcome no conclusions could be reached regarding the comparative effectiveness of interventions. Renal failure, an outcome considered important given that many OMBP strategies involve ingestion of large volumes of solutions, was not reported in any study. This nonstandardized and partial reporting of harms represents a lost opportunity, i.e., could have been averted by better planning of the conduct and reporting of said studies.

Finally, the majority of the available studies are small, and probably underpowered to detect modest or small effect sizes, let alone relatively rare harms. Across all 88 analyzable results (outcome/comparison combinations) 27 were statistically significant —visually, in the three Figures the gray hollow markers outnumber the black ones. However, there is no readily discernible pattern. Because the true distribution of effects in this body of literature is unknown, and because these analyses are not independent (per study, they are in the same patients), one cannot make statements on whether the identified statistically significant findings are more than what would be expected by chance.

### RCTs of Alternative Active OMBP Strategies in Children

Two studies reported information on the comparison of alternative OMBP strategies in children. The studies only reported information on vomiting and electrolyte imbalance.

#### Vomiting

Both studies reported information on vomiting. In the first study41 7 of 28 patients treated with whole gut irrigation with PEG experienced vomiting, compared to 13 of 23 patients treated with whole gut irrigation with normal saline and added potassium (P = 0.09). The second study79 compared whole gut irrigation with PEG, Ringer's lactate and NaCl and reported that vomiting was experienced by 11 of 55 patients, 5 of 31 patients, and 2 of 40 patients, respectively (P = 0.10, across groups).

#### Electrolyte Imbalance

One study79 reported that no clinically significant electrolyte imbalances were observed after OMBP in the three compared groups (whole gut irrigation with PEG, NaCl, or Ringer's lactate).

### NRCSs Comparing Alternative Active OMBP Strategies

None of the two NRCSs comparing alternative active OMBP strategies versus no preparation reported information on the prespecified adverse events.

### Single-Group Cohorts of Active OMBP Strategies

Six studies met our inclusion criteria for single group cohorts and reported results on at least one of the prespecified adverse events of pertaining to Key Question 2. Of note all six studies were large comparative studies of antibiotic treatments (5 studies) or enema use (1 study) for patients with colorectal cancer. Because these studies used a uniform OMBP treatment for all patients – for the purposes of this report – they were treated as single group studies.

#### Vomiting

In one study47 of OMBP with saline or mannitol the rate of vomiting was approximately 1.6 percent (5 of 308 patients). All patients were also receiving metronidazole and ceftriaxone. Vomiting was not attributed to the OMBP drugs by the authors. No vomiting was reported among 307 patients included in the same study and treated with the same OMBP regimen, plus metronidazole and cefepime instead of ceftriaxone.

In one study84 of OMBP with senna the rate of vomiting was approximately 3.9 percent (20 of 517 patients; 277 received povidone-iodine and 240 sodium hypochlorite enema). Vomiting was not attributed to the OMBP drugs by the authors.

Finally, in one study48 of OMBP with sodium phosphate the rate of vomiting was approximately 17 percent (51 of 300 patients; 100 received three doses of oral antibiotic, 100 received a single dose, and 100 received no oral antibiotics). Vomiting was not attributed to the OMBP drugs by the authors; the rate of vomiting was 31 percent among patients receiving three doses of oral antibiotics, 11 percent among those receiving a single dose, and 9 percent among those receiving no oral antibiotics (P < 0.001 for the comparison across groups).

#### Nausea

One study47 of OMBP with saline or mannitol plus metronidazole and ceftriaxone reported nausea in approximately 1 percent of patients (3 of 308). Nausea was not attributed to the OMBP drugs by the authors. No nausea was reported among 307 patients included in the same study and treated with the same OMBP regimen plus metronidazole and cefepime (instead of ceftriaxone).

In one study48 of OMBP with sodium phosphate the rate of nausea was approximately 25 percent (75 of 300 patients; 100 received three doses of oral antibiotic, 100 received a single dose, and 100 received no oral antibiotics). The authors did not attribute nausea to the OMBP drugs. The rate of nausea was 44 percent among patients receiving three doses of oral antibiotics, 18 percent among those receiving a single dose, and 13 percent among those receiving no oral antibiotics (P < 0 .001 for the comparison across groups).

#### Vomiting and Nausea (Combined)

In one study61 of OMBP with PEG, the rate of nausea and vomiting was approximately 2.2 percent (11 of 491 patients; 245 received intravenous antibiotics and 246 received both intravenous and oral antibiotics). The authors did not attribute these events to the OMBP drugs (they considered them probably related to the antibiotics).

#### Allergic Reactions

In one study47 of OMBP with enemas and laxatives the rate of allergic reactions (maculopapular rash) was 2.7 percent (7 events among 263 patients). However, all patients were also receiving cephalosporin antibiotics. The authors did not attribute the allergic reactions to the OMBP drugs.

In a study91 of OMBP with saline or mannitol the rate of allergic reactions was approximately 1 percent (3 of 308 patients). All patients were also receiving ceftriaxone plus metronidazole antibiotics. The authors did not attribute the allergic reactions to the OMBP drugs.

In a third study61 of OMBP with PEG, no hypersensitivity reactions were observed (0 of 491 patients; 245 received intravenous antibiotics and 246 received both intravenous and oral antibiotics).

In a fourth study45 of OMBP with sodium phosphate and enemas the rate of urticaria was less than 1 percent (1 of 241 patients; 121 treated with cefoxitin and 120 treated without parenteral antibiotics). The authors did not attribute the allergic reaction to the OMBP drugs (urticaria developed in a patient in the cefoxitin group).

#### Risk of Bias in Single Group Cohort Studies

(Please refer to the corresponding section of Key Question 1 for a description of the risk of bias of the comparative studies.)

We assessed the risk of bias of these studies using a set of items based on the Newcastle-Ottawa scale. Briefly, we examined whether there was risk of selection bias, the methods of exposure ascertainment, whether patients were outcome-free at baseline, whether rates of events were adjusted for key patient characteristics (e.g., whether incidence rates were standardized or stratified by age or sex), the methods for outcome assessment, and the adequacy of followup.

These studies were prospective (and were designed to provide information on the use of antibiotics or enemas). There was low risk that patients had the adverse events at baseline. Exposure was protocol-determined in all cases. Four of six studies explicitly reported enrolling consecutive patients, thus reducing the risk of selection bias. However, no study reported adjustment or standardization of event rates by key patient characteristics. Methods for outcome ascertainment were unclear in six studies, performed by an independent observer in one study, and based on a combination of self-report and care provider observation in two cases.

## Comparisons of Inpatient Versus Outpatient OMBP

The two studies (1 RCT51 and 1 NRCS64) comparing inpatient versus outpatient administration of OMBP did not report information on the prespecified adverse events of interest.

## Key Question 2b

How does the use of OMBP, with or without cointerventions (e.g., antibiotics, rectal enema), compare with no OMBP or with OMBP plus different cointerventions with respect to presurgical and postsurgical adverse events?

- What are the comparative adverse events of OMBP in subgroups of patients especially susceptible to the potential adverse events?

We sought information on adverse events of OMBP when used by patients who may be particularly susceptible to adverse events. Specifically, we aimed to identify evidence on the impact of OMBP on adults and children with cardiovascular or pulmonary disease, patients at the extremes of age, patients who have undergone adjuvant chemotherapy or radiotherapy, and patients with diabetes, kidney disease, or compromised immune function (including drug-induced immunosuppression) who undergo elective colorectal surgery.

No study in this report provided such information. Studies often excluded individuals who would be at particular high risk of adverse events following the use of OMBP. For example, several studies reported excluding patients with severe renal failure or hypertension at diagnosis. Among studies that did not report such exclusions (including a minority that explicitly stated including individuals belonging to the susceptible groups of interest to this Key Question), none reported outcome information limited to the populations of interest. Because of the sparseness of the evidence on these subgroups of patients, we considered the strength of the evidence to be insufficient.