# References

1 Guenaga KF, Matos D, Wille-Jorgensen P. Mechanical bowel preparation for elective colorectal surgery. Cochrane Database Syst Rev. 2011;(9):CD001544. [pmid: 21901677].
2 CDC. National Hospital Discharge Survey. 2009. www.cdc.gov/nchs/nhds.htm.
3 Wick EC, Shore AD, Hirose K, et al. Readmission rates and cost following colorectal surgery. Diseases of the Colon and Rectum. Dec. 2011;54(12):1475-9. [pmid: 22067174].
4 Nichols RL, Condon RE. Preoperative preparation of the colon. Surgery, Gynecology & Obstetrics. Feb. 1971;132(2):323-37.
5 Aydin HN, Remzi FH, Tekkis PP, et al. Hartmann's reversal is associated with high postoperative adverse events. Diseases of the Colon and Rectum. Nov. 2005;48(11):2117-26. [pmid: 16228835].
6 Vermeulen J, Coene PP, Van Hout NM, et al. Restoration of bowel continuity after surgery for acute perforated diverticulitis: should Hartmann's procedure be considered a one-stage procedure?. Colorectal disease: the official journal of the Association of Coloproctology of Great Britain and Ireland. Jul. 2009;11(6):619-24. [pmid: 18727727].
7 Eagye KJ, Nicolau DP. Deep and organ/space infections in patients undergoing elective colorectal surgery: incidence and impact on hospital length of stay and costs. American Journal of Surgery. Sep. 2009;198(3):359-67. [pmid: 19306972].
8 Pena-Soria MJ, Mayol JM, Anula R, et al. Single-blinded randomized trial of mechanical bowel preparation for colon surgery with primary intraperitoneal anastomosis. Journal of Gastrointestinal Surgery: Official Kournal of the Society for Surgery of the Alimentary Tract. Dec. 2008;12(12):2103-8. discussion 8-9. [pmid: 18820977].
9 Zmora O, Wexner SD, Hajjar L, et al. Trends in preparation for colorectal surgery: survey of the members of the American Society of Colon and Rectal Surgeons. The American Surgeon. Feb. 2003;69(2):150-4. [pmid: 12641357].
10 Englesbe MJ, Brooks L, Kubus J, et al. A statewide assessment of surgical site infection following colectomy: the role of oral antibiotics. Annals of Surgery. Sep. 2010;252(3):514-9. discussion 9-20. [pmid: 20739852].
11 Beck DE, Fazio VW, Jagelman DG. Comparison of oral lavage methods for preoperative colonic cleansing. Diseases of the Colon and Rectum. Nov. 1986;29(11):699-703. [pmid: 3095080].
12 Duthie GS, Foster ME, Price-Thomas JM, et al. Bowel preparation or not for elective colorectal surgery. Journal of the Royal College of Surgeons of Edinburgh. Jun. 1990;35(3):169-71. [pmid: 2395132].
13 Itani KM, Kim L. Mechanical bowel preparation or not for elective colorectal surgery. Surgical Infections. Dec. 2008;9(6):563-5. [pmid: 19216667].
14 Eskicioglu C, Forbes SS, Fenech DS, et al. Preoperative bowel preparation for patients undergoing elective colorectal surgery: a clinical practice guideline endorsed by the Canadian Society of Colon and Rectal Surgeons. Canadian Journal of Surgery, Journal Canadien de Chirurgie. Dec. 2010;53(6):385-95. [pmid: 21092431].
15 Nelson DB, Barkun AN, Block KP, et al. Technology Status Evaluation report. Colonoscopy preparations. May 2001. Gastrointestinal Endoscopy. Dec. 2001;54(6):829-32. [pmid: 11726878].
16 Morotomi M, Guillem JG, Pocsidio J, et al. Effect of polyethylene glycol-electrolyte lavage solution on intestinal microflora. Applied and Environmental Microbiology. Apr. 1989;55(4):1026-8. [pmid: 2729976].
17 Bellows CF, Mills KT, Kelly TN, et al. Combination of oral non-absorbable and intravenous antibiotics versus intravenous antibiotics alone in the prevention of surgical site infections after colorectal surgery: a meta-analysis of randomized controlled trials. Techniques in Coloproctology. Dec. 2011;15(4):385-95. [pmid: 21785981].
18 Nichols RL, Broido P, Condon RE, et al. Effect of preoperative neomycin-erythromycin intestinal preparation on the incidence of infectious complications following colon surgery. Annals of Surgery. Oct. 1973;178(4):453-62. [pmid: 4743867].
19 Roig JV, Garcia-Fadrique A, Garcia-Armengol J, et al. Mechanical bowel preparation and antibiotic prophylaxis in colorectal surgery: use by and opinions of Spanish surgeons. Colorectal Disease : The Official Journal of the Association of Coloproctology of Great Britain and Ireland. Jan. 2009;11(1):44-8. [pmid: 18462218].
20 Hasenberg T, Keese M, Langle F, et al. ‘Fast-track’ colonic surgery in Austria and Germany--results from the survey on patterns in current perioperative practice. Colorectal Disease : The Official Journal of the Association of Coloproctology of Great Britain and Ireland. Feb. 2009;11(2):162-7. [pmid: 18462237].
21 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Annals of Internal Medicine. Aug. 18. 2009;151(4):264-9. W64. [pmid: 19622511].
22 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
23 Ip S, Hadar N, Keefe S, et al. A Web-based archive of systematic review data. Systematic Reviews. 2012;1:15. [pmid: 22588052].
24 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
25 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technology Assessment. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
26 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Statistics in Medicine. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
27 Dias S, Sutton AJ, Ades AE, et al. A Generalized Linear Modeling Framework for Pairwise and Network Meta-analysis of Randomized Controlled Trials. Medical Decision Making. Jul. 2013;33(5):607-17. [pmid: 23104435].
28 Lau J, Ioannidis JP, Terrin N, et al. The case of the misleading funnel plot. BMJ. Sep. 16. 2006;333(7568):597-600. [pmid: 16974018].
29 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
30 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. 2012. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318.
31 Ali M. Randomized prospective clinical trial of no preparation versus mechanical bowel preparation before elective colorectal surgery. Med Channel. 2007;13(1):32-5.
32 Balogh A, Karadi J, Bence G, et al. The “Mannit-Ceftriaxon” preparation for elective colorectal surgery. Acta Chirurgica Hungarica. 1992;33(3-4):287-98. [pmid: 1345388].
33 Beck DE, DiPalma JA. A new oral lavage solution vs cathartics and enema method for preoperative colonic cleansing. Arch Surg. May. 1991;126(5):552-5. [pmid: 2021332].
34 Beck DE, Harford FJ, DiPalma JA. Comparison of cleansing methods in preparation for colonic surgery. Diseases of the Colon and Rectum. Jul. 1985;28(7):491-5. [pmid: 4017808].
35 Bertani E, Chiappa A, Biffi R, et al. Comparison of oral polyethylene glycol plus a large volume glycerine enema with a large volume glycerine enema alone in patients undergoing colorectal surgery for malignancy: a randomized clinical trial. Colorectal Disease : The Official Journal of the Association of Coloproctology of Great Britain and Ireland. Oct. 2011;13(10):e327-34. [pmid: 21689356].
36 Bretagnol F, Panis Y, Rullier E, et al. Rectal cancer surgery with or without bowel preparation: The French GRECCAR III multicenter single-blinded randomized trial. Annals of Surgery. Nov. 2010;252(5):863-8. [pmid: 21037443].
37 Bucher P, Gervaz P, Egger JF, et al. Morphologic alterations associated with mechanical bowel preparation before elective colorectal surgery: a randomized trial. Diseases of the Colon and Rectum. Jan. 2006;49(1):109-12. [pmid: 16273330].
38 Bucher P, Gervaz P, Soravia C, et al. Randomized clinical trial of mechanical bowel preparation versus no preparation before elective left-sided colorectal surgery. The British Journal of Surgery. Apr. 2005;92(4):409-14. [pmid: 15786427].
39 Burke P, Mealy K, Gillen P, et al. Requirement for bowel preparation in colorectal surgery. The British Journal of Surgery. Jun. 1994;81(6):907-10. [pmid: 8044619].
40 Cannon JA, Altom LK, Deierhoi RJ, et al. Preoperative oral antibiotics reduce surgical site infection following elective colorectal resections. Diseases of the Colon and Rectum. Nov. 2012;55(11):1160-6. [pmid: 23044677].
41 Chattopadhyay A, Prakash B, Vepakomma D, et al. A prospective comparison of two regimes of bowel preparation for pediatric colorectal procedures: normal saline with added potassium vs. polyethylene glycol. Pediatric Surgery International. Feb. 2004;20(2):127-9. [pmid: 14752676].
42 Christensen PB, Kronborg O. Whole-gut irrigation versus enema in elective colorectal surgery: a prospective, randomized study. Diseases of the Colon and Rectum. Nov-Dec. 1981;24(8):592-5. [pmid: 7318622].
43 Chung RS, Gurll NJ, Berglund EM. A controlled clinical trial of whole gut lavage as a method of bowel preparation for colonic operations. American Journal of Surgery. Jan. 1979;137(1):75-81. [pmid: 365010].
44 Contant CM, Hop WC, van't Sant HP, et al. Mechanical bowel preparation for elective colorectal surgery: a multicentre randomised trial. Lancet. Dec. 22. 2007;370(9605):2112-7. [pmid: 18156032].
45 Coppa GF, Eng K, Gouge TH, et al. Parenteral and oral antibiotics in elective colon and rectal surgery. A prospective, randomized trial. American Journal of Surgery. Jan. 1983;145(1):62-5. [pmid: 6336918].
46 Dueholm S, Rubinstein E, Reipurth G. Preparation for elective colorectal surgery. A randomized, blinded comparison between oral colonic lavage and whole-gut irrigation. Diseases of the Colon and Rectum. May. 1987;30(5):360-4. [pmid: 3552504].
47 Eisenberg HW. Cefamandole preparation for colonic surgery. Diseases of the Colon and Rectum. Nov-Dec. 1981;24(8):610-2. [pmid: 7318626].
48 Espin-Basany E, Sanchez-Garcia JL, Lopez-Cano M, et al. Prospective, randomised study on antibiotic prophylaxis in colorectal surgery. Is it really necessary to use oral antibiotics?. International Journal of Colorectal Disease. Nov. 2005;20(6):542-6. [pmid: 15843938].
49 Fa-Si-Oen P, Roumen R, Buitenweg J, et al. Mechanical bowel preparation or not? Outcome of a multicenter, randomized trial in elective open colon surgery. Diseases of the Colon and Rectum. Aug. 2005;48(8):1509-16. [pmid: 15981065].
50 Fleites RA, Marshall JB, Eckhauser ML, et al. The efficacy of polyethylene glycol-electrolyte lavage solution versus traditional mechanical bowel preparation for elective colonic surgery: a randomized, prospective, blinded clinical trial. Surgery. Oct. 1985;98(4):708-17. [pmid: 3901374].
51 Frazee RC, Roberts J, Symmonds R, et al. Prospective, randomized trial of inpatient vs. outpatient bowel preparation for elective colorectal surgery. Diseases of the Colon and Rectum. Mar. 1992;35(3):223-6. [pmid: 1740065].
52 Grundel K, Schwenk W, Bohm B, et al. Improvements in mechanical bowel preparation for elective colorectal surgery. Diseases of the Colon and Rectum. Nov. 1997;40(11):1348-52. [pmid: 9369111].
53 Holte K, Andersen J, Jakobsen DH, et al. Cyclo-oxygenase 2 inhibitors and the risk of anastomotic leakage after fast-track colonic surgery. The British Journal of Surgery. Jun. 2009;96(6):650-4. [pmid: 19434706].
54 Horvat M, Krebs B, Potrc S, et al. Preoperative synbiotic bowel conditioning for elective colorectal surgery. Wiener klinische Wochenschrift. May. Suppl 2. 2010;122:26-30. [pmid: 20517667].
55 Hughes ES. Asepsis in large-bowel surgery. Annals of the Royal College of Surgeons of England. Dec. 1972;51(6):347-56. [pmid: 4621021].
56 Itani KM, Wilson SE, Awad SS, et al. Polyethylene glycol versus sodium phosphate mechanical bowel preparation in elective colorectal surgery. American Journal of Surgery. Feb. 2007;193(2):190-4. [pmid: 17236845].
57 Jung B, Lannerstad O, Pahlman L, et al. Preoperative mechanical preparation of the colon: the patient's experience. BMC surgery. 2007;7:5. [pmid: 17480223].
58 Jung B, Pahlman L, Nystrom PO, et al. Multicentre randomized clinical trial of mechanical bowel preparation in elective colonic resection. The British Journal of Surgery. Jun. 2007;94(6):689-95. [pmid: 17514668].
59 Khan SA, Hadi A, Ahmad S, et al. Mechanical bowel preparation in elective colorectal surgery. J Med Sci. 2011;19(1):31-4.
60 Kim EK, Sheetz KH, Bonn J, et al. A Statewide Colectomy Experience: The Role of Full Bowel Preparation in Preventing Surgical Site Infection. Annals of Surgery. 2013. Aug. 23. [pmid: 23979289].
61 Kobayashi M, Mohri Y, Tonouchi H, et al. Randomized clinical trial comparing intravenous antimicrobial prophylaxis alone with oral and intravenous antimicrobial prophylaxis for the prevention of a surgical site infection in colorectal cancer surgery. Surgery Today. 2007;37(5):383-8. [pmid: 17468819].
62 Koussidis GA, Koussidis A. Preoperative bowel preparation with meglumine and sodium diatrizoate (Gastrografin): a prospective randomised comparison. The European Journal of Surgery = Acta Chirurgica. Dec. 2001;167(12):899-902. [pmid: 11841079].
63 Krapohl GL, Phillips LR, Campbell DA Jr., et al. Bowel preparation for colectomy and risk of Clostridium difficile infection. Diseases of the Colon and Rectum. Jul. 2011;54(7):810-7. [pmid: 21654247].
64 Le TH, Timmcke AE, Gathright JB Jr., et al. Outpatient bowel preparation for elective colon resection. Southern Medical Journal. May. 1997;90(5):526-30. [pmid: 9160073].
65 Makino M, Hisamitsu K, Sugamura K, et al. Randomized comparison of two preoperative methods for preparation of the colon: oral administration of a solution of polyethylene glycol plus electrolytes and total parenteral nutrition. Hepato-Gastroenterology. Jan-Feb. 1998;45(19):90-4. [pmid: 9496494].
66 Matheson DM, Arabi Y, Baxter-Smith D, et al. Randomized multicentre trial of oral bowel preparation and antimicrobials for elective colorectal operations. The British Journal of Surgery. Sep. 1978;65(9):597-600. [pmid: 359083].
67 Miettinen RP, Laitinen ST, Makela JT, et al. Bowel preparation with oral polyethylene glycol electrolyte solution vs. no preparation in elective open colorectal surgery: prospective, randomized study. Diseases of the Colon and Rectum. May. 2000;43(5):669-75. discussion 75-7. [pmid: 10826429].
68 Morris DL, Hares MM, Voogt RJ, et al. Metronidazole need not be combined with an aminoglycoside when used for prophylaxis in elective colorectal surgery. The Journal of Hospital Infection. Mar. 1983;4(1):65-9. [pmid: 6190888].
69 Nicholson GA, Finlay IG, Diament RH, et al. Mechanical bowel preparation does not influence outcomes following colonic cancer resection. The British Journal of Surgery. Jun. 2011;98(6):866-71. [pmid: 21412756].
70 Oliveira L, Wexner SD, Daniel N, et al. Mechanical bowel preparation for elective colorectal surgery. A prospective, randomized, surgeon-blinded trial comparing sodium phosphate and polyethylene glycol-based oral lavage solutions. Diseases of the Colon and Rectum. May. 1997;40(5):585-91. [pmid: 9152189].
71 Panton ON, Atkinson KG, Crichton EP, et al. Mechanical preparation of the large bowel for elective surgery. Comparison of whole-gut lavage with the conventional enema and purgative technique. American Journal of Surgery. May. 1985;149(5):615-9. [pmid: 3887955].
72 Pena-Soria MJ, Mayol JM, Anula-Fernandez R, et al. Mechanical bowel preparation for elective colorectal surgery with primary intraperitoneal anastomosis by a single surgeon: interim analysis of a prospective single-blinded randomized trial. Journal of Gastrointestinal Surgery : Official Journal of the Society for Surgery of the Alimentary Tract. May. 2007;11(5):562-7. [pmid: 17394048].
73 Platell C, Barwood N, Makin G. Randomized clinical trial of bowel preparation with a single phosphate enema or polyethylene glycol before elective colorectal surgery. The British Journal of Surgery. Apr. 2006;93(4):427-33. [pmid: 16491463].
74 Ram E, Sherman Y, Weil R, et al. Is mechanical bowel preparation mandatory for elective colon surgery? A prospective randomized study. Arch Surg. Mar. 2005;140(3):285-8. [pmid: 15781794].
75 Reddy BS, Macfie J, Gatt M, et al. Randomized clinical trial of effect of synbiotics, neomycin and mechanical bowel preparation on intestinal barrier function in patients undergoing colectomy. The British Journal of Surgery. May. 2007;94(5):546-54. [pmid: 17443852].
76 Santos JC Jr., Batista J, Sirimarco MT, et al. Prospective randomized trial of mechanical bowel preparation in patients undergoing elective colorectal surgery. The British Journal of Surgery. Nov. 1994;81(11):1673-6. [pmid: 7827905].
77 Sasaki J, Matsumoto S, Kan H, et al. Objective assessment of postoperative gastrointestinal motility in elective colonic resection using a radiopaque marker provides an evidence for the abandonment of preoperative mechanical bowel preparation. Journal of Nippon Medical School = Nippon Ika Daigaku zasshi. 2012;79(4):259-66. [pmid: 22976604].
78 Scabini S, Rimini E, Romairone E, et al. Colon and rectal surgery for cancer without mechanical bowel preparation: one-center randomized prospective trial. World Journal of Surgical Oncology. 2010;8:35. [pmid: 20433721].
79 Sinha SK, Kanojia RP, Rawat JD, et al. Comparison of three solutions for total gut irrigation in pediatric patients. Pediatric Surgery International. Jun. 2007;23(6):581-4. [pmid: 17394002].
80 Soballe PW, Greif JM. Preoperative whole-gut lavage vs. traditional three-day bowel preparation in left colon surgery. Military Medicine. Apr. 1989;154(4):198-201. [pmid: 2499830].
81 Tahirkheli MUI, Shukr I, Iqbal RA. Anastomotic leak in prepared versus unprepared bowel. Gomal Journal of Medical Sciences. 2013;11(1):73-7.
82 Toneva GD, Deierhoi RJ, Morris M, et al. Oral antibiotic bowel preparation reduces length of stay and readmissions after colorectal surgery. Journal of the American College of Surgeons. Apr. 2013;216(4):756-62. discussion 62-3. [pmid: 23521958].
83 Valverde A, Hay JM, Fingerhut A, et al. Senna vs polyethylene glycol for mechanical preparation the evening before elective colonic or rectal resection: a multicenter controlled trial. French Association for Surgical Research. Arch Surg. May. 1999;134(5):514-9. [pmid: 10323423].
84 Valverde A, Msika S, Kianmanesh R, et al. Povidone-iodine vs sodium hypochlorite enema for mechanical preparation before elective open colonic or rectal resection with primary anastomosis: a multicenter randomized controlled trial. Arch Surg. Dec. 2006;141(12):1168-74. discussion 75. [pmid: 17178958].
85 Van't Sant HP, Slieker JC, Hop WC, et al. The influence of mechanical bowel preparation in elective colorectal surgery for diverticulitis. Techniques in Coloproctology. Aug. 2012;16(4):309-14. [pmid: 22706733].
86 Van't Sant HP, Weidema WF, Hop WC, et al. The influence of mechanical bowel preparation in elective lower colorectal surgery. Annals of Surgery. Jan. 2010;251(1):59-63. [pmid: 20009750].
87 Watanabe M, Murakami M, Nakao K, et al. Randomized clinical trial of the influence of mechanical bowel preparation on faecal microflora in patients undergoing colonic cancer resection. The British Journal of Surgery. Dec. 2010;97(12):1791-7. [pmid: 20799286].
88 Wolff BG, Beart RW Jr., Dozois RR, et al. A new bowel preparation for elective colon and rectal surgery. A prospective, randomized clinical trial. Arch Surg. Jul. 1988;123(7):895-900. [pmid: 3132910].
89 Wolters U, Keller HW, Sorgatz S, et al. Prospective randomized study of preoperative bowel cleansing for patients undergoing colorectal surgery. The British Journal of Surgery. Apr. 1994;81(4):598-600. [pmid: 8205446].
90 Yoshioka K, Connolly AB, Ogunbiyi OA, et al. Randomized trial of oral sodium phosphate compared with oral sodium picosulphate (Picolax) for elective colorectal surgery and colonoscopy. Digestive Surgery. 2000;17(1):66-70. [pmid: 10720834].
91 Zanella E, Rulli F. A multicenter randomized trial of prophylaxis with intravenous cefepime + metronidazole or ceftriaxone + metronidazole in colorectal surgery. The 230 Study Group. Journal of Chemotherapy (Florence, Italy). Feb. 2000;12(1):63-71. [pmid: 10768517].
92 Zmora O, Mahajna A, Bar-Zakai B, et al. Colon and rectal surgery without mechanical bowel preparation: a randomized prospective trial. Annals of Surgery. Mar. 2003;237(3):363-7. [pmid: 12616120].
93 Zmora O, Mahajna A, Bar-Zakai B, et al. Is mechanical bowel preparation mandatory for left-sided colonic anastomosis? Results of a prospective randomized trial. Techniques in Coloproctology. Jul. 2006;10(2):131-5. [pmid: 16773286].
94 Scabini S, Rimini E, Romairone E, et al. Retraction: colon and rectal surgery for cancer without mechanical bowel preparation: one-center randomized prospective trial. World Journal of Surgical Oncology. Sep. 20. 2012;10(1):196. [pmid: 22992274].
95 Chan AW, Altman DG. Identifying outcome reporting bias in randomised trials on PubMed: review of publications and survey of authors. BMJ. Apr. 2. 2005;330(7494):753. [pmid: 15681569].
96 Chan AW, Krleza-Jeric K, Schmid I, et al. Outcome reporting bias in randomized trials funded by the Canadian Institutes of Health Research. CMAJ : Canadian Medical Association Journal = Journal de l'Association Medicale Canadienne. Sep. 28. 2004;171(7):735-40. [pmid: 15451835].
97 Phatak UR, Pedroza C, Millas SG, et al. Revisiting the effectiveness of interventions to decrease surgical site infections in colorectal surgery: A Bayesian perspective. Surgery. Aug. 2012;152(2):202-11. [pmid: 22828141].
98 Slim K, Vicaut E, Launay-Savary MV, et al. Updated systematic review and meta-analysis of randomized clinical trials on the role of mechanical bowel preparation before colorectal surgery. Annals of Surgery. Feb. 2009;249(2):203-9. [pmid: 19212171].
99 Cao F, Li J, Li F. Mechanical bowel preparation for elective colorectal surgery: updated systematic review and meta-analysis. International Journal of Colorectal Disease. Jun. 2012;27(6):803-10. [pmid: 22108902].
100 Gravante G, Caruso R, Andreani SM, et al. Mechanical bowel preparation for colorectal surgery: a meta-analysis on abdominal and systemic complications on almost 5,000 patients. International Journal of Colorectal Disease. Dec. 2008;23(12):1145-50. [pmid: 18836729].
101 Pineda CE, Shelton AA, Hernandez-Boussard T, et al. Mechanical bowel preparation in intestinal surgery: a meta-analysis and review of the literature. Journal of Gastrointestinal Surgery: Official Journal of the Society for Surgery of the Alimentary Tract. Nov. 2008;12(11):2037-44. [pmid: 18622653].
102 Varadhan KK, Neal KR, Dejong CH, et al. The enhanced recovery after surgery (ERAS) pathway for patients undergoing major elective open colorectal surgery: a meta-analysis of randomized controlled trials. Clinical Nutrition. Aug. 2010;29(4):434-40. [pmid: 20116145].