# Methods

This comparative effectiveness review evaluated the impact of alternative oral mechanical bowel preparation (OMBP) strategies for patients undergoing elective colorectal surgery. We considered comparisons between use of OMBP and its omission, as well as comparisons among alternative OMBP strategies.

We performed a systematic review of the published literature using established methodologies as outlined in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter referred to as the Methods Guide^a^). The main sections in this chapter reflect the elements of the protocol established for the comparative effectiveness review. We followed the reporting requirements listed in the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.21 All methods and analyses were determined a priori. The protocol was developed with input from external clinical and methodological experts and in consultation with the AHRQ task order officer (TOO); it was posted online to solicit additional public comments. Its PROSPERO registration number is CRD42013004381.

a Available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm; last accessed May 11, 2013.

## AHRQ Task Order Officer

The AHRQ TOO assigned to this project was responsible for overseeing all aspects of this report. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all queries from the Evidence-based Practice Center (EPC) regarding the scope and processes of the project. The TOO and other staff at AHRQ reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## External Stakeholder Input

An initial set of questions for evidence review were nominated to the Effective Healthcare Program by a representative of a professional society. During a topic refinement phase, the initial questions that had previously been nominated for this report were refined with input from a panel of Key Informants representing clinicians, patients, and payers. After a public review of the proposed Key Questions, a group of experts was convened to form the Technical Expert Panel (TEP), which provided input to help the EPC team identify important issues and to define parameters for the review of evidence. TEP members included representatives of professional societies, experts in colorectal surgery, experts on the preoperative preparation of patients undergoing elective surgery, and an infectious disease specialist. Several TEP members had methodological expertise in health technology assessment.

## Key Questions

Two Key Questions were posed. Key Question 1 pertained to the comparative effectiveness of alternative OMBP strategies, including a strategy of no preparation. Key Question 2 pertained to adverse events of alternative OMBP strategies, including a strategy of no preparation. The complete Key Questions have been presented at the end of the Introduction section.

## Analytic Framework

We developed an analytic framework (Figure 1) that maps the Key Questions within the context of populations, interventions, comparators, and outcomes of interest, as well as the chain of logic that evidence must support to link the interventions to health outcomes. Briefly, the framework illustrates that OMBP, together with various cointerventions (e.g., enemas, oral or intravenous antibiotics, nutritional modifications), can impact intermediate and terminal outcomes (e.g., surgical site infections, anastomotic leakage, mortality), and can also be associated with adverse events (e.g., nausea and vomiting, electrolyte imbalance).

Figure 1 Analytic framework

KQ = Key Question; OMBP = oral mechanical bowel preparation

Note: Key Questions are shown within the context of the PICO (Population, Intervention, Comparators, and Outcomes) formalism. Interventions (alternative OMBP strategies or no OMBP) are compared in relevant clinical populations (patients undergoing elective large bowel surgery) with regard to intermediate outcomes (e.g., anastomotic leakage, reoperation, costs, etc.), final outcomes (mortality), or adverse events (e.g., nausea, vomiting, etc.). The intervention effect may be modified by several patient-level factors (e.g., cointerventions, anatomic location of the surgery, use of antibiotics, etc.). See the preceding section for a detailed description of the populations, interventions, and outcomes of interest.

Figure 1 depicts the Analytic Framework. Key Questions are shown within the context of the PICO (Population, Intervention, Comparators, and Outcomes) formalism. Interventions (alternative OMBP strategies or no OMBP) are compared in relevant clinical populations (patients undergoing elective large bowel surgery) with regard to intermediate outcomes (e.g., anastomotic leakage, reoperation, costs, etc.), final outcomes (mortality), or adverse events (e.g., nausea, vomiting, etc.). The intervention effect may be modified by several patient-level factors (e.g., cointerventions, anatomic location of the surgery, use of antibiotics, etc.). See the preceding section for a detailed description of the populations, interventions, and outcomes of interest.

## Literature Search and Abstract Screening

We searched PubMed^®^, the Cochrane Central Trials Registry^®^, Embase^®^, and CINAHL^®^ without any language or publication date restriction to identify literature relevant to the report. Searches were conducted on September 6, 2013. Search strings included terms for the populations and treatments of interest (see Appendix A for the exact search queries, which were extensively validated against previous reviews on the treatments of interest). We also performed a targeted search of the FDA Web site (last search performed on May 17, 2013).

To supplement searches, we asked technical experts to provide additional citations of potentially relevant articles. We identified additional studies by perusing reference lists of eligible studies, published clinical practice guidelines, and relevant narrative and systematic reviews. On the basis of preliminary searches conducted during topic refinement, we provided the Scientific Resource Center (SRC, an entity within the Effective Health Care Program unrelated to the Brown EPC) with a list of relevant technologies and manufacturers. Per EPC procedures, the SRC solicits information from the manufacturers and organizes all obtained material into submission information packages (SIPs). However, as of May 17, 2013 no documents were sent to the SRC from outside sources. All articles identified through sources other than electronic database searches were reviewed for eligibility in full text, using the same criteria as for articles identified through our database searches. Finally, we searched the ClinicalTrials.gov Web site (with the last search performed on May 15, 2013) for ongoing comparative trials of alternative OMBP strategies. We did not consider unpublished data other than the information included in the FDA documents or ClinicalTrials.gov.

Three investigators first screened a common set of 200 abstracts and discussed discrepancies in order to standardize screening practices and ensure understanding of the criteria. The same investigators screened 200 additional abstracts to ensure that selection criteria had been standardized. Remaining abstracts were screened in duplicate and discrepancies were resolved by consensus. Abstracts were manually screened, using Abstrackr.22 Reviewers aimed to be inclusive in order to increase the sensitivity of abstract screening.

## Study Selection and Eligibility Criteria

Full-text articles were reviewed independently by two investigators to determine eligibility. Disagreements regarding inclusion or relevance to a specific question were resolved by consensus including at least one additional investigator. Below we detail the study selection criteria for each Key Question.

We did not include studies in languages other than English but we recorded the number of such studies. We excluded narrative reviews, editorials, letters to the editor, and other papers not presenting primary research data. We also excluded studies reporting exclusively on healthy individuals or studies reporting exclusively the results of animal experiments. Appendix B lists all the studies excluded after full-text screening and the reason for exclusion.

### Populations and Conditions of Interest

For Key Question 1 the population of interest was adults and children who underwent elective colon (Key Questions 1a and 1b) or rectal surgery (Key Question 1c). Subgroups of interest were those defined by anastomosis location and type (e.g., based on the bowel segments anastomosed or the method of anastomosis, hand-sewn versus stapled), type of surgical procedure (open versus laparoscopic), patient age (children versus adults), and indications for surgery (cancer versus inflammatory bowel disease versus diverticulitis versus other).

For Key Question 2a the population of interest was adults and children who undergo elective colon or rectal surgery. Key Question 2b focused specifically on adverse events in susceptible patient groups undergoing elective colorectal surgery, including adults and children with cardiovascular or pulmonary disease, those at the extremes of age (young children and the elderly), patients who have undergone adjuvant chemotherapy or radiotherapy, and patients with diabetes, kidney disease, or compromised immune function (including drug-induced immunosuppression).

We considered out of the scope of this review studies of patients receiving OMBP in preparation for endoscopic procedures or studies in patients who presented with complete bowel obstruction requiring surgical or endoscopic intervention to initiate OMBP. We also excluded studies of patients undergoing emergency colorectal surgery, and studies reporting results on the use of OMBP on patients undergoing noncolorectal surgery or on mixed populations in which less than 80 percent of patients underwent colorectal surgery (unless data on the subgroup undergoing colorectal surgery were reported separately).

### Interventions

For all Key Questions, the intervention of interest was OMBP administered before colon or rectal surgery. Studies in which the preparation was administered via nasogastric tube were also considered eligible. Mechanical bowel preparation delivered through other routes (e.g., retrograde preparation) was not considered within the scope of the review.

We considered the following cointerventions to be of interest when administered along with OMBP: oral or intravenous antibiotics administered before surgery (e.g., neomycin, erythromycin, metronidazole, various cephalosporins), rectal enemas, and dietary modification in preparation for surgery.

### Comparators

We considered alternative OMBP strategies (with or without cointerventions), including a strategy of not using OMBP as the comparators of interest.

### Outcomes

For Key Question 1 we considered the following intermediate outcomes: clinical outcomes (infectious outcomes [whenever possible, these were classified according to the definitions proposed by the Centers for Disease Control and Prevention^b^], anastomotic leakage, planned and unplanned ostomies, failed attempts to restore bowel continuity, venous thromboembolism [deep venous thrombosis and pulmonary embolism]); health system and resource utilization outcomes (readmissions after surgery, reoperation, additional interventional procedures [endoscopy, interventional radiology], length of stay [postoperative and overall], admission to intensive care unit, admission to nursing care); and patient-centered outcomes (patient satisfaction, and quality of life). We also extracted data on mortality, which was considered the terminal clinical outcome of interest (including all-cause and cause specific mortality). In general, we adopted the outcome definitions used in the primary studies that we reviewed (when available). For example, we operationally defined peritonitis/ intra-abdominal abscess (an infectious outcome of interest) as the presence of localized (abscess) or non-localized infection in the abdominal cavity. For this outcome, we included data from studies that reported information exclusively on abscess formation, as well as data from studies that reported information on “peritonitis” (however defined).

b Available at www.cdc.gov/hicpac/SSI/002_SSI.html#IB1; accessed February 11, 2013

For Key Question 2 we considered the following adverse events: nausea, vomiting, dehydration, electrolyte imbalance (e.g., hypokalemia, hypernatremia), kidney damage, emergency admissions prior to surgery; cancelled, delayed, or rescheduled surgeries, allergic reactions, seizures. Studies reporting any of these prespecified outcomes were included, regardless of causal attribution to OMBP (i.e., regardless of whether the authors of individual reports considered them to be related to OMBP use as opposed to any of the cointerventions); however, we collected information on causal attribution, when available.

### Timing, Followup Duration, and Setting

We did not select studies on the basis of followup duration and, when possible, outcome data (for all outcomes) were evaluated separately for the preoperative and postoperative periods. We also did not use the setting where studies were conducted as a selection criterion.

### Study Designs

For both Key Questions we considered randomized controlled trials (RCTs) comparing OMBP with non-OMBP preparation strategies or alternative active OMBP strategies in patient populations undergoing elective colon or rectal surgery. We required that RCTs enrolled at least 10 subjects per arm; smaller sample sizes were considered unlikely to provide estimates of treatment effects that are adequately precise. We also considered nonrandomized comparative studies (NRCS, prospective or retrospective; observational or experimental) comparing at least two of the interventions of interest in patients undergoing elective colon or rectal surgery. We required that NRCS enrolled at least 100 subjects (per arm); this cutoff was chosen because we expected that adjustments for confounders would be made, and that these would require a minimum sample size. This cutoff is probably lenient.^c^

c Assuming that at least three potential confounders are to be considered, regression models have to include at least four predictor variables (one per confounder and the treatment indicator). Using the (fairly optimistic) rule of 10, this means that a study should include at least 40 (= 4 × 10) outcome events for statistical analysis. This implies relatively large sample sizes, especially for low incidence rate events: Even if the outcome rate is relatively high, e.g., 10 percent, the sample size needs to be >400 patients, which is much larger than the cutoff employed here.

For Key Question 2, in addition to RCTs and NRCS, we also considered single-group studies (i.e., cohort studies where all patients are managed with OMBP and followed up longitudinally) and then undergo elective colon or rectal surgery. We required that single group studies reported results on at least 200 patients. This cutoff was chosen to ensure that studies would be likely to observe events that have relatively low incidence rates.^d^ For Key Question 2b (adverse events in susceptible subgroups) we specifically required that studies reported formal interaction tests or allowed for the calculation of statistics that compare the treatment effect among strata of the modifier of interest.

d For example, assuming the true incidence proportion is 0.01 (=1%) the probability of observing at least one event is approximately 87 percent for a study of 200 patients.

### Data Extraction

A single investigator extracted data from each study; a second reviewer verified quantitative results. Disagreements were resolved by consensus involving a third investigator. Data were extracted into electronic forms stored in the Systematic Review Data Repository23; separate forms were generated for each Key Question. Extraction forms were piloted on three to five articles for each Key Question and revisions were made as needed. We extracted information on the following items: patient selection criteria, population characteristics, sample size, study design, analytic details, and outcomes.

We prespecified that we would contact authors for the following reasons: (1) to clarify information reported in the papers that is hard to interpret (e.g., inconsistencies between tables and text); (2) to obtain missing data on key subgroups of interest when not available in the published reports (e.g., location of the surgery—right or left colon, rectum); and (3) to verify suspected overlap between study populations in publications from the same group of investigators. We contacted the corresponding author of each study by email or regular mail to collect additional information. We made a primary contact attempt (once all eligible studies had been identified) and sent two reminder emails (approximately 2 and 4 weeks after the first attempt).

### Population Overlap Across Publications

We took particular care to avoid double counting (both in qualitative and quantitative analyses) when published papers reported on potentially (fully or partially) overlapping patient populations. Potential overlap was assessed on the basis of the sampling population of each study, the enrollment period for each publication, the patient selection criteria, and information on overlap provided by the authors in the published papers. When overlap could not be ruled out on the basis of the above criteria, we used a conservative approach of considering as potentially overlapping in any studies conducted by the same investigators. In the presence of suspected overlap we based our analysis on the study reporting the largest number of outcome events (typically, the study reporting on the longest followup for longitudinal studies).

### Risk of Bias and Completeness of Reporting of Individual Studies

For assessing the risk of bias, we followed recently updated guidance from the Methods Guide. We used different criteria for assessing the risk of bias (and when appropriate, the completeness of reporting) for each study design. For RCTs, we based our assessment on items derived from the Cochrane risk of bias tool.24 For NRCSs and single-group studies, we used items from the Newcastle-Ottawa tool^e^, with the addition of items relevant to statistical analysis.25

e Available at: www.ohri.ca/programs/clinical_epidemiology/oxford.asp; accessed May 30, 2013.

We did not merge items into composite quality scores. Instead, we assessed and reported each methodological quality item (as Yes, No, or Unclear/Not Reported) for each eligible study. We rated each study as being of low, intermediate, or high risk of bias on the basis of these items Generally, studies with low risk of bias have the following features: lowest likelihood of confounding due to comparison to a randomized controlled group; a clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; clear reporting of dropouts and a dropout rate less than 20 percent; and no apparent bias. Studies with moderate risk of bias are susceptible to some bias but not sufficiently to invalidate results. They do not meet all the criteria for low risk of bias owing to some deficiencies, but none are likely to introduce major bias. Studies with moderate risk of bias may not be randomized or may be missing information, making it difficult to assess limitations and potential problems. Studies with high risk of bias are those with indications of bias that may invalidate the reported findings (e.g., observational studies not adjusting for any confounders, studies using historical controls, or studies with very high dropout rates). These studies have serious errors in design, analysis, or reporting and contain discrepancies in reporting or have large amounts of missing information.

Assessment of risk of bias was outcome specific. For example, a given study that was well designed, conducted and reported with respect to its primary outcome, but did a suboptimal analysis for a secondary outcome was graded of different quality for the two outcomes.

### Data Synthesis

#### Qualitative Synthesis

We summarized the findings of the report according to the order of the Key Questions. Within each Key Question, results were organized for each appropriate subgroup on the basis of the populations assessed, comparisons performed (e.g., OMBP versus no OMBP; or comparisons among alternative OMBP strategies), and outcomes assessed. We used tables and graphs (e.g., weighted scatterplots) to synthesize information across studies.

Single-group studies of OMBP were used to obtain ranges of adverse event rates among patients receiving the interventions of interest. These ranges were used to help contextualize the effects observed in comparative studies, and inform on their applicability.

#### Quantitative Synthesis

##### Meta-Analysis

For each comparison of interest, we assessed whether the eligible studies were sufficiently similar (“exchangeable”) to be combined in a meta-analysis on the basis of clinical heterogeneity of patient populations and interventions, as well as methodological heterogeneity of study designs and outcomes reported. RCTs and nonrandomized designs (NRCSs and single group studies) were not combined quantitatively because of heterogeneity in the comparisons and outcomes reported, as well as on the basis of concerns regarding risk of bias in nonrandomized studies.

The determination on the appropriateness of meta-analysis was made before any data analysis; we did not base the decision to perform a meta-analysis on statistical criteria for heterogeneity. Such criteria are often inadequate (e.g., have low power when the number of studies is small) and do not account for the ability to explore and explain heterogeneity by examining study-level characteristics. Main analyses included all relevant studies (e.g., studies of colon and rectum surgeries and those with mixed populations); subgroup analyses (e.g., separately by anatomic site of surgery, or by year when study enrollment was started) were performed, when possible. In cases where only a subset of the available studies could be quantitatively combined (e.g., when some studies were judged to be so clinically different from others as to be excluded from meta-analysis) we synthesized findings qualitatively by taking into account the magnitude and direction of effects.

###### Pairwise Meta-Analyses

Direct pairwise meta-analyses were undertaken when there were more than three non-overlapping studies evaluating the same intervention and comparator and reporting the same outcomes. All meta-analyses used random effects models. We fit models in the generalized linear mixed model framework using the binomial family for within study variability and a logit link function (i.e., the odds ratio was the measure of association). Estimation was via Bayesian Markov chain Monte Carlo methods. These methods incorporate uncertainty in the summary estimates of treatment effects more fully than frequentist methods. Heterogeneity was assessed based on the posterior distribution of the between-study heterogeneity parameter. Prior distributions for all model parameters were noninformative and were subjected to extensive sensitivity analyses, including the use of informative priors. Additional sensitivity analyses (including leave-one-out analyses, analyses assuming a fixed effects model, and reanalyses after excluding a group of studies) where undertaken when deemed important (e.g., in the presence of studies with outlying effect sizes or evidence of temporal changes in effect sizes). We explored between-study heterogeneity using subgroup and meta-regression analyses.

Frequentist meta-analysis methods (which do not require the specification of prior distributions for model parameters) were also used as in sensitivity analyses. In these analyses, for all statistical tests, except those for heterogeneity, statistical significance was defined as a two-sided P-value where P < 0.05. Heterogeneity was considered statistically significant when the P-value of Cochran's Q statistic was P < 0.1 to account for the low statistical power of the test. Between-study inconsistency was quantified with the I^2^ statistic.26

###### Network Meta-Analysis

###### Network Topology

We used network meta-analysis to jointly analyze evidence on the effectiveness of the following treatment strategies: OMBP, with or without enema, enema alone and no preparation. Studies comparing enema alone and no preparation were not in the scope of this report, and such studies (if any exist) are not included the analyses. This does not induce any bias in estimates of treatment effects obtained from comparisons reported in the included studies (i.e., OMBP versus no preparation; OMBP versus enema).

The topology of the network corresponds to the separate meta-analyses reported in a recent Cochrane Systematic Review.1 Specifically, in the main analysis we considered OMBP-treated groups as a single network node (i.e., we constructed a 3-node network, comprising OMBP, with or without enema, versus enema alone versus no preparation). Thus, treatment groups receiving OMBP were analyzed together, regardless of the use of enema in conjunction with OMBP. We believe that this analysis represents a compromise between obtaining informative estimates of the relative effects of interventions when few trials are available and the desire for more granular groupings of these interventions. It is also consistent with previous work on the topic.1 We did not construct or analyze networks that include comparisons between alternative active OMBP interventions, because of substantial concerns that head-to-head studies between active OMBP strategies are not similar to studies included in the above network. Specifically, we observed substantial heterogeneity in the cointerventions, the details of the OMBP strategies, and in the examined outcomes. We also observed that most studies with head-to-head comparisons of OMBP regimens were conducted more than two decades ago (e.g., 60 percent finished enrollment in or before 1990). By contrast, most comparisons of OMBP versus no OMBP (with or without enema) were conducted in more recent years (e.g., 86 percent begun enrollment after 1990). This temporal pattern in the design of OMBP studies parallels evolving trends in surgical practice (e.g., the use of enhanced recovery protocols, use of intravenous antibiotics), and suggests that secular changes have occurred in the characteristics of the enrolled populations and the typical cointerventions/preparation for surgery. This was deemed substantial ground for disputing the similarity between older studies comparing active OMBP strategies, and the more recent ones that compare using versus not using OMBP.

###### Models and Estimation

Similar to the pairwise analyses, we fit models in the generalized linear mixed model framework using the binomial family for within study variability and a logit link function. Network meta-analyses were performed for all outcomes of interest where several studies (at least 6 studies for at least one of the direct contrasts) existed.27 Models accounted for between-study heterogeneity and assumed homogeneity of the random effects variances at the between-study level. This assumption is typical especially when few studies provide information for each edge of the network.

In the main analysis (3-node network) no included study reported a comparison of enema versus no enema. Because the effect size for this comparison is only indirectly estimated, no assessment of consistency between direct and indirect effects is possible. In sensitivity analysis (4-node network), we had a closed loop and therefore the opportunity to test for inconsistency. We did not perform a formal test for inconsistency, but evaluated its presence qualitatively by comparing results from pairwise meta-analyses (direct effects) with results from the network analyses (combined direct and indirect effects). This is because in networks with relatively few and small studies quantitative assessments of inconsistency are very uncertain, and almost noninformative.

Network meta-analysis models were fit using Bayesian Markov Chain Monte Carlo (MCMC) methods because they offer additional modeling flexibility and because they allowed direct probabilistic statements regarding the magnitude and direction of the treatment effect. Prior distributions for all model parameters (including treatment effects and between-study variance components) were noninformative. For example, treatment effect priors did not exclude very large benefits or very large harms, as the variance in the prior for the true log odds ratio was set to 1000. Similarly, priors for variance components were consistent with no heterogeneity as well as very large heterogeneity. The prior for the between-study variance ranged from 0 to 25 on the log-odds ratio scale.

###### Reporting of Results

We obtained estimates of the treatment effects of interest (e.g., odds ratios for anastomotic leakage comparing OMBP versus no OMBP), as well as the rank probabilities for each treatment strategy (e.g., probability that OMBP is the best treatment). We also estimated probabilities that the difference (in the odds ratio scale) between pairs of treatments was larger than 1.00, 1.10, 1.25, 1.50, 2.00, 3.00, and 5.00 (or smaller than the inverse of these values, to capture extreme effects in the other direction). These cutoffs were chosen after discussion with the TEP.

##### Subgroup and Meta-Regression Analysis

For pairwise comparisons OMBP versus enema or no preparation we assessed the impact of study-level characteristics on estimates of the effect size, using subgroup and random effects meta-regression analyses. Such analyses were performed for anatomic location (colon versus rectum), year of study publication, and items related to study risk of bias (specifically, randomized sequence generation and allocation concealment).

##### Small-Study Effects and Publication Bias

We did not use funnel plots or statistical tests of funnel plot asymmetry to assess the presence of small-study effects in pairwise meta-analyses — that is, differences between larger (more precise) and smaller (less precise) studies. Although these methods are sometimes considered as diagnostics for publication bias, theoretical and empirical studies show that they cannot differentiate publication bias from genuine heterogeneity.28,29 Furthermore, selective outcome reporting, other biases, or chance can also lead to significant results. Because of these reasons, we only provide qualitative dispositions regarding publication bias.

##### Software

All analyses were performed using Stata IC (version 13.1 Stata Corp., College Station, TX). MCMC methods were implemented in Winbugs (version 1.4.3; MRC Biostatistics Unit, Cambridge, UK), through calls from Stata. Results from Bayesian analyses are reported as medians and 95% central credible intervals (CrI) from the posterior distributions. All frequentist tests were two-sided (except those for heterogeneity) and statistical significance was defined as a P value of less than 0.05. We did not perform any adjustments for multiple comparisons. Graphs were generated in Stata.

### Grading the Body of Evidence

We followed the Methods Guide to evaluate the strength of the body of evidence for each Key Question with respect to the following domains: risk of bias, consistency, directness, precision, and reporting bias.

Briefly, we determined risk of bias (low, medium, or high) on the basis of the study design and the methodological quality of the studies.

We rated the consistency of the data as no inconsistency, inconsistency present, or not applicable (if there is only one study available). We did not use rigid counts of studies as standards of evaluation (e.g., four of five studies agree, therefore the data are consistent); instead, we assessed the direction, magnitude, and statistical significance of all studies and made a determination. We described our logic when studies were not unanimous.

We assessed directness of the evidence (direct versus indirect) on the basis of the use of surrogate outcomes or the need for indirect comparisons (e.g., when treatments had not been directly compared and inference was based on observations across studies).

We assessed the precision of the evidence as precise or imprecise on the basis of the degree of certainty surrounding each effect estimate. Generally, a precise estimate is one that allows for a clinically useful conclusion. An imprecise estimate is one for which the credible (or confidence) interval is wide enough to include clinically distinct conclusions and that therefore precludes a conclusion.

The potential for reporting bias (suspected versus not suspected) was evaluated with respect to publication bias, selective outcome reporting bias, and selective analysis reporting bias. For reporting bias, we provided qualitative dispositions rather than perform formal statistical tests to evaluate differences in the effect sizes between more precise (larger) and less precise (smaller) studies (see above, under Small-Study Effects and Publication Bias). We evaluated the reported results across studies qualitatively, on the basis of completeness of reporting (separately for each outcome of interest), number of enrolled patients, and numbers of observed events. Judgment on the potential for selective outcome reporting bias will be based on reporting patterns for each outcome of interest across studies. We acknowledge that both types of reporting bias are difficult to reliably detect on the basis of data available in published research studies (i.e., without access to study protocols and detailed analysis plans). Although some degree of subjectivity is unavoidable in this assessment, we present explicitly all operational decisions and provide the rationale for our judgment on reporting bias.

Finally, we rated the body of evidence using four strength of evidence levels: high, moderate, low, and insufficient. These ratings describe our level of certainty that the evidence reflects the true effect for the major comparisons of interest.

### Assessing Applicability

We followed the Methods Guide30 to evaluate the applicability of included studies to patient populations of interest. We evaluated studies (or subgroups of studies) of elderly adults (operationally defined as patients 65 years of age or older) separately if data are available. Applicability will also be judged separately for various indications of OMBP use (e.g., left-sided versus right-sided colon surgery, rectal surgery), characteristics of the OMBP preparation strategy (e.g., total duration of preparation, inpatient versus outpatient use); patient sex (men versus women), and setting of care.