# Acknowledgments

The authors would like to thank Dr. Cameron Platell (St. John of God Subiaco Hospital, Perth, Australia) for providing unpublished outcome data from a randomized trial included in this report; Dr. Mike Parker (Keyhole Surgery Ltd, Kent, United Kingdom) for providing clarifications regarding the mechanical preparation protocol for a randomized trial that was deemed ineligible for inclusion; and Dr. Shehzad Akbar Khan (Hayatabad Medical Complex, Peshawar, Pakistan) for providing access to study materials (reprints). The authors also acknowledge the individuals listed below for their contributions to this project:

## Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Fizan Abdullah, M.D., Ph.D.
  Associate Professor of Surgery
  Assistant Program Director, Residency in General Surgery
  Associate Professor of International Health
  Bloomberg School of Public Health
  Program Director, Fellowship in Pediatric Surgery
  Johns Hopkins Children's Center
  Baltimore, MD
- Waleed Lutfiyya, M.D.
  Kaiser Permanente
  Portland, OR
- Laura Porter, M.D.
  Colon Cancer Alliance
  Washington, DC
- Robert Sawyer, M.D.
  Professor of Surgery and Public Health Sciences
  Chief of Acute Care Surgery
  University of Virginia Health System
  Charlottesville, VA
- John Sperati, M.D.
  Assistant Professor of Medicine
  Associate Program Director
  Osler Medical Residency Program
  Johns Hopkins Medical Institutions
  Baltimore, MD
- Mark Welton, M.D.
  Vice Chief of Staff, Stanford Hospital and Clinics
  Professor of Surgery, Stanford University Medical School
  Stanford, CA
- Judy Zerzan, M.D., M.P.H.
  Chief Medical Officer/Deputy Medicaid Director
  Colorado Department of Health Care Policy and Financing
  Clinical Assistant Professor
  University of Colorado, Denver
  Denver, CO

## Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Michael Barza, M.D.
  Chief of Medicine and Program Director
  Steward Carney Hospital
  Vice Chairman for Clinical Affairs
  Department of Medicine
  Tufts Medical Center
  Boston, MA
- Nancy Baxter, M.D.
  Associate Professor, Department of Surgery and Institute of Health Policy, Management and Evaluation (IHPME)
  University of Toronto
  Head, Division of General Surgery
  St Michael's Hospital
  Toronto, Ontario, Canada
- Julio Garcia-Aguilar, M.D.
  Chief, Colorectal Service
  Stuart HQ Quan Chair in Colorectal Surgery
  Memorial Sloan Kettering Cancer Center
  New York, NY
- Kamal Itani, M.D.
  Professor of Surgery, Boston University
  Chief of General Surgery, Boston VA
  Health Care System
  Boston, MA
- Peter Mattei, M.D.
  Associate Professor of Surgery
  University of Pennsylvania
  Attending Physician
  Division of General, Thoracic and Fetal Surgery
  Children's Hospital of Philadelphia
  Philadelphia, PA
- Marcia McGory Russell, M.D.
  Staff Surgeon
  Los Angeles VA Health Care System
  Assistant Professor-in-Residence
  University of California – Los Angeles
  Los Angeles, CA
- Robin McLeod, M.D.
  Staff Surgeon, Mount Sinai Hospital
  Vice Chair, Quality and Performance
  Centre for Patient Safety
  Professor of Surgery, Public Health Sciences, and Health Policy, Management and Evaluation
  University of Toronto
  Surgical Lead, Quality Improvement and Knowledge Transfer
  Surgical Oncology Program
  Cancer Care Ontario
  Toronto, Ontario, Canada
- Mark Welton, M.D.
  Vice Chief of Staff
  Stanford Hospital and Clinics
  Professor of Surgery
  Stanford University Medical School
  Stanford, CA
- Nancy You, M.D.
  Affiliate Faculty, Clinical Cancer Genetics Program
  MD Anderson Cancer Center
  Assistant Professor
  Department of Surgical Oncology
  University of Texas
  Houston, TX

## Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Michael Barza, M.D.
  Chief of Medicine and Program Director
  Steward Carney Hospital
  Vice Chairman for Clinical Affairs
  Department of Medicine
  Tufts Medical Center
  Boston, MA
- Nancy Baxter, M.D.
  Associate Professor
  Department of Surgery and Institute of Health Policy, Management and Evaluation (IHPME)
  University of Toronto
  Head, Division of General Surgery
  St Michael's Hospital
  Toronto, Ontario, Canada
- David Berger, M.D., M.H.C.M.
  VP and CMO, Baylor College of Medicine Medical Center
  Professor of Surgery, Baylor College of Medicine
  Member, Houston Center for Innovations in Quality, Effectiveness and Safety
  Houston, TX
- Robert Fanelli, M.D., FACS, FASGE
  Chief, Minimally Invasive Surgery
  Chief, Surgical Endoscopy
  The Guthrie Clinic, Ltd.
  Sayre, PA
- Donald Fry, M.D.
  Executive Vice President for Clinical Outcomes Management, MPA
  Adjunct Professor of Surgery, Northwestern University
  Professor Emeritus of Surgery, University of New Mexico School of Medicine
  Chicago, IL
- Julio Garcia-Aguilar, M.D.
  Chief, Colorectal Service
  Stuart HQ Quan Chair in Colorectal Surgery
  Memorial Sloan Kettering Cancer Center
  New York, NY
- Mary Hawn, M.D., M.P.H.
  Professor of Surgery
  University of Alabama Medical School
  Chief, GI Surgery, University of Alabama Medical Center
  Birmingham, AL
- Barbel Jung, M.D.
  Chief of Surgery
  Ostergotland County Council
  Linköping, Sweden
- Peter Mattei, M.D.
  Associate Professor of Surgery
  University of Pennsylvania
  Attending Physician
  Division of General, Thoracic and Fetal Surgery
  Children's Hospital of Philadelphia
  Philadelphia, PA
- Marcia McGory Russell, M.D.
  Staff Surgeon
  Los Angeles VA Health Care System
  Assistant Professor-in-Residence
  University of California – Los Angeles
  Los Angeles, CA
- Robin McLeod, M.D.
  Staff Surgeon, Mount Sinai Hospital
  Vice Chair, Quality and Performance
  Centre for Patient Safety
  Professor of Surgery, Public Health Sciences, and Health Policy, Management and Evaluation
  University of Toronto
  Surgical Lead, Quality Improvement and Knowledge Transfer
  Surgical Oncology Program
  Cancer Care Ontario
  Toronto, Ontario, Canada
- Matthew Mutch, M.D.
  Associate Professor of Surgery
  Washington University School of Medicine in St. Louis
  St. Louis, MO
- Ben Vandermeer, M.Sc.
  Alberta Research Centre for Health Evidence
  Edmonton, Alberta, Canada
- Mark Welton, M.D.
  Vice Chief of Staff
  Stanford Hospital and Clinics
  Professor of Surgery
  Stanford University Medical School
  Stanford, CA
- Steven D. Wexner, M.D., Ph.D. (Hon), FACS, FRCS, FRCS(Ed)
  Director, Digestive Disease Center
  Chair, Department of Colorectal Surgery
  Emeritus Chief of Staff
  Cleveland Clinic Florida
  Affiliate Professor
  Florida Atlantic University College of Medicine
  Clinical Professor
  Florida International University College of Medicine
  Weston, FL