# Discussion

## Key Findings

We reviewed 60 studies spanning 40 years of empirical data on the benefits and harms of alternative OMBP strategies for elective colorectal surgery. After examining the literature for a wide range of clinical outcomes, we found no evidence that OMBP with or without enema differs from enema or no preparation. However, the uncertainty accompanying the estimated treatment effects was considerable. Based on the boundaries of the credible intervals, one cannot exclude a modest (e.g., 30 to 50 percent) change in odds in either direction for all-cause mortality, anastomotic leakage, wound infection, and peritonitis. This uncertainty is explained by the relatively small sample size of included studies and the relative rarity of key clinical events such as death, anastomotic leakage, reoperation, and severe infection. Of more concern is that important subgroups, such as anatomic location (colon vs. rectum) and type of surgery (laparoscopic versus open) were sparsely reported in the published literature, as was information on important potential effect modifiers (e.g., oral or parenteral antibiotics).

We also found that the evidence on the comparative effectiveness and safety of alternative preparation strategies was insufficient and probably not very applicable to current clinical practice. Information on the safety of OMBP was not consistently reported. It is also unclear whether the type or frequency of adverse events of OMBP differ across patient subgroups, e.g., in patients with cardiac, pulmonary, or renal disease; cancer; suppressed immune function; or patients receiving chemotherapy, radiotherapy or immunosuppression.

We observed that the early trials explored comparisons among alternative active OMBP strategies, with later published and recent studies evaluating the more fundamental question of using versus not using OMBP. This reflects an apparent shift in the prevailing opinions about the role of OMBP prior to elective colorectal surgery. Since the early 1970's OMBP was widely considered highly desirable, presumably on the basis of pathophysiological and practical rationales but without serious concomitant empirical support.4,13 Clinical equipoise presumably existed between alternative OMBP strategies; today, it is probably fair to state that the question is between using simple short-duration OMBP regimens versus not.

## Assessment of the Strength of Evidence

Table 7 presents a summary of the report's key findings for each Key Question. Strength of evidence was assessed separately for the comparison of OMBP (with or without enema) versus no preparation and the comparison of OMBP versus enema, for consistency with previous work on the same topic and because studies of OMBP versus enema generally exhibited greater statistical heterogeneity, as compared to studies of OMBP versus no preparation. Our conclusions for the overall comparison of OMBP versus no OMBP are similar. Please see the Methods section for a detailed discussion of our approach to rating the strength of evidence. Overall, we found weak evidence that OMBP and no preparation had similar effectiveness with respect to the outcomes of all-cause mortality, anastomotic leakage, wound infection, and peritonitis. The ORs for these outcomes were all close to 1 and the credible intervals from pairwise meta-analyses excluded large differences (e.g., increasing the odds of an outcome by 2-3 times). For all other outcomes for this comparison, results were too imprecise to exclude even larger treatment effects and thus insufficient to draw conclusions. Similarly, we found that evidence on the comparison of OMBP versus enema was insufficient for all outcomes of interest.

Table 7 Summary assessment of the strength of evidence

Population | Outcome | Comparison | Assessment of the Strength of Evidence | Key Findings and Comments^*^
KQ1 : Adult patients undergoing colorectal surgery | All-cause mortality | OMBP versus no prep | Low (for lack of difference) | The OR in meta-analysis of 10 studies was 1.09 (95% CrI 0.57 to 2.99), indicating moderate to substantial uncertainty in the summary estimate. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | All-cause mortality | OMBP versus enema | Insufficient | The OR in meta-analysis of 4 studies was 1.99 (95% CrI 0.27 to 18.45), indicating substantial uncertainty in the summary estimate. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | Anastomotic leakage | OMBP versus no prep | Low (for lack of difference) | The OR in meta-analysis of 12 studies was 1.06 (95% CrI 0.73 to 1.73), indicating moderate uncertainty in the summary estimate. Pairwise analysis concurred. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | Anastomotic leakage | OMBP versus enema | Insufficient | The OR in meta-analysis of 4 studies was 1.24 (95% CrI 0.38 to 4.72), indicating substantial uncertainty in the summary estimate. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | Wound infection | OMBP versus no prep | Low (for lack of difference) | The OR in meta-analysis of 12 studies was 1.27 (95% CrI 0.95 to 1.88), indicating moderate uncertainty in the summary estimate. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | Wound infection | OMBP versus enema | Insufficient | The OR in meta-analysis of 4 studies was 1.04 (95% CrI 0.37 to 3.34), indicating substantial uncertainty in the summary estimate. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | Peritonitis/ intra-abdominal infection | OMBP versus no prep | Low (for lack of difference) | The OR in meta-analysis of 10 studies was 0.84 (95% CrI 0.45 to 2.00), indicating moderate uncertainty in the summary estimate. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | Peritonitis/ intra-abdominal infection | OMBP versus enema | Insufficient | The OR in meta-analysis of 4 studies was 0.99 (95% CrI 0.21 to 4.68), indicating substantial uncertainty in the summary estimate. Studies were at moderate ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | Reoperation | OMBP versus no prep | Insufficient | The OR in meta-analysis of 6 studies was 1.15 (95% CrI 0.73 to 2.50), indicating substantial uncertainty in the summary estimate. Studies were at moderate ROB. There was some concern regarding selective outcome reporting. There was statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected; the 2.5th percentile of the posterior distribution of the between-study variance of the log-OR was 0.27.
KQ1 : Adult patients undergoing colorectal surgery | Reoperation | OMBP versus enema | Insufficient | The OR in meta-analysis of 2 studies was 0.50 (95% CrI 0.03 to 6.12), indicating substantial uncertainty in the summary estimate. Studies were at moderate ROB. There was some concern regarding selective outcome reporting. There was statistical evidence of inconsistency; however, estimates were imprecise.
KQ1 : Adult patients undergoing colorectal surgery | All other effectiveness outcomes | OMBP versus no prep | Insufficient | Few if any studies reported information; study-specific results were imprecise. There was concern about selective outcome reporting.
KQ1 : Adult patients undergoing colorectal surgery | All other effectiveness outcomes | OMBP versus enema | Insufficient | Few if any studies reported information; study-specific results were imprecise. There was concern about selective outcome reporting.
KQ1 : Adult patients undergoing colorectal surgery | All outcomes | Alternative active OMBP strategies versus each other | Insufficient | Individual studies compared diverse interventions and reported outcomes heterogeneously, precluding synthesis. Study specific results were imprecise. Studies were at moderate to high ROB. There was no indication of selective outcome reporting. There was no statistical evidence of inconsistency; however, because there are only a few studies and most of them are small, statistical heterogeneity cannot be reliably detected.
KQ1 : Adult patients undergoing colorectal surgery | All outcomes | Inpatient vs. outpatient OMBP | Insufficient | Only 2 studies were available (1 RCT, at moderate ROB, and 1 NRCS, at high ROB). Study-specific estimates were imprecise.
KQ1 : Children undergoing elective colorectal surgery | All outcomes | All comparisons | Insufficient | Only 2 studies provided evidence on children undergoing elective colorectal surgery. Studies reported information only for wound infection (no other effectiveness outcomes were assessed) and produced imprecise results.
KQ1 : Patients undergoing elective surgery for right-sided or left-sided colon, or rectal surgery | All outcomes | All comparisons | Insufficient | Only a minority of studies provided anatomic location specific results (and only for anastomotic leakage). Subgroup analyses did not reveal a difference in the effect of OMBP compared to enema or no preparation between colon and rectal surgery population with respect to the outcome of anastomotic leakage. Results were very imprecise for both subgroups and anatomic location was heterogeneously defined across studies. There is concern regarding selective analysis reporting.
KQ2: Patients undergoing elective colorectal surgery (general surgical population) | Adverse events | All comparisons | Insufficient | When interpreting the data available for this review results are insufficient. Most prespecified adverse events of interest were evaluated by a small minority of studies or not examined at all. When reported, study-specific results did not lead to definitive conclusions due to imprecise results, and lack of validation of the measurement scales used (for patient symptom scores). However, the evolution of the preparation strategies used in trials (with most recent studies using PEG-based strategies, possibly in combination with laxatives) indicates that these preparations may be considered the safest or more palatable for patients.
KQ2: Patients undergoing elective surgery who may be at particular risk for adverse events | Adverse events | All comparisons | Insufficient | No relevant studies were identified.

CrI = credible interval; KQ = key question; NRCS = nonrandomized comparative study; no prep = no OMBP and no enema; OR = odds ratio; PEG = polyethylene glycol; RCT = randomized controlled trial; ROB = risk of bias

* Summary estimates reported in this table are those from the pairwise Bayesian meta-analysis. Results from extensive sensitivity analyses and network meta-analyses were consistent with those presented in the Table.

Compared to a recent Cochrane Review of OMBP we have included a broader spectrum of study designs (including NRCSs and single group cohorts) and have performed more extensive data analyses using state-of-the art methods that more fully account for the uncertainties in the synthesis of evidence.97 Thus, our interpretation of the evidence base is more conservative than that of the Cochrane review on the same topic1 and other recent meta-analyses.98-101 While, similarly to those reviews, we did not find evidence of clear benefit from OMBP, the wider credible intervals around our results lead us to conclude that modest benefit or harm cannot be excluded. Given the very large number of colorectal surgeries performed annually, modest effects can be clinically significant and therefore further research is urgently needed to provide a definitive answer. In the future research section we argue that a comprehensive evaluation of the comparative effectiveness of OMBP is entirely possible.

## Applicability

The existing evidence base comparing OMBP (with or without enema) versus enema or no preparation, appears to be applicable to U.S. settings. Studies enrolled patients with an age distribution similar to that of patients undergoing colorectal surgery in the U.S., and for indications that represent the most prevalent indications in U.S. clinical practice. However, none of these studies has been conducted in the U.S., raising some concern that system-level differences may render findings less applicable to surgical practice. Findings may be most applicable to patients undergoing colon surgery; data on patients undergoing rectal surgery were sparse, and thus the applicability of findings to this population is at best unclear. Similarly, the applicability of our findings to patients undergoing laparoscopic colorectal surgery is unclear, because few studies reported relevant information.

Preparation of the bowel is only one of many supportive interventions used prior to colorectal surgery with the goal of attaining better surgical outcomes and earlier postoperative recovery. Other pertinent interventions include preoperative (counseling, feeding, etc.), perioperative (avoiding hypothermia, using epidural analgesia, etc.), and postoperative (e.g., avoiding nasogastric tubes and drains, encouraging early mobilization and oral feeding) aspects of care.102 Often such interventions are “bundled” in “Early Recovery After Surgery” (ERAS) programs that aim to reduce the length of stay and improve clinical outcomes. Although existing trials of ERAS programs include, among other things, the omission of OMBP as an intervention component, it is not clear how our findings apply in settings where additional ERAS components are implemented.102

Regarding studies comparing alternative active OMBP strategies, applicability appears to be limited, because they examined OMBP regimens that have fallen out of use in modern practice. Overall, the reviewed studies of active versus active OMBP strategies provide little information on comparative effectiveness and safety that is applicable to current clinical use. Further, there is reemerging interest in the use of oral antibiotics agents in bowel preparation. The majority of the included studies did not use oral antibiotics, but we deemed that this did not limit their applicability.

## Limitations of the Evidence

On the basis of the reviewed studies, we believe that the evidence regarding OMBP for colorectal surgery is limited in the following ways:

- Most studies enrolled small numbers of patients and reported low event rates for major clinical events during followup. This led to imprecise study-specific results; for many outcomes substantial imprecision remained after combining evidence from most available published trials.
- Studies did not report results for important clinical subgroups, particularly those defined by anatomic location of surgery (colon versus rectal surgery) and the type of surgical procedure performed (e.g., open versus laparoscopic surgery).
- Studies did not consistently report information on potential effect modifiers (particularly the co-administration of oral antibiotics).
- The literature comparing alternative active OMBP strategies for colorectal strategy was fragmented because studies used a large number of diverse preparation regimens and reported results for heterogeneous, often poorly defined, outcomes. It is not clear how most of these map to current standard definitions of outcomes (e.g., CDC definitions for wound infections).
- Nonrandomized trials, and particularly observational studies, could not effectively supplement the results of randomized trials because exposure ascertainment was often not done in detail, analyses were not adjusted for or stratified by important patient-, disease-, or system-level characteristics, and methods to adequately control confounding bias were not consistently used.
- Studies, particularly those conducted in earlier years, typically did not report adequate information to judge whether the outcome definitions of reported events matched currently recommended definitions (e.g., those proposed by the Center's for Disease Control and Prevention).

## Limitations of This Review

Several limitations need to be considered when interpreting our results. First, our conclusions, to a large extent, reflect weaknesses of the underlying evidence base. For example, our ability to perform subgroup analyses to explore the impact of patient-, disease-, or system-level characteristics on the effectiveness of OMBP is limited by the incomplete reporting of relevant information in the published papers. Second, we excluded studies not published in English. Previous work that included non-English language studies identified only three publications with small sample sizes (totaling 269 patients). Third, we have relied mainly on electronic database searches and perusal of reference lists to identify relevant studies. Unpublished relevant studies may have been missed. Fourth, indexing of nonrandomized studies – and single-group cohort studies in particular – is less complete than that of randomized trials and we may have failed to identify relevant studies. However, we did not use search filters that limit results to specific study designs, in order to increase the sensitivity of our searches.

## Ongoing Research

A search on May 15, 2013, in the ClinicalTrials.gov registry identified 11 potentially relevant records. After full text review, 5 records of studies that are be expected to provide information relevant to the Key Questions of this report were identified (3 studies are comparisons of OMBP versus enema or no preparation; one is a comparison of two OMBP strategies and 1 is a comparison of OMBP against a nutritional intervention). Appendix G summarizes information from these studies. None of these studies provided results in the ClinicalTrials.gov database at the time of this search.

## Evidence Gaps

Table 8 summarizes the evidence gaps with regards to the two Key Questions of this systematic review.

Table 8 Evidence gaps

Key Question | Category | Evidence Gap
Comparative effectiveness of OMBP strategies | General | - There was substantial uncertainty regarding the effectiveness of OMBP versus enema or no preparation for patients undergoing colorectal surgery.
Comparative effectiveness of OMBP strategies | Population | - Limited information was available for patients undergoing elective rectal surgery.; - Very limited information is available for patients undergoing laparoscopic surgery.
Comparative effectiveness of OMBP strategies | Interventions & Comparators | - The optimal preparation regimen for patients undergoing elective colorectal surgery remains unclear.; - Potential interactions between OMBP regimens and cointerventions (e.g., enema, oral antibiotics) have not been explored adequately.
Comparative effectiveness of OMBP strategies | Outcomes | - Studies did not always use consistent outcome definition or did not provide adequate details on outcome ascertainment to reliably assess whether outcomes were “similar enough” across studies.; - Studies often heterogeneously and incompletely reported key clinical results, representing a “lost opportunity” for synthesis across studies.
Adverse events of OMBP strategies | General | - Limited information was available for key adverse events of interest.; - Many adverse events have not been evaluated in trials comparing alternative active OMBP strategies.
Adverse events of OMBP strategies | Outcomes | - Limited information for specified outcomes across all investigated study designs.; - Nonrandomized studies did not offer.
Adverse events in susceptible groups | General | - No studies provided information on OMBP-related adverse events in patient groups that may be particularly susceptible (adults and children with cardiovascular or pulmonary disease, extremes of age, patients who have undergone adjuvant chemotherapy or radiotherapy, and patients with diabetes, kidney disease, or compromised immune function).

OMBP = oral mechanical bowel preparation

## Future Research

This review identified major gaps in the published evidence on the comparative effectiveness and safety of OMBP for elective colorectal surgery. We believe that the following evidence gaps can be fruitful areas for future research:

- RCTs to evaluate the comparative effectiveness of OMBP: Given the uncertainty in meta-analytic estimates for most key clinical outcomes, a large, pragmatic RCT could substantially reduce uncertainty and definitively settle the main question. Conducting such a trial appears to be quite feasible, given the large number of elective colorectal surgeries performed annually, the relatively low cost of the interventions to be compared (OMBP, enema, no preparation), and that only a short-term followup (e.g., 30 days) is sufficient to assess almost all postsurgical outcomes of interest. Furthermore, if a non-inferiority design is adopted the required sample size should be relatively easy to accrue in a multicenter setting. Conducting a new large trial in the U.S. may facilitate uptake of the findings in this country by mitigating concerns about applicability. Consideration should also be given to factorial designs that can provide evidence on the comparative effectiveness of multiple interventions of interest (e.g., OMBP × enema × oral antibiotics). The study should be powered to evaluate major clinical outcomes including mortality, anastomotic leakage, and surgical site infections (using the latest CDC guidelines^j^: superficial, deep incisional, organ/space). Figure 16 presents some example sample size calculations for different trial designs, treatment effects (or non-inferiority margins), and baseline event rates. Of note, a single primary study is unlikely to reliably address all decisionmaking uncertainties for all populations of interest in isolation from existing evidence; for this reason plans should be in place for a prospective meta-analysis to combine the results of a new study with previously completed trials (if possible using patient-level data).
  j Available at www.cdc.gov/nhsn/pdfs/pscmanual/9pscssicurrent.pdf; accessed May 30, 2013.
- Conducting an individual patient data meta-analysis of existing trials of OMBP: a consortium of investigators could perform such an analysis at much lower cost compared to a new trial. While it is unlikely that a reanalysis would result in more precise estimates, it would allow the opportunity to explore effects on subgroups for which no information is currently available (e.g., by anatomic location). By pooling existing datasets, an effort could be made to standardize outcome definitions and perform joint analyses for important subgroups of patients (e.g., colon versus rectal surgery). The results of such individual-patient data meta-analyses could be used to inform the design of future primary trials.
- Conducting observational studies for the comparative effectiveness and harms of OMBP: observational studies can inform the comparative effectiveness of alternative OMBP strategies, particularly for susceptible groups (e.g., patients with compromised function of major systems) that have not been represented in the RCTs thus far. Such studies should have large sample sizes (to account for the low incidence of most outcome events) chosen on the basis of prospective power analyses, include patients representative of those seen in clinical practice, and use strong methods to address confounding bias (e.g., propensity score or instrumental variable methods). Further, exposure assessment should include the collection of details regarding the preparation strategy (i.e., the OMBP regimen and any cointerventions) and outcome ascertainment should be done using standardized definitions for all outcomes of interest. Quantitative bias analyses could be used to address concerns regarding unobserved confounding in nonrandomized studies. Although the use of observational data always requires additional assumptions for valid inference on treatment effects (compared to randomized designs), well designed observational studies can offer valuable information both regarding the effectiveness and adverse effects of OMBP.

Figure 16 Sample size requirements for superiority and noninferiority

The figure presents sample size calculations for 1:1 randomized trials comparing alternative OMBP strategies (e.g., OMBP vs. no preparation), over different baseline event rates (ranging from a low event rate of 1% to a common event rate of 50%, as could be observed for a composite outcome). The panel on the left presents sample size calculations for a superiority design, for alternative magnitudes of the treatment effect (RR; ranging from 0.9, a small protective effect to 0.8, a modest effect); calculations are based on a two-sided test for the difference of two proportions with α=0.05. The panel on the right presents sample size calculations for a non-inferiority design, for alternative non-inferiority margins (δ; ranging from a narrow marging of 5% to a somewhat broad margin of 10%); calculations are for a one-sided test for the difference of two proportions with α=0.025.

Figure 16 presents sample size calculations for 1:1 randomized trials comparing alternative OMBP strategies (e.g., OMBP vs. no preparation), over different baseline event rates (ranging from a low event rate of 1% to a common event rate of 50%, as could be observed for a composite outcome). The panel on the left presents sample size calculations for a superiority design, for alternative magnitudes of the treatment effect (RR; ranging from 0.9, a small protective effect to 0.8, a modest effect); calculations are based on a two-sided test for the difference of two proportions with α=0.05. The panel on the right presents sample size calculations for a non-inferiority design, for alternative non-inferiority margins (δ; ranging from a narrow marging of 5% to a somewhat broad margin of 10%); calculations are for a one-sided test for the difference of two proportions with α=0.025.

## Conclusions

We found weak evidence suggesting that OMBP has similar effectiveness with no preparation with respect to all-cause mortality, anastomotic leakage, wound infection, and peritonitis for patients undergoing elective colorectal surgery. However, the evidence base was too weak to confidently exclude either modest (30–50%) benefit or modest harm. Evidence on the comparative effectiveness of OMBP versus no preparation was insufficient for all other outcomes, as was evidence on the comparative effectiveness of OMBP versus enema for all outcomes. The body of literature on alternative active OMBP strategies was largely irrelevant to current surgical decisionmaking because the trials were underpowered, reported poorly defined outcomes, and compared preparations no longer in use. Future studies, including pooled reanalyses of existing data and new comparative studies (both randomized and nonrandomized), hold promise for informing clinical decisions.