# Background

## Oral Mechanical Preparation for Colorectal Surgery

In the U.S. oral mechanical bowel preparation (OMBP), defined as an oral preparation given prior to surgery to clear fecal material from the bowel lumen, is often prescribed preoperatively for patients undergoing elective colorectal surgery.1 OMBP is sometimes used as a precaution in anticipation of possible iatrogenic bowel injury during abdominal and pelvic surgeries that do not entail resection of the colon or rectum (e.g., urologic or gynecologic procedures). OMBP is also routinely prescribed prior to colonoscopy, to allow maximal visualization of the intraluminal bowel during the procedure, although that use is not within the scope of this report.

In 2009 there were 254,000 surgeries categorized as partial excisions of the large intestine;2 of these, 99.2 percent were for patients 15 years of age or older, and 50.4 percent were for patients 65 years of age or older. An analysis of claims from one large insurer demonstrated that the most common indication for colorectal surgery was cancer (43.9 percent), followed by diverticulitis (30.4 percent), and inflammatory bowel disease (4.5 percent).3

In the context of colorectal surgery, many have considered OMBP necessary to prevent infectious complications, mainly based on the belief that postoperative infectious morbidities are related to spillage of septic bowel contents during surgery and anastomotic leakage immediately after surgery.4 Gross spillage of fecal material in the operative field increases the need for a stoma, which can impact patients' quality of life. Moreover, a stoma requires additional surgery (to reverse it), and possibly other surgeries should complications such as bowel obstructions or incisional hernia arise.5,6 Complication rates for elective colorectal surgery range between 4 and 36 percent.7,8 A surgical site infection can increase the hospitalization stay from approximately 4 to 21 days and increase costs from approximately $11,000 to $43,000.^7^ A recent analysis of more than 10,000 patients from a commercial insurance database reported that the 90-day readmission rate was 23.3 percent and the 30-day surgical site infection rate was 18.8 percent, following colorectal surgery.3 The median cost of a surgical site infection readmission was $12,835.

OMBP for colon or rectal surgery appears to be widespread practice in the United States. A 2003 U.S. survey showed that more than 99 percent of colorectal surgeons routinely employed OMBP.9 A recent study (2007–2009) of 24 Michigan hospitals reported that 86 percent of all elective colorectal surgeries were preceded by OMBP (49.6 percent without oral antibiotics and 36.4 percent with oral antibiotics).10 In addition, anecdotal data from a recent meeting of the American Society of Colon and Rectal Surgeons indicated that OMBP use is widespread in the U.S. although recent surveys indicate that some surgeons have discontinued use of OMBP for right-side colon surgery.

The initial adoption of OMBP prior to colorectal surgery was based on expert opinion and observational data.11,12 Recently, several trials (mostly conducted in Europe) found no statistically significant benefit for OMBP with colon surgery. For example, a recent large randomized trial found that the rate of anastomotic leakage, wound infections, and mortality did not differ by more than 3% between patients assigned to OMBP as compared to those assigned to the control group. On the basis of these data, utilization of OMBP has declined in Europe, but less so in the U.S.13

Clinical guidelines reflect this uncertainty. For example, the 2010 guidelines of the Canadian Society of Colon and Rectal Surgeons stated that good evidence supported the omission of OMBP in the preoperative management of patients undergoing open elective right-sided and left-sided colorectal surgical resections.14 However, the guidelines also stated that there was insufficient evidence to support or refute the omission of OMBP for patients undergoing low anterior resection (with or without diverting stomas) or for patients undergoing laparoscopic colorectal surgery. The evidence regarding the use of enemas was also considered insufficient.

## Clinical Use of OMBP Regimens

In the U.S. commonly used OMBP agents are approved by the U.S. Food and Drug Administration and are available over the counter. OMBP regimens in clinical use differ with respect to their mechanism of action, volume of preparation that needs to be ingested, and duration of use. The most commonly used oral laxative agents currently are over-the-counter, large-volume, osmotically balanced polyethylene glycol (PEG) solutions (e.g., MiraLAX^®^, GoLYTELY^®^, NuLYTELY^®^) or reduced-volume PEG with the addition of bisacodyl (HalfLytely^®^). PEG solutions evacuate the bowel by washout of ingested fluid (approximately 4 liters), with no substantial fluid or electrolyte shifts.7 Bisacodyl, a poorly absorbed diphenylmethane, stimulates colonic peristalsis and requires a smaller volume of ingested fluid (approximately 2 liters).15 Hyperosmotic preparations (e.g., Fleet^®^) that draw water into the bowel to achieve washout are less used because of concern about electrolyte imbalances.15

Typically, the patient starts the OMBP at home the day before surgery. Elderly and frail patients may undergo OMBP in the hospital. Patients dislike the large quantities of unpleasant-tasting laxative solutions required and the long time spent on the toilet. A minority of patients requires medical attention for vomiting, dehydration, and other reactions to OMBP; this may require cancellation and rescheduling of surgery. Additionally, liquid bowel contents from OMBP use may be less safely handled during surgery than solid contents and may represent a source of infection. Individuals who may be at greater risk of adverse effects of OMBP are the elderly (for example, ≥65 years of age) and those with comorbidities such as cardiovascular and pulmonary disease, diabetes, kidney disease, and compromised immune conditions.

## Cointerventions

Evaluation of the effectiveness of OMBP needs to take into account the effects of cointerventions, such as enemas or antibiotics, on clinical outcomes. An enema is sometimes given the night before or the morning of surgery. Oral or intravenous antibiotics are also often administered in preparation for surgery. Mechanical cleansing of the large intestine decreases the total volume of stool in the colon but does not change the concentration of bacteria.16 For this reason, in addition to the intravenous antibiotics routinely given immediately before and during colorectal surgery, some surgeons also prescribe oral antibiotics.17 A common oral antibiotic regimen (Nichols-Condon) consists of neomycin and erythromycin given the day before surgery.18 Metronidazole is often substituted for erythromycin because of its increased effectiveness against anaerobic organisms in the gut. Differences in antibiotic regimens between trials may confound comparisons of postoperative infection rates among trials that otherwise have similar preoperative preparation regimens. Decreased infection rates have been reported when oral antibiotics are added to intravenous antibiotics and OMBP,10,17 and it was conjectured that oral antibiotics may be more effective when the burden of colonic bacteria has been reduced by means of OMBP.17

## Current Uncertainties Regarding OMBP

A recent Cochrane systematic review (covering studies up to December 1, 2010) found no benefit for OMBP in terms of anastomotic leaks, other surgical complications, or mortality for mixed populations of patients undergoing colon or rectal resection.1 Several studies have been published since the last search of the Cochrane review, suggesting that an updated synthesis is needed. Furthermore, large variation in practice exists in different parts of the world, perhaps suggesting that existing syntheses of the evidence do not adequately address all decisionmaking uncertainties.19,20 Specifically, current reviews do not adequately examine the comparative effectiveness of all feasible alternative bowel preparation strategies and have relied on pairwise comparisons between interventions, often lumping different OMBP methods or combining control groups who receive no intervention with groups using enemas. This approach may introduce heterogeneity (if alternative OMBP methods have different effectiveness or if enemas are superior to no intervention) and is not helpful in identifying the most effective OMBP approach. By contrast, a joint synthesis of data on all relevant treatment options, including direct comparisons between alternative OMBP strategies, could provide information on which treatment is most effective.

## Scope of This Review

The purpose of this review was to systematically evaluate experimental and observational evidence on the benefits and harms associated with the use of OMBP in patients undergoing elective colorectal surgery. We also aimed to identify patient and procedural characteristics that modify the effect of OMBP on outcomes.

## Key Questions

On the basis of the original topic nomination and an extensive process of topic development and refinement, we formulated the following Key Questions to guide the review:

Key Question 1: How do various preoperative OMBP strategies compare between them and versus a control with respect to their effectiveness for preventing surgical or postsurgical complications?

a. For elective right colon surgery?
b. For elective left colon surgery?
c. For elective rectal surgery?

Key Question 2: How does the use of OMBP, with or without cointerventions (e.g., antibiotics, rectal enema), compare with no OMBP or with OMBP plus different cointerventions with respect to presurgical and postsurgical adverse events?

a. What are the comparative adverse events of the various OMBP strategies?
b. What are the comparative adverse events of OMBP in subgroups of patients especially susceptible to the potential adverse events?