# Ongoing Studies

Appendix Table G1 Ongoing studies

Clinical Trial Identifier | Study name | Status as of May 15, 2013 | Availability of results | Population | Comparison
NCT01797770 | Trial on Mechanical Bowel Preparation in Laparoscopic Colorectal Surgery | Recruiting | NA | colon and rectal cancer | OMBP vs. no preparation
NCT00687570 | Bowel Preparation Before Rectal Cancer Surgery | Recruiting | NA | rectal cancer | OMBP vs. nutritional
NCT00940030 | Comparison of Mechanical Bowel Preparation Versus Enema for Candidates to Colorectal Resection for Adenocarcinoma | Recruiting | NA | colorectal cancer | OMBP vs. enema
NCT00643084 | Bowel Prep vs. Non-Bowel Prep for Laparoscopic Colorectal Surgery | Not yet recruiting | NA | colorectal surgery | OMBP vs. no preparation
NCT00618930 | Moviprep Versus Fleet Phospho-Soda (Golden Standard): A Study That Compared Two Laxatives on Patients Undergoing Colo-Rectal Cleansing Prior to an Abdominal Operation | Completed | NA | colorectal surgery | Comparison of two OMBP strategies

NA = not available; OMBP = oral mechanical bowel preparation.