# Structural Sensitivity Analysis for Network Meta-Analysis (4-Node Network Structure)

Appendix Figure F1 4-node network structure used in sensitivity analysis

OMBP = oral mechanical bowel preparation; prep = preparation.

Appendix Figure F1 depicts the 4-node network structure used in sensitivity analyses. The network includes 4 nodes: OMBP alone; OMBP + enema; enema; and no preparation. Direct comparisons were available between OMBP with or without enema versus no preparation, and OMBP with or without enema versus enema.

Appendix Table F1 Summary estimates from the 4-node network meta-analysis

Outcome | Comparison | OR (95% CrI)
All cause mortality | OMBP vs. no preparation | 1.06 (0.43, 5.78)
All cause mortality | OMBP + enema vs. no preparation | 1.31 (0.26, 9.32)
All cause mortality | OMBP vs. enema | 4.68 (0.27, 205.40)
All cause mortality | OMBP + enema vs. enema | 5.61 (0.14, 388.46)
Anastomotic leakage | OMBP vs. no preparation | 1.09 (0.70, 1.97)
Anastomotic leakage | OMBP + enema vs. no preparation | 1.00 (0.46, 2.41)
Anastomotic leakage | OMBP vs. enema | 0.75 (0.21, 2.31)
Anastomotic leakage | OMBP + enema vs. enema | 0.68 (0.21, 2.00)
Wound infection | OMBP vs. no preparation | 1.23 (0.87, 1.97)
Wound infection | OMBP + enema vs. no preparation | 1.42 (0.81, 2.61)
Wound infection | OMBP vs. enema | 0.66 (0.30, 1.37)
Wound infection | OMBP + enema vs. enema | 0.76 (0.32, 1.65)
Peritonitis/ Intra-abdominal abscess | OMBP vs. no preparation | 0.73 (0.31, 2.22)
Peritonitis/ Intra-abdominal abscess | OMBP + enema vs. no preparation | 1.18 (0.35, 5.07)
Peritonitis/ Intra-abdominal abscess | OMBP vs. enema | 1.31 (0.10, 20.41)
Peritonitis/ Intra-abdominal abscess | OMBP + enema vs. enema | 2.10 (0.17, 31.49)

* Based only on indirect comparisons.

CrI = credible interval; OMBP = oral mechanical bowel preparation; OR = odds ratio.