# Sensitivity Analysis for Pairwise Contrasts Using Frequentist Methods (No Prior Specification)

Appendix Table E1 Meta-analysis results using frequentist methods

Outcome | Comparison | N studies (N events / N patients, per group) | OR (95% CI); P value | Heterogeneity (P_Q_; I^2^)
All cause mortality | OMBP +/- enema vs. no OMBP | 14 (45 / 2550 vs. 44 / 2544) | 1.00 (0.65, 1.53); P = 0.99 | 0.86; 0%
All cause mortality | OMBP +/- enema vs. no prep | 10 (38 / 2024 vs. 40 / 2014) | 0.94 (0.60, 1.48); P = 0.78 | 0.88; 0%
All cause mortality | OMBP +/- enema vs. enema | 4 (7 / 526 vs. 4 / 530) | 1.67 (0.45, 6.13); P = 0.44 | 0.32; 0%
Anastomotic leakage | OMBP +/- enema vs. no OMBP | 16 (126 / 2702 vs. 124 / 2680) | 1.00 (0.76, 1.31); P = 1.00 | 0.43; 2%
Anastomotic leakage | OMBP +/- enema vs. no prep | 12 (102 / 2176 vs. 103 / 2150) | 0.97 (0.73, 1.30); P = 0.84 | 0.48; 0%
Anastomotic leakage | OMBP +/- enema vs. enema | 4 (24 / 526 vs. 21 / 530) | 1.16 (0.51, 2.64); P = 0.71 | 0.21; 34%
Wound infection | OMBP +/- enema vs. no OMBP | 16 (266 / 2612 vs. 239 / 2603) | 1.13 (0.94, 1.36); P = 0.21 | 0.46; 0%
Wound infection | OMBP +/- enema vs. no prep | 12 (218 / 2086 vs. 190 / 2073) | 1.17 (0.95, 1.45); P = 0.14 | 0.71; 0%
Wound infection | OMBP +/- enema vs. enema | 4 (48 / 526 vs. 49 / 530) | 1.02 (0.53, 1.93); P = 0.96 | 0.11; 50%
Peritonitis | OMBP +/- enema vs. no OMBP | 14 (51 / 2381 vs. 70 / 2362) | 0.71 (0.48, 1.04); P = 0.08 | 0.54; 0%
Peritonitis | OMBP +/- enema vs. no prep | 10 (45 / 1855 vs. 64 / 1832) | 0.75 (0.46, 1.24); P = 0.26 | 0.29; 17%
Peritonitis | OMBP +/- enema vs. enema | 4 (6 / 526 vs. 6 / 530) | 1.00 (0.31, 3.24); P = 0.99 | 0.87; 0%
Reoperation | OMBP +/- enema vs. no OMBP | 8 (124 / 1967 vs. 119 / 1945) | 1.15 (0.77, 1.70); P = 0.50 | 0.19; 29%
Reoperation | OMBP +/- enema vs. no prep | 6 (117 / 1742 vs. 111 / 1723) | 1.04 (0.79, 1.37); P = 0.76 | 0.49; 0%
Reoperation | OMBP +/- enema vs. enema | 2 (7 / 225 vs. 8 / 222) | 0.61 (0.01, 32.65); P = 0.81 | 0.02; 83%
SSI | OMBP +/- enema vs. no OMBP | 7 (206 / 1279 vs. 197 / 1230) | 1.17 (0.70, 1.95); P = 0.55 | 0.00; 74%
SSI | OMBP +/- enema vs. no prep | 5 (173 / 1087 vs. 171 / 1040) | 1.08 (0.59, 2.00); P = 0.79 | 0.00; 77%
SSI | OMBP +/- enema vs. enema | 2 (33 / 192 vs. 26 / 190) | 1.51 (0.38, 6.06); P = 0.56 | 0.02; 81%

CI = confidence interval; OMBP = oral mechanical bowel preparation; OR = odds ratio; SSI = surgical site infection.