# Sensitivity Analysis for Pairwise Contrasts Using Bayesian Methods (Alternative Prior Specification)

Please consult Turner et al., International Journal of Epidemiology 2012, for details regarding prior selection.

Appendix Table D1 Sensitivity analysis for pairwise meta-analysis (using alternative priors)

Outcome | Prior distribution for between-study variance | Comparison | N studies (N events / N patients, per group) | OR (95% CrI) | Between-study variance (95% CrI)
All cause mortality | Informative, log-normal, mortality, pharmacologic intervention vs. control | OMBP vs. no OMBP | 14 (45 / 2550 vs. 44 / 2544) | 1.08 (0.68, 1.75) | 0.02 (0.00, 0.21)
All cause mortality | Informative, log-normal, mortality, pharmacologic intervention vs. control | OMBP +/- enema vs. enema | 4 (7 / 526 vs. 4 / 530) | 1.87 (0.53, 7.78) | 0.02 (0.00, 0.30)
All cause mortality | Informative, log-normal, mortality, pharmacologic intervention vs. control | OMBP +/- enema vs. no prep | 10 (38 / 2024 vs. 40 / 2014) | 0.96 (0.60, 1.66) | 0.01 (0.00, 0.19)
All cause mortality | Uninformative, U(0,5) | OMBP vs. no OMBP | 14 (45 / 2550 vs. 44 / 2544) | 1.17 (0.66, 2.84) | 0.15 (0.00, 2.32)
All cause mortality | Uninformative, U(0,5) | OMBP +/- enema vs. enema | 4 (7 / 526 vs. 4 / 530) | 2.01 (0.04, 134.30) | 3.27 (0.01, 22.73)
All cause mortality | Uninformative, U(0,5) | OMBP +/- enema vs. no prep | 10 (38 / 2024 vs. 40 / 2014) | 1.12 (0.57, 3.35) | 0.18 (0.00, 4.16)
Anastomotic leakage | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP vs. no OMBP | 16 (126 / 2702 vs. 124 / 2680) | 1.05 (0.79, 1.48) | 0.03 (0.00, 0.33)
Anastomotic leakage | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. enema | 4 (24 / 526 vs. 21 / 530) | 1.19 (0.57, 2.55) | 0.05 (0.00, 1.21)
Anastomotic leakage | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. no prep | 12 (102 / 2176 vs. 103 / 2150) | 1.03 (0.75, 1.52) | 0.03 (0.00, 0.39)
Anastomotic leakage | Uninformative, U(0,5) | OMBP vs. no OMBP | 16 (126 / 2702 vs. 124 / 2680) | 1.09 (0.79, 1.63) | 0.09 (0.00, 0.72)
Anastomotic leakage | Uninformative, U(0,5) | OMBP +/- enema vs. enema | 4 (24 / 526 vs. 21 / 530) | 1.25 (0.22, 9.49) | 1.02 (0.00, 16.70)
Anastomotic leakage | Uninformative, U(0,5) | OMBP +/- enema vs. no prep | 12 (102 / 2176 vs. 103 / 2150) | 1.07 (0.73, 1.76) | 0.10 (0.00, 0.94)
Wound infection | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP vs. no OMBP | 16 (266 / 2612 vs. 239 / 2603) | 1.18 (0.93, 1.53) | 0.02 (0.00, 0.20)
Wound infection | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. enema | 4 (48 / 526 vs. 49 / 530) | 1.00 (0.57, 1.91) | 0.06 (0.00, 1.11)
Wound infection | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. no prep | 12 (218 / 2086 vs. 190 / 2073) | 1.24 (0.96, 1.72) | 0.02 (0.00, 0.23)
Wound infection | Uninformative, U(0,5) | OMBP vs. no OMBP | 16 (266 / 2612 vs. 239 / 2603) | 1.19 (0.93, 1.63) | 0.04 (0.00, 0.43)
Wound infection | Uninformative, U(0,5) | OMBP +/- enema vs. enema | 4 (48 / 526 vs. 49 / 530) | 1.04 (0.23, 5.48) | 0.70 (0.00, 13.59)
Wound infection | Uninformative, U(0,5) | OMBP +/- enema vs. no prep | 12 (218 / 2086 vs. 190 / 2073) | 1.27 (0.95, 1.90) | 0.05 (0.00, 0.49)
Peritonitis | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP vs. no OMBP | 14 (51 / 2381 vs. 70 / 2362) | 0.77 (0.51, 1.30) | 0.05 (0.00, 0.59)
Peritonitis | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. enema | 4 (6 / 526 vs. 6 / 530) | 0.98 (0.27, 3.43) | 0.04 (0.00, 0.88)
Peritonitis | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. no prep | 10 (45 / 1855 vs. 64 / 1832) | 0.76 (0.48, 1.40) | 0.07 (0.00, 0.89)
Peritonitis | Uninformative, U(0,5) | OMBP vs. no OMBP | 14 (51 / 2381 vs. 70 / 2362) | 0.84 (0.50, 1.66) | 0.24 (0.00, 1.84)
Peritonitis | Uninformative, U(0,5) | OMBP +/- enema vs. enema | 4 (6 / 526 vs. 6 / 530) | 1.01 (0.13, 7.78) | 0.68 (0.00, 16.23)
Peritonitis | Uninformative, U(0,5) | OMBP +/- enema vs. no prep | 10 (45 / 1855 vs. 64 / 1832) | 0.85 (0.44, 2.20) | 0.42 (0.00, 3.94)
Reoperation | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP vs. no OMBP | 8 (124 / 1967 vs. 119 / 1945) | 1.09 (0.75, 1.73) | 0.04 (0.00, 0.86)
Reoperation | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. enema | 2 (7 / 225 vs. 8 / 222) | 0.64 (0.01, 5.57) | 0.91 (0.00, 17.18)
Reoperation | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. no prep | 6 (117 / 1742 vs. 111 / 1723) | 1.10 (0.78, 1.72) | 0.03 (0.00, 0.41)
Reoperation | Uninformative, U(0,5) | OMBP vs. no OMBP | 8 (124 / 1967 vs. 119 / 1945) | 1.14 (0.50, 2.94) | 0.43 (0.00, 6.44)
Reoperation | Uninformative, U(0,5) | OMBP +/- enema vs. enema | 2 (7 / 225 vs. 8 / 222) | 0.21 (0.00, 43.38) | 13.05 (1.52, 24.37)
Reoperation | Uninformative, U(0,5) | OMBP +/- enema vs. no prep | 6 (117 / 1742 vs. 111 / 1723) | 1.15 (0.72, 2.63) | 0.10 (0.00, 2.41)
SSI | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP vs. no OMBP | 7 (206 / 1279 vs. 197 / 1230) | 1.16 (0.68, 2.10) | 0.30 (0.03, 1.38)
SSI | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. enema | 2 (33 / 192 vs. 26 / 190) | 1.39 (0.54, 4.30) | 0.13 (0.00, 2.27)
SSI | Informative, log-normal, semi-objective outcomes, pharmacologic intervention vs. control | OMBP +/- enema vs. no prep | 5 (173 / 1087 vs. 171 / 1040) | 1.06 (0.57, 2.14) | 0.27 (0.02, 1.64)
SSI | Uninformative, U(0,5) | OMBP vs. no OMBP | 7 (206 / 1279 vs. 197 / 1230) | 1.19 (0.55, 2.77) | 0.64 (0.11, 4.10)
SSI | Uninformative, U(0,5) | OMBP +/- enema vs. enema | 2 (33 / 192 vs. 26 / 190) | 1.51 (0.03, 85.24) | 3.73 (0.06, 22.89)
SSI | Uninformative, U(0,5) | OMBP +/- enema vs. no prep | 5 (173 / 1087 vs. 171 / 1040) | 1.10 (0.34, 3.82) | 0.85 (0.11, 9.19)

CI = confidence interval; OMBP = oral mechanical bowel preparation; OR = odds ratio; prep = preparation; SSI = surgical site infection.