# Sensitivity Analysis for Pairwise Contrasts Using Bayesian Methods (Sensitivity to Study Selection)

Appendix Table C1 Sensitivity analysis for pairwise meta-analysis (adding or removing particular studies)

Sensitivity analysis | Outcome | Comparison | N studies (N events / N patients, per group) | OR (95% CrI); P value | Between-study variance (95% CrI)
Include Scabini, 2012 | All cause mortality | OMBP vs. no OMBP | 15 (49 / 2670 vs. 46 / 2668) | 1.24 (0.72, 2.68) | 0.13 (0.00, 1.72)
Include Scabini, 2012 | All cause mortality | OMBP +/- enema vs. no prep | 10 (38 / 2024 vs. 40 / 2014) | 1.09 (0.57, 2.99) | 0.17 (0.00, 2.61)
Include Scabini, 2012 | All cause mortality | OMBP +/- enema vs. enema | 5 (11 / 646 vs. 6 / 654) | 2.02 (0.44, 10.44) | 0.50 (0.00, 3.61)
Include Scabini, 2012 | Anastomotic leakage | OMBP vs. no OMBP | 17 (133 / 2822 vs. 129 / 2804) | 1.09 (0.80, 1.61) | 0.07 (0.00, 0.62)
Include Scabini, 2012 | Anastomotic leakage | OMBP +/- enema vs. no prep | 12 (102 / 2176 vs. 103 / 2150) | 1.06 (0.73, 1.73) | 0.09 (0.00, 0.95)
Include Scabini, 2012 | Anastomotic leakage | OMBP +/- enema vs. enema | 5 (31 / 646 vs. 26 / 654) | 1.28 (0.50, 3.62) | 0.35 (0.00, 3.26)
Include Scabini, 2012 | Wound infection | OMBP vs. no OMBP | 17 (277 / 2732 vs. 245 / 2727) | 1.22 (0.96, 1.66) | 0.04 (0.00, 0.40)
Include Scabini, 2012 | Wound infection | OMBP +/- enema vs. no prep | 12 (218 / 2086 vs. 190 / 2073) | 1.27 (0.95, 1.88) | 0.05 (0.00, 0.50)
Include Scabini, 2012 | Wound infection | OMBP +/- enema vs. enema | 5 (59 / 646 vs. 55 / 654) | 1.17 (0.51, 3.07) | 0.41 (0.00, 3.14)
Exclude Hughes, 1972 | All cause mortality | OMBP vs. no OMBP | 13 (42 / 2504 vs. 42 / 2493) | 1.15 (0.64, 2.92) | 0.16 (0.00, 2.38)
Exclude Hughes, 1972 | All cause mortality | OMBP +/- enema vs. no prep | 9 (35 / 1978 vs. 38 / 1963) | 1.07 (0.52, 3.38) | 0.20 (0.00, 3.02)
Exclude Hughes, 1972 | All cause mortality | OMBP +/- enema vs. enema | 4 (7 / 526 vs. 4 / 530) | 1.99 (0.27, 18.45) | 0.82 (0.00, 3.76)
Exclude Hughes, 1972 | Anastomotic leakage | OMBP vs. no OMBP | 16 (126 / 2702 vs. 124 / 2680) | 1.08 (0.79, 1.63) | 0.08 (0.00, 0.72)
Exclude Hughes, 1972 | Anastomotic leakage | OMBP +/- enema vs. no prep | 12 (102 / 2176 vs. 103 / 2150) | 1.06 (0.73, 1.73) | 0.09 (0.00, 0.95)
Exclude Hughes, 1972 | Anastomotic leakage | OMBP +/- enema vs. enema | 4 (24 / 526 vs. 21 / 530) | 1.24 (0.38, 4.72) | 0.61 (0.00, 3.59)
Exclude Hughes, 1972 | Wound infection | OMBP vs. no OMBP | 15 (259 / 2566 vs. 229 / 2552) | 1.22 (0.94, 1.73) | 0.05 (0.00, 0.47)
Exclude Hughes, 1972 | Wound infection | OMBP +/- enema vs. no prep | 11 (211 / 2040 vs. 180 / 2022) | 1.32 (0.97, 2.08) | 0.05 (0.00, 0.59)
Exclude Hughes, 1972 | Wound infection | OMBP +/- enema vs. enema | 4 (48 / 526 vs. 49 / 530) | 1.04 (0.37, 3.34) | 0.52 (0.00, 3.46)
Exclude studies using selective enema strategies | All cause mortality | OMBP vs. no OMBP | 12 (42 / 2285 vs. 41 / 2276) | 1.22 (0.65, 3.27) | 0.20 (0.00, 2.51)
Exclude studies using selective enema strategies | All cause mortality | OMBP +/- enema vs. no prep | 10 (38 / 2024 vs. 40 / 2014) | 1.09 (0.57, 2.99) | 0.17 (0.00, 2.61)
Exclude studies using selective enema strategies | All cause mortality | OMBP +/- enema vs. enema | 2 (4 / 261 vs. 1 / 262) | 5.44 (0.22, 293.40) | 0.99 (0.00, 3.80)
Exclude studies using selective enema strategies | Anastomotic leakage | OMBP vs. no OMBP | 14 (114 / 2437 vs. 119 / 2412) | 0.99 (0.71, 1.48) | 0.07 (0.00, 0.68)
Exclude studies using selective enema strategies | Anastomotic leakage | OMBP +/- enema vs. no prep | 12 (102 / 2176 vs. 103 / 2150) | 1.06 (0.73, 1.73) | 0.09 (0.00, 0.95)
Exclude studies using selective enema strategies | Anastomotic leakage | OMBP +/- enema vs. enema | 2 (12 / 261 vs. 16 / 262) | 0.69 (0.11, 3.77) | 0.64 (0.00, 3.69)
Exclude studies using selective enema strategies | Wound infection | OMBP vs. no OMBP | 14 (244 / 2347 vs. 225 / 2335) | 1.14 (0.88, 1.59) | 0.04 (0.00, 0.45)
Exclude studies using selective enema strategies | Wound infection | OMBP +/- enema vs. no prep | 12 (218 / 2086 vs. 190 / 2073) | 1.27 (0.95, 1.88) | 0.05 (0.00, 0.50)
Exclude studies using selective enema strategies | Wound infection | OMBP +/- enema vs. enema | 2 (26 / 261 vs. 35 / 262) | 0.67 (0.13, 3.27) | 0.53 (0.00, 3.64)
Exclude studies enrolling mixed populations of children and adults | All cause mortality | OMBP vs. no OMBP | 13 (45 / 2478 vs. 44 / 2467) | 1.17 (0.66, 2.69) | 0.13 (0.00, 1.97)
Exclude studies enrolling mixed populations of children and adults | All cause mortality | OMBP +/- enema vs. no prep | 9 (38 / 1952 vs. 40 / 1937) | 1.10 (0.58, 2.99) | 0.16 (0.00, 2.57)
Exclude studies enrolling mixed populations of children and adults | All cause mortality | OMBP +/- enema vs. enema | 4 (7 / 526 vs. 4 / 530) | 1.99 (0.27, 18.45) | 0.82 (0.00, 3.76)
Exclude studies enrolling mixed populations of children and adults | Anastomotic leakage | OMBP vs. no OMBP | 15 (119 / 2630 vs. 120 / 2603) | 1.04 (0.75, 1.60) | 0.08 (0.00, 0.77)
Exclude studies enrolling mixed populations of children and adults | Anastomotic leakage | OMBP +/- enema vs. no prep | 11 (95 / 2104 vs. 99 / 2073) | 1.02 (0.69, 1.71) | 0.09 (0.00, 1.03)
Exclude studies enrolling mixed populations of children and adults | Anastomotic leakage | OMBP +/- enema vs. enema | 4 (24 / 526 vs. 21 / 530) | 1.24 (0.38, 4.72) | 0.61 (0.00, 3.59)
Exclude studies enrolling mixed populations of children and adults | Wound infection | OMBP vs. no OMBP | 15 (249 / 2540 vs. 230 / 2526) | 1.13 (0.88, 1.53) | 0.03 (0.00, 0.37)
Exclude studies enrolling mixed populations of children and adults | Wound infection | OMBP +/- enema vs. no prep | 11 (201 / 2014 vs. 181 / 1996) | 1.19 (0.88, 1.77) | 0.03 (0.00, 0.48)
Exclude studies enrolling mixed populations of children and adults | Wound infection | OMBP +/- enema vs. enema | 4 (48 / 526 vs. 49 / 530) | 1.04 (0.37, 3.34) | 0.52 (0.00, 3.46)
Exclude Tahirkheli, 2013 | All cause mortality | OMBP vs. no OMBP | 14 (45 / 2550 vs. 44 / 2544) | 1.17 (0.67, 2.67) | 0.12 (0.00, 1.99)
Exclude Tahirkheli, 2013 | All cause mortality | OMBP +/- enema vs. no prep | 10 (38 / 2024 vs. 40 / 2014) | 1.09 (0.57, 2.99) | 0.17 (0.00, 2.61)
Exclude Tahirkheli, 2013 | All cause mortality | OMBP +/- enema vs. enema | 4 (7 / 526 vs. 4 / 530) | 1.99 (0.27, 18.45) | 0.82 (0.00, 3.76)
Exclude Tahirkheli, 2013 | Anastomotic leakage | OMBP vs. no OMBP | 15 (118 / 2654 vs. 118 / 2632) | 1.07 (0.76, 1.67) | 0.10 (0.00, 0.87)
Exclude Tahirkheli, 2013 | Anastomotic leakage | OMBP +/- enema vs. no prep | 11 (94 / 2128 vs. 97 / 2102) | 1.04 (0.69, 1.80) | 0.11 (0.00, 1.15)
Exclude Tahirkheli, 2013 | Anastomotic leakage | OMBP +/- enema vs. enema | 4 (24 / 526 vs. 21 / 530) | 1.24 (0.38, 4.72) | 0.61 (0.00, 3.59)
Exclude Tahirkheli, 2013 | Wound infection | OMBP vs. no OMBP | 16 (266 / 2612 vs. 239 / 2603) | 1.19 (0.93, 1.63) | 0.04 (0.00, 0.41)
Exclude Tahirkheli, 2013 | Wound infection | OMBP +/- enema vs. no prep | 12 (218 / 2086 vs. 190 / 2073) | 1.27 (0.95, 1.88) | 0.05 (0.00, 0.50)
Exclude Tahirkheli, 2013 | Wound infection | OMBP +/- enema vs. enema | 4 (48 / 526 vs. 49 / 530) | 1.04 (0.37, 3.34) | 0.52 (0.00, 3.46)

CI = confidence interval; OMBP = oral mechanical bowel preparation; OR = odds ratio; prep = preparation; SSI = surgical site infection.