# List of Excluded Studies by Reason for Exclusion

Appendix Table B1 Reasons for study exclusion

Reason for Exclusion | Reference Number
Irrelevant | 1-80
N<10 | 81-100
No Primary Data | 101-222
Not Elective Colorectal Surgery | 223-276
Not English Language | 277-415 416-540
Conference Proceedings | 541-583
Non-Randomized Controlled Studies with N<100 | 584-650
Single Group Study with N<200 or No Reporting Outcomes of Interest | 651-836

## References to Excluded Studies

1 Circular transanal stapled procedure for incomplete rectal prolapse associated with outlet obstruction versus conventional procedure. Minimally invasive therapy & allied technologies. MITAT : official journal of the Society for Minimally Invasive Therapy. Jul. 2001;10(4):235-8. [pmid: 16754021].
2 Alves A, Panis Y, Bouhnik Y, et al. Factors that predict conversion in 69 consecutive patients undergoing laparoscopic ileocecal resection for Crohn's disease: a prospective study. Diseases of the colon and rectum. Dec. 2005;48(12):2302-8. [pmid: 16228824].
3 Ameh EA, Lukong CS, Mshelbwala PM, et al. One-day bowel preparation in children with colostomy using normal saline. African journal of paediatric surgery : AJPS. Sep-Dec. 2011;8(3):291-3. [pmid: 22248892].
4 Andersen J, Christensen H, Pachler JH, et al. Effect of the laxative magnesium oxide on gastrointestinal functional recovery in fast-track colonic resection: a double-blind, placebo-controlled randomized study. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Jun. 2012;14(6):776-82. [pmid: 21883811].
5 Andersen J, Thorup J, Wille-Jorgensen P. Use of preoperative bowel preparation in elective colorectal surgery in Denmark remains high. Danish medical bulletin. Sep. 2011;58(9):A4313. [pmid: 21893013].
6 Anthony T, Murray BW, Sum-Ping JT, et al. Evaluating an evidence-based bundle for preventing surgical site infection: a randomized trial. Arch Surg. Mar. 2011;146(3):263-9. [pmid: 21079110].
7 Bakker IS, Morks AN, Hoedemaker HO, et al. The C-seal trial: colorectal anastomosis protected by a biodegradable drain fixed to the anastomosis by a circular stapler, a multi-center randomized controlled trial. BMC surgery. 2012;12:23. [pmid: 23153188].
8 Barbuscia M, Melita G, Trovato M, et al. Nosocomial infections in colo-rectal surgery of the old patient. Acta bio-medica : Atenei Parmensis. Suppl 1. 2005;76:16-20. [pmid: 16450501].
9 Barisic G, Krivokapic Z, Markovic V, et al. The role of overlapping sphincteroplasty in traumatic fecal incontinence. Acta chirurgica Iugoslavica. 2000;47(4 Suppl 1):37-41. [pmid: 11432241].
10 Barker K, Graham NG, Mason MC, et al. The relative significance of preoperative oral antibiotics, mechanical bowel preparation, and preoperative peritoneal contamination in the avoidance of sepsis after radical surgery for ulcerative colitis and Crohn's disease of the large bowel. The British journal of surgery. Apr. 1971;58(4):270-3. [pmid: 4929350].
11 Bassi MA, Podgaec S, Dias JA Jr., et al. Quality of life after segmental resection of the rectosigmoid by laparoscopy in patients with deep infiltrating endometriosis with bowel involvement. Journal of minimally invasive gynecology. Nov-Dec. 2011;18(6):730-3. [pmid: 21930435].
12 Bedin N, Agresta F. Colorectal surgery in a community hospital setting: have attitudes changed because of laparoscopy? A general surgeons' last 5 years experience review. Surgical laparoscopy, endoscopy & percutaneous techniques. Feb. 2010;20(1):30-5. [pmid: 20173618].
13 Bierca J, Kosim A, Kolodziejczak M, et al. Effectiveness of Lichtenstein repairs in planned treatment of giant inguinal hernia - own experience. Wideochirurgia i inne techniki malo inwazyjne. Videosurgery and other miniinvasive techniques. kwartalnik pod patronatem Sekcji Wideochirurgii TChP oraz Sekcji Chirurgii Bariatrycznej TChP. Mar. 2013;8(1):36-42. [pmid: 23630552].
14 Biviano I, Badiali D, Candeloro L, et al. Comparative outcome of stapled trans-anal rectal resection and macrogol in the treatment of defecation disorders. World journal of gastroenterology : WJG. Oct. 7. 2011;17(37):4199-205. [pmid: 22072851].
15 Buess G, Kipfmuller K, Hack D, et al. Technique of transanal endoscopic microsurgery. Surgical endoscopy. 1988;2(2):71-5. [pmid: 3413659].
16 Cooney DR, Wassner JD, Grosfeld JL, et al. Are elemental diets useful in bowel preparation?. Arch Surg. Aug. 1974;109(2):206-10. [pmid: 4211025].
17 Danne PD. Intra-operative colonic lavage: safe single-stage, left colorectal resections. The Australian and New Zealand journal of surgery. Jan. 1991;61(1):59-65. [pmid: 1994886].
18 Duthie GS, Foster ME, Price-Thomas JM, et al. Bowel preparation or not for elective colorectal surgery. Journal of the Royal College of Surgeons of Edinburgh. Jun. 1990;35(3):169-71. [pmid: 2395132].
19 Eisenberg HW, Turnbull RB Jr., Weakley FL. Hyperalimentation as preparation for surgery in transmural colitis (Crohn's disease). Diseases of the colon and rectum. Jul-Aug. 1974;17(4):469-75. [pmid: 4212060].
20 Englesbe MJ, Brooks L, Kubus J, et al. A statewide assessment of surgical site infection following colectomy: the role of oral antibiotics. Annals of surgery. Sep. 2010;252(3):514-9. discussion 9-20. [pmid: 20739852].
21 Errett LE, Girotti M, Paloschi G. Single-layer large-bowel anastomosis: a report of 250 cases. Canadian journal of surgery Journal canadien de chirurgie. Mar. 1985;28(2):148-9. [pmid: 3882209].
22 Eskicioglu C, Gagliardi A, Fenech DS, et al. Can a tailored knowledge translation strategy improve short term outcomes? A pilot study to increase compliance with bowel preparation recommendations in general surgery. Surgery. Jul. 2011;150(1):68-74. [pmid: 21596413].
23 Fa-Si-Oen PR, Penninckx F. The effect of mechanical bowel preparation on human colonic tissue in elective open colon surgery. Diseases of the colon and rectum. Jun. 2004;47(6):948-9. [pmid: 15085437].
24 Fong Y, Zenn M, Barie PS. Preparation of small caliber intestine for anastomosis with the EEA stapler. Surgery, gynecology & obstetrics. Jun. 1992;174(6):525-6. [pmid: 1595031].
25 Giannessi S, Paroli GM, Fedi M, et al. Self expandable metal stent as bridge-to-surgery in acute bowel obstruction. Minerva chirurgica. Jun. 2013;68(3):299-306. [pmid: 23774095].
26 Greenberg BM, Low D, Rosato EF. The use of omental grafts in operations performed upon the colon and rectum. Surgery, gynecology & obstetrics. Nov. 1985;161(5):486-8. [pmid: 4049220].
27 Grier WR, Postel AH, Syarse A, et al. An Evaluation of Colonic Stoma Management without Irrigations. Surgery, gynecology & obstetrics. Jun. 1964;118:1234-42. [pmid: 14179992].
28 Gurry JF, Ellis-pegler RB. An elemental diet as preoperative preparation of the colon. The British journal of surgery. Dec. 1976;63(12):969-72. [pmid: 1009348].
29 Hashad MM, Atta M, Elabbady A, et al. Safety of no bowel preparation before ileal urinary diversion. BJU international. Dec. 2012;110(11 Pt C):E1109-13. [pmid: 23167296].
30 Hidalgo Grau LA, Heredia Budo A, Llorca Cardenosa S, et al. Day case stapled anopexy for the treatment of haemorrhoids and rectal mucosal prolapse. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Jun. 2012;14(6):765-8. [pmid: 21831169].
31 Huang Y, Zheng S, Xiao X. A follow-up study on postoperative function after a transanal Soave 1-stage endorectal pull-through procedure for Hirschsprung's disease. Journal of pediatric surgery. Sep. 2008;43(9):1691-5. [pmid: 18779008].
32 Hughes ES, McDermott FT, Polglase AL, et al. Total and subtotal colectomy for colonic obstruction. Diseases of the colon and rectum. Mar. 1985;28(3):162-3. [pmid: 3971821].
33 Hung WT. Treatment of Hirschsprung's disease with a modified Duhamel-Grob-Martin operation. Journal of pediatric surgery. Jul. 1991;26(7):849-52. [pmid: 1895197].
34 Jansen JO, O'Kelly TJ, Krukowski ZH, et al. Right hemicolectomy: mechanical bowel preparation is not required. Journal of the Royal College of Surgeons of Edinburgh. Jun. 2002;47(3):557-60. [pmid: 12109610].
35 Javed A, Agarwal AK. Total laparoscopic esophageal bypass using a colonic conduit for corrosive-induced esophageal stricture. Surgical endoscopy. 2013:1-7. PMID:.
36 Jimenez Rodriguez RM, Diaz Pavon JM, de La Portilla de Juan F, et al. Prospective randomised study: robotic-assisted versus conventional laparoscopic surgery in colorectal cancer resection. Cirugia espanola. Aug-Sep. 2011;89(7):432-8. [pmid: 21530948].
37 Jones FE, DcCosse JJ, Condon RE. Experimental evaluation of “instant” preparation of the colon with povidone-iodine. The Surgical clinics of North America. Dec. 1975;55(6):1343-8. [pmid: 1198291].
38 Krapohl GL. Preventing Health Care-Associated Infection: Development of a Clinical Prediction Rule for Clostridium difficile Infection. Dissertations and Theses. 2011. PMID:.
39 Larsen SG, Wiig JN, Tretli S, et al. Surgery and pre-operative irradiation for locally advanced or recurrent rectal cancer in patients over 75 years of age. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Mar. 2006;8(3):177-85. [pmid: 16466556].
40 Madsen PO. The Etiology of Hyperchloremic Acidosis Following Urointestinal Anastomosis: An Experimental Study. The Journal of urology. Nov. 1964;92:448-54. [pmid: 14226471].
41 Mahajna A, Krausz M, Rosin D, et al. Bowel preparation is associated with spillage of bowel contents in colorectal surgery. Diseases of the colon and rectum. Aug. 2005;48(8):1626-31. [pmid: 15981063].
42 Mann B, Kleinschmidt S, Stremmel W. Prospective study of hand-sutured anastomosis after colorectal resection. The British journal of surgery. Jan. 1996;83(1):29-31. [pmid: 8653354].
43 Marchaim D, Slim J, Dhar S, et al. A Regional Survey of the Use of Mechanical Bowel Preparations Prior to Colorectal Surgery. Annals of surgery. 2011. Feb. 17. [pmid: 21336101].
44 Marchaim D, Slim J, Dhar S, et al. A regional survey of the use of mechanical bowel preparations prior to colorectal surgery. Annals of surgery. 2011. PMID:.
45 Marti MC, Auckenthaler R. Antibiotic prophylaxis in large bowel surgery: results of a controlled clinical trial. Surgery. Jan. 1983;93(1 Pt 2):190-6. [pmid: 6336862].
46 Mastalier B, Tihon C, Ghita B, et al. Surgical treatment of colon cancer: Colentina surgical clinic experience. Journal of medicine and life. Sep. 15. 2012;5(3):348-53. [pmid: 23144667].
47 Meunier K, Mucci S, Quentin V, et al. Colorectal surgery in cirrhotic patients: assessment of operative morbidity and mortality. Diseases of the colon and rectum. Aug. 2008;51(8):1225-31. [pmid: 18521677].
48 Miles AE, Stevens PJ. A suggested method of preparation of the large bowel for investigation and surgery. South African medical journal. Suid-Afrikaanse tydskrif vir geneeskunde. Oct. 8. 1977;52(16):639-41. [pmid: 929342].
49 Mohr JJ, Mahoney CC, Nelson EC, et al. Improving health care, Part 3: Clinical benchmarking for best patient care. The Joint Commission journal on quality improvement. Sep. 1996;22(9):599-616. [pmid: 8904689].
50 Muleta M, Tafesse B, Aytenfisu HG. Antibiotic use in obstetric fistula repair: single blinded randomized clinical trial. Ethiopian medical journal. Jul. 2010;48(3):211-7. [pmid: 21073082].
51 Nam YS, Wexner SD. Clinical value of prophylactic ureteral stent indwelling during laparoscopic colorectal surgery. Journal of Korean medical science. Oct. 2002;17(5):633-5. [pmid: 12378014].
52 Nascimbeni R, Donato F, Ghirardi M, et al. Constipation, anthranoid laxatives, melanosis coli, and colon cancer: a risk assessment using aberrant crypt foci. Cancer epidemiology, biomarkers & prevention : a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Aug. 2002;11(8):753-7. [pmid: 12163329].
53 Nichols RL, Broido P, Condon RE, et al. Effect of preoperative neomycin-erythromycin intestinal preparation on the incidence of infectious complications following colon surgery. 1973. Surgical infections. Summer. 2000;1(2):133-41. discussion 43, 45-6, 47-8. [pmid: 12594901].
54 Ozel L, Krand O, Ozel MS, et al. Elective and emergency surgery in chronic hemodialysis patients. Renal failure. 2011;33(7):672-6. [pmid: 21787157].
55 Polacek MA, Close AS. The effect of antibiotic bowel preparation and peritoneal irrigation on the duration of post-operative ileus. American journal of surgery. Jun. 1963;105:768-70. [pmid: 13944278].
56 Polacek MA, Sanfelippo P. Oral antibiotic bowel preparation and complications in colon surgery. Arch Surg. Sep. 1968;97(3):412-7. [pmid: 5675954].
57 Qureshi MS, Ali S, Parkash D, et al. Short term clinical outcome of stapled haemorrhoidectomy. JPMA The Journal of the Pakistan Medical Association. May. 2010;60(5):335-7. [pmid: 20527600].
58 Rakovec S, Gubina M. Chemoprophylaxis of postoperative infections in colorectal surgery. International journal of clinical pharmacology research. 1985;5(3):181-3. [pmid: 4018952].
59 Raventos JM, Symmonds RE. Surgical management of acute diverticulitis in women. Obstetrics and gynecology. Nov. 1981;58(5):557-65. [pmid: 7301230].
60 Ren L, Zhu D, Wei Y, et al. Enhanced Recovery After Surgery (ERAS) program attenuates stress and accelerates recovery in patients after radical resection for colorectal cancer: a prospective randomized controlled trial (Structured abstract). World journal of surgery. [serial on the Internet]. 2012;36(2). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22012019734/frame.html. Last accessed.
61 Ryan P. An experimental preparation suitable for studying the effect of bacterial contamination and infection upon the healing of colon wounds. The Australian and New Zealand journal of surgery. May. 1969;38(4):364-9. [pmid: 4892233].
62 Shin JY, Hong KH. Risk factors for early postoperative small-bowel obstruction after colectomy in colorectal cancer. World journal of surgery. Oct. 2008;32(10):2287-92. [pmid: 18642044].
63 Sourkati EO, Fahal AH, Suliman SH, et al. Intestinal obstruction in Khartoum. East African medical journal. May. 1996;73(5):316-9. [pmid: 8756035].
64 Stefanini P, Castrini G, Pappalardo G. Surgical treatment of cancer of the colon. International surgery. Apr-Jun. 1981;66(2):125-31. [pmid: 6268561].
65 Stefanovic A, Jeremic K, Kadija S, et al. Intestinal surgery in treatment of advanced ovarian cancer--review of our experience. European journal of gynaecological oncology. 2011;32(4):419-22. [pmid: 21941966].
66 Stephens JH, Hewett PJ. Clinical trial assessing VSL#3 for the treatment of anterior resection syndrome. ANZ journal of surgery. Jun. 2012;82(6):420-7. [pmid: 22571474].
67 Tancer ML, Lasser D, Rosenblum N. Rectovaginal fistula or perineal and anal sphincter disruption, or both, after vaginal delivery. Surgery, gynecology & obstetrics. Jul. 1990;171(1):43-6. [pmid: 2193413].
68 Taslim H. Clostridium difficile infection in the elderly. Acta medica Indonesiana. Jul. 2009;41(3):148-51. [pmid: 19752488].
69 Vandamme JP, Timmermans T, Steyaert P. One hundred elective resections of the left colon and rectum with unprotected manual anastomosis. Acta chirurgica Belgica. Sep-Oct. 1986;86(5):255-8. [pmid: 3538730].
70 van't Sant HP, Weidema WF, Hop WC, et al. Evaluation of morbidity and mortality after anastomotic leakage following elective colorectal surgery in patients treated with or without mechanical bowel preparation. American journal of surgery. Sep. 2011;202(3):321-4. [pmid: 21871987].
71 Venditti D, Gravante G, Sena G, et al. Iatrogenic rectal perforations from phosphate enemas: a retrospective series over 1 year of activity in a university hospital. The American surgeon. May. 2013;79(5):E187-9. [pmid: 23635564].
72 Venkatesh KS, Ramanujam P. Fibrin glue application in the treatment of recurrent anorectal fistulas. Diseases of the colon and rectum. Sep. 1999;42(9):1136-9. [pmid: 10496552].
73 Wang JS, Lee HC, Huang FY, et al. Unexpected mortality in pediatric patients with postoperative Hirschsprung's disease. Pediatric surgery international. Jul. 2004;20(7):525-8. [pmid: 15179519].
74 Wick EC, Hobson DB, Bennett JL, et al. Implementation of a surgical comprehensive unit-based safety program to reduce surgical site infections. Journal of the American College of Surgeons. Aug. 2012;215(2):193-200. [pmid: 22632912].
75 Willox GL. The Surgical Management of Chronic Ulcerative Colitis. Canadian Medical Association journal. Jul. 4. 1964;91:36-9. [pmid: 14182562].
76 Won H, Maley P, Salim S, et al. Surgical and patient outcomes using mechanical bowel preparation before laparoscopic gynecologic surgery: a randomized controlled trial. Obstetrics and gynecology. Mar. 2013;121(3):538-46. [pmid: 23635616].
77 Wong AL, Kravarusic D, Wong SL. Impact of cecostomy and antegrade colonic enemas on management of fecal incontinence and constipation: ten years of experience in pediatric population. Journal of pediatric surgery. Aug. 2008;43(8):1445-51. [pmid: 18675633].
78 Yang LC, Arden D, Lee TT, et al. Mechanical bowel preparation for gynecologic laparoscopy: a prospective randomized trial of oral sodium phosphate solution vs single sodium phosphate enema. Journal of minimally invasive gynecology. Mar-Apr. 2011;18(2):149-56. [pmid: 21167795].
79 Yeh CY, Changchien CR, Wang JY, et al. Pelvic drainage and other risk factors for leakage after elective anterior resection in rectal cancer patients: a prospective study of 978 patients. Annals of surgery. Jan. 2005;241(1):9-13. [pmid: 15621985].
80 Young JM, Leong DC, Armstrong K, et al. Concordance with national guidelines for colorectal cancer care in New South Wales: a population-based patterns of care study. The Medical journal of Australia. Mar. 19. 2007;186(6):292-5. [pmid: 17371209].
81 Adeniran JO. One-stage correction of imperforate anus and rectovestibular fistula in girls: Preliminary results. Journal of pediatric surgery. Jun. 2002;37(6):E16. [pmid: 12037777].
82 Al-Jurf AS, Jochimsen PR. Gastrocolic fistula: preparation for surgery. American journal of proctology, gastroenterology & colon & rectal surgery. Jul-Aug. 1979;30(4):30-2. [pmid: 525691].
83 Campisi P, Badhwar V, Morin S, et al. Postoperative hypocalcemic tetany caused by fleet phospho-soda preparation in a patient taking alendronate sodium: report of a case. Diseases of the colon and rectum. Nov. 1999;42(11):1499-501. [pmid: 10566542].
84 Cheng KP, Roslani AC, Sehha N, et al. ALEXIS O-Ring wound retractor vs conventional wound protection for the prevention of surgical site infections in colorectal resections(1). Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Jun. 2012;14(6):e346-51. [pmid: 22568647].
85 Cohn I Jr., Longacre AB. Neomycinnystatin for preoperative preparation of the colon. The American surgeon. Mar. 1956;22(3):301-7. [pmid: 13302698].
86 Descamps C, Cabrera G, Depierreux M, et al. Acute renal insufficiency after colon cleansing. Endoscopy. Feb. 2000;32(2):S11. [pmid: 10696848].
87 Hill AG, Parry BR. Hypokalaemia following bowel cleansing with sodium phosphate. The New Zealand medical journal. Sep. 13. 1996;109(1029):347. [pmid: 8862361].
88 Ho JM, Cavalcanti RB. A shocking bowel preparation: severe electrolyte disturbances after polyethylene glycol-based bowel preparation. Journal of the American Geriatrics Society. Sep. 2009;57(9):1729-30. [pmid: 19895448].
89 Keen RR, Orsay CP. Rectosigmoid stent for obstructing colonic neoplasms. Diseases of the colon and rectum. Sep. 1992;35(9):912-3. [pmid: 1511655].
90 London FA. Help the patient comply with the colonic prep. Gastroenterology. May. 1990;98(5 Pt 1):1393. [pmid: 2323531].
91 Ozdil B, Kece C, Cosar A. Acute hemorrhagic colitis following administration of sennosides for colon cleansing. The Annals of pharmacotherapy. Apr. 2010;44(4):770-1. [pmid: 20332338].
92 Paskauskas S, Latkauskas T, Valeikaite G, et al. Colonic intussusception caused by colonic lipoma: a case report. Medicina (Kaunas). 2010;46(7):477-81. [pmid: 20966621].
93 Scully JC. Preoperative preparation of patients with carcinoma of the colon. Journal - Michigan State Medical Society. Dec. 1946;45(12):1630-2. [pmid: 20278659].
94 Smith B. Effect of irritant purgatives on the myenteric plexus in man and the mouse. Gut. Apr. 1968;9(2):139-43. [pmid: 5655023].
95 Stollman N, Manten HD. Angioedema from oral polyethylene glycol electrolyte lavage solution. Gastrointestinal endoscopy. Aug. 1996;44(2):209-10. [pmid: 8858338].
96 Tan HL, Liew QY, Loo S, et al. Severe hyperphosphataemia and associated electrolyte and metabolic derangement following the administration of sodium phosphate for bowel preparation. Anaesthesia. May. 2002;57(5):478-83. [pmid: 11966559].
97 Tatsuno B, Murariu D, Bergmann L, et al. Novel technique for preoperative localization of colorectal tumors for laparoscopic resection. Surgical laparoscopy, endoscopy & percutaneous techniques. Oct. 2012;22(5):e281-3. [pmid: 23047407].
98 Velling TE, Hall LD, Brennan FJ. Colonic stent placement facilitated by percutaneous cecostomy and antegrade enema. AJR American journal of roentgenology. Jul. 2000;175(1):119-20. [pmid: 10882259].
99 Wang CW, Lee CL, Soong YK. Bowel injury by the suction-irrigator during operative laparoscopy. The Journal of the American Association of Gynecologic Laparoscopists. May. 1995;2(3):353-4. [pmid: 9050584].
100 Yamamoto C, Aoyagi K, Maeda K, et al. Polyethylene glycol-electrolyte lavage solution causes reversible mucosal elevation surrounding a minute depressed-type rectal cancer. Endoscopy. Oct. 2005;37(10):1027-9. [pmid: 16189779].
101 Bowel preparation for surgery. Lancet. Nov. 25. 1978;2(8100):1132-3. [pmid: 82688].
102 From our follow-up files. Harvard Health Letter. 2010. PMID:.
103 Retraction: Colon and rectal surgery for cancer without mechanical bowel preparation: one-center randomized prospective trial. World journal of surgical oncology. 2012;10:196. [pmid: 22992274].
104 Akiyoshi T, Watanabe T, Ueno M. Incidence of anastomotic leakage after rectal cancer surgery without bowel preparation. Annals of surgery. Oct. 2011;254(4):676-7. author reply 7. [pmid: 21876431].
105 Basso L, Joyce WP. Mechanical bowel preparation for elective colorectal surgery. Diseases of the colon and rectum. Jan. 1998;41(1):121-2. [pmid: 9510324].
106 Basu S, Shukla VK. Mechanical bowel preparation: are we ready for a paradigm shift?. Digestive surgery. 2008;25(5):325-7. [pmid: 18818500].
107 Beck DE, Harford FJ, DiPalma JA, et al. Bowel cleansing with polyethylene glycol electrolyte lavage solution. Southern medical journal. Dec. 1985;78(12):1414-6. [pmid: 4071165].
108 Berry MA, DiPalma JA. Gastrointestinal lavage for colon cleansing. Surgical technology international. 1997;6:97-100. [pmid: 16160961].
109 Boehme EJ, Cattell RB. Cancer of the rectum; a discussion of preoperative preparation, postoperative complications and colostomy management. The Surgical clinics of North America. Jun. 1946;26:564-73. [pmid: 20988002].
110 Bogden PE, Pien FD. Cefamandole preparation for colonic surgery. Diseases of the colon and rectum. Sep. 1982;25(6):625. [pmid: 7117071].
111 Brisinda G, Vanella S, Crocco A, et al. The influence of mechanical bowel preparation in elective lower colorectal surgery. Annals of surgery. Sep. 2010;252(3):574-5. author reply 5-6. [pmid: 20739867].
112 Bruch HP. Crohn's disease. Alternatives of preparation. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Aug. 2009;80(8):734. [pmid: 19669717].
113 Bucher P, Gervaz P, Morel P. Should preoperative mechanical bowel preparation be abandoned?. Annals of surgery. Apr. 2007;245(4):662. [pmid: 17414618].
114 Bucher P, Morel P. Notice of duplicate publication: “Mechanical bowel preparation for elective colorectal surgery: a meta-analysis” (Arch Surg. 2004;139:1359-1364). Arch Surg. Feb. 2006;141(2):217. [pmid: 16490904].
115 Bulmer FM. Bowel preparation for rectal and colonic investigation. Nurs Stand. Feb. 2-8. 2000;14(20):32-5. [pmid: 11209355].
116 Cao F, Li J, Li F. Mechanical bowel preparation for elective colorectal surgery: Updated systematic review and meta-analysis. International journal of colorectal disease. 2012;27(6):803-10. PMID:. [pmid: 22108902].
117 Cardi E. Mechanical bowel preparation for elective colorectal surgery. Rhode Island medical journal. Apr. 1985;68(4):185. [pmid: 3858942].
118 Chambers WM, Mortensen NJ. Postoperative leakage and abscess formation after colorectal surgery. Best practice & research Clinical gastroenterology. Oct. 2004;18(5):865-80. [pmid: 15494283].
119 Chappell D, Rehm M, Jacob M. Preoperative bowel preparation. Lancet. May. 17. 2008;371(9625):1661. author reply 2. [pmid: 18486732].
120 Clarke DL, Madiba TE, Thomson SR. Abandoning bowel preparation for rectal surgery--are we attempting to square a circle?. South African journal of surgery Suid-Afrikaanse tydskrif vir chirurgie. Aug. 2007;45(3):108. 10. author reply 10. [pmid: 17892191].
121 Cohn I Jr. Choice of agents for preoperative preparation of the colon. Southern medical journal. Jul. 1960;53:881-4. [pmid: 13811038].
122 Cohn I Jr. Bacteriologic preparation for colonic operations. The Surgical clinics of North America. Oct. 1962;42:1277-84. [pmid: 14022136].
123 Cohn I Jr. Preparation for surgery of the colon. Surgery. Oct. 1970;68(4):725-6. [pmid: 5473050].
124 Collins DC. Newer Developments in Proctology: Viii. American journal of proctology. Feb. 1964;15:23-35. CONTD. [pmid: 14123467].
125 Condon RE. Bowel preparation for colorectal operations. Arch Surg. Mar. 1982;117(3):265. [pmid: 7065867].
126 Corman ML. Anal sphincter reconstruction. The Surgical clinics of North America. Apr. 1980;60(2):457-63. [pmid: 6992308].
127 Cox AG. Bowel preparation. Nursing times. Apr. 4. 1974;70(14):502-3. [pmid: 4822962].
128 Dantas W. Effect of laxatives on human rectal mucosa. Gastroenterology. Mar. 1978;74(3):639. [pmid: 631496].
129 Davies ML, Harris D, Davies M, et al. Selection criteria for the radical treatment of locally advanced rectal cancer. International journal of surgical oncology. 2011;2011:678506. [pmid: 22312517].
130 de Lalla F. Antimicrobial prophylaxis in colorectal surgery: focus on ertapenem. Therapeutics and clinical risk management. 2009;5:829-39. [pmid: 19898647].
131 Deka P, Negi SS. The role of mechanical bowel preparation before colorectal surgery. The National medical journal of India. Mar-Apr. 2009;22(2):76-7. [pmid: 19852343].
132 Dellinger EP. Re: “Colon preparation and surgical site infection”. American journal of surgery. Nov. 2012;204(5):804-5. [pmid: 22321854].
133 Dickinson JD. Want to get a jump start on preventing infections? Have patients do the prep work. Same-Day Surgery. 2013. PMID:.
134 DiPalma JA, Brady CE 3rd. Colon cleansing for diagnostic and surgical procedures: polyethylene glycol-electrolyte lavage solution. The American journal of gastroenterology. Sep. 1989;84(9):1008-16. [pmid: 2672787].
135 Dunphy JE. Preoperative preparation of the colon and other factors affecting anastomotic healing. Cancer. Jul. 1971;28(1):181-2. [pmid: 5110629].
136 Ellis C. Bowel preparation before elective colorectal surgery: what is the evidence. Seminars in Colon & Rectal Surgery. 2010;21(3):144-7. PMID:.
137 Ellis CN. Bowel Preparation Before Elective Colorectal Surgery: What is the Evidence. Seminars in Colon and Rectal Surgery. 2010;21(3):144-7. PMID:.
138 Eskicioglu C, Forbes SS, Fenech DS, et al. Preoperative bowel preparation for patients undergoing elective colorectal surgery: a clinical practice guideline endorsed by the Canadian Society of Colon and Rectal Surgeons. Canadian journal of surgery Journal canadien de chirurgie. Dec. 2010;53(6):385-95. [pmid: 21092431].
139 Eskicioglu C, Gagliardi AR, Fenech DS, et al. Surgical site infection prevention: a survey to identify the gap between evidence and practice in University of Toronto teaching hospitals. Canadian journal of surgery Journal canadien de chirurgie. Aug. 2012;55(4):233-8. [pmid: 22617541].
140 Fallis LS. Importance of preoperative preparation of the patient in surgery of the colon. Journal - Michigan State Medical Society. Sep. 1949;48(9):1162-5. [pmid: 18138557].
141 Francis MD, Caswell M. Patients on bisphosphonates should not be at increased risk for hypocalcemic-induced tetany when given Fleet Phospho-soda. Diseases of the colon and rectum. Dec. 2003;46(12):1717-8. [pmid: 14668604].
142 Fujita T. Evaluating bowel cleansing method for rectal cancer surgery. Annals of surgery. Oct. 2011;254(4):675-6. [pmid: 21878811].
143 Fujita T. Role of mechanical bowel preparation and anastomotic technique in low-anterior resection. Annals of surgery. Mar. 2011;253(3):629. [pmid: 21248630].
144 G G. Safe use of oral bowel-cleansing preparations. Nursing Standard. 2013;27(22):35-8. PMID:.
145 Goldstone AR, Kennedy N, Metcalfe M. Randomized clinical trial of mechanical bowel preparation versus no preparation before elective left-sided colorectal surgery (Br J Surg 2004; 92: 409-414). The British journal of surgery. Aug. 2005;92(8):1046. [pmid: 16034805].
146 Goodwin WE, Scardino PT. Ureterosigmoidostomy. The Journal of urology. Jul. 1977;118(1 Pt 2):169-74. [pmid: 327103].
147 Gravante G, Caruso R. Mechanical bowel preparation for elective colorectal surgery: is it enough?. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jul. 2009;13(7):1392-4. author reply 5. [pmid: 18516650].
148 Gray M, Colwell JC. Mechanical bowel preparation before elective colorectal surgery. Journal of wound, ostomy, and continence nursing : official publication of The Wound, Ostomy and Continence Nurses Society / WOCN. Nov-Dec. 2005;32(6):360-4. [pmid: 16301900].
149 Gustafsson UO, Scott MJ, Schwenk W, et al. Guidelines for perioperative care in elective colonic surgery: Enhanced Recovery After Surgery (ERAS(R)) Society recommendations. Clin Nutr. Dec. 2012;31(6):783-800. [pmid: 23099039].
150 Habr-Gama A. Colon and rectal surgery without mechanical bowel preparation: a randomized prospective trial. Techniques in coloproctology. Oct. 2003;7(3):212-3. discussion 3. [pmid: 14635618].
151 Habr-Gama A. Colon and rectal surgery without mechanical bowel preparation: a randomized prospective trial. Ann Surg. 2003;237:363-367. Techniques in coloproctology 2004 Aug;8(2):128; discussion. [pmid: 12616120].
152 Hares MM, Alexander-Williams J. The effect of bowel preparation on colonic surgery. World journal of surgery. Mar. 1982;6(2):175-81. [pmid: 7090402].
153 Herter FP. Preparation of the bowel for surgery. The Surgical clinics of North America. Aug. 1972;52(4):859-70. [pmid: 5047528].
154 Holt EW, Verhille MS. Improving the quality of bowel preparation: one step closer to the holy grail?. Digestive diseases and sciences. Feb. 2011;56(2):273-5. [pmid: 21132528].
155 Holte K. Pathophysiology and clinical implications of peroperative fluid management in elective surgery. Danish medical bulletin. Jul. 2010;57(7):B4156. [pmid: 20591343].
156 Huber DA. Colon preparation. Gastroenterology nursing : the official journal of the Society of Gastroenterology Nurses and Associates. Nov-Dec. 2005;28(6):510-1. [pmid: 16418587].
157 Irvin TT. Letter: Preparation for colonic surgery. Lancet. Dec. 6. 1975;2(7945):1150. [pmid: 53637].
158 Johnson EK, Cirocco WC. Mechanical bowel preparation for elective colorectal surgery. Diseases of the colon and rectum. 2010;53(3):370-1. PMID:.
159 Johnston D. Bowel preparation for colorectal surgery. The British journal of surgery. Jul. 1987;74(7):553-4. [pmid: 3620858].
160 Keighley MR. A clinical and physiological evaluation of bowel preparation for elective colorectal surgery. World journal of surgery. Jul. 1982;6(4):464-70. [pmid: 7123984].
161 Keighley MR, Lee JR, Ambrose NS. Indications and techniques for bowel preparation in colorectal cancer. International advances in surgical oncology. 1983;6:257-70. [pmid: 6874084].
162 Kim LT. Surgical site infection: Still waiting on the revolution. JAMA - Journal of the American Medical Association. 2011;305(14):1478-9. PMID:.
163 Konings K. Preop use of Golytely in pediatrics. Pediatric nursing. Sep-Oct. 1989;15(5):473-4. [pmid: 2587105].
164 Lockhart-Mummery HE. Preparation of the large bowel for surgery. Postgraduate medical journal. Apr. 1954;30(342):192-6. [pmid: 13155262].
165 Lockwood RA, Taylor WA. Posterior surgical approach to the rectum. California medicine. Aug. 1956;85(2):104-6. [pmid: 13343017].
166 Lombardo PR. Bowel preparation for cancer surgery: beneficial or detrimental?. The Journal of the American Osteopathic Association. May. 1970;69(9):917-26. [pmid: 5200429].
167 Madden JL, Cohn I Jr., Freeark RJ, et al. Preoperative preparation and postoperative care of the colon. Diseases of the colon and rectum. May-Jun. 1968;11(3):163-77. [pmid: 4299091].
168 Mahoney M, Baxter K, Burgess J, et al. Procedure for Obtaining a Urine Sample From a Urostomy, Ileal Conduit, and Colon Conduit: A Best Practice Guideline for Clinicians. Journal of Wound, Ostomy & Continence Nursing. 2013;40(3):277-9. PMID:.
169 Matsou A, Vrakas G, Doulgerakis M, et al. Mechanical bowel preparation before elective colorectal surgery: is it necessary?. Techniques in coloproctology. Oct. Suppl 1. 2011;15:S59-62. [pmid: 21901518].
170 McGinnis LS. Surgical treatment options for colorectal cancer. Cancer. Oct. 1. 1994;74(7 Suppl):2147-50. [pmid: 7522123].
171 McPherson C. Preparation of the patient for colon surgery. American journal of proctology. Jun. 1963;14:188-91. [pmid: 13932258].
172 Mikal S. Metabolic effects of preoperative intestinal preparation. American journal of proctology. Dec. 1965;16(6):437-42. [pmid: 5839640].
173 Nasirkhan MU, Abir F, Longo W, et al. Anastomotic disruption after large bowel resection. World journal of gastroenterology : WJG. Apr. 28. 2006;12(16):2497-504. [pmid: 16688793].
174 Nelson RL. Bowel preparation: Give it up. BMJ. Jan. 19. 2008;336(7636):110. [pmid: 18202043].
175 Nichols RL, Choe EU, Weldon CB. Mechanical and antibacterial bowel preparation in colon and rectal surgery. Chemotherapy. Suppl 1. 2005;51:115-21. [pmid: 15855756].
176 Nichols RL, Condon RE. Antibiotic preparation of the colon: failure of commonly used regimens. The Surgical clinics of North America. Feb. 1971;51(1):223-31. [pmid: 4932924].
177 Nichols RL, Condon RE. Preoperative preparation of the colon. Surgery, gynecology & obstetrics. Feb. 1971;132(2):323-37. [pmid: 4929735].
178 Nicholson G, Morrison DS, Finlay IG, et al. Long-term outcomes following mechanical bowel preparation in elective colonic resection. Annals of surgery. Mar. 2010;251(3):577. author reply. [pmid: 20101168].
179 Noble EJ, Daniels IR. Multicentre randomized clinical trial of mechanical bowel preparation in elective colonic resection (Br J Surg 2007; 94: 689-695). The British journal of surgery. Oct. 2007;94(10):1306. author reply. [pmid: 17874443].
180 Nygren J, Thacker J, Carli F, et al. Guidelines for perioperative care in elective rectal/pelvic surgery: Enhanced Recovery After Surgery (ERAS(R)) Society recommendations. Clin Nutr. Dec. 2012;31(6):801-16. [pmid: 23062720].
181 Oh YS. What are we missing when colon preparation is inadequate?. Gastrointestinal endoscopy. Jun. 2012;75(6):1204-5. [pmid: 22624811].
182 Pappalardo G, Coiro S. Bowel preparation may be an important adjunct to ERAS in rectal surgery. World journal of surgery. Jul. 2012;36(7):1716. author reply 7-8. [pmid: 22441727].
183 Patel MG, Pashankar DS. Bowel preparation in children: is polyethylene glycol an answer?. Journal of pediatric gastroenterology and nutrition. Feb. 2013;56(2):115. [pmid: 23201706].
184 Patterson HA. Preoperative preparation of patients with carcinoma of the colon and rectum. Diseases of the colon and rectum. Jan-Feb. 1959;2(1):109-13. [pmid: 13639820].
185 Peters D. Bowel preparation for surgery. Nursing times. Jul. 13-9. 1983;79(28):32-4. [pmid: 6555700].
186 Pring C, Hornung B, Burke D, et al. Letter 1: randomized clinical trial of bowel preparation with a single phosphate enema or polyethylene glycol before elective colorectal surgery (Br J Surg 2006; 93: 427-433). The British journal of surgery. Sep. 2006;93(9):1147. author reply -8. [pmid: 16915583].
187 Rawal N. Fast-track postoperative protocols-how effective are they?. Regional anesthesia and pain medicine. 2012;37(5):E134-E5. PMID:.
188 Reich AL. Preoperative preparation and postoperative care in anorectal operations. The Review of gastroenterology. Dec. 1947;14(12):873-6. [pmid: 18895651].
189 Rerknimitr R. Sorbitol can be the cause of colonic explosion. Endoscopy. Mar. 2007;39(3):257. [pmid: 17385112].
190 Roig JV, Garcia-Armengol J. Randomized clinical trial of bowel preparation with a single phosphate enema or polyethylene glycol before elective colorectal surgery (Br J Surg 2006; 93; 427-433). The British journal of surgery. Dec. 2006;93(12):1563. [pmid: 17115397].
191 Rose D, Koniges F, Frazier TG. A simplified technique for a totally diverting transverse loop colostomy and distal irrigation. Surgery, gynecology & obstetrics. Dec. 1985;161(6):592-3. [pmid: 4071376].
192 Rovera F, Dionigi G, Boni L, et al. Antibiotic prophylaxis and preoperative colorectal cleansing: are they useful?. Surgical oncology. Dec. Suppl 1. 2007;16:S109-11. [pmid: 18023177].
193 Roy HK, Bianchi LK. Purging the colon while preserving the kidneys. Archives of internal medicine. Mar. 24. 2008;168(6):565-7. [pmid: 18362246].
194 Schmelzer M. The need for a national study of colon cleansing procedures. Gastroenterology nursing : the official journal of the Society of Gastroenterology Nurses and Associates. Mar-Apr. 2005;28(2):152-3. [pmid: 15832120].
195 Schreve RH, Bijnen AB, Westbroek DL. Radiopaque markers for the assessment of mechanical preoperative bowel preparation. The Netherlands journal of surgery. Oct. 1985;37(5):153. [pmid: 4058780].
196 Sganga G. New perspectives in antibiotic prophylaxis for intra-abdominal surgery. The Journal of hospital infection. Jan. Suppl A. 2002;50:S17-21. [pmid: 11993640].
197 Shorb PE Jr. Surgical therapy for Crohn's disease. Gastroenterology clinics of North America. Mar. 1989;18(1):111-28. [pmid: 2646219].
198 Slater RC. Managing quality of life in the older person with a stoma. British journal of community nursing. Oct. 2010;15(10):480-2. 4. [pmid: 20966842].
199 Slim K. Reply. Annals of surgery. 2010;252(1):200-1. PMID:. [pmid: 20562680].
200 Slim K. Is the Surgical Community Ready to Omit Mechanical Bowel Preparation Before Colon Surgery?. Annals of surgery. 2011. Feb. 21. [pmid: 21346544].
201 Slim K. Reply. Annals of surgery. 2011;253(4):839-40. PMID:. [pmid: 21475031].
202 Strodel WE, Brothers T. Colonoscopic decompression of pseudo-obstruction and volvulus. The Surgical clinics of North America. Dec. 1989;69(6):1327-35. [pmid: 2688153].
203 Swinton NW Sr., O'Keefe DD. Preoperative evaluation and preparation of the patient with colonic cancer. The Surgical clinics of North America. Jun. 1970;50(3):737-41. [pmid: 5446560].
204 Symmonds RE Jr. Surgical management of complicated diverticulitis. Clinics in geriatric medicine. May. 1985;1(2):471-83. [pmid: 3830380].
205 Tai LS, Chia YW. Endoscopic Nd:YAG laser treatment of inoperable lower gastrointestinal cancer. Annals of the Academy of Medicine, Singapore. Sep. 1996;25(5):712-6. [pmid: 8924011].
206 Tanner CH. Surgical conditions of the rectum and anal canal. I. Causes, diagnosis and preparation for major surgery. Nursing times. Mar. 29. 1963;59:378-80. [pmid: 13984883].
207 Thalheimer A, Germer CT. Mechanical bowel preparation before colorectal surgery?. Digestive surgery. 2008;25(5):328. [pmid: 19110689].
208 Tomillero A, Moral MA. Summary. Methods and findings in experimental and clinical pharmacology. 2010;32(2):133-47. PMID:. [pmid: 20401351].
209 Turell R. The management of bowel evacuation in surgical patients. AMA archives of surgery. Nov. 1958;77(5):824-32. [pmid: 13582446].
210 Turell R, Landau SJ. Antibiotics in the preoperative preparation of the colon: evaluation of the present status. The Journal of the International College of Surgeons. Feb. 1959;31(2):215-24. [pmid: 13641731].
211 Turell R, Vallecillo LA, Paradny R, et al. Preoperative preparation of the colon with sulfonamides or antibiotics. The Surgical clinics of North America. Oct. 1955;(Nationwide No):1211-20. [pmid: 13267698].
212 Tutchenko M. Diagnosis and management of colorectal obstruction. Przeglad lekarski. Suppl 5. 2000;57:76-8. [pmid: 11202303].
213 Tyson RR, Spaulding EH. Should antibiotics be used in large bowel preparation. Surgery, gynecology & obstetrics. May. 1959;108(5):623-6. [pmid: 13647219].
214 Walls AD. Colon preparation. Journal of the Royal College of Surgeons of Edinburgh. Jan. 1980;25(1):26-31. [pmid: 7359455].
215 Walworth EZ. Re: Polyethylene glycol versus sodium phosphate mechanic bowel preparation in elective colorectal surgery. American journal of surgery. May. 2008;195(5):717. [pmid: 18424294].
216 Weber FH Jr. Optimizing colonic preparation: the solution is becoming clearer and clearer. Clinical gastroenterology and hepatology : the official clinical practice journal of the American Gastroenterological Association. Apr. 2011;9(4):286-9. [pmid: 21195792].
217 Welvaart K, Hoogstraten MM. Preparation of the colon by whole-gut irrigation--some practical remarks. The Netherlands journal of surgery. 1980;32(2):71-3. [pmid: 7413100].
218 Wexner SD. Preoperative preparation prior to colorectal surgery. Gastrointestinal endoscopy. May. 1996;43(5):530-1. [pmid: 8726777].
219 Wexner SD. Standardized perioperative care protocols and reduced lengths of stay after colon surgery. Journal of the American College of Surgeons. May. 1998;186(5):589-93. [pmid: 9583701].
220 Wood D, Cota A, Daniels IR. Letter 2: randomized clinical trial of bowel preparation with a single phosphate enema or polyethylene glycol before elective colorectal surgery (Br J Surg 2006; 93: 427-433). The British journal of surgery. Sep. 2006;93(9):1147. author reply -8. [pmid: 16915584].
221 Yarze JC, Chase MP. Avoidance of PEG 3350 in patients with CHF, cirrhosis, and chronic kidney disease. Gastrointestinal endoscopy. Jul. 2011;74(1):236-7. author reply 7. [pmid: 21704825].
222 Zygon J, Golabek-Dropiewska K, Sowa M, et al. “Fast Track” technique in patients undergoing elective colon surgery. Nowotwory. 2011;61(2):150-8. PMID:.
223 Al-Mulhim AS. Pain after inguinal hernia repair. Possible role of bowel preparation. Saudi medical journal. Nov. 2007;28(11):1682-5. [pmid: 17965789].
224 Atkinson RJ, Save V, Hunter JO. Colonic ulceration after sodium phosphate bowel preparation. The American journal of gastroenterology. Nov. 2005;100(11):2603-5. [pmid: 16279928].
225 Bornside GH, Cohn I Jr. Intestinal antisepsis. Stability of fecal flora during mechanical cleansing. Gastroenterology. Nov. 1969;57(5):569-73. [pmid: 5348091].
226 Caldera F, Selby L. How to avoid common pitfalls with bowel preparation agents. Gastrointestinal endoscopy. Feb. 2011;73(2):346-8. [pmid: 21295645].
227 Cheng YM, Wang ST, Chou CY. Serum CA-125 in preoperative patients at high risk for endometriosis. Obstetrics and gynecology. Mar. 2002;99(3):375-80. [pmid: 11864662].
228 Chun YJ, Yoon NR, Park JM, et al. Prospective assessment of risk of bacteremia following colorectal stent placement. Digestive diseases and sciences. Apr. 2012;57(4):1045-9. [pmid: 22057286].
229 Cohn I Jr., Longacre AB. Thiostrepton and thiostrepton-neomycin for preoperative preparation of the colon. Surgery. Nov. 1957;42(5):865-73. [pmid: 13486397].
230 Cohn I Jr., Longacre AB. Ristocetin and ristocetin-neomycin for preoperative preparation of the colon. AMA archives of surgery. Aug. 1958;77(2):224-9. [pmid: 13558851].
231 Davis GR, Santa Ana CA, Morawski SG, et al. Development of a lavage solution associated with minimal water and electrolyte absorption or secretion. Gastroenterology. May. 1980;78(5 Pt 1):991-5. [pmid: 7380204].
232 Dervisoglou A, Condilis N, Liveranou S, et al. A causal factors and treatment of obstructive ileus in 369 patients. Annali italiani di chirurgia. Sep-Oct. 2005;76(5):477-80. [pmid: 16696223].
233 DiPalma JA, Brady CE 3rd, Pierson WP. Colon cleansing: acceptance by older patients. The American journal of gastroenterology. Aug. 1986;81(8):652-5. [pmid: 3740024].
234 Faintuch JS. Endoscopic laser therapy in colorectal carcinoma. Hematology/oncology clinics of North America. Mar. 1989;3(1):155-70. [pmid: 2465292].
235 Fireman Z, Rozen P, Fine N, et al. Reproducibility studies and effects of bowel preparations on measurements of rectal epithelial proliferation. Cancer letters. Apr. 1989;45(1):59-64. [pmid: 2713823].
236 Glass RL, Winship DH, Rogers WA. Comparison of intragastric infusion with conventional mechanical bowel preparation. Diseases of the colon and rectum. Nov-Dec. 1981;24(8):589-91. [pmid: 7318621].
237 Gonzalez R, Nguyen DH, Koleilat N, et al. Compatibility of enterocystoplasty and the artificial urinary sphincter. The Journal of urology. Aug. 1989;142(2 Pt 2):502-4. discussion 20-1. [pmid: 2746766].
238 Hawes RH, Lehman GA, Brunelle RL, et al. Comparative efficacy of colon-cleansing methods: standard preparation vs. Colimmac lavage. AJR American journal of roentgenology. Feb. 1984;142(2):309-10. [pmid: 6607596].
239 Hixson LJ. Colorectal ulcers associated with sodium phosphate catharsis. Gastrointestinal endoscopy. Jul. 1995;42(1):101-2. [pmid: 7557166].
240 Hookey LC, Vanner S. Recognizing the clinical contraindications to the use of oral sodium phosphate for colon cleansing: a case study. Canadian journal of gastroenterology. Journal canadien de gastroenterologie. Jul. 2004;18(7):455-8. [pmid: 15229748].
241 Jimenez-Perez J, Casellas J, Garcia-Cano J, et al. Colonic stenting as a bridge to surgery in malignant large-bowel obstruction: a report from two large multinational registries. The American journal of gastroenterology. Dec. 2011;106(12):2174-80. [pmid: 22085816].
242 Kale TI, Kuzu MA, Tekeli A, et al. Aggressive bowel preparation does not enhance bacterial translocation, provided the mucosal barrier is not disrupted: a prospective, randomized study. Diseases of the colon and rectum. May. 1998;41(5):636-41. [pmid: 9593249].
243 Kusiak JF. Considerations for reconstruction after surgery for recurrent cancer. Seminars in oncology. Oct. 1993;20(5):430-45. [pmid: 8211192].
244 Liang JT, Lai HS, Lee PH. Elective laparoscopically assisted sigmoidectomy for the sigmoid volvulus. Surgical endoscopy. Nov. 2006;20(11):1772-3. [pmid: 17024540].
245 Lubowski D, de Carle D, Hunt DR. Colonic lavage with polyethylene glycol. The Medical journal of Australia. Feb. 18. 1985;142(4):256. [pmid: 3974464].
246 McLaren RH, Barrett DM, Zincke H. Rectal injury occurring at radical retropubic prostatectomy for prostate cancer: etiology and treatment. Urology. Oct. 1993;42(4):401-5. [pmid: 8212438].
247 Millet JB. Cecostomy and the Miller-Abbott tube; a report on their combined use in the preparation of the obstructed large bowel for surgery. Surgery, gynecology & obstetrics. Jun. 1947;84(6):1083-6. [pmid: 20240239].
248 Montes Lopez C, Romeo Martinez JM, Tejero Cebrian E, et al. Treatment of left colon neoplasic obstruction by placement of self-expandable stents. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Apr. 2001;93(4):226-37. [pmid: 11488119].
249 Mosimann F, Cornu P. Are enemas given before abdominal operations useful? A prospective randomised trail. The European journal of surgery. Acta chirurgica. Jul. 1998;164(7):527-30. discussion 31-2. [pmid: 9696975].
250 Mukai M, Tajima T, Suzuki R, et al. Reducing the volume of polyethylene glycol electrolyte lavage solution to less than 2 liters for bowel preparation. The Tokai journal of experimental and clinical medicine. Apr. 2000;25(1):27-32. [pmid: 11023053].
251 Newstead GL, Morgan BP. Bowel preparation with mannitol. The Medical journal of Australia. Dec. 1. 1979;2(11):582-3. [pmid: 119149].
252 Nichols RL, Condon RE, DiSanto AR. Preoperative bowel preparation. Erythromycin base serum and fecal levels following oral administration. Arch Surg. Dec. 1977;112(12):1493-6. [pmid: 931637].
253 Nichols RL, Condon RE, Gorbach SL, et al. Efficacy of preoperative antimicrobial preparation of the bowel. Annals of surgery. Aug. 1972;176(2):227-32. [pmid: 4562009].
254 Nichols RL, Gorbach SL, Condon RE. Alteration of intestinal microflora following preoperative mechanical preparation of the colon. Diseases of the colon and rectum. Mar-Apr. 1971;14(2):123-7. [pmid: 4934194].
255 Poth EJ. The role of intestinal antisepsis in the preoperative preparation of the colon. Surgery. Jun. 1960;47:1018-28. [pmid: 14434452].
256 Rooney PS, Clarke PA, Gifford KA, et al. Cell kinetics of the in vitro metaphase arrest technique and the clinical applications. Eur J Cancer Prev. Sep. 1993;2(5):387-92. [pmid: 8401173].
257 Russell RI, Hall MJ. Elemental diet therapy in the management of complicated Crohn's disease. Scottish medical journal. Oct. 1979;24(4):291-5. [pmid: 555815].
258 Sack RA, Kroener WF Jr. Hypokalemia of various etiologies complicating elective surgical procedures. American journal of obstetrics and gynecology. May. 1. 1984;149(1):74-8. [pmid: 6720776].
259 Saida Y, Sumiyama Y, Nagao J, et al. Stent endoprosthesis for obstructing colorectal cancers. Diseases of the colon and rectum. May. 1996;39(5):552-5. [pmid: 8620807].
260 Soto S, Lopez-Roses L, Gonzalez-Ramirez A, et al. Endoscopic treatment of acute colorectal obstruction with self-expandable metallic stents: experience in a community hospital. Surgical endoscopy. Jul. 2006;20(7):1072-6. [pmid: 16703437].
261 Stefanidis D, Brown K, Nazario H, et al. Safety and efficacy of metallic stents in the management of colorectal obstruction. JSLS : Journal of the Society of Laparoendoscopic Surgeons / Society of Laparoendoscopic Surgeons. Oct-Dec. 2005;9(4):454-9. [pmid: 16381366].
262 Stephens RB. Bowel preparation for elective colon surgery--current Irish habits 1979. Irish medical journal. Feb. 1980;73(2):73-5. [pmid: 7364557].
263 Stipa F, Pigazzi A, Bascone B, et al. Management of obstructive colorectal cancer with endoscopic stenting followed by single-stage surgery: open or laparoscopic resection?. Surgical endoscopy. Jun. 2008;22(6):1477-81. [pmid: 18027039].
264 Strang M, Luey K. Colon cleansing at home. Nurs N Z. Oct. 1995;1(9):24-5. [pmid: 7584652].
265 Swidsinski A, Loening-Baucke V, Theissig F, et al. Comparative study of the intestinal mucus barrier in normal and inflamed colon. Gut. Mar. 2007;56(3):343-50. [pmid: 16908512].
266 Syn WK, Patel M, Ahmed MM. Metallic stents in large bowel obstruction: experience in a District General Hospital. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Jan. 2005;7(1):22-6. [pmid: 15606580].
267 Tamim WZ, Ghellai A, Counihan TC, et al. Experience with endoluminal colonic wall stents for the management of large bowel obstruction for benign and malignant disease. Arch Surg. Apr. 2000;135(4):434-8. [pmid: 10768708].
268 Tejero E, Fernandez-Lobato R, Mainar A, et al. Initial results of a new procedure for treatment of malignant obstruction of the left colon. Diseases of the colon and rectum. Apr. 1997;40(4):432-6. [pmid: 9106691].
269 Tsai MS, Lin MT, Chang KJ, et al. Optimal interval from decompression to semi-elective operation in sigmoid volvulus. Hepato-gastroenterology. May-Jun. 2006;53(69):354-6. [pmid: 16795971].
270 Turan M, Sen M, Karadayi K, et al. Our sigmoid colon volvulus experience and benefits of colonoscope in detortion process. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Jan. 2004;96(1):32-5. [pmid: 14971995].
271 Van den Bogaard AE, Weidema WF. Colonization resistance and preoperative preparation of patients for colorectal surgery. Annali dell'Istituto superiore di sanita. 1986;22(3):911-4. [pmid: 3103514].
272 Watson MA, Baker TP, Nguyen A, et al. Association of prescription of oral sodium polystyrene sulfonate with sorbitol in an inpatient setting with colonic necrosis: a retrospective cohort study. American journal of kidney diseases : the official journal of the National Kidney Foundation. Sep. 2012;60(3):409-16. [pmid: 22683337].
273 Wong KS, Cheong DM, Wong D. Treatment of acute malignant colorectal obstruction with self-expandable metallic stents. ANZ journal of surgery. Jun. 2002;72(6):385-8. [pmid: 12121153].
274 Xu M, Zhong Y, Yao L, et al. Endoscopic decompression using a transanal drainage tube for acute obstruction of the rectum and left colon as a bridge to curative surgery. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. May. 2009;11(4):405-9. [pmid: 18513190].
275 Yao LQ, Zhong YS, Xu MD, et al. Self-expanding metallic stents drainage for acute proximal colon obstruction. World journal of gastroenterology : WJG. Jul. 28. 2011;17(28):3342-6. [pmid: 21876623].
276 Yerkes EB, Rink RC, Cain MP, et al. Shunt infection and malfunction after augmentation cystoplasty. The Journal of urology. Jun. 2001;165(6 Pt 2):2262-4. [pmid: 11371959].
277 Abolmasov EI. Preoperative preparation of patients with colorectal cancer by enteral feeding using special diets. Vestnik khirurgii imeni I I Grekova. Apr. 1988;140(4):129-32. [pmid: 3138807].
278 Acher YA, Lemozy J, Massip P, et al. Bacteriological data concerning the utilisation of antibiotics in the preparation of colo-rectal surgery (author's transl). Annales de chirurgie. May. 1979;33(5):377-80. [pmid: 507712].
279 Ackermann D, Akovbiantz A. Turning-point of the bowel preparation?. Helvetica chirurgica acta. Feb. 1979;45(6):835-46. [pmid: 429190].
280 Aeberhard P. Conventional large intestine preparation with laxatives and enemas. Helvetica chirurgica acta. Feb. 1982;48(6):759-65. [pmid: 7068419].
281 Aeberhard P, Fluckiger M, Berger J, et al. Parenteral antibiotic prophylaxis or oral antimicrobial bowel preparation for colorectal surgery (author's transl). Langenbecks Archiv fur Chirurgie. 1981;353(4):233-40. [pmid: 7230984].
282 Aguilar J, Castro J, Perez P. Impact of the mechanical and chemotherapeutic preparation of the colon in the genesis of postoperative complications. Revista espanola de las enfermedades del aparato digestivo. Apr. 1986;69(4):339-43. [pmid: 3726254].
283 Alcantara Moral M, Serra Aracil X, Bombardo Junca J, et al. A prospective, randomised, controlled study on the need to mechanically prepare the colon in scheduled colorectal surgery. Cirugia espanola. Jan. 2009;85(1):20-5. [pmid: 19239933].
284 Alfonsi PL, Gargani G. Preoperative reduction of the intestinal flora with streptomycin-sulfamide-vitamin preparation in surgery of the large intestine. Minerva chirurgica. May. 31. 1952;7(10):379-81. [pmid: 14956712].
285 Aliev SA. Surgical management in complicated sigmoid cancer. Khirurgiia (Mosk). 1999;(11):26-30. [pmid: 10578570].
286 Aliev Sh G. Comparative evaluation of surgical interventions in patients with colonic tuberculosis. Problemy tuberkuleza i boleznei legkikh. 2003;(7):33-4. [pmid: 12939875].
287 Amgwerd R. Preoperative colon preparation through intestinal irrigation. Helvetica chirurgica acta. Dec. 1976;43(5-6):587-9. [pmid: 1002519].
288 Andina F, Allemann O. Disinfection of the colon in preparation for colonic and rectal surgery, following the principle of limited disinfection. Schweizerische medizinische Wochenschrift. Nov. 11. 1950;80(45):1201-10. [pmid: 14787419].
289 Andina F, Allemann O. Antibacterial therapy of the large intestines as a preparation for surgery of the colon and rectum. (According to the principle of aimed antibacterial therapy). Rassegna internazionale di clinica e terapia. Mar. 31. 1951;31(6):179-85. [pmid: 14844738].
290 Andina F, Allemann O. Antibacterial preoperative preparation of the large intestine; neomycin-sulfanilamide preparation. Therapeutische Umschau Revue therapeutique. Jul. 1954;11(4):68-72. [pmid: 13187423].
291 Andina F, Allemann O. Temporary repression of intestinal bacteria as preparation for operations of the large intestines. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jan. 1955;26(1):12-5. [pmid: 14364696].
292 Assalia A, Kopelman D, Hashmonai M. The necessity of mechanical bowel preparation in colo-rectal surgery. Harefuah. Jan. 1. 1996;130(1):23-4. [pmid: 8682375].
293 Balogh A, Karadi J, Bence G, et al. Preparation for elective colon surgery using the mannitol-ceftriaxone method. Orvosi hetilap. Feb. 9. 1992;133(6):343-7. [pmid: 1741151].
294 Barone C, Hell K. Neomycin versus plus metronidazol for large bowel preparation in elective colon surgery. Helvetica chirurgica acta. Sep. 1980;47(3-4):511-6. [pmid: 6782044].
295 Barsukov Iu A, Tkachev SI, Oltarzhevskaia ND, et al. Combined treatment for rectal cancer using different radiomodification means. Voprosy onkologii. 2008;54(3):350-3. [pmid: 18652242].
296 Baumann J, Schmoz G, Hartig W, et al. A balanced synthetic diet (Berlamin) in colonic surgery (author's transl). Zentralblatt fur Chirurgie. 1978;103(24):1610-7. [pmid: 742246].
297 Baumann V, Kothe W, Albert H, et al. Preoperative phase of colonic surgery (author's transl). Zentralblatt fur Chirurgie. 1980;105(16):1033-41. [pmid: 7456826].
298 Beaurang J, Delvaux G, Willems G. Whole bowel irrigation as preparation for colorectal surgery. Acta chirurgica Belgica. Nov-Dec. 1986;86(6):329-32. [pmid: 3825412].
299 Becker H, Probst M, Ungeheuer E. Does a one-time colonic or rectal resection without protective colostomy increase the rate of postoperative complications?. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Apr. 1979;50(4):244-8. [pmid: 446235].
300 Beliakov NA, Martyniuk VV, Fridman M, et al. Enterosorption in the preparation of patients for surgery of the large intestine. Vestnik khirurgii imeni I I Grekova. Feb. 1989;142(2):30-3. [pmid: 2728234].
301 Berthelet O, Rolachon A, Papillon E, et al. Rectal mucosal lesions associated with Fleet-Phospho-soda. Gastroenterologie clinique et biologique. Apr. 2001;25(4):437-9. [pmid: 11449138].
302 Bigard MA, Gelot MA, Dollet JM, et al. Concentration of explosive colonic gases after preparation by polyethylene glycol solution. Gastroenterologie clinique et biologique. Aug-Sep. 1987;11(8-9):610. [pmid: 3653621].
303 Bohm B, Nouchirvani K, Hucke HP, et al. Morbidity and mortality after elective resections of colorectal cancers. Langenbecks Archiv fur Chirurgie. 1991;376(2):93-101. [pmid: 2056845].
304 Bojanowicz K. Preparation of patients for coloscopy and treatment of diseases of large intestine with food absorbed in the small intestine. Wiad Lek. Jun. 1. 1974;27(11):985-7. [pmid: 4600459].
305 Bojanowicz K, Wasiak J. The use of residue-free resorbable nutrient preparations in colonic surgery. Infusionstherapie und klinische Ernahrung. Jun. 1975;2(3):164-7. [pmid: 810426].
306 Bondar GV, Borota AV, Zolotukhin SE, et al. Intensive therapy and strategy of management of patients with rectal cancer after the colonic descending to the perineum. Klinichna khirurhiia / Ministerstvo okhorony zdorov'ia Ukrainy, Naukove tovarystvo khirurhiv Ukrainy. Dec. 2000;(12):26-8. [pmid: 11247482].
307 Borzone A, Di Rossa P, Mattana C, et al. Preparation of the stenotic colon for surgery. Chirurgia e patologia sperimentale. Aug. 1983;31(4):145-8. [pmid: 6443350].
308 Bottger TC, Mohseni D, Beardi J, et al. Learning curve in laparoscopic rectum surgery. Zentralblatt fur Chirurgie. Jun. 2011;136(3):273-81. [pmid: 21360430].
309 Bousquet F, Delpuech N, Flores M, et al. Colorectal cancers. Preparation for surgery and postoperative surveillance. Nursing care. Soins Chir. 1994 Dec-1995 Jan. (166-167):22-6. [pmid: 7886335].
310 Bresadola F, Intini S, Anania G, et al. Chemotherapeutic prophylaxis in the preparation of the large intestine for surgical interventions: rifaximin P.O. vs. cephalosporin I.V. Annali italiani di chirurgia. Mar-Apr. 1992;63(2):201-7. [pmid: 1503379].
311 Bross W, Slopek S, Slowikowski J, et al. Preoperative preparation of the large intestine. Polski przeglad chirurgiczny. May. 1958;30(5):589-92. [pmid: 13591048].
312 Brousse N, Abdelli N, Grimaud JC, et al. Endoscopic and histological findings of colonic pseudo-lesions induced by Fleet Phospho-Soda (R). Gastroenterologie clinique et biologique. Jan. 2002;26(1):105-6. [pmid: 11938057].
313 Brusilovskii MI, Eropkina AG, Eropkin PV, et al. Preoperative preparation of patients with rectal cancer and accompanying arterial hypertension. Khirurgiia (Mosk). Oct. 1977;(10):77-81. [pmid: 916553].
314 Burkhardt F, Maurer W. Preoperative Reduction of Bacteria in Surgery of the Large Intestine with a Combination Preparation of Neomycin and Bacitracin. Bacteriological and Clinical Studies. Arzneimittel-Forschung. Nov. 1963;13:957-61. [pmid: 14210431].
315 Cafiero F, Sertoli MR, Rubagotti A, et al. Antibiotic preparation in operations on the large intestine. Experimental study. Minerva chirurgica. Jul. 15-31. 1981;36(13-14):941-3. [pmid: 7266894].
316 Cagetti M, Murgia C, Uccheddu A. Preparation of the colon by orthograde wash-out. Personal experience and comparative evaluation of 3 different methods. Minerva chirurgica. Apr. 15. 1983;38(7):481-5. [pmid: 6408532].
317 Calabi V, Niceta P. Amminosidine in the preparation for operations on the large intestine. Giornale italiano di chemioterapia. Oct-Dec. 1962;6-9:353-6. [pmid: 14017776].
318 Carli E, Fonzi E, Moltrer F, et al. Phosphate containing enemas: an undervalued risky practice? The management of an adverse event. Assistenza Infermieristica e Ricerca. 2013;32(2):84-91. PMID:. [pmid: 23877495].
319 Champault G, Adloff M, Alexandre JH, et al. Pre-operative preparation of the colon: a controlled prospective multicentre study in 215 patients (author's transl). Journal de chirurgie. Nov. 1981;118(11):677-84. [pmid: 6798049].
320 Champault G, Patel JC. Apropos of the communication by L. F. Hollender (12 October 1977): Our experience with wash-out in colon surgery. Colon preparation; usefulness of digestive irrigation with oral absorption of 10 percent Mannitol. Chirurgie; memoires de l'Academie de chirurgie. Nov. 1977;103(11):998-9. [pmid: 608405].
321 Champault G, Patel JC. Colonic preparation for surgery. Interest of digestive irrigation (author's transl). Journal de chirurgie. Dec. 1978;115(12):689-700. [pmid: 744776].
322 Charvat T. Orthograde preparation of the large intestine. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Dec. 1984;63(12):823-5. [pmid: 6523287].
323 Ciesielski L, Lupinski S, Staniaszczyk M. Preparation of patients for operations on the large intestine using commercial nutritional formulas and irrigation of the intestine. Wiad Lek. Jan. 1. 1986;39(1):9-15. [pmid: 3716438].
324 Cittadini G, Rollandi GA, Giribaldi M. Simple, safe and effective method of intestinal cleansing without enemas. La Radiologia medica. Jun. 1980;66(6):415-20. [pmid: 7455266].
325 Collazo Chao E, Panadero Ruz MD. Preoperative preparation and nutrition in colorectal cancer. Nutricion hospitalaria : organo oficial de la Sociedad Espanola de Nutricion Parenteral y Enteral. May-Jun. 1994;9(3):155-62. [pmid: 8018756].
326 Cordier B, Rocheteau M, Piperault C. Preparation of the patient with colonic cancer. Soins Chir. Oct. 1984;(44):15-6. [pmid: 6569636].
327 Cornu P, Mosimann F. Mechanical preparation of the colon with sodium picosulfate. Helvetica chirurgica acta. Mar. 1992;58(5):725-8. [pmid: 1592645].
328 Corsale I, Foglia E, Mandato M, et al. Intestinal occlusion caused by malignant neoplasia of the colon: surgical strategy. Il Giornale di chirurgia. Mar. 2003;24(3):86-91. [pmid: 12822214].
329 d'Almeida JB, Bessa JS, Costa e Silva R, et al. Emergency surgery of complicated diverticular disease of the colon. Chirurgie; memoires de l'Academie de chirurgie. 1990;116(1):65-70. discussion -1. [pmid: 2226041].
330 Datsenko BM, Liapunov NA, Kulikovskii VF. The use of the foam preparation Suliodovizol for preventing suppurative complications during hemorrhoidectomy and other operations on the large intestine. Vestnik khirurgii imeni I I Grekova. Feb. 1992;148(2):230-5. [pmid: 8594733].
331 Datsenko BM, Makhmudov A, Liapunov NA, et al. Prevention of peritonitis after surgery of the stomach and large intestine. Klinichna khirurhiia / Ministerstvo okhorony zdorov'ia Ukrainy, Naukove tovarystvo khirurhiv Ukrainy. 1994;(4):22-5. [pmid: 7799579].
332 Datsenko BM, Pulatov AK, Druzhinin EB. Preparation of the large intestine for the surgical treatment of intestinal obstruction. Khirurgiia (Mosk). Oct. 1994;(10):41-4. [pmid: 7723267].
333 Datsenko BM, Rakhimov R, Vorob'ev GI, et al. A method of preparing the large intestine for surgery by using the peroral administration of a polyethylene oxide solution. Khirurgiia (Mosk). Apr. 1992;(4):69-77. [pmid: 1447890].
334 De Cesare A, Martinazzoli A, Bononi M, et al. Use of a polymeric enteral diet in the preparation of the colon and rectum for surgery. Il Giornale di chirurgia. Feb. 1988;9(2):117-20. [pmid: 3155287].
335 de la Lande P. Colo-rectal preoperative preparation. Soins; la revue de reference infirmiere. Nov. 1981;26(21):19-20. [pmid: 6918107].
336 de la Serna Higuera C, Rodriguez Gomez SJ, Fuentes Coronel A, et al. Colonic preparation with polyethylene glycol, hypophosphatemia and acute confusional syndrome. Gastroenterologia y hepatologia. Apr. 2005;28(4):258-9. [pmid: 15811271].
337 De Reyes Pugnaire M. Preparation for surgery of patients with rectal cancer. Criteria of operability. Revista espanola de las enfermedades del aparato digestivo. Oct. 1. 1971;35(3):305-14. [pmid: 5119590].
338 Decker P. The use of antibiotics in the preparation for colon surgery. Helvetica chirurgica acta. Sep. 1954;21(3-4):268-73. [pmid: 13200988].
339 Delmotte JS, Desurmont P, Houcke P, et al. The value of a polyethylene glycol-based solution, tradename Fordtran, in the preparation of the colon for endoscopy and surgery. Annales de gastroenterologie et d'hepatologie. Jun-Sep. 1988;24(4):211-6. [pmid: 3138936].
340 Delmotte JS, Rey JF. Colonic preparation: once or twice?. Gastroenterologie clinique et biologique. 1990;14(10):788. [pmid: 2262133].
341 Detry R, Ballet T, Hennaut M, et al. Digestive fistulas in Crohn's disease. Acta chirurgica Belgica. May-Jun. 1985;85(3):193-7. [pmid: 4036461].
342 Dionigi R, Dominioni L, Nazari S, et al. Use of a semisynthetic enteral diet in preparation for surgery of the large intestine. Minerva dietologica e gastroenterologica. Jul-Sep. 1984;30(3):233-8. [pmid: 6438561].
343 DiPiro JT, Welage LS, Levine BA, et al. Single-dose cefmetazole versus multiple dose cefoxitin for prophylaxis in abdominal surgery. The Journal of antimicrobial chemotherapy. Apr. Suppl D. 1989;23:71-7. [pmid: 2722725].
344 Dorges J, Bohme PE. Results of surgical treatment of colorectal cancers in patients over 70. Zentralblatt fur Chirurgie. 1983;108(20):1299-304. [pmid: 6649976].
345 Dueholm S. Mechanical bowel preparation prior to elective colorectal surgery. Ugeskrift for laeger. Jan. 11. 1988;150(2):73-6. [pmid: 3287724].
346 Duhamel J, Ngo B, Romand-Heuyer Y. Preparation of a patient for common proctologic interventions. Soins; la revue de reference infirmiere. Nov. 1981;26(21):21-6. [pmid: 6918109].
347 Erhart KP. Preparation for surgery of the colon. Purging of large intestine with X-prep. Fortschritte der Medizin. Jul. 19. 1973;91(20):887-8. [pmid: 4719630].
348 Fass J. Wound healing disorder in surgery of colorectal cancer--a multifactorial computer analysis. Langenbecks Archiv fur Chirurgie. 1985;367(1):63-73. [pmid: 3912641].
349 Fedorov VD. Therapeutic tactics in diffuse polyposis of the large intestine (on A.M. Aminev's article). Khirurgiia (Mosk). Feb. 1983;(2):76-80. [pmid: 6682461].
350 Feng RY. Reconstructive operation of the gastric cardia with cardiectomy and ileo-colon replacement of the esophagus, stomach and cardia in gastric cardiac cancer. Zhonghua zhong liu za zhi. Chinese journal of oncology. May. 1990;12(3):231-3. [pmid: 2249601].
351 Fernandez Lobato R, Fernandez Luengas D, Jimenez Miramon FJ, et al. Electrolyte levels and polyethylene glycol administration. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Jun. 2001;93(6):404-5. [pmid: 11482046].
352 Ferraris R, Fornaro R, Borzone E, et al. Preoperative preparation in elective recto-colonic surgery. Our experience. Minerva chirurgica. May. 31. 1985;40(10):693-701. [pmid: 4033978].
353 Fluckiger M, Berger J, Casey P, et al. Antibiotic preparation of the colon or preoperative parenteral prophylaxis in colon surgery. A randomized study. Helvetica chirurgica acta. Dec. 1980;47(5):659-62. [pmid: 7009502].
354 Fuchs M, Kohler H, Schaper A, et al. Disorders of wound healing of the sacral cavity after abdomino-perineal resection of the rectum. Zentralblatt fur Chirurgie. 1991;116(6):375-9. [pmid: 1858449].
355 Gainant A. Prevention of anastomotic dehiscence in colorectal surgery. Journal de chirurgie. Feb. 2000;137(1):45-50. [pmid: 10790619].
356 Garcia Romero E. Preoperative preparation for surgery of colon and rectal cancer. Revista clinica espanola. Jul. 15-31. 1977;146(1-2):89-94. [pmid: 331413].
357 Geisbe H. Colon and rectal cancer. Langenbecks Archiv fur Chirurgie. 1984;364:157-61. [pmid: 6503514].
358 Grundel K, Schwenk W, Bohm B, et al. Effect of orthograde intestinal irrigation with Prepacol and polyethyleneglycol solution on duration of postoperative ileus after colorectal resections. Langenbecks Archiv fur Chirurgie. 1996;381(3):160-4. [pmid: 8767376].
359 Gu FZ, Zhao YL, Zhao J, et al. Elemental diet for preoperative care in colon surgery. Zhonghua hu li za zhi. Chinese journal of nursing. Oct. 1992;27(10):439-41. [pmid: 1301272].
360 Guller R, Reichlin B, Jost G. Colonic preparation with sodium phosphate. Prospective, randomized, placebo-controlled double blind study with various antiemetics. Schweizerische medizinische Wochenschrift. Aug. 6. 1996;126(31-32):1352-7. [pmid: 8765377].
361 Gullino D, Giordano O, Ghione S, et al. The single-stage surgery of colorectal neoplastic occlusion. The experience of 133 cases. Minerva chirurgica. Jan-Feb. 1999;54(1-2):37-47. [pmid: 10230227].
362 Gullino D, Giordano O, Masella M, et al. The single-stage surgery of perforated colon carcinoma. Our experience of 46 cases. Minerva chirurgica. Mar. 1999;54(3):127-37. [pmid: 10352522].
363 Habr-Gama A, Teixeira MG, Alves PR, et al. The use of a 10% mannitol solution in the preparation of the large intestine for colonoscopy and surgery. Revista do Hospital das Clinicas. Dec. 1981;36(6):239-43. [pmid: 6808648].
364 Hejnal J, Hrdlicka Z, Schindler J, et al. Antibiotics in preoperative preparation of the large intestine. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Aug. 1959;38:507-15. [pmid: 14400803].
365 Herfarth CH. Crohn's disease--Indication for surgery (author's transl). Leber, Magen, Darm. Aug. 1978;8(4):212-7. [pmid: 682817].
366 Hettler M. Preparation of the small and large intestines for diagnostic and therapeutic measures. Dtsch Med Wochenschr. Nov. 3. 1961;86:2120-2. [pmid: 13907035].
367 Hildebrandt J, Diettrich H. Modern mechanical antibiotic preparation in colorectal operations. Results of a prospective study. Zentralblatt fur Chirurgie. 1985;110(2-3):93-7. [pmid: 3984559].
368 Hildebrandt J, Lauschke G, Sinkwitz KD, et al. Preoperative preparation of the colon with special reference to orthograde intestinal lavage. Acta chirurgica Academiae Scientiarum Hungaricae. 1980;21(4):309-18. [pmid: 7336842].
369 Hirt HJ, Stock W, Schaal KP. Orthograde intestinal lavage in the preoperative preparation for colon surgery. Zentralblatt fur Chirurgie. 1977;102(9):569-70. [pmid: 883445].
370 Hoch J, Nyc O, Jech Z, et al. Augmentin and Tiberal in elective colorectal surgery (comparison of serum and tissue levels and clinical results. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Apr. 1995;74(3):122-5. [pmid: 7652613].
371 Holbling N, Miller K, Speil T, et al. Value of a new simple mechanical large intestine preparation in comparison with PEG lavage. Zeitschrift fur Gastroenterologie. Feb. 1990;28(2):97-100. [pmid: 2181789].
372 Hold H. Local effectiveness of surgical preparation using a chemically defined diet in colon surgery. Infusionstherapie und klinische Ernahrung. Apr. 1976;3(2):84-9. [pmid: 823103].
373 Huang S, Chen M, Chen S, et al. Strategies in shortening preoperative preparation for laparoscopic colorectal surgery. [Chinese]. Tzu Chi Nursing Journal. 2010:118. PMID:.
374 Huang S, Li L, Chia Y, et al. Enhancing the rate of complete preoperative preparation for patients in the colorectal surgical unit. Tzu Chi Nursing Journal. 2011;10(5):87. PMID:.
375 Huang XK. Effects of intra-operative colonic irrigation on colonic flora in patients with intestinal obstruction caused by left colonic carcinomas. Zhonghua wai ke za zhi. Chinese journal of surgery. Dec. 1993;31(12):746-8. [pmid: 8033705].
376 Hubmann R, Rohardt H. Comparative studies of the preoperative intestinal sterilization in surgery of the large intestine. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jun. 1966;37(6):241-4. [pmid: 6014751].
377 Huk I, Starlinger M, Schiessel R, et al. Orthograde intestinal irrigation as a preoperative intestinal preparation. Reduction of the intestinal flora using antibiotics. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Feb. 1980;51(2):106-9. [pmid: 7398470].
378 Huskes KP, Hardt KU. Primary wound healing of the sacral cavity following rectum amputation, also a comment on the discussion contribution by G. Jatzko and D. Schlapper, Chirurg (1988) 59: 855. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Dec. 1989;60(12):878-80. discussion 80-1. [pmid: 2620550].
379 Hut'an M, Lukac I, Poticny V. Prevention of the anastomosis dehiscence following low anterior rectal resections. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Oct. 2005;84(10):501-4. [pmid: 16259519].
380 Iarovenko IA, Shchitinin VE, Korneva TK, et al. Preoperative antibacterial preparation of the large intestine in children with a colostomy. Khirurgiia (Mosk). Jul. 1988;(7):71-4. [pmid: 3184727].
381 Ionescu GN, Lazar A, Pop C. Preoperative preparation of the colon. Revista de chirurgie, oncologie, radiologie, orl, oftalmologie, stomatologie Chirurgie. Jan-Feb. 1985;34(1):29-36. [pmid: 3158030].
382 Ivanisevic M, Krznar B, Sojat H, et al. High colonic-vaginal fistulas. Lijecnicki vjesnik. Jan-Feb. 1990;112(1-2):22-5. [pmid: 2366617].
383 Jevtic M, Petrovic M, Stankovic N. Antibiotic prophylaxis in elective colorectal surgery. Vojnosanitetski pregled Military-medical and pharmaceutical review. May-Jun. 1993;50(3):251-5. [pmid: 8212650].
384 Jitea N, Angelescu N, Burcos T, et al. Immediate and early reinterventions in the surgery of colorectal cancer. Chirurgia (Bucur). Jan-Feb. 1998;93(1):9-12. [pmid: 9567456].
385 Jostarndt L, Thiede A, Sonntag HG, et al. Systemic antibiotic prophylaxis in elective colon surgery. Results of a controlled study. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jun. 1981;52(6):398-402. [pmid: 6265162].
386 Joyeux H, Matias J, Gouttebel MC, et al. Therapeutic strategy in 46 cases of radiation injury of the intestine. Chirurgie; memoires de l'Academie de chirurgie. 1994;120(12):129-33. [pmid: 8746016].
387 Juarez Diaz F, Mier y Diaz J, Robledo Ogazon F. Preparation of the colon for elective surgery. Revista de gastroenterologia de Mexico. Apr-Jun. 1989;54(2):79-82. [pmid: 2772480].
388 Juvara I, Vereanu I, Sabau D. The use of 10-percent mannitol solution in colonic surgery. Revista de chirurgie, oncologie, radiologie, orl, oftalmologie, stomatologie Chirurgie. Nov-Dec. 1979;28(6):401-5. [pmid: 120565].
389 Kargel W. 4 years' experience with the Rekonval balanced diet in colon and rectum surgery. Zentralblatt fur Chirurgie. 1983;108(15):942-6. [pmid: 6637201].
390 Kewenter J, Jonsson O. Bowel preparation before colorectal surgery--a survey of Swedish surgeons. Lakartidningen. Aug. 10. 1983;80(32-33):2888-90. [pmid: 6633040].
391 Khanevich MD, Shasholin MA, Ziazin AA, et al. Frontal resection as a means of decision for surgical treatment of rectum cancer. Vestnik khirurgii imeni I I Grekova. 2005;164(2):26-8. [pmid: 16082831].
392 Khanevich MD, Shasholin MA, Ziazin AA, et al. Treatment of tumoral colonic obstruction. Vestnik khirurgii imeni I I Grekova. 2005;164(1):85-9. [pmid: 15957819].
393 Kiss L. The intraoperative colonic irrigation in emergency surgery. Chirurgia (Bucur). Sep-Oct. 2001;96(5):499-504. [pmid: 12731192].
394 Klaue HJ. Comment on Willis S., Stumpf M. (2004). Insufficiencies after interventions on the lower gastrointestinal tract. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jun. 2005;76(6):612-3. author reply 3. [pmid: 16050010].
395 Klug WA, Capelhuchnick P. Comparative study of 2 drug administration schedules in the preparation of the intestine for colorectal surgery. Revista paulista de medicina. Jan-Mar. 1981;97(1-3):29-32. [pmid: 7323581].
396 Klug WA, Capelhuchnik P. Preparation of the color for surgery with neomycin and erythromycin. AMB : revista da Associacao Medica Brasileira. Jun. 1981;27(6):185-6. [pmid: 6977148].
397 Klur V, Kostiuchenko AL, Litarskii AL. Hemodynamic and homeostatic effects of the isoperistaltic preparation of the large intestine in colorectal surgery. Vestnik khirurgii imeni I I Grekova. Sep. 1985;135(9):38-43. [pmid: 4071908].
398 Knysh VI, Anan'ev VS, Gorobets ES. Preoperative preparation in the surgical treatment of cancer of the large intestine. Klinicheskaia meditsina. Jan. 1985;63(1):146-9. [pmid: 3990184].
399 Kockerling F, Parth R, Meissner M, et al. Ileostomy--cecal fistula--colostomy--which is the most suitable fecal diversion method with reference to technique, function, complications and reversal?. Zentralblatt fur Chirurgie. 1997;122(1):34-8. [pmid: 9133134].
400 Kottmann F, Haralambie E, Eigler FW. Length of antibiotic preparation for surgery of the large intestine. Aktuelle Probleme in Chirurgie und Orthopadie. 1981;19:114-8. [pmid: 6112909].
401 Kronberger L, Kraft-Kinz J. Prevention of septic complications in colorectal surgery (author's transl). Wien Med Wochenschr. 1981;131(8):209-11. [pmid: 7257433].
402 Kujat R, Pichlmayr R. Side effects of different irrigation solutions in orthograde intestinal lavage. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Oct. 1983;54(10):669-72. [pmid: 6432490].
403 Kunin N, Letoquart JP, La Gamma A, et al. Volvulus of the colon. Apropos of 37 cases. Journal de chirurgie. Dec. 1992;129(12):531-6. [pmid: 1299667].
404 Ladurner R, Trupka A, Schmidbauer S, et al. The use of an underlay polypropylene mesh in complicated incisional hernias: sucessful French surgical technique. Minerva chirurgica. Feb. 2001;56(1):111-7. [pmid: 11283488].
405 Lambertini M, Tamburini A, Corinaldesi F, et al. Metal endoprosthesis in the treatment of acute neoplastic occlusion of the colon. Our experience. Tumori. Jul-Aug. 2003;89(4 Suppl):86-9. [pmid: 12903557].
406 Lampe CE. Bisacodyl (Dulcolax) solution added to cathartics and contrast media in colon examinations. Ugeskrift for laeger. Apr. 4. 1968;130(14):597-600. [pmid: 5707586].
407 Leger L, Chiche B. Irrigation-lavage of the intestines for in preparation of the colon for surgery. La Nouvelle presse medicale. May. 8. 1976;5(19):1255-6. [pmid: 934843].
408 Lehur PA, Letessier E. Adult fecal incontinence due to anal sphincter lesions: which preoperative preparations? Which surgical solutions?. Journal de chirurgie. May. 1998;135(2):83-9. [pmid: 9773017].
409 Lehur PA, Petiot JM, Leborgne J. Intraoperative colonic irrigation in emergency colorectal surgery. Annales de chirurgie. 1990;44(5):348-51. [pmid: 2372196].
410 Lennert KA, Graf K. Rectosigmoid cancer. Report on 442 cases. Dtsch Med Wochenschr. Jul. 9. 1982;107(27):1045-9. [pmid: 7084070].
411 Limbosch JM, Druart ML, Blondiau J, et al. Analysis of 66 cases of colorectal side-to-end anastomosis by the Baker method. Acta chirurgica Belgica. Jul-Aug. 1986;86(4):216-21. [pmid: 3532653].
412 Liou TY, Hsu H, Chen SS, et al. Evaluation of rapid colon preparation by oral intake of dulcolax for colorectal surgery. Zhonghua yi xue za zhi. Chinese medical journal; Free China ed. Aug. 1989;44(2):103-8. [pmid: 2819572].
413 Liu Y, Tao KX, Wang GB, et al. Effect of enteral nutrition as replacement of traditional bowel preparation on the intraperitoneal and intraluminal disseminated tumor cells, recurrence and metastasis in patients with colorectal cancer. Zhonghua wei chang wai ke za zhi. Chinese journal of gastrointestinal surgery. Apr. 2013;16(4):350-3. [pmid: 23608797].
414 Liu Z, Wang XD, Li L. Perioperative fast track programs enhance the postoperative recovery after rectal carcinoma resection. Zhonghua wei chang wai ke za zhi. Chinese journal of gastrointestinal surgery. Nov. 2008;11(6):551-3. [pmid: 19031133].
415 Liverani A, Chiarot M, Bezzi M, et al. Is surgery duration really a complication factor?. Minerva chirurgica. Sep. 1994;49(9):747-50. [pmid: 7991186].
416 Loran OB, Gorokhov ME, Chertin V, et al. Recurrent urethrorectal fistulae. Urologiia i nefrologiia. Sep-Oct. 1993;(5):9-11. [pmid: 8310588].
417 Lu X, Mao YL, Sang XT, et al. One-day bowel preparation with sodium phosphate prior to colorectal surgery: a prospective, randomized, controlled clinical trial. Zhonghua wai ke za zhi. Chinese journal of surgery. Oct. 1. 2006;44(19):1327-9. [pmid: 17217818].
418 Maiborodin IV, Luibarskii MS, Sparin SA. Structural organization of sigmoid and rectum wall in patients with cancer after use of enterosorbent with adsorbed metronidazole. Arkhiv patologii. May-Jun. 2000;62(3):33-7. [pmid: 10897435].
419 Makhov NI, Seleznev GF. Preoperative preparation and postoperative management of patients following operations on the intestines. Khirurgiia (Mosk). Mar. 1963;39:3-8. [pmid: 13932339].
420 Mansvelt B, Arrigo E, Passelecq E, et al. Minimal intestinal preparation before colectomy for cancer. Experience of 189 cases. Annales de chirurgie. 1992;46(7):592-5. [pmid: 1456688].
421 Mao YL, Lu X. Bowel preparation before colorectal surgery: from intestinal mucosal barrier. Zhongguo yi xue ke xue yuan xue bao Acta Academiae Medicinae Sinicae. Oct. 2004;26(5):591-4. [pmid: 15562779].
422 Marino BM, Drago GW, Rossi R, et al. Endoscopic resolutions of volvulus of the sigmoid colon. Minerva chirurgica. Apr. 15. 1990;45(7):463-7. [pmid: 2370958].
423 Marojevic I, Miletic D, Atanasijevic G, et al. Single-layer anastomosis of the colon. Acta chirurgica Iugoslavica. 1994;41(2 Suppl 2):257-9. [pmid: 8693862].
424 Marshak AM, Nurov AU. Antibacterial preoperative preparation of the large intestine. Vestnik khirurgii imeni I I Grekova. Mar. 1969;102(3):66-8. [pmid: 4982612].
425 Marti MC. Preparation of the colon: a rapid method. Zeitschrift fur Krankenpflege Revue suisse des infirmieres. Aug. 1976;69(8-9):240-1. [pmid: 1051200].
426 Marti MC, Bordiogoni P. Results of a fast colic preparation. Helvetica chirurgica acta. May. 1978;45(1-2):89-92. [pmid: 659253].
427 Marti MC, Pouret JP. Rapid colon preparation. Chirurgie; memoires de l'Academie de chirurgie. May. 1976;102(5):330-4. [pmid: 954530].
428 Masek J, Apetaurova B. Our experience with rapid preparation of the large intestine for surgery. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. 1980;59(9):629-34. [pmid: 7256439].
429 Mendes da Costa P, Klastersky J, Gerard A. Controlled study of oral administration of antibiotics in the preparation of digestive surgery (author's transl). Acta chirurgica Belgica. Sep-Oct. 1977;76(5):475-80. [pmid: 919994].
430 Messmer P, Thoni F, Ackermann C, et al. Perioperative morbidity and mortality of colon resection in colonic carcinoma. Schweizerische medizinische Wochenschrift. Jun. 27. 1992;122(26):1011-4. [pmid: 1626249].
431 Messmer P, Thoni F, Ackermann C, et al. Perioperative morbidity and mortality in colon resection for colon cancer. Helvetica chirurgica acta. Sep. 1993;60(1-2):105-9. [pmid: 8226035].
432 Micheau P, Grolleau JL. Incisional hernia. Patient management. Approach to the future operated patients. Annales de chirurgie plastique et esthetique. Aug. 1999;44(4):325-38. [pmid: 10550913].
433 Milanov NO, Pugaev AV, Achkasov EE, et al. Extended, combined, and concurrent surgery in patients with neoplastic obturation large bowel obstruction. Vestnik Rossiiskoi akademii meditsinskikh nauk / Rossiiskaia akademiia meditsinskikh nauk. 2008;(11):18-24. [pmid: 19140462].
434 Militsa NN, Toropov Iu D, Kozlov VB, et al. Strategies of treatment of acute obturative colonic ileus. Klinichna khirurhiia / Ministerstvo okhorony zdorov'ia Ukrainy, Naukove tovarystvo khirurhiv Ukrainy. Mar. 2002;(3):29-32. [pmid: 12024710].
435 Miron A, Giulea C, Gologan S, et al. Evaluation of efficacy of mechanical bowel preparation in colorectal surgery. Chirurgia (Bucur). Nov-Dec. 2008;103(6):651-8. [pmid: 19274909].
436 Montanari M, Violi V, De Bernardinis M, et al. Efficacy of a low-residue diet in the prevention of immuno-nutritional changes caused by the preparation of the colon for surgery. Chirurgia italiana. Feb. 1988;40(1):23-8. [pmid: 3359548].
437 Moreaux J, Horiot A. Colonic anastomoses: principles and early complications on the basis of a serie of 663 colectomies (author's transl). La Nouvelle presse medicale. Mar. 12. 1980;9(17):1211-3. [pmid: 6969883].
438 Nazarov LU, Agavelian AM, Akopian AS, et al. Loop colostomy in patients with cancer of the colon and rectum. Klinichna khirurhiia / Ministerstvo okhorony zdorov'ia Ukrainy, Naukove tovarystvo khirurhiv Ukrainy. 1992;(8):53-6. [pmid: 1287340].
439 Nazarov LU, Akopian AS, Agabelian AM, et al. The surgical treatment of patients with colonic cancer complicated by perifocal inflammation of the tissues. Klinichna khirurhiia / Ministerstvo okhorony zdorov'ia Ukrainy, Naukove tovarystvo khirurhiv Ukrainy. 1993;(2):32-4. [pmid: 10912064].
440 Neugebauer R. Surgical treatment of colon cancer. 4. Preoperative preparation of the colon. Aktuelle Probleme in Chirurgie und Orthopadie. 1979;(10):38-40. [pmid: 32789].
441 Nowak W. A prophylactic regimen for infections in colorectal surgery (author's transl). Zentralblatt fur Chirurgie. 1979;104(15):961-8. [pmid: 388929].
442 Nowak W, Erbe HJ. Wound infection prophylaxis in colonic and rectal surgery with metronidazole and neomycin--a prospective study. Zentralblatt fur Chirurgie. 1982;107(13):763-7. [pmid: 7136329].
443 Nurov AU, Viliavin GD. Preparation of patients for surgery on the large intestine. Khirurgiia (Mosk). Jan. 1973;49(1):91-6. [pmid: 4703299].
444 Olbert PJ, Baumann L, Hegele A, et al. Fast-track concepts in the perioperative management of patients undergoing radical cystectomy and urinary diversion: review of the literature and research results. Der Urologe Ausg A. Feb. 2009;48(2):137-42. [pmid: 19142627].
445 Ono S, Kato S, Tanaka T, et al. Preoperative oral antimicrobial bowel preparations in elective colorectal surgery. Nihon Geka Gakkai zasshi. Aug. 1990;91(8):972-9. [pmid: 2233670].
446 Ortega Bevia JM, Prada Lorenzo D, Baez Romero F, et al. Enteral nutrition as preparation for high-risk surgery. Revista espanola de las enfermedades del aparato digestivo. Oct. 1986;70(4):345-51. [pmid: 3097768].
447 Pacilli P, Confalonieri MA, Gandini A, et al. A rare cause of intestinal obstruction. Il Giornale di chirurgia. Oct. 1996;17(10):501-7. [pmid: 9044602].
448 Palade R, Vasile D, Roman H, et al. The advantage of preparing the colon with Fortrans for diagnostic explorations or surgical interventions. Chirurgia (Bucur). May-Jun. 1998;93(3):189-93. [pmid: 9755585].
449 Palese A, Clementi R, Busetti R. Variability of intestinal preparation in patients undergoing stomach, intestine, uterus surgery at 4 hospitals. Assistenza infermieristica e ricerca : AIR. Jan-Mar. 2003;22(1):13-8. [pmid: 12789834].
450 Pan ZZ, Wan DS, Ding PR, et al. Long-term result of low anterior resection with stapling devices for rectal cancer. Ai zheng = Aizheng. Chinese journal of cancer. Nov. 2004;23(11 Suppl):1508-11. [pmid: 15566668].
451 Perego P, Brivio F, Pulinetti B, et al. A new solution for orthograde intestinal lavage. Minerva medica. Sep. 22. 1984;75(36):2079-81. [pmid: 6483260].
452 Perov Iu A, Postolov PM, Popova IS. Changes in hemodynamics during preparation of proctologic patients for surgery using the intestinal lavage method. Khirurgiia (Mosk). Jul. 1987;(7):80-4. [pmid: 3657006].
453 Peters H. Large bowel preparation in colon surgery: elemental diet (author's transl). Langenbecks Archiv fur Chirurgie. Nov. 1978;347:591-2. [pmid: 732469].
454 Peters H, Langer S. Dietetic and antibiotic preparation in surgery of the large intestine. Infusionstherapie und klinische Ernahrung. Dec. 1976;3(6):361-4. [pmid: 1034623].
455 Petrozzi CA, Camps R. Surgical preparation of the colon: use of paromomycin sulfate and other chemotherapeutic agents. El Dia medico. Jun. 25. 1962;34:1099-102. [pmid: 14485989].
456 Pfeiffer M, Winkler R. Parenteral nutrition in surgery preparation in large intestinal diseases. Indication, procedure and results. Infusionstherapie und klinische Ernahrung. Jun. 1982;9(3):146-8. [pmid: 6809620].
457 Piardi T, Ferrari Bravo A, Giampaoli F, et al. Deferred elective colonic resection in complicated acute diverticulitis. Chirurgia italiana. Mar-Apr. 2003;55(2):153-60. [pmid: 12744088].
458 Picardi N. Optimal preparation of the colon for elective surgery. A personal proposal. Annali italiani di chirurgia. 1989;60(3):157-62. [pmid: 2694880].
459 Picardi N, Gulla G. Mechanical and antimicrobial preparation of the colon for resection operations. Modern aspects. Annali italiani di chirurgia. 1985;57(4):289-98. [pmid: 3837615].
460 Piccinelli D, Dagradi V, Lolli P, et al. Mechanical and chemotherapeutic preparation of the colon for surgical intervention. Chirurgia italiana. Apr. 1984;36(2):179-86. [pmid: 6441651].
461 Pichlmaier H. Preparation of intestines. Dtsch Med Wochenschr. Oct. 24. 1980;105(43):1488-90. [pmid: 7428652].
462 Pira L. Considerations on the pre- and peri-operative preparations in surgery of the colon. Minerva chirurgica. Aug. 31. 1989;44(15-16):1825-9. [pmid: 2682374].
463 Pisciotta M, Gulotta G, Profita G, et al. Synchronous carcinoma of the colorectum. Minerva chirurgica. Jun. 30. 1991;46(12):661-70. [pmid: 1961589].
464 Probst M, Ungeheuer E. Cancer surgery in advanced age. Zeitschrift fur Gerontologie. May-Jun. 1985;18(3):149-53. [pmid: 2412358].
465 Ragni F, Braga M, Balzano R, et al. Intestinal anastomosis with biodegradable ring. Minerva chirurgica. Nov. 1996;51(11):925-31. [pmid: 9072720].
466 Reinecke FW. Preoperative large intestine preparation with achromycin-neomycin. Bruns' Beitrage zur klinischen Chirurgie. Jun. 1958;196(4):459-63. [pmid: 13560933].
467 Ressetta G, Simeth C, Ziza F, et al. Colonic diverticulosis complicated with perforation. Analysis of several prognosis variables and criteria for emergency surgery. Annali italiani di chirurgia. Jan-Feb. 1998;69(1):63-70. discussion -1. [pmid: 11995040].
468 Ribichini P, Polacchini G, Fussi A, et al. Whole-gut irrigation: a new method for the surgical preparation of the colon. Minerva medica. Mar. 17. 1980;71(10):803-5. [pmid: 7360369].
469 Rodriguez-Cuellar E, Ruiz Lopez P, Romero Simo M, et al. Analysis of the quality of surgical treatment of colorectal cancer, in 2008. A national study. Cirugia espanola. Oct. 2010;88(4):238-46. [pmid: 20850713].
470 Rodriguez-Wong U, Cruz-Reyes JM, Santamaria-Aguirre JR, et al. Postobstetric rectovaginal fistula: surgical treatment using endorectal advancement flap. Cirugia y cirujanos. May-Jun. 2009;77(3):201-5. [pmid: 19671272].
471 Roher HD, Stahlknecht CD, Hesterberg R. Is the protective colostomy in left-sided resections of the colorectum necessary?. Langenbecks Archiv fur Chirurgie. 1985;367(1):21-6. [pmid: 3912640].
472 Roig JV, Garcia-Fadrique A, Salvador A, et al. Selective intestinal preparation in a multimodal rehabilitation program. Influence on preoperative comfort and the results after colorectal surgery. Cirugia espanola. Mar. 2011;89(3):167-74. [pmid: 21333970].
473 Rosato L, Mondini G, Serbelloni M, et al. Stapled versus hand sewn anastomosis in elective and emergency colorectal surgery. Il Giornale di chirurgia. May. 2006;27(5):199-204. [pmid: 16857108].
474 Roseau E. Surgery of the anal canal. 1. Preparation of patients. La Nouvelle presse medicale. Feb. 17. 1973;2(7):447-8. [pmid: 4688245].
475 Roseau E. Preparation for subsequent relocation of continuity during Hartmann surgery. La Nouvelle presse medicale. May. 21. 1977;6(21):1875-6. [pmid: 876833].
476 Rosen HR, Schiessel R. Anterior rectum resection. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Feb. 1996;67(2):99-109. [pmid: 8881205].
477 Rossi R, Cagliani P, Arienti E. Use of total isoperistaltic entero-lavage in surgery of the large intestine. Minerva chirurgica. Nov. 30. 1977;32(22):1393-9. [pmid: 556343].
478 Rothlin M, Rietschi G, Largiader F. Value of Hartmann's operation as an emergency intervention in sigmoid diverticulitis. Swiss surgery. Schweizer Chirurgie = Chirurgie suisse = Chirurgia svizzera. 1997;3(3):107-11. [pmid: 9264856].
479 Rubino T, Tagliaferri A, Bissi O. Total isoperistaltic lavage of the intestines with 20% mannitol in the preparation of the large intestine for surgical intervention. Minerva chirurgica. Nov. 15. 1983;38(21):1787-9. [pmid: 6422344].
480 Rudichenko VM, Lomonosov SP, Rudychenko VF, et al. An antibacterial sorptive preparation for preparing the large intestine for a surgical intervention. Klinichna khirurhiia / Ministerstvo okhorony zdorov'ia Ukrainy, Naukove tovarystvo khirurhiv Ukrainy. 1995;(3):28-9. [pmid: 9053221].
481 Rudin EP, Vorob'ev GI, Uskov AG. Preoperative preparation of patients with large-intestine fistulae. Khirurgiia (Mosk). Oct. 1982;(10):52-7. [pmid: 7176384].
482 Schiessel R. Whole-gut irrigation for large bowel preparation in colorectal surgery (author's transl). Langenbecks Archiv fur Chirurgie. Nov. 1978;347:587-90. [pmid: 732468].
483 Schiessel R, Starlinger M, Rotter M, et al. Whole gut irrigation for large bowel preparation (author's transl). Langenbecks Archiv fur Chirurgie. Apr. 7. 1978;344(4):265-9. [pmid: 306010].
484 Schneiders H, Haralambie E, Towfigh H, et al. Effectiveness of antibiotic premedication in colonic surgery. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jan. 1976;47(1):33-8. [pmid: 964056].
485 Schneiter R. Favorable surgical-clinical experiences with a new laxative acting on the large intestine. Schweizerische Rundschau fur Medizin Praxis = Revue suisse de medecine Praxis. Oct. 17. 1972;61(42):1311-2. [pmid: 4563624].
486 Schwenk W, Bohm B, Stock W. Perioperative treatment in elective colorectal resection in Germany. Zentralblatt fur Chirurgie. 1992;117(7):403-11. [pmid: 1414051].
487 Schwenk W, Hucke HP, Stock W. Postoperative complications of elective resection of the colon in diverticulitis. Dtsch Med Wochenschr. Jan. 10. 1992;117(2):41-5. [pmid: 1730200].
488 Scintu F, Deriu IP, Canu L, et al. Mechanical and antibiotic preparation and infections in colorectal surgery. Comparison of 2 methods of orthograde lavage. Minerva chirurgica. Aug. 1992;47(15-16):1287-92. [pmid: 1407630].
489 Seifert JK, Junginger T. Standards and controversies in preoperative bowel preparation. Zentralblatt fur Chirurgie. 1997;122(1):29-33. [pmid: 9133133].
490 Seifert JK, Walgenbach S, Junginger T. Orthograde intestinal irrigation or Fordtran solution for bowel preparation in elective colorectal surgery. Prospective outcome study. Langenbecks Archiv fur Chirurgie. 1995;380(6):327-32. [pmid: 8559001].
491 Serra Aracil X, Bombardo Junca J, Mora Lopez L, et al. Transanal endoscopic microsurgery (TEM). Current situation and future expectations. Cirugia espanola. Sep. 2006;80(3):123-32. [pmid: 16956547].
492 Shishkin VP. Preoperative preparation and postoperative care in rectal cancer. Meditsinskaia sestra. Feb. 1955;2:21-4. [pmid: 14383065].
493 Sitkovskii NB, Kaplan VM, Dan'shin TI, et al. Surgical treatment of recurrent and acquired fistulae of the rectum and urogenital system in children. Vestnik khirurgii imeni I I Grekova. Dec. 1985;135(12):85-90. [pmid: 3914135].
494 Slim K, Panis Y, Chipponi J. Mechanical colonic preparation for surgery or how surgeons fight the wrong battle. Gastroenterologie clinique et biologique. Aug-Sep. 2002;26(8-9):667-9. [pmid: 12434065].
495 Slim K, Valleur P. How to clean the colon before colorectal surgery?. Annales de chirurgie. Jul. 2003;128(6):385-7. [pmid: 12943835].
496 Smirnova VI, Nikitin AM, Lapina TA, et al. Correction of water-electrolyte disorders in preparation of patients for surgery of the colon. Khirurgiia (Mosk). Oct. 1976;(10):98-101. [pmid: 1022952].
497 Starosel'skii IV, Lisetskii VA, Kaban AP, et al. Prevention of postoperative complications in the surgical treatment of cancer of the lung, esophagus, stomach, large intestine and the rectum in patients over 60 years old. Voprosy onkologii. 1991;37(7-8):873-7. [pmid: 1842647].
498 Stella M, Pulcini M, Angelici A, et al. Intestinal preparation for endoscopic examination and colorectal surgery. Annali italiani di chirurgia. 1984;56(4):381-93. [pmid: 6537728].
499 Stelzner F. Bowel preparation for surgery of the anus, rectum and colon. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jan. 1993;64(1):48-52. [pmid: 8436049].
500 Stock W, Hirt HJ, Schaal KP, et al. Preoperative reduction of intestinal bacteria through orthograde lavage of the large intestine. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Mar. 1977;48(3):161-5. [pmid: 844389].
501 Stoppa R, Warlaumont C, Verhaeghe P, et al. Clinical trial of Cefacidal in preparing the colon for surgery. Medecine & chirurgie digestives. 1981;10(3):267-71. [pmid: 7022045].
502 Taat CW, Boissevain AC, van Coevorden F, et al. Orthograde intestinal lavage as preoperative intestinal preparation in elective colorectal surgery. Nederlands tijdschrift voor geneeskunde. Sep. 5. 1981;125(36):1456-60. [pmid: 7279032].
503 Tan ZJ, Gu C, Zhang GL, et al. Application of transanal ileus tube followed by laparoscopic surgery for malignant colorectal obstruction. Zhonghua wai ke za zhi. Chinese journal of surgery. Jun. 1. 2011;49(6):522-5. [pmid: 21914302].
504 Tataru N, Romedea SN. The effect of preoperative preparation of the patient with rectal cancer on postoperative course. Revista medico-chirurgicala a Societatii de Medici si Naturalisti din Iasi. Jan-Mar. 2010;114(1):129-34. [pmid: 20509289].
505 Tesauro B. Current methods of preparation of the large intestine for resection operations and methods of monolayer suturing. Minerva chirurgica. Feb. 28. 1982;37(4):223-8. [pmid: 7045722].
506 Thorsen G. Colon irrigation as a preparation for coloscopy or colorectal surgery. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Feb. 20. 1980;100(5):287-9. [pmid: 7385154].
507 Tocchi A, Lepre L, Costa G, et al. Preoperative bowel cleansing: outpatient versus inpatient preparation. Il Giornale di chirurgia. Nov-Dec. 1998;19(11-12):463-5. [pmid: 9882950].
508 Tokov P, Viiachki I. Preoperative preparation of the large intestine and rectum for planned surgical interventions. Khirurgiia. 1987;40(6):41-8. [pmid: 3325690].
509 Torres Panuncia B, Rodriguez Fernandez Z, Pina Prieto LR. Results of preoperative preparation with mannitol in colorectal surgery. January-December 1995. Revista cubana de enfermeria. May-Aug. 1998;14(2):107-11. [pmid: 9934233].
510 Totikov VZ, Khestanov AK, Zuraev KE, et al. Surgical treatment of obturation obstruction of the colon. Khirurgiia (Mosk). 2001;(8):51-4. [pmid: 11552532].
511 Towfigh H, Haralambie E, Eigler FW, et al. Results of enteral antibiotic preparation prior to colon surgery. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Aug. 1978;49(8):496-500. [pmid: 688827].
512 Ungeheuer E, Becker H, Probst M. Preoperative preparation in colorectal surgery: antibiotics (author's transl). Langenbecks Archiv fur Chirurgie. Nov. 1978;347:583-6. [pmid: 732467].
513 Vacher B, Rodary M, Hay JM, et al. Colorectal preparation for excision surgery. Development after 4 randomized multicenter studies. Chirurgie; memoires de l'Academie de chirurgie. 1990;116(4-5):409-14. [pmid: 2128929].
514 Vannocci C. A sulfamide associated with formaldehyde in the preoperative preparation of the patient with infections of the large intestine. Minerva chirurgica. Nov. 1. 1951;6(21):649-53. [pmid: 14919141].
515 Vazquez Valdes E, Barradas Guevara MC, Tajonar Salazar OE. Preparation of the colon for closure of colostomy. Revista de gastroenterologia de Mexico. Jan-Mar. 1985;50(1):47-50. [pmid: 4089442].
516 Vila Carbo JJ, Garcia-Sala C, Gutierrez C, et al. Whole gut irrigation in pediatric patients: a comparative study. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jan. 1992;5(1):3-11. [pmid: 1567745].
517 Vitebskii Ia D, Ivanov GG, Matveenko ME, et al. Specific preoperative preparation of patients and technic for surgical interventions on the large intestine. Klinichna khirurhiia / Ministerstvo okhorony zdorov'ia Ukrainy, Naukove tovarystvo khirurhiv Ukrainy. Feb. 1981;(2):16-9. [pmid: 7218675].
518 Voinchet O, Guivarch M, Reveillard C. Polyethylene glycol for peroral preparation of the colon to endoscopy and surgery (author's transl). Gastroenterologie clinique et biologique. May. 1982;6(5):443-7. [pmid: 7095354].
519 Vorob'ev GI, Akopian AS, Korneva TK, et al. Preparation of the large intestine for surgery by the method of lavage of the gastrointestinal tract. Khirurgiia (Mosk). Sep. 1985;(9):44-9. [pmid: 4057884].
520 Vorob'ev GI, Zikas VS, Paval'kis DK. Preparation of patients with double-channel and marginal colostomies for restorative treatment. Khirurgiia (Mosk). Mar. 1991;(3):93-5. [pmid: 1861399].
521 Vorob'ev GI, Zikas VS, Paval'kis DK, et al. The removal of colostomies in patients with cancer of the large intestine. Voprosy onkologii. 1991;37(3):340-5. [pmid: 2031330].
522 Waldner H, Hallfeldt K, Siebeck M. Perioperative standards for prevention of anastomotic insufficiency. Zentralblatt fur Chirurgie. 1997;122(1):25-8. [pmid: 9133132].
523 Wang S, Qi Q. Influence of pre-operational medicated dachengqi granule on inflammatory mediator in tumor patients. Zhongguo Zhong xi yi jie he za zhi Zhongguo Zhongxiyi jiehe zazhi. Chinese journal of integrated traditional and Western medicine. Zhongguo Zhong xi yi jie he xue hui, Zhongguo Zhong yi yan jiu yuan zhu ban. Jun. 1999;19(6):337-9. [pmid: 11783197].
524 Wang S, Wang ML, Li Y, et al. Clinical study on risk factor associated with gut flora change in patients with rectal cancer during perioperative period. Zhonghua wei chang wai ke za zhi. Chinese journal of gastrointestinal surgery. Jun. 2012;15(6):570-3. [pmid: 22736124].
525 Widmaier U, Karrer M, Schoenberg MH. “Fast-track” and elective, laparoscopic colo-rectal surgery. Zentralblatt fur Chirurgie. Aug. 2007;132(4):342-8. discussion 8-9. [pmid: 17724638].
526 Wiig JN, Erichsen HG. Whole gut irrigation as preparation for colonic surgery. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Jan. 10. 1983;103(1):13-5. [pmid: 6845289].
527 Wolters U, Keller HW, Schlesinger A, et al. Preoperative intestinal lavage with a polyethyleneglycol-containing solution. A prospective randomized study in comparison with Ringer's lactate solution. Zentralblatt fur Chirurgie. 1992;117(7):412-6. [pmid: 1414052].
528 Wu YJ, Wu CT, Zhang XB, et al. Clinical study of different bowel preparations on changes of gut flora in patients undergoing colorectal resection. Zhonghua wei chang wai ke za zhi. Chinese journal of gastrointestinal surgery. Jun. 2012;15(6):574-7. [pmid: 22736125].
529 Xia Y, Yang Z, Chen HQ, et al. Effect of bowel preparation with probiotics on intestinal barrier after surgery for colorectal cancer. Zhonghua wei chang wai ke za zhi. Chinese journal of gastrointestinal surgery. Jul. 2010;13(7):528-31. [pmid: 20658369].
530 Yamada K, Hase S, Yoshimura A, et al. Studies on 5-FU concentration and thymidine phosphorylase activity in tissues of patients with colorectal cancer after SF-SP administration. Gan to kagaku ryoho Cancer & chemotherapy. Dec. 1990;17(12):2333-7. [pmid: 2260869].
531 Yao HW, Liu YH. Advantage and disadvantage of preoperative bowel preparation before colorectal surgery. Zhonghua wei chang wai ke za zhi. Chinese journal of gastrointestinal surgery. Jun. 2012;15(6):537-9. [pmid: 22736115].
532 Yaramov N, Sokolov M, Angelov K, et al. Obstructive syndrome caused by primary colon-rectal cancer. Khirurgiia. 2009;(4-5):5-9. [pmid: 20506797].
533 Yaramov N, Viyachki I, Viyachki D, et al. Primary colorectal carcinoma as an underlying cause of obturation of the ileum. Khirurgiia. 1999;55(3):24-7. [pmid: 11194665].
534 Ye X, Yang F. One-day bowel cleaning for colorectal surgery. Zhonghua hu li za zhi. Chinese journal of nursing. May. 1997;32(5):254-6. [pmid: 9304981].
535 Young Tabusso F, Celis Zapata J, Berrospi Espinoza F, et al. Mechanical preparation in elective colorectal surgery, a usual practice or a necessity?. Revista de gastroenterologia del Peru : organo oficial de la Sociedad de Gastroenterologia del Peru. Apr-Jun. 2002;22(2):152-8. [pmid: 12098743].
536 Zaharie F, Mocan L, Tomus C, et al. Risk factors for anastomotic leakage following colorectal resection for cancer. Chirurgia (Bucur). Jan-Feb. 2012;107(1):27-32. [pmid: 22480112].
537 Zhao YQ, Tong WH, Wang Q. Fast-track colorectal surgery. World Chinese Journal of Digestology. 2011;19(19):2048-52. PMID:.
538 Zhu D, Chen X, Wu J, et al. Effect of perioperative intestinal probiotics on intestinal flora and immune function in patients with colorectal cancer. Nan fang yi ke da xue xue bao. Journal of Southern Medical University. Aug. 2012;32(8):1190-3. [pmid: 22931620].
539 Zimmerli W, Girardet G, Nassiopoulos K, et al. Personal experience with preventive use of antibiotics in elective colon surgery. A retrospective study. Helvetica chirurgica acta. Sep. 1993;60(1-2):71-3. [pmid: 8226087].
540 Zubarev PN, Ignatovich IG, Sinenchenko GI. Procedures for the surgical treatment of cancer of the distal portions of the large intestine. Vestnik khirurgii imeni I I Grekova. 1998;157(5):20-2. [pmid: 9915052].
541 Aarts MA, Okrainec A, Glicksman A, et al. Adoption of enhanced recovery after surgery (ERAS) strategies for colorectal surgery at academic teaching hospitals and impact on total length of hospital stay. Surgical endoscopy. Feb. 2012;26(2):442-50. [pmid: 22011937].
542 Abraham N. 111 ERAS colorectal resections for cancer with a median stay of 5 days. The era of fast track colorectal cancer surgery. Colorectal Disease. 2011;13:41. PMID:.
543 Abrao MS. Surgical management of deep infiltrating endometriosis. International Journal of Gynecology and Obstetrics. 2012;119:S161. PMID:.
544 Bertani E, Chiappa A, Biffi R, et al. Low anterior resection of the rectum for cancer without mechanical bowel preparation. Early results from a single-centre, randomized clinical trial. European Surgery - Acta Chirurgica Austriaca. 2011;43:5. PMID:.
545 Bretagnol F, Panis Y, Rullier E, et al. Rectal cancer surgery without bowel preparation. The French Greccar III multicentre single-blinded randomized trial. Colorectal Disease. 2010;12:1. PMID:.
546 Buchs NC, Pugin F, Volonte F, et al. Robotic transanal endoscopic microsurgery: Technical details for the lateral approach. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S313. PMID:.
547 Ciga M, Oteiza F, Fernandez-Rico L, et al. Comparative study of one stage left colectomy in emergency and elective surgery without mechanical preparation. Diseases of the colon and rectum. 2010;53(4):560. PMID:.
548 Collin A, Folkesson J, Jung B, et al. Does mechanical bowel preparation preceding colonic cancer surgery affect 5 year mortality and cancer recurrence?. Colorectal Disease. 2012;14:1. PMID:.
549 Collin A, Folkesson J, Jung B, et al. Does mechanical bowel preparation preceding colon cancer operation affect 5-year mortality and cancer recurrence rate?. Diseases of the colon and rectum. 2013;56(4):e91-e2. PMID:.
550 El-Badawi K, Asgeirsson T, Mascarenhas C, et al. Mechanical bowel preparation with oral antibiotics: Is it superior?. Diseases of the colon and rectum. 2010;53(4):559-60. PMID:.
551 Emir S, Kavlakoglu B, Yazar F. Mechanical bowel preparation before colorectal surgery: Is it necessary?. European Surgical Research. 2013;50(2):243-4. PMID:.
552 Foo FJ, Dibnah M, Thompson S, et al. The enhanced recovery programme in colorectal surgery: What do patients think?. Colorectal Disease. 2012;14:19. PMID:. [pmid: 23136820].
553 Fridman A, Larson SB, Kumar S, et al. Application of a fast track protocol for colorectal surgery in a community hospital. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S279. PMID:.
554 Garcia-Fadrique A, Roig JV, Salvador A, et al. Influence of mechanical bowel preparation in the preoperative comfort and postsurgical results after colorectal surgery. Colorectal Disease. 2010;12:36. PMID:.
555 Garcia-Fadrique A, Roig JV, Salvador A, et al. Influence of mechanical bowel preparation in the preoperative comfort and postsurgical results after colorectal surgery. Colorectal Disease. [serial on the Internet]. 2010:12. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/471/CN-00783471/frame.html. Last accessed.
556 Ishibashi N, Takahashi K, Kibe S, et al. Increase of perioperative oral energy and protein intake with shortening of perioperative fasting time, affects rate of surgical site infection after open colon surgery. Clinical Nutrition, Supplement. 2012;7(1):68. PMID:.
557 Jain N. Excision of rectovaginal nodule. Journal of minimally invasive gynecology. 2011;18(6):S40. PMID:.
558 Kahokehr A, Robertson P, Srinivasa S, et al. Peri-operative care: A survey of New Zealand and Australian colorectal surgeons. Colorectal Disease. 2011;13:10. PMID:. [pmid: 21284796].
559 Karl A, Buchner A, Becker A, et al. Fast track concept in patients undergoing radical cystectomy for bladder cancer-results of a prospective mono-centre study. Journal of Urology. 2013;189(4):e210. PMID:.
560 Karl A, Buchner A, Weninger E, et al. A simple fast track regimen for patients undergoing radical cystectomy for bladder cancer. Journal of Urology. 2012;187(4):e215-e6. PMID:.
561 Kim EK, Bonn J, DeRoo S, et al. The role of mechanical bowel preparation with non-absorbable oral antibiotics in improving surgical outcomes in elective colectomy within a state-wide collaborative. Journal of Surgical Research. 2013;179(2). PMID:.
562 Kim JG. Early experience of two port laparoscopic colectomy as a preparation phase for single-port surgery. Techniques in coloproctology. 2011;15(2):247-8. PMID:.
563 Kwak JM, Kim SH, Kim J, et al. Mechanical bowel preparation can affect the clinical outcomes of anastomotic leakage in rectal cancer surgery. Colorectal Disease. 2012;14:10. PMID:.
564 Lai CW, Challand C, Minto GW, et al. Mechanical bowel preparation and fasting may influence aerobic capacity in cardiopulmonary exercise testing. Colorectal Disease. 2011;13:46. PMID:.
565 Luchtefeld M, Kubus J, Senagore A, et al. Practice variations in the performance of segmental colectomy: A state-wide audit. Diseases of the colon and rectum. 2010;53(4):687-8. PMID:.
566 Maley P, Verma A, Won HR, et al. Surgical and patient outcomes using mechanical bowel preparation before laparoscopic gynecological procedures in the posterior compartment: A single blinded randomized controlled trial. Journal of minimally invasive gynecology. 2010;17(6):S151. PMID:.
567 Mari G, Costanzi A, Maggioni A, et al. Fast track vs conventional care in laparoscopic left hemicolectomy. A pilot prospective randomized study. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S2. PMID:.
568 McNally F. Overcoming challenges when developing an Enhanced Recovery Programme and a review of results achieved 1 year on. Colorectal Disease. 2012;14:10. PMID:.
569 No JH, Kim JS, Lim CH, et al. Preoperative colonoscopy through the colonic stent in patients of colon cancer obstruction. Gastrointestinal endoscopy. 2012;75(4):AB413. PMID:.
570 Nygren J, Gustafsson U. Diverting stoma did not improve outcome in 289 consecutive patients undergoing low anterior resection for rectal cancer within an ERAS program. Colorectal Disease. 2011;13:68. PMID:.
571 Ozdemir S, Ozis E, Gulpinar K, et al. Effects of preoperative mechanic bowel preparation with oral antibiotics over the incidence of postoperative wound infection. Diseases of the colon and rectum. 2010;53(4):703-4. PMID:.
572 Parakkal D, Devi R, Sifuentes H, et al. Bowel preparation for colonic argon plasma coagulation therapy: Results of a survey of ACG members and literature review. American Journal of Gastroenterology. 2011;106:S544-S5. PMID:.
573 Pittet O, Nocito A, Balke H, et al. Full mechanical bowel preparation is not necessary for primary rectal cancer surgery. Swiss medical weekly. 2012;142:17S. PMID:.
574 Pittet O, Nocito A, Duvoisin C, et al. Full mechanical bowel preparation is not necessary for primary rectal cancer surgery. Colorectal Disease. 2012;14:56. PMID:. [pmid: 21176063].
575 Saar M, Kamradt J, Ohlmann CH, et al. Fast-track program for robotic-assisted laparoscopic cystectomy-improvement of postoperative recovery?. European Urology, Supplements. 2012;11(1):e715-ea. PMID:.
576 Scabini S, Rimini E, Romairone E, et al. Colon and rectal surgery for cancer without mechanical bowel preparation: One-center randomized prospective trial. World journal of surgical oncology. 2010:8. PMID:. [pmid: 20137082].
577 Scott NB. Enhanced recovery after surgery- the way forward. Regional anesthesia and pain medicine. 2012;37(5):E128-E31. PMID:.
578 Sellahewa C, Sonsken J, Patel R. Significant reduction in hospital stay following introduction of laparoscopic colorectal surgery in a DGH. Colorectal Disease. 2010;12:23. PMID:.
579 Thomas E, Owen T, Johnson J, et al. Re-Audit of enhanced recovery procedures for adult patients undergoing elective colo-rectal surgery at Royal Preston Hospital (RPH). Anaesthesia. 2012;67:25. PMID:.
580 Villanueva-Herrero J, Alarcon-Bernes Y, Carreon G, et al. Endoscopic endorectal surgery with the endorec system and conventional laparoscopic instruments. Diseases of the colon and rectum. 2013;56(4):e218-e9. PMID:.
581 Warren SJ, Pratt R, Saeed BZ, et al. Enhanced recovery after laparoscopic and open colorectal surgery: Does protocol adherence drift with time?. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S73. PMID:.
582 Won H, Maley P, Stephanie S, et al. A single blind randomised controlled trial of surgical and patient outcomes using mechanical bowel preparation before laparoscopic gynaecological surgery. Journal of minimally invasive gynecology. 2012;19(6):S40. PMID:.
583 Zitta D, Subbotin V, Busirev Y. Early oral feeding and avoidance of mechanical bowel preparation in elective major colorectal surgery. Colorectal Disease. 2012;14:19. PMID:. [pmid: 23136820].
584 Acin-Gandara D, Rodriguez-Caravaca G, Duran-Poveda M, et al. Incidence of surgical site infection in colon surgery: comparison with regional, national spanish, and United States standards. Surgical infections. Aug. 2013;14(4):339-44. [pmid: 23859676].
585 Alcantara M, Serra X, Bombardo J, et al. Colorectal stenting as an effective therapy for preoperative and palliative treatment of large bowel obstruction: 9 years' experience. Techniques in coloproctology. Dec. 2007;11(4):316-22. [pmid: 18060531].
586 Ambrose NS, Johnson M, Burdon DW, et al. A physiological appraisal of polyethylene glycol and a balanced electrolyte solution as bowel preparation. The British journal of surgery. Jul. 1983;70(7):428-30. [pmid: 6871626].
587 Arabi Y, Dimock F, Burdon DW, et al. Influence of bowel preparation and antimicrobials on colonic microflora. The British journal of surgery. Aug. 1978;65(8):555-8. [pmid: 354736].
588 Arnspiger RC, Helling TS. An evaluation of results of colon anastomosis in prepared and unprepared bowel. Journal of clinical gastroenterology. Dec. 1988;10(6):638-41. [pmid: 3230279].
589 Baradnay G, Nagy A. Modern trends in colorectal surgery. Acta chirurgica Hungarica. 1983;24(4):195-206. [pmid: 6670427].
590 Barker P, Trotter T, Hanning C. A study of the effect of Picolax on body weight, cardiovascular variables and haemoglobin concentration. Annals of the Royal College of Surgeons of England. Sep. 1992;74(5):318-9. [pmid: 1416702].
591 Bretagnol F, Alves A, Ricci A, et al. Rectal cancer surgery without mechanical bowel preparation. The British journal of surgery. Oct. 2007;94(10):1266-71. [pmid: 17657719].
592 Buckland GH, Elbourne I, Crowe PJ. Gastrointestinal lavage reduces total body water. The Australian and New Zealand journal of surgery. Feb-Mar. 1997;67(2-3):123-5. [pmid: 9068554].
593 Burdon DW, Keighley MR, Alexander-Williams J. Prophylactic trials in colon surgery with special regard to bowel preparation. Aktuelle Probleme in Chirurgie und Orthopadie. 1981;19:97-100. [pmid: 6112930].
594 Canedo J, Ricciardi K, DaSilva G, et al. Are postoperative complications more common following colon and rectal surgery in patients with chronic kidney disease?. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Jan. 2013;15(1):85-90. [pmid: 22632259].
595 Chaleoykitti B. Comparative study between polyethylene glycol and sodium phosphate solution in elective colorectal surgery. Journal of the Medical Association of Thailand. Chotmaihet thangphaet. Jan. 2002;85(1):92-6. [pmid: 12075728].
596 Chen CF, Lin JK, Leu SY, et al. Evaluation of rapid colon preparation with Golytely. Zhonghua yi xue za zhi. Chinese medical journal; Free China ed. Jul. 1989;44(1):45-56. [pmid: 2819568].
597 Debo Adeyemi S, Tai da Rocha-Afodu J. Clinical studies of 4 methods of bowel preparation in colorectal surgery. European surgical research Europaische chirurgische Forschung Recherches chirurgicales europeennes. 1986;18(5):331-6. [pmid: 3093238].
598 DeGennaro VA, Corman ML, Coller JA, et al. Wound infections after colectomy. Diseases of the colon and rectum. Nov-Dec. 1978;21(8):567-72. [pmid: 738171].
599 Donato D, Angelides A, Irani H, et al. Infectious complications after gastrointestinal surgery in patients with ovarian carcinoma and malignant ascites. Gynecologic oncology. Jan. 1992;44(1):40-7. [pmid: 1730424].
600 Dutta HK. Clinical experience with a new modified transanal endorectal pull-through for Hirschsprung's disease. Pediatric surgery international. Jul. 2010;26(7):747-51. [pmid: 20532528].
601 Farha GJ, Beahm TM, Chang FC. Bowel preparations: a comparative study. The Journal of the Kansas Medical Society. Sep. 1979;80(9):490-3. 508. [pmid: 512447].
602 Farmer RG. Preoperative preparation of the patients with carcinoma of the colon. The Surgical clinics of North America. Dec. 1975;55(6):1335-41. [pmid: 1105833].
603 Fa-Si-Oen PR, Verwaest C, Buitenweg J, et al. Effect of mechanical bowel preparation with polyethyleneglycol on bacterial contamination and wound infection in patients undergoing elective open colon surgery. Clinical microbiology and infection : the official publication of the European Society of Clinical Microbiology and Infectious Diseases. Feb. 2005;11(2):158-60. [pmid: 15679494].
604 Gerritsen GP, Hendriks WD. The effects of bowel preparation for colon surgery on the colon microflora. The Netherlands journal of surgery. May. 1982;34(2):67-71. [pmid: 6896557].
605 Gervaz P, Bucher P, Scheiwiller A, et al. The duration of postoperative ileus after elective colectomy is correlated to surgical specialization. International journal of colorectal disease. Sep. 2006;21(6):542-6. [pmid: 16267669].
606 Hares MM, Nevah E, Minervini S, et al. An attempt to reduce the side effects of mannitol bowel preparation by intravenous infusion. Diseases of the colon and rectum. May-Jun. 1982;25(4):289-91. [pmid: 6806051].
607 Hartzenberg HB, McQuaide JR. Whole-gut irrigation as a preparation for colorectal surgery. South African medical journal. Suid-Afrikaanse tydskrif vir geneeskunde. Jul. 17. 1982;62(3):91-3. [pmid: 7089797].
608 Hay JM, Boussougant Y, Lacaine F, et al. Povidone-iodine enema as a preoperative bowel preparation for colorectal surgery. A bacteriologic study. Diseases of the colon and rectum. Jan. 1989;32(1):9-13. [pmid: 2910665].
609 Hay JM, Boussougant Y, Roverselli D, et al. The use of povidone-iodine enema as pre-operative preparation for colorectal surgery: bacteriological study. The Journal of hospital infection. Mar. Suppl A. 1985;6:115-6. [pmid: 2860154].
610 Herbst CA Jr., Schorlemmer G, Wild R. Patient acceptance and cleansing effectiveness of Golytely for colon surgery. North Carolina medical journal. Feb. 1989;50(2):63-6. [pmid: 2927514].
611 Hinchey EJ, Richards GK, Prentis J. Metronidazole as a prophylactic agent in wound infection after colon surgery. Surgery. Jan. 1983;93(1 Pt 2):197-200. [pmid: 6336863].
612 Ho S, Nambiar R. Whole bowel irrigation--an alternative to traditional bowel washout. Annals of the Academy of Medicine, Singapore. Oct. 1983;12(4):592-5. [pmid: 6678139].
613 Howard DD, White CQ, Harden TR, et al. Incidence of surgical site infections postcolorectal resections without preoperative mechanical or antibiotic bowel preparation. The American surgeon. Aug. 2009;75(8):659-63. discussion 63-4. [pmid: 19725287].
614 Huddy SP, Rayter Z, Webber PP, et al. Preparation of the bowel before elective surgery using a polyethylene glycol solution at home and in hospital compared with conventional preparation using magnesium sulphate. Journal of the Royal College of Surgeons of Edinburgh. Feb. 1990;35(1):16-20. [pmid: 2342002].
615 Johnson WC. Oral elemental diet: a new bowel preparation. Arch Surg. Jan. 1974;108(1):32-4. [pmid: 4859599].
616 Jottard KJ, van Berlo C, Jeuken L, et al. Changes in outcome during implementation of a fast-track colonic surgery project in a university-affiliated general teaching hospital: advantages reached with ERAS (Enhanced Recovery After Surgery project) over a 1-year period. Digestive surgery. 2008;25(5):335-8. [pmid: 18827488].
617 Jung B, Matthiessen P, Smedh K, et al. Mechanical bowel preparation does not affect the intramucosal bacterial colony count. International journal of colorectal disease. Apr. 2010;25(4):439-42. [pmid: 20012296].
618 Keighley MR, Taylor EW, Hares MM, et al. Influence of oral mannitol bowel preparation on colonic microflora and the risk of explosion during endoscopic diathermy. The British journal of surgery. Aug. 1981;68(8):554-6. [pmid: 6791730].
619 Kolovrat M, Busic Z, Lovric Z, et al. Mechanical bowel preparation in colorectal surgery. Collegium antropologicum. Dec. 2012;36(4):1343-6. [pmid: 23390831].
620 Leal AJG, Tannuri ACA, Tannuri U. Mechanical bowel preparation for esophagocoloplasty in children: Is it really necessary?. Diseases of the Esophagus. 2013;26(5):475-8. PMID:. [pmid: 22816994].
621 Lee EC, Roberts PL, Taranto R, et al. Inpatient vs. outpatient bowel preparation for elective colorectal surgery. Diseases of the colon and rectum. Apr. 1996;39(4):369-73. [pmid: 8878493].
622 Leys CM, Austin MT, Pietsch JB, et al. Elective intestinal operations in infants and children without mechanical bowel preparation: a pilot study. Journal of pediatric surgery. Jun. 2005;40(6):978-81. discussion 82. [pmid: 15991181].
623 Makela JT, Kiviniemi H, Laitinen S. Risk factors for anastomotic leakage after left-sided colorectal resection with rectal anastomosis. Diseases of the colon and rectum. May. 2003;46(5):653-60. [pmid: 12792443].
624 Marks CG, Ritchie JK, Todd IP, et al. Primary suture of the perineal wound following rectal excision for inflammatory bowel disease. The British journal of surgery. Aug. 1978;65(8):560-4. [pmid: 354737].
625 Memon MA, Devine J, Freeney J, et al. Is mechanical bowel preparation really necessary for elective left sided colon and rectal surgery?. International journal of colorectal disease. 1997;12(5):298-302. [pmid: 9401846].
626 Mileski WJ, Joehl RJ, Rege RV, et al. One-stage resection and anastomosis in the management of colovesical fistula. American journal of surgery. Jan. 1987;153(1):75-9. [pmid: 3799895].
627 Minervini S, Alexander-Williams J, Donovan IA, et al. Comparison of three methods of whole bowel irrigation. American journal of surgery. Sep. 1980;140(3):400-2. [pmid: 6775548].
628 Montanari M, Violi V, Roncoroni L, et al. Changes in nutritional and immunologic parameters after preparation for colonic surgery. Acta chirurgica Scandinavica. Aug-Sep. 1986;152:527-30. [pmid: 3788397].
629 Moronczyk DA, Krasnodebski IW. Implementation of the fast track surgery in patients undergoing the colonic resection: own experience. Polski przeglad chirurgiczny. Sep. 2011;83(9):482-7. [pmid: 22166736].
630 Morris DM, Rayburn D. Loop colostomies are totally diverting in adults. American journal of surgery. Jun. 1991;161(6):668-71. [pmid: 1862826].
631 Otchy DP, Crosby ME, Trickey AW. Colectomy without mechanical bowel preparation in the private practice setting. Techniques in coloproctology. 2013. Mar. 7. [pmid: 23467770].
632 Petrelli NJ, Conte CC, Herrera L, et al. A prospective, randomized trial of perioperative prophylactic cefamandole in elective colorectal surgery for malignancy. Diseases of the colon and rectum. Jun. 1988;31(6):427-9. [pmid: 3378465].
633 Phalen PT. Surgical Treatment of Diverticulitis of the Colon. Arizona medicine. Nov. 1963;20:244-6. [pmid: 14078896].
634 Philip RS. Efficacy of preoperative bowel preparation at home. The American surgeon. Apr. 1995;61(4):368-70. [pmid: 7893108].
635 Pitot D, Bouazza E, Chamlou R, et al. Elective colorectal surgery without bowel preparation: a historical control and case-matched study. Acta chirurgica Belgica. Jan-Feb. 2009;109(1):52-5. [pmid: 19341196].
636 Potter DD, Bruny JL, Allshouse MJ, et al. Laparoscopic suture rectopexy for full-thickness anorectal prolapse in children: an effective outpatient procedure. Journal of pediatric surgery. Oct. 2010;45(10):2103-7. [pmid: 20920740].
637 Raynor MC, Lavien G, Nielsen M, et al. Elimination of preoperative mechanical bowel preparation in patients undergoing cystectomy and urinary diversion. Urologic oncology. Jan. 2013;31(1):32-5. [pmid: 21719323].
638 Rickwood AM, Hemalatha V, Brooman P. Closure of colostomy in infants and children. The British journal of surgery. Apr. 1979;66(4):273-4. [pmid: 454997].
639 Serrurier K, Liu J, Breckler F, et al. A multicenter evaluation of the role of mechanical bowel preparation in pediatric colostomy takedown. Journal of pediatric surgery. Jan. 2012;47(1):190-3. [pmid: 22244415].
640 Shapira Z, Feldman L, Lavy R, et al. Bowel preparation: comparing metabolic and electrolyte changes when using sodium phosphate/polyethylene glycol. Int J Surg. 2010;8(5):356-8. [pmid: 20457286].
641 Sindell S, Causey MW, Bradley T, et al. Expediting return of bowel function after colorectal surgery. American journal of surgery. May. 2012;203(5):644-8. [pmid: 22459445].
642 Spinelli A, Bazzi P, Sacchi M, et al. Short-term outcomes of laparoscopy combined with enhanced recovery pathway after ileocecal resection for Crohn's disease: a case-matched analysis. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jan. 2013;17(1):126-32. discussion p 32. [pmid: 22948838].
643 Takada H, Ambrose NS, Galbraith K, et al. Quantitative appraisal of Picolax (sodium picosulfate/magnesium citrate) in the preparation of the large bowel for elective surgery. Diseases of the colon and rectum. Aug. 1990;33(8):679-83. [pmid: 2376224].
644 Todorov AT, Mantchev ID, Atanasov TB. Traditional bowel preparation versus osmotic agent mannitol for preoperative colonic cleansing in elective colorectal surgery. Folia medica. 2002;44(1-2):36-9. [pmid: 12422625].
645 van den Bogaard AE, Weidema W, Hazen MJ, et al. A bacteriological evaluation of three methods of bowel preparation for elective colorectal surgery. Antonie van Leeuwenhoek. Mar. 1981;47(1):86-8. [pmid: 7247394].
646 Veenhof AA, Sietses C, Giannakopoulos GF, et al. Preoperative polyethylene glycol versus a single enema in elective bowel surgery. Digestive surgery. 2007;24(1):54-7. discussion 7-8. [pmid: 17369682].
647 Verma GR, Pareek S, Singh R. Mechanical bowel preparation in elective colo-rectal surgery: a practice to purge or promote?. Indian journal of gastroenterology : official journal of the Indian Society of Gastroenterology. May-Jun. 2007;26(3):142-3. [pmid: 17704589].
648 Yakimets WW. Complications of closure of loop colostomy. Canadian journal of surgery Journal canadien de chirurgie. Jul. 1975;18(4):366-70. [pmid: 1097083].
649 Yura J, Kato F, Shibata K. Postoperative infections in colorectal surgery. International surgery. Jul-Aug. 1978;63(5):61-2. [pmid: 365819].
650 Zmora O, Lebedyev A, Hoffman A, et al. Laparoscopic colectomy without mechanical bowel preparation. International journal of colorectal disease. Oct. 2006;21(7):683-7. [pmid: 16231142].
651 Abel ME, Chiu YS, Russell TR, et al. Autologous fibrin glue in the treatment of rectovaginal and complex fistulas. Diseases of the colon and rectum. May. 1993;36(5):447-9. [pmid: 8482163].
652 Abraham-Nordling M, Hjern F, Pollack J, et al. Randomized clinical trial of fluid restriction in colorectal surgery. The British journal of surgery. Feb. 2012;99(2):186-91. [pmid: 21948211].
653 Abreu RA, Vaz FA, Laurino R, et al. Randomized clinical trial comparing spinal anesthesia with local anesthesia with sedation for loop colostomy closure. Arquivos de gastroenterologia. Jul-Sep. 2010;47(3):270-4. [pmid: 21140088].
654 Akasu T, Takawa M, Yamamoto S, et al. Risk factors for anastomotic leakage following intersphincteric resection for very low rectal adenocarcinoma. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jan. 2010;14(1):104-11. [pmid: 19841989].
655 Ambrose NS, Keighley MR. An aid to the assessment of bowel preparation prior to colonic resection. Annals of the Royal College of Surgeons of England. Jan. 1986;68(1):34-6. [pmid: 3947012].
656 Arango A, Lester JL 3rd, Martinez OV, et al. Bacteriologic and systemic effects of intraoperative segmental bowel preparation with povidone iodine. Arch Surg. Feb. 1979;114(2):154-7. [pmid: 426621].
657 Bacon HE, Lowell EJ Jr., Spaulding EH, et al. Evaluation of neomycin-phthalylsulfathiazole in preparation of the large bowel for surgery. AMA archives of surgery. Mar. 1954;68(3):344-9. [pmid: 13137692].
658 Badner N, Mocon A. Effect of Outpatient Bowel Preparation On Preoperative Electrolytes. Ambulatory Surgery. 2010;16(2):38-40. PMID:.
659 Banu T, Hannan MJ, Hoque M, et al. Anovestibular fistula with normal anus. Journal of pediatric surgery. Mar. 2008;43(3):526-9. [pmid: 18358294].
660 Barber MS, Hirschberg BC, Rice CL, et al. Parenteral antibiotics in elective colon surgery? A prospective, controlled clinical study. Surgery. Jul. 1979;86(1):23-9. [pmid: 377539].
661 Barnett JE, Endrey-Walder P, Pheils MT. Closure of colostomy. The Australian and New Zealand journal of surgery. May. 1976;46(2):131-3. [pmid: 1067069].
662 Bartlett JG, Condon RE, Gorbach SL, et al. Veterans Administration Cooperative Study on Bowel Preparation for Elective Colorectal Operations: impact of oral antibiotic regimen on colonic flora, wound irrigation cultures and bacteriology of septic complications. Annals of surgery. Aug. 1978;188(2):249-54. [pmid: 686893].
663 Basse L, Madsen JL, Billesbolle P, et al. Gastrointestinal transit after laparoscopic versus open colonic resection. Surgical endoscopy. Dec. 2003;17(12):1919-22. [pmid: 14574544].
664 Becker JM, Alexander DP. Colectomy, mucosal proctectomy, and ileal pouch-anal anastomosis. A prospective trial of optimal antibiotic management. Annals of surgery. Mar. 1991;213(3):242-7. [pmid: 1847796].
665 Bellantone R, Pacelli F, Sofo L, et al. Systemic perioperative prophylaxis in elective oncological colorectal surgery: cefotetan versus clindamicin plus aztreonam. Drugs under experimental and clinical research. 1988;14(12):763-6. [pmid: 3150952].
666 Bernardi C, Pescatori M. Reconstructive perineoplasty in the management of non-healing wounds after anorectal surgery. Techniques in coloproctology. Apr. 2001;5(1):27-32. [pmid: 11793257].
667 Blair JE, McLeod RS, Cohen Z, et al. Ticarcillin/clavulanic acid (Timentin) compared to metronidazole/netilmicin in preventing postoperative infection after elective colorectal surgery. Canadian journal of surgery Journal canadien de chirurgie. Mar. 1987;30(2):120-2. [pmid: 3548930].
668 Bowden TA Jr., DiPiro JT, Michael KA. Polyethylene glycol electrolyte lavage solution (PEG-ELS). A rapid, safe mechanical bowel preparation for colorectal surgery. The American surgeon. Jan. 1987;53(1):34-6. [pmid: 3800162].
669 Brass C, Richards GK, Ruedy J, et al. The effect of metronidazole on the incidence of postoperative wound infection in elective colon surgery. American journal of surgery. Jan. 1978;135(1):91-6. [pmid: 341733].
670 Brau SA. Video endoscopic surgery in the community hospital. Surgical laparoscopy & endoscopy. Jun. 1994;4(3):222-4. [pmid: 8044367].
671 Brosnahan J. Intravenous fluid replacement minimised dehydration during sodium picosulphate bowel preparation for colonic surgery. Evidence-based nursing. Jul. 2002;5(3):85. [pmid: 12123269].
672 Buess G, Kipfmuller K, Naruhn M, et al. Endoscopic microsurgery of rectal tumors. Endoscopy. Nov. Suppl 1. 1987;19:38-42. [pmid: 3428240].
673 Cabasares HV, Schoffstall RO. Low complication rate of colostomy closures. Southern medical journal. Dec. 1980;73(12):1572-5. [pmid: 7444545].
674 Campbell JR, Webber BR, Harrison MW, et al. Esophageal replacement in infants and children bv colon interposition. American journal of surgery. Jul. 1982;144(1):29-34. [pmid: 7091527].
675 Cintron JR, Abcarian H, Chaudhry V, et al. Treatment of fistula-in-ano using a porcine small intestinal submucosa anal fistula plug. Techniques in coloproctology. Apr. 2013;17(2):187-91. [pmid: 23053440].
676 Clarke JS, Condon RE, Bartlett JG, et al. Preoperative oral antibiotics reduce septic complications of colon operations: results of prospective, randomized, double-blind clinical study. Annals of surgery. Sep. 1977;186(3):251-9. [pmid: 889372].
677 Cleary RK, Grossmann R, Fernandez FB, et al. Metronidazole may inhibit intestinal colonization with Clostridium difficile. Diseases of the colon and rectum. Apr. 1998;41(4):464-7. [pmid: 9559631].
678 Cohn I Jr., Longacre AB. Tetracycline (achromycin)- neomycin for preoperative colon preparation. AMA archives of surgery. Mar. 1956;72(3):371-6. [pmid: 13291958].
679 Cohn I Jr., Longacre AB. Chlorquinaldol (sterosan) and chlorquinaldolneomycin for preoperative preparations of the colon. Gastroenterology. May. 1957;32(5):855-60. [pmid: 13438143].
680 Condon RE, Bartlett JG, Nichols RL, et al. Preoperative prophylactic cephalothin fails to control septic complications of colorectal operations: results of controlled clinical trial. A Veterans Administration cooperative study. American journal of surgery. Jan. 1979;137(1):68-74. [pmid: 365009].
681 Coppa GF, Eng K. Factors involved in antibiotic selection in elective colon and rectal surgery. Surgery. Nov. 1988;104(5):853-8. [pmid: 3055394].
682 Crapp AR, Tillotson P, Powis SJ, et al. Preparation of the bowel by whole-gut irrigation. Lancet. Dec. 20. 1975;2(7947):1239-40. [pmid: 53726].
683 Dowle CS, Beasley SW, Isbister WH. The EEA stapler in colorectal surgery: a Wellington experience. The Australian and New Zealand journal of surgery. Apr. 1983;53(2):121-3. [pmid: 6576756].
684 Downing R, Dorricott NJ, Keighley MR, et al. Whole gut irrigation: a survey of patient opinion. The British journal of surgery. Mar. 1979;66(3):201-2. [pmid: 154935].
685 Downing TP, Bennion RS, Sadeghi AM. Effect of preoperative colon preparation on serum potassium. The American surgeon. Aug. 1983;49(8):414-6. [pmid: 6614662].
686 Duncan ND, Plummer J, Dundas SE, et al. Adult Hirschsprung's disease in Jamaica: operative treatment and outcome. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Apr. 2011;13(4):454-8. [pmid: 20041921].
687 Eckhauser ML, Imbembo AL, Mansour EG. The role of pre-resectional laser recanalization for obstructing carcinomas of the colon and rectum. Surgery. Oct. 1989;106(4):710-6. discussion 6-7. [pmid: 2799646].
688 Engum SA, Carter ME, Murphy D, et al. Home bowel preparation for elective colonic procedures in children: cost savings with quality assurance and improvement. Journal of pediatric surgery. Feb. 2000;35(2):232-4. [pmid: 10693671].
689 Evans MD, Barton K, Pritchard GA, et al. Plasma magnesium should be monitored perioperatively in patients undergoing colorectal resection. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Jul. 2009;11(6):613-8. [pmid: 18624818].
690 Eykyn SJ. The therapeutic use of metronidazole in anaerobic infection: six years' experience in a London hospital. Surgery. Jan. 1983;93(1 Pt 2):209-14. [pmid: 6849207].
691 Eykyn SJ, Jackson BT, Lockhart-Mummery HE, et al. Prophylactic peroperative intravenous metronidazole in elective colorectal surgery. Lancet. Oct. 13. 1979;2(8146):761-4. [pmid: 90859].
692 Fan YB, Cheng YS, Chen NW, et al. Clinical application of self-expanding metallic stent in the management of acute left-sided colorectal malignant obstruction. World journal of gastroenterology : WJG. Feb. 7. 2006;12(5):755-9. [pmid: 16521189].
693 Fernandez de Bustos A, Creus Costas G, Pujol Gebelli J, et al. Per os early nutrition for colorectal pathology susceptible of laparoscopy-assisted surgery. Nutricion hospitalaria : organo oficial de la Sociedad Espanola de Nutricion Parenteral y Enteral. Mar-Apr. 2006;21(2):173-8. [pmid: 16734069].
694 Finco C, Magnanini P, Sarzo G, et al. Prospective randomized study on perioperative enteral immunonutrition in laparoscopic colorectal surgery. Surgical endoscopy. Jul. 2007;21(7):1175-9. [pmid: 17356942].
695 Fingerhut A, Hay JM. Single-dose ceftriaxone, ornidazole, and povidone-iodine enema in elective left colectomy. A randomized multicenter controlled trial. The French Association for Surgical Research. Arch Surg. Feb. 1993;128(2):228-32. [pmid: 8431124].
696 Forshaw MJ, Sankararajah D, Stewart M, et al. Self-expanding metallic stents in the treatment of benign colorectal disease: indications and outcomes. Colorectal disease: the official journal of the Association of Coloproctology of Great Britain and Ireland. Feb. 2006;8(2):102-11. [pmid: 16412069].
697 Freiha FS. Preoperative bowel preparation in urologic surgery. The Journal of urology. Dec. 1977;118(6):955-6. [pmid: 926273].
698 Fujita S, Saito N, Yamada T, et al. Randomized, multicenter trial of antibiotic prophylaxis in elective colorectal surgery: single dose vs 3 doses of a second-generation cephalosporin without metronidazole and oral antibiotics. Arch Surg. Jul. 2007;142(7):657-61. [pmid: 17638804].
699 Furukawa K, Onda M, Suzuki H, et al. The usefulness of conducting investigations on intra-abdominal bacterial contamination in digestive tract operations. Surgery today. 1999;29(8):701-6. [pmid: 10483742].
700 Galandiuk S, Fazio VW. Postoperative irrigation-suction drainage after pelvic colonic surgery. A prospective randomized trial. Diseases of the colon and rectum. Mar. 1991;34(3):223-8. [pmid: 1999128].
701 Geisler DJ, Reilly JC, Vaughan SG, et al. Safety and outcome of use of nonabsorbable mesh for repair of fascial defects in the presence of open bowel. Diseases of the colon and rectum. Aug. 2003;46(8):1118-23. [pmid: 12907910].
702 Gilat T, Ben Hur H, Gelman-Malachi E, et al. Alterations of the colonic flora and their effect on the hydrogen breath test. Gut. Jul. 1978;19(7):602-5. [pmid: 680594].
703 Glotzer DJ, Boyle PL, Silen W. Preoperative preparation of the colon with an elemental diet. Surgery. Nov. 1973;74(5):703-7. [pmid: 4200512].
704 Goldring J, McNaught W, Scott A, et al. Prophylactic oral antimicrobial agents in elective colonic surgery. A controlled trial. Lancet. Nov. 22. 1975;2(7943):997-1000. [pmid: 53548].
705 Golematis BC, Delikaris PG, Haritopoulos NK, et al. Current thoughts on the surgical treatment of rectal cancer. The American journal of gastroenterology. Jan. 1976;65(1):68-73. [pmid: 1274932].
706 Gordon HE, Gaylor DW, Richmond DM, et al. Operations on the colon. The role of antibiotics in preoperative preparation. California medicine. Oct. 1965;103(4):243-6. [pmid: 5318351].
707 Goriainov V, Miles AJ. Anastomotic leak rate and outcome for laparoscopic intra-corporeal stapled anastomosis. Journal of minimal access surgery. Apr. 2008;4(2):39-43. [pmid: 19547680].
708 Goriainov V, Miles AJ. Anastomotic leak rate and outcome for laparoscopic intra-corporeal stapled anastomosis. Journal of minimal access surgery. Jan. 2010;6(1):6-10. [pmid: 20585487].
709 Gottrup F, Diederich P, Sorensen K, et al. Prophylaxis with whole gut irrigation and antimicrobials in colorectal surgery. A prospective, randomized double-blind clinical trial. American journal of surgery. Mar. 1985;149(3):317-22. [pmid: 3883822].
710 Grace RH. The role of Picolax before whole gut irrigation in the preparation of the colon for large bowel surgery. Annals of the Royal College of Surgeons of England. Sep. 1988;70(5):322-3. [pmid: 3190131].
711 Griffith CD, Hardcastle JD. Intraoperative testing of anastomotic integrity after stapled anterior resection for cancer. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1990;35(2):106-8. [pmid: 2355372].
712 Guzman-Valdivia G, Guerrero TS, Laurrabaquio HV. Parastomal hernia-repair using mesh and an open technique. World journal of surgery. Mar. 2008;32(3):465-70. [pmid: 18080706].
713 Haggman M, Brandstedt S, Norlen BJ. Rectal perforation after retropubic radical prostatectomy: occurrence and management. European urology. 1996;29(3):337-40. [pmid: 8740020].
714 Hakansson T, Raahave D, Hansen OH, et al. Effectiveness of single dose prophylaxis with cefotaxime and metronidazole compared with three doses of cefotaxime alone in elective colorectal surgery. The European journal of surgery. Acta chirurgica. Mar. 1993;159(3):177-80. [pmid: 8102894].
715 Hall C, Curran F, Burdon DW, et al. A randomized trial to compare amoxycillin/clavulanate with metronidazole plus gentamicin in prophylaxis in elective colorectal surgery. The Journal of antimicrobial chemotherapy. Nov. Suppl B. 1989;24:195-202. [pmid: 2691480].
716 Harder F, Vogelbach P. Single-layer end-on continuous suture of colonic anastomoses. American journal of surgery. Apr. 1988;155(4):611-4. [pmid: 3281497].
717 Heald RJ. Towards fewer colostomies--the impact of circular stapling devices on the surgery of rectal cancer in a district hospital. The British journal of surgery. Mar. 1980;67(3):198-200. [pmid: 7362961].
718 Hendry PO, Balfour A, Potter MA, et al. Preoperative conditioning with oral carbohydrate loading and oral nutritional supplements can be combined with mechanical bowel preparation prior to elective colorectal resection. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Nov. 2008;10(9):907-10. [pmid: 18294261].
719 Henry MM, Everett WG. Loop colostomy closure. The British journal of surgery. Apr. 1979;66(4):275-7. [pmid: 454998].
720 Herter FP, Slanetz CA Jr. Influence of antibiotic preparation of the bowel on complications after colon resection. American journal of surgery. Feb. 1967;113(2):165-72. [pmid: 6016714].
721 Herter FP, Slanetz CA Jr. Preoperative intestinal preparation in relation to the subsequent development of cancer at the suture line. Surgery, gynecology & obstetrics. Jul. 1968;127(1):49-56. [pmid: 5657781].
722 Hewitt J, Reeve J, Rigby J, et al. Whole-gut irrigation in preparation for large-bowel surgery. Lancet. Aug. 18. 1973;2(7825):337-40. [pmid: 4124525].
723 Hida K, Yamaguchi T, Hata H, et al. Risk factors for complications after laparoscopic surgery in colorectal cancer patients: experience of 401 cases at a single institution. World journal of surgery. Aug. 2009;33(8):1733-40. [pmid: 19506946].
724 Hill AG, Teo W, Still A, et al. Cellular potassium depletion predisposes to hypokalaemia after oral sodium phosphate. The Australian and New Zealand journal of surgery. Dec. 1998;68(12):856-8. [pmid: 9885868].
725 Hirsch JE, Campbell FB, Campbell JG. Preoperative antibiotic and mechanical preparation of the colon. Diseases of the colon and rectum. Nov-Dec. 1959;2:562-4. [pmid: 14401976].
726 Hoffmann CE, McDonald PJ, Watts JM. Use of peroperative cefoxitin to prevent infection after colonic and rectal surgery. Annals of surgery. Mar. 1981;193(3):353-6. [pmid: 7011223].
727 Hojer H, Brote L, Nystrom PO, et al. Systemic prophylaxis in colorectal surgery a comparison between tinidazole and doxycycline. Scandinavian journal of infectious diseases Supplementum. 1981;26:75-8. [pmid: 6941460].
728 Houghton GW. The use of gentamicin for preoperative preparation of the large bowel. The Medical journal of Australia. May. 11. 1968;1(19):796-9. [pmid: 4872366].
729 Hulbert J, Blair DW. One-day kanamycin regime for pre-operative bowel preparation. Postgraduate medical journal. May. 1967;(Suppl):27-36. [pmid: 6042977].
730 Hunt PS, Francis JK, Peck G, et al. Tinidazole in the prevention of wound infection after elective colorectal surgery. The Medical journal of Australia. Feb. 24. 1979;1(4):107-9. [pmid: 372777].
731 Iancu C, Mocan LC, Todea-Iancu D, et al. Host-related predictive factors for anastomotic leakage following large bowel resections for colorectal cancer. Journal of gastrointestinal and liver diseases : JGLD. Sep. 2008;17(3):299-303. [pmid: 18836623].
732 Irvin GL 3rd, Robinson DS, Hubbard S. Operative risks in patients with colorectal cancer. The American surgeon. Jul. 1985;51(7):418-22. [pmid: 4014884].
733 Irvin TT, Hayter CJ, Warren KE, et al. The effect of intestinal preparation on fluid and electrolyte balance. The British journal of surgery. Jun. 1973;60(6):484-8. [pmid: 4715179].
734 Ishibashi K, Ishida H, Kuwabara K, et al. Short-term intravenous antimicrobial prophylaxis for elective rectal cancer surgery: results of a prospective randomized non-inferiority trial. Surgery today. 2013. Aug. 29. [pmid: 23989910].
735 Ishibashi K, Kumamoto K, Kuwabara K, et al. Usefulness of sennoside as an agent for mechanical bowel preparation prior to elective colon cancer surgery. Asian journal of surgery / Asian Surgical Association. Apr. 2012;35(2):81-7. [pmid: 22720863].
736 Ishida H, Yokoyama M, Nakada H, et al. Impact of oral antimicrobial prophylaxis on surgical site infection and methicillin-resistant Staphylococcus aureus infection after elective colorectal surgery. Results of a prospective randomized trial. Surgery today. 2001;31(11):979-83. [pmid: 11766085].
737 Jagelman DG, Fazio VW, Lavery IC, et al. A prospective, randomized, double-blind study of 10% mannitol mechanical bowel preparation combined with oral neomycin and short-term, perioperative, intravenous Flagyl as prophylaxis in elective colorectal resections. Surgery. Nov. 1985;98(5):861-5. [pmid: 3933134].
738 Jagelman DG, Fazio VW, Lavery IC, et al. A prospective randomized study of prophylactic mannitol (10%)-neomycin-cefotaxime therapy in patients undergoing elective colonic and rectal surgery. Clinical therapeutics. Suppl A. 1982;5:32-7. [pmid: 6293716].
739 Jagelman DG, Fazio VW, Lavery IC, et al. Single-dose piperacillin versus cefoxitin combined with 10 percent mannitol bowel preparation as prophylaxis in elective colorectal operations. American journal of surgery. Nov. 1987;154(5):478-81. [pmid: 3118725].
740 Jewesson P, Chow A, Wai A, et al. A double-blind, randomized study of three antimicrobial regimens in the prevention of infections after elective colorectal surgery. Diagnostic microbiology and infectious disease. Nov. 1997;29(3):155-65. [pmid: 9401808].
741 Johnston DW. Restoration of gastrointestinal continuity (Pauchet's operation). Canadian journal of surgery Journal canadien de chirurgie. Jan. 1979;22(1):90-2. [pmid: 445244].
742 Judd ES. Preoperative neomycin-tetracycline preparation of the colon for elective operations. The Surgical clinics of North America. Dec. 1975;55(6):1325-30. [pmid: 1105831].
743 Junghans T, Neuss H, Strohauer M, et al. Hypovolemia after traditional preoperative care in patients undergoing colonic surgery is underrepresented in conventional hemodynamic monitoring. International journal of colorectal disease. Oct. 2006;21(7):693-7. [pmid: 16331465].
744 Juul P, Merrild U, Kronborg O. Topical ampicillin in addition to a systemic antibiotic prophylaxis in elective colorectal surgery. A prospective randomized study. Diseases of the colon and rectum. Nov. 1985;28(11):804-6. [pmid: 3902413].
745 Kang SG, Jung GS, Cho SG, et al. The efficacy of metallic stent placement in the treatment of colorectal obstruction. Korean journal of radiology : official journal of the Korean Radiological Society. Apr-Jun. 2002;3(2):79-86. [pmid: 12087197].
746 Kaska M, Grosmanova T, Havel E, et al. The impact and safety of preoperative oral or intravenous carbohydrate administration versus fasting in colorectal surgery--a randomized controlled trial. Wiener klinische Wochenschrift. Jan. 2010;122(1-2):23-30. [pmid: 20177856].
747 Katz R, Borkowski T, Hoznek A, et al. Operative management of rectal injuries during laparoscopic radical prostatectomy. Urology. Aug. 2003;62(2):310-3. [pmid: 12893341].
748 Khan O, Nixon HH. Metronidazole prophylaxis for elective large bowel surgery in children: a prospective trial. The British journal of surgery. Nov. 1978;65(11):804-7. [pmid: 363217].
749 Kiely EM. Bowel preparation in children using magnesium sulphate. South African journal of surgery Suid-Afrikaanse tydskrif vir chirurgie. Mar. 1980;18(1):19-22. [pmid: 7384952].
750 Kingsley AN. Post traumatic anal incontinence. The Nebraska medical journal. Dec. 1990;75(12):321-3. [pmid: 2277654].
751 Kjellgren K, Sellstrom H. Effect of prophylactic systemic administration of cephalothin in colorectal surgery. Acta chirurgica Scandinavica. 1977;143(7-8):473-7. [pmid: 345708].
752 Kling PA, Dahlgren S. Oral prophylaxis with neomycin and erythromycin in colorectal surgery. More proof for efficacy than failure. Arch Surg. Jun. 1989;124(6):705-7. [pmid: 2658918].
753 Kuijper CF, Aronson DC. Anterior or posterior sagittal anorectoplasty without colostomy for low-type anorectal malformation: how to get a better outcome?. Journal of pediatric surgery. Jul. 2010;45(7):1505-8. [pmid: 20638533].
754 Kujath P, Dusel W, Bruch HP, et al. The pharmacokinetic properties of cefotetan and its relevance for prophylaxis in elective colorectal surgery. Chemioterapia : international journal of the Mediterranean Society of Chemotherapy. Aug. 1988;7(4):229-32. [pmid: 3180301].
755 Lau WY, Chu KW, Poon GP, et al. Prophylactic antibiotics in elective colorectal surgery. The British journal of surgery. Aug. 1988;75(8):782-5. [pmid: 3167527].
756 Leandoer L, Ekelund G, Genell S, et al. Antibiotic prophylaxis in colorectal surgery. doxycycline compared to a combination of benzylpenicillin and streptomycin. A preliminary report. Scandinavian journal of infectious diseases Supplementum. 1976;(9):106-8. [pmid: 795007].
757 Lee JM, Tam PK, Saing H. Whole-gut irrigation in infants and young children. Diseases of the colon and rectum. Apr. 1986;29(4):252-4. [pmid: 3948616].
758 Leo WA, Von Riesen VL, Roberts GG, et al. Twenty-four hour preparation of the large bowel for surgery using neomycin-sulfathalidine or neomycin-oxytetracycline: a comparative evaluation. Annals of surgery. Mar. 1958;147(3):359-65. [pmid: 13509583].
759 Lewis RT, Goodall RG, Marien B, et al. Is neomycin necessary for bowel preparation in surgery of the colon? Oral neomycin plus erythromycin versus erythromycin-metronidazole. Canadian journal of surgery Journal canadien de chirurgie. Jul. 1989;32(4):265-70. [pmid: 2660973].
760 Lykkegaard Nielsen M, Scheibel JH, Wamberg T. Septic complications in colo-rectal surgery after 24 hours versus 60 hours of preoperative antibiotic bowel preparation. I. Prospective, randomized, double-blind clinical study. Acta chirurgica Scandinavica. 1978;144(7-8):523-6. [pmid: 371318].
761 MacFarlane SD, Ryan JA Jr. Prevention of wound infection after elective colorectal resection. American journal of surgery. Nov. 1987;154(5):482-6. [pmid: 3674295].
762 Maralcan G, Baskonus I, Aybasti N, et al. The use of fibrin glue in the treatment of fistula-in-ano: a prospective study. Surgery today. 2006;36(2):166-70. [pmid: 16440165].
763 Matheson NA, Valerio D, Farquharson A, et al. Single-layer anastomosis in the large bowel: ten years' experience. Journal of the Royal Society of Medicine. Jan. 1981;74(1):44-8. [pmid: 7007639].
764 Mazier WP, Senagore AJ, Schiesel EC. Operative repair of anovaginal and rectovaginal fistulas. Diseases of the colon and rectum. Jan. 1995;38(1):4-6. [pmid: 7813343].
765 Mehigan BJ, Monson JR, Hartley JE. Stapling procedure for haemorrhoids versus Milligan-Morgan haemorrhoidectomy: randomised controlled trial. Lancet. Mar. 4. 2000;355(9206):782-5. [pmid: 10711925].
766 Mehigan D, Zuidema GD, Cameron JL. The role of systemic antibiotics in operations upon the colon. Surgery, gynecology & obstetrics. Oct. 1981;153(4):573-6. [pmid: 7280947].
767 Menaker GJ, Litvak S, Bendix R, et al. Operations on the colon without preoperative oral antibiotic therapy. Surgery, gynecology & obstetrics. Jan. 1981;152(1):36-8. [pmid: 7455888].
768 Menon P, Rao KL. Primary anorectoplasty in females with common anorectal malformations without colostomy. Journal of pediatric surgery. Jun. 2007;42(6):1103-6. [pmid: 17560229].
769 Meyer KA, Kozoll DD. Preparation for surgery of patients with colon lesions. Q Bull Northwest Univ Med Sch. 1945;19(4):249-58. [pmid: 21004070].
770 Nessim A, Wexner SD, Agachan F, et al. Is bowel confinement necessary after anorectal reconstructive surgery? A prospective, randomized, surgeon-blinded trial. Diseases of the colon and rectum. Jan. 1999;42(1):16-23. [pmid: 10211515].
771 Nezhat C, Nezhat F, Ambroze W, et al. Laparoscopic repair of small bowel and colon. A report of 26 cases. Surgical endoscopy. Mar-Apr. 1993;7(2):88-9. [pmid: 8456375].
772 Nichols RL, Broido P, Condon RE, et al. Effect of preoperative neomycin-erythromycin intestinal preparation on the incidence of infectious complications following colon surgery. Annals of surgery. Oct. 1973;178(4):453-62. [pmid: 4743867].
773 Nmadu PT. Complications of colostomy closure in Zaria, Nigeria: a report of 70 cases. The Central African journal of medicine. Nov. 1990;36(11):287-91. [pmid: 2092883].
774 Ohigashi S, Sudo K, Kobayashi D, et al. Significant changes in the intestinal environment after surgery in patients with colorectal cancer. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Sep. 2013;17(9):1657-64. [pmid: 23807702].
775 O'Rourke JS, Johnson A, Collins P, et al. An association between hypocholesterolaemia and colorectal carcinoma in an Irish population. Gut. Jul. 1992;33(7):950-3. [pmid: 1644336].
776 Page CP, Carlton PK Jr., Becker DW. Closure of the pelvic and perineal wounds after removal of the rectum and anus. Diseases of the colon and rectum. Jan-Feb. 1980;23(1):2-9. [pmid: 7379646].
777 Parker MC, Ashby EC, Nicholls MW, et al. Povidone-iodine bowel irrigation before resection of colorectal carcinoma. Annals of the Royal College of Surgeons of England. Jul. 1985;67(4):227-8. [pmid: 4037631].
778 Pello MJ, Beauregard W, Shaikh K, et al. Colon operations without wound infection. Principles and techniques in 101 cases. The American surgeon. Jul. 1984;50(7):362-5. [pmid: 6430140].
779 Pereira RM, Zanatta A, de Mello Bianchi PH, et al. Transvaginal ultrasound after bowel preparation to assist surgical planning for bowel endometriosis resection. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. Feb. 2009;104(2):161. [pmid: 19081567].
780 Perko Z, Druzijanic N, Bilan K, et al. Laparoscopic colon surgery: our results. Collegium antropologicum. Mar. 2008;32(1):187-91. [pmid: 18494203].
781 Petrelli N, Rosenfield L, Herrera L, et al. The morbidity of perineal wounds following abdominoperineal resection for rectal carcinoma. Journal of surgical oncology. Jul. 1986;32(3):138-40. [pmid: 3736049].
782 Piessen G, Muscari F, Rivkine E, et al. Prevalence of and risk factors for morbidity after elective left colectomy: cancer vs noncomplicated diverticular disease. Arch Surg. Oct. 2011;146(10):1149-55. [pmid: 22006873].
783 Playforth MJ, Smith GM, Evans M, et al. Antimicrobial bowel preparation. Oral, parenteral, or both?. Diseases of the colon and rectum. Feb. 1988;31(2):90-3. [pmid: 3276469].
784 Plumley PF. A simple regime for preparation of colon before large-bowel surgery. The British journal of surgery. May. 1966;53(5):413-4. [pmid: 4952337].
785 Pollock AV, Arnot RS, Leaper DJ, et al. The role of antibacterial preparation of the intestine in the reduction of primary wound sepsis after operations on the colon and rectum. Surgery, gynecology & obstetrics. Dec. 1978;147(6):909-12. [pmid: 581421].
786 Pollock AV, Evans M. Antimicrobial preparation of the colon. The New England journal of medicine. Oct. 30. 1980;303(18):1066. [pmid: 7421908].
787 Portnoy J, Kagan E, Gordon PH, et al. Prophylactic antibiotics in elective colorectal surgery. Diseases of the colon and rectum. May. 1983;26(5):310-13. [pmid: 6360591].
788 Raahave D, Hesselfeldt P, Pedersen T, et al. No effect of topical ampicillin prophylaxis in elective operations of the colon or rectum. Surgery, gynecology & obstetrics. Feb. 1989;168(2):112-4. [pmid: 2643188].
789 Ramadan E, Vishne T, Dreznik Z. Harmonic scalpel hemorrhoidectomy: preliminary results of a new alternative method. Techniques in coloproctology. Sep. 2002;6(2):89-92. [pmid: 12402052].
790 Rehm CG, Talucci RC, Ross SE. Colostomy in trauma surgery: friend or foe?. Injury. Oct. 1993;24(9):595-6. [pmid: 8288377].
791 Reines HD, Reines MO, Abrams JS. Use of standard colon preparation in elective colectomy for carcinoma of the colon. Review of surgery. Nov-Dec. 1977;34(6):432-4. [pmid: 918536].
792 Rietz KA, Ahlman B, Lahnborg G. A simple regimen for control of postoperative sepsis in colorectal surgery. Diseases of the colon and rectum. Aug. 1984;27(8):519-22. [pmid: 6468186].
793 Rosenberg IL, Graham NG, De Dombal FT, et al. Preparation of the intestine in patients undergoing major large-bowel surgery, mainly for neoplasms of the colon and rectum. The British journal of surgery. Apr. 1971;58(4):266-9. [pmid: 5108232].
794 Rosenberg IL, Graham NG, Dombal FT, et al. The relative significance of preoperative mechanical bowel preparation, phthalylsulphathiazole, and neomycin in the avoidance of sepsis after radical large-bowel surgery. The British journal of surgery. May. 1970;57(5):389. [pmid: 5468111].
795 Rouzrokh M, Khaleghnejad AT, Mohejerzadeh L, et al. What is the most common complication after one-stage transanal pull-through in infants with Hirschsprung's disease?. Pediatric surgery international. Oct. 2010;26(10):967-70. [pmid: 20632018].
796 Rumley TO, Lineaweaver WC, Davis JM. Low residue nutritional supplementation as an adjunct to mechanical preparation for surgical treatment of the colon. Surgery, gynecology & obstetrics. Apr. 1987;164(4):345-50. [pmid: 3563847].
797 Sakanoue Y, Kusunoki M, Shoji Y, et al. The efficacy of whole gut irrigation with polyethylene glycol electrolyte solution in elective colorectal surgery for cancer. Acta chirurgica Scandinavica. Jun-Jul. 1990;156(6-7):463-6. [pmid: 2368551].
798 Salvati EP, Rubin RJ, Eisenstat TE, et al. Value of subcutaneous and intraperitoneal antibiotics in reducing infection in clean contaminated operations of the colon. Surgery, gynecology & obstetrics. Oct. 1988;167(4):315-8. [pmid: 3420506].
799 Sanders G, Arthur CH, Hosie KB, et al. Is patient outcome affected by the administration of intravenous fluid during bowel preparation for colonic surgery?. Annals of the Royal College of Surgeons of England. Jul. 2007;89(5):487-9. [pmid: 17688720].
800 Sanders G, Mercer SJ, Saeb-Parsey K, et al. Randomized clinical trial of intravenous fluid replacement during bowel preparation for surgery. The British journal of surgery. Oct. 2001;88(10):1363-5. [pmid: 11578293].
801 Santoro E, Agresta F, Veltri S, et al. Minilaparoscopic colorectal resection: a preliminary experience and an outcomes comparison with classical laparoscopic colon procedures. Surgical endoscopy. May. 2008;22(5):1248-54. [pmid: 17943359].
802 Sasaki K, Kazama S, Sunami E, et al. One-stage segmental colectomy and primary anastomosis after intraoperative colonic irrigation and total colonoscopy for patients with obstruction due to left-sided colorectal cancer. Diseases of the colon and rectum. Jan. 2012;55(1):72-8. [pmid: 22156870].
803 Scharli AF, Sossai R. Hypoganglionosis. Seminars in pediatric surgery. Aug. 1998;7(3):187-91. [pmid: 9718658].
804 Scheibel JH, Lykkegaard Nielsen M, Wamberg T. Septic complications in colo-rectal surgery after 24 hours versus 60 hours of preoperative antibiotic bowel preparation. II. Significance of bacterial concentrations in the bowel for contamination of the operation field and subsequent wound infection. Acta chirurgica Scandinavica. 1978;144(7-8):527-32. [pmid: 371319].
805 Schiessel R, Huk I, Starlinger M, et al. Postoperative infections in colonic surgery after enteral bacitracin-neomycin-clindamycin or parenteral mezlocillin-oxacillin prophylaxis. The Journal of hospital infection. Sep. 1984;5(3):289-97. [pmid: 6208248].
806 Schoetz DJ Jr., Roberts PL, Murray JJ, et al. Addition of parenteral cefoxitin to regimen of oral antibiotics for elective colorectal operations. A randomized prospective study. Annals of surgery. Aug. 1990;212(2):209-12. [pmid: 2100983].
807 Schwarz M, Isenmann R, Weikert E, et al. Pharmacokinetic basis for oral perioperative prophylaxis with ofloxacin in general surgery. Infection. Aug. 2001;29(4):222-7. [pmid: 11545485].
808 Seifart W. Technique and results using the glass-rectoscope for tumour resection. Endoscopic surgery and allied technologies. Oct. 1994;2(5):265-8. [pmid: 7866760].
809 Sellwood RA, Burn JI, Waterworth PM, et al. A second clinical trial to compare two methods for preoperative preparation of the large bowel. The British journal of surgery. Aug. 1969;56(8):610-2. [pmid: 4894615].
810 Senocak ME, Buyukpamukcu N, Hicsonmez A. Whole bowel irrigation in children: prolonged post-irrigation diarrhea due to isotonic saline. The Turkish journal of pediatrics. Jul-Sep. 1990;32(3):197-200. [pmid: 2093255].
811 Sentovich SM. Fibrin glue for anal fistulas: long-term results. Diseases of the colon and rectum. Apr. 2003;46(4):498-502. [pmid: 12682544].
812 Sharma S, Gupta DK. Delayed presentation of anorectal malformation for definitive surgery. Pediatric surgery international. Aug. 2012;28(8):831-4. [pmid: 22828918].
813 Smith MB, Goradia VK, Holmes JW, et al. Suppression of the human mucosal-related colonic microflora with prophylactic parenteral and/or oral antibiotics. World journal of surgery. Sep-Oct. 1990;14(5):636-41. [pmid: 2238665].
814 Srinivasa S, Taylor MH, Singh PP, et al. Randomized clinical trial of goal-directed fluid therapy within an enhanced recovery protocol for elective colectomy. The British journal of surgery. Jan. 2013;100(1):66-74. [pmid: 23132508].
815 Suzuki T, Sadahiro S, Maeda Y, et al. Optimal duration of prophylactic antibiotic administration for elective colon cancer surgery: A randomized, clinical trial. Surgery. Feb. 2011;149(2):171-8. [pmid: 20655559].
816 Szabo LE, Csikos F, Helembai L, et al. Metronidazole in the chemoprophylaxis of colon and rectum operations. Acta chirurgica Academiae Scientiarum Hungaricae. 1982;23(3):135-43. [pmid: 7170876].
817 Takesue Y, Yokoyama T, Akagi S, et al. A brief course of colon preparation with oral antibiotics. Surgery today. 2000;30(2):112-6. [pmid: 10664331].
818 Tannuri AC, Tannuri U, Romao RL. Transanal endorectal pull-through in children with Hirschsprung's disease--technical refinements and comparison of results with the Duhamel procedure. Journal of pediatric surgery. Apr. 2009;44(4):767-72. [pmid: 19361638].
819 Tartter PI. Preoperative lymphocyte subsets and infectious complications after colorectal cancer surgery. Surgery. Feb. 1988;103(2):226-30. [pmid: 3257590].
820 Tartter PI, Quintero S, Barron DM. Perioperative blood transfusion associated with infectious complications after colorectal cancer operations. American journal of surgery. Nov. 1986;152(5):479-82. [pmid: 3777324].
821 Taylor EW, Lindsay G. Selective decontamination of the colon before elective colorectal surgery. West of Scotland Surgical Infection Study Group. World journal of surgery. Nov-Dec. 1994;18(6):926-31. discussion 31-2. [pmid: 7846921].
822 Taylor SA, Cawdery HM. The use of metronidazole in the preparation of the bowel for surgery. Proceedings of the Royal Society of Medicine. Jul. 1977;70(7):481-2. [pmid: 578314].
823 Taylor SA, Cawdery HM, Smith J. The use of metronidazole in the preparation of the bowel for surgery. The British journal of surgery. Mar. 1979;66(3):191-2. [pmid: 371742].
824 Tran KT, Kuijpers HC, van Nieuwenhoven EJ, et al. Transposition of the rectus abdominis muscle for complicated pouch and rectal fistulas. Diseases of the colon and rectum. Apr. 1999;42(4):486-9. [pmid: 10215049].
825 Trollope ML, Cohen RG, Lee RH, et al. A 7 year experience with low anterior sigmoid resections using the EEA stapler. American journal of surgery. Jul. 1986;152(1):11-5. [pmid: 3728802].
826 Tsimoyiannis EC, Paizis JB, Kabbani K, et al. Short-term antibiotic prophylaxis in elective colorectal surgery. Chemotherapy. 1991;37(1):66-9. [pmid: 2013244].
827 Tuggle DW, Hoelzer DJ, Tunell WP, et al. The safety and cost-effectiveness of polyethylene glycol electrolyte solution bowel preparation in infants and children. Journal of pediatric surgery. Jun. 1987;22(6):513-5. [pmid: 3112357].
828 Ulrich C. 24-hour systemic antibiotic prophylaxis in large-bowel surgery. The Netherlands journal of surgery. Mar. 1981;33(1):3-9. [pmid: 7015174].
829 Vallance S, Jones B, Arabi Y, et al. Importance of adding neomycin to metronidazole for bowel preparation. Journal of the Royal Society of Medicine. Apr. 1980;73(4):238-40. [pmid: 7017122].
830 Vergnes D, Moatti N, Monrozies X, et al. Pre-operative colonic preparation using kanamycin and metronidazole: qualitative and quantitative effects on the bacterial flora of the intestine. The Journal of antimicrobial chemotherapy. Nov. 1980;6(6):709-16. [pmid: 7440463].
831 Vignali A, Fazio VW, Lavery IC, et al. Factors associated with the occurrence of leaks in stapled rectal anastomoses: a review of 1,014 patients. Journal of the American College of Surgeons. Aug. 1997;185(2):105-13. [pmid: 9249076].
832 Vila JJ, Gutierrez C, Garcia-Sala C, et al. Whole bowel irrigation: experience in pediatric patients. Journal of pediatric surgery. May. 1987;22(5):447-50. [pmid: 3585669].
833 Weidema WF, van den Boogaard AE, Wesdorp RI, et al. 24-hour systemic antimicrobial prophylaxis with gentamicin and metronidazole, or metronidazole alone, in elective colorectal surgery after mechanical bowel preparation with mannitol and whole gut irrigation. Acta chirurgica Belgica. Nov-Dec. 1985;85(6):349-53. [pmid: 3937403].
834 Wren SM, Ahmed N, Jamal A, et al. Preoperative oral antibiotics in colorectal surgery increase the rate of Clostridium difficile colitis. Arch Surg. Aug. 2005;140(8):752-6. [pmid: 16103284].
835 Yabata E, Okabe S, Endo M. A prospective, randomized clinical trial of preoperative bowel preparation for elective colorectal surgery--comparison among oral, systemic, and intraoperative luminal antibacterial preparations. Journal of medical and dental sciences. Dec. 1997;44(4):75-80. [pmid: 12160204].
836 Yeom CH, Cho MM, Baek SK, et al. Risk Factors for the Development of Clostridium difficile-associated Colitis after Colorectal Cancer Surgery. Journal of the Korean Society of Coloproctology. Oct. 2010;26(5):329-33. [pmid: 21152135].