# Search Strategy

The following search strategy was utilized in PubMed (September 6, 2013):

(((surgic* OR surgery OR surgeri* OR operativ* OR operation OR
operations OR preoper* OR pre-oper* OR preoperative OR
“surgery”[Subheading] OR “surgical procedures, operative”[MeSH])

AND

(“colorectal”[all fields] OR colon OR coloni* OR colore* OR recta* OR
rectu* OR “colo-rectal” OR ((large) AND (bowel* OR intestin*)) OR
“Intestine, Large”[Mesh] OR colon[mesh] OR rectum[mesh])) OR
(“Colorectal Surgery”[Mesh]))

AND

(prepara* OR enema* OR cathartics[MeSH] OR cathartic* OR polyethylene glycols[MeSH] OR (polyethylene AND (glycol OR glycols)) OR
phosphates[MeSH] OR phosphate* OR “Laxatives”[MeSH] OR laxative* OR
“Senna Extract”[Mesh] OR (senna AND extract*) OR “Bisacodyl”[Mesh] OR
“bisacodyl”[all fields] OR “Cascara”[Mesh] OR “cascara”[all fields] OR
“Enema”[Mesh] OR “PEG”[all fields] OR “miralax”[all fields] OR
“golytely”[all fields] OR “nulytely”[all fields] OR “halflytely”[all fields] OR “fleet”[all fields] OR “dulcolax”[all fields] OR “pico salax”[all fields] )

The search strategy was translated for use in the Cochrane Central Register Of Controlled Trials, EMBASE, and CINAHL. Searches in these databases only included years 2010 to 2013 (because earlier years had been covered by the Cochrane Review by Guenaga et al. 1 ).