# Results

## Search Results

Figure 5 describes our search process. We retrieved 10,088 unique citations from our search. After reviewing the titles, abstracts, and full text, we included a total of 60 studies (62 publications). We found 37 studies (38 publications) evaluating advanced wound dressings,20-56 1 study evaluating antibiotics,57 8 studies (nine publications) comparing a surgical intervention with compression systems,58-66 3 studies comparing at least 2 different surgical interventions,67-69 and 11 evaluating a surgical intervention with no concurrent comparison group.14, 70-79 In most studies, the mean or median age was greater than 60 years. Twenty-two studies received industry support.20, 21, 23, 25, 27, 28, 30-33, 36-39, 43, 44, 47, 49-51, 53, 54

Figure 5 Summary of literature search (number of articles)

The figure is a summary of the literature, showing the search flow of the literature search. The overall structure is a vertical flow chart. The first box is the electronic databases, showing 5689 titles from PubMed, 9695 from EMBASE, 827 from Cochrane, and 1355 from CINAHL which is the cumulative index of nursing and allied health literature. The next box is total titles retrieved, which is 17566. A side box shows more added to the search via Handsearching, which is 8. Then, a side box showing removal of 6890 duplicates is followed by the Title Review box, which has 10676 titles. A side box with Excluded shows 6974 excluded titles from the title review. Then, the abstract review of 3702 excluded 3099 which is shown in the next box and side box. The next box is article review of 603, and a side box of 541 excluded. The last box is the included studies, which is 60 studies and 62 publications, 37 (38 publications) of which evaluated advanced wound dressings, 1 evaluated antibiotics, 8 studies (9 publications) compared surgery with compression, and 14 evaluated surgical procedures. Two boxes are off of the excluded from abstract review and from article review and each show the reasons for exclusion. The reasons for exclusion at abstract review show as no original data with 1480, no chronic venous ulcers with 894, no comparison group of interest with 749, no human subjects with 140, intermittent compression with 9, different levels of compression with 58, and other exclusion with 73. The reasons for exclusion at the article review level include: no original data with 114, no separate analysis of chronic venous ulcers with 137, no intervention of interest with 150, no concurrent comparison with 58, intermittent compression with 7, less than 2 levels of compression with 74, no outcome of interest with 65, fewer than 4 weeks followup with 19, case series with fewer than 30 participants with 73, no key question applied with 20, no human subjects with 1, case series without reported ulcer healing with 8, case series with no sampling frame with 4, case series with no demographics reported with 40, and other exclusion with 48.

## Key Question 1 For patients with chronic venous leg ulcers, what are the benefits and harms of using dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components in conjunction with compression systems when compared with using solely compression systems?

### Key Points

#### Wound Healing

- The randomized controlled trials (RCTs) that evaluated the most advanced wound dressings (transparent films, alginate, acellular human skin equivalents, cryo-preserved human fibroblast-derived dermal substitutes, and antimicrobial dressings vs. compression; hydrocolloid, transparent films, alginates, and cellular human skin equivalents vs. other types of dressings; and head-to-head comparisons of different types of alginate, foam, and antimicrobial dressings) did not find a statistically significant difference between the comparison and study groups in terms of the proportion of ulcers healed. We could not draw definitive conclusions about the comparative effectiveness of most advanced wound dressings due to limitations in study quality, imprecise estimates, and the heterogeneity in study designs. (Insufficient strength of evidence)
- Hydrocolloid dressings were not more effective than compression therapy alone in terms of the proportion of chronic venous ulcers healed. The results from the three studies addressing this comparison were imprecise and subject to some bias. (Low strength of evidence)
- Collagen dressings healed a greater proportion of ulcers than compression alone. (Low strength of evidence)
- The cellular human skin equivalent dressing, Apligraf^®^, healed a greater proportion of ulcers and provided as much as 3 times more rapid healing of chronic venous ulcers than compression alone, especially for ulcers that had failed therapy and were present for over 1 year. (Moderate strength of evidence)
- Autologous keratinocytes in fibrin sealant healed a greater proportion of ulcers and achieved a shorter median time to complete wound closure versus compression. (Low strength of evidence)
- Some antimicrobial dressings improved wound area reduction by 20 percent or more as compared with other nonantimicrobial dressings. However, silver dressings did not improve wound healing as compared with nonsilver dressings. (Moderate strength of evidence)

#### Mortality

- When reported, mortality rates were generally rare (occurring in less than 5 percent of the study population), and did not differ between intervention groups.

#### Pain and Quality of Life

- We were unable to draw conclusions about the effects of advanced wound dressings on pain or quality of life (QOL) due to the inconsistent manner of reporting these outcomes.

#### Condition of the Wound Bed

- Due to the heterogeneity in study design and the inconsistency of evaluating and reporting on the condition of the wound bed, we were unable to draw conclusions about the effect of advanced wound dressings on the condition of the wound bed.

#### Adverse Events

- Evidence was lacking on the effects of advanced wound dressings on maceration, contact dermatitis, venous or arterial impairment, and cellulitis.
- Compared with compression, patients receiving hydrocolloid dressings and cellular products for chronic venous ulcers experienced similar infection rates.

### Study Design Characteristics

We included 37 studies (38 publications) for review (Appendix D, Tables 1 and 2).20-56 These studies enrolled a total of 4,062 patients with chronic venous ulcers (median, 79; range, 18 to 309). All, except one,46 of the studies were RCTs. Two of the RCTs had a factorial design.28, 29 Most of the studies were of short duration; the length of followup ranged between 4 weeks and 1 year (median, 12 weeks).

Most (59 percent) of the studies took place in Europe.20-24, 26, 28-30, 32-34, 36, 37, 39, 40, 44, 46-50, 53, 54 Five took place exclusively in the United States,35, 38, 42, 51, 52 one took place in the United States, Canada, and the United Kingdom,32 and one was conducted in the United States and the United Kingdom.39 One took place in Canada and Europe.27 One study each took place in Canada, the United Kingdom,47 Brazil,45 and Mexico.56

Thirteen studies did not report the location from where the study recruited patients.20, 21, 25-27, 30, 34, 39, 45, 51, 52, 54, 55 Most of the other studies reported recruiting patients from some type of outpatient center: five recruited from dermatology clinics,22, 32, 37, 40, 41 11 from wound centers,24, 29, 31-33, 35, 36, 43, 49, 53, 56 and two from vascular clinics.24, 32 Three studies recruited patients from a hospital setting.24, 28, 48 None of the studies recruited patients from a nursing home or long-term care facility.

Most studies (80 percent) did not report the number of patients screened.20, 21, 23, 26-28, 30, 32, 34-46, 48, 49, 51-56 Among the studies that did report the number of patients screened, the percent they enrolled ranged from 38 to 94 percent.22, 24, 25, 29, 31, 33, 47, 50

### Study Population Characteristics

The majority of studies we included for final analysis had similar profiles for the patient populations evaluated (Appendix D, Table 3). The median age of patients was between 60 and 70 years with a female preponderance. Most studies excluded patients under the age of 18 to minimize enrollment of patients with genetic or clotting abnormalities. Patients tended to be overweight in studies that reported weight. Almost all studies excluded patients with insulin dependent diabetes, but did include patients with elevated blood sugars. Studies uniformly evaluated patients for their arterial blood flow competence by obtaining ankle brachial indices; studies excluded patients with ankle brachial index ratios of below 0.8. Less than 50 percent of the studies used venous ultrasound or the equivalent. When reported, patients most often had abnormal venous function, usually of the reflux type.

All studies that we included used venous compression of at least two layers or, where measured, 20 mm Hg. Compliance with the interventions was rarely reported.

### Wound Healing, Including Proportion of Ulcers Healed, Time to Wound Healing, Wound Healing Rates, and Wound Recurrence

#### Hydrocolloid Dressings

##### Hydrocolloid Dressings Plus Compression Versus Compression Systems Alone

Three RCTs (total N=361) compared hydrocolloid dressings with compressions systems alone (Table 5 and Appendix D, Table 4a).29, 43, 49 One trial was a factorial design that compared pentoxiphylline, knitted viscose, and hydrocolloid with single-layer and four-layer wraps.29 The data the studies extracted focused on the comparison of hydrocolloid with knitted viscose under the four-layer compression. Results showed decreased time-to-healing in the hydrocolloid group (median 99 days vs. 127 days knitted viscose), but healing rates were not significantly different between groups, 20 of 33 (60 percent) healed in the hydrocolloid group versus 17 of 27 (63 percent) in the knitted viscose group (the hazard ratio for healing with hydrocolloid compared with knitted viscose was 1.1, 95% confidence interval [CI], 0.8 to 1.6).29 The other two RCTs evaluated percent healing over time as well as percent ulcers healed.43, 49 After 12 weeks in one trial, 13 of 30 (43 percent) ulcers healed in the hydrocolloid group, compared with only seven of 30 (23 percent) in the compression group, but the difference was not statistically significant (P > 0.05).49 Cumulative healing rates in this second trial were 46 percent in the hydrocolloid group and 17 percent in the compression group over 12 weeks (relative risk [RR], 2.25; 95% CI, 0.88 to 5.75).49 The third trial evaluated the percentage of ulcer area healed each week and percentage of ulcers healed after 12 weeks and found no clinically important difference between groups.43 Hydrocolloids healed 18.0 percent and compression dressings healed 20.5 percent of the original ulcer size per week.43 After 12 weeks, 21 (75 percent) of the hydrocolloid group and 22 (78 percent) of the compression group healed completely (P > 0.05).43

Table 5 Summary of wound healing measures^*^ among patients with chronic venous ulcers comparing hydrocolloid dressings with compression systems alone

Author, Year | Intervention, N | Compression Used in Both Groups | Followup Time | Proportion of Ulcers Healed, n / N (%) | Time-to-Healing | Wound Healing Rates
Moffatt, 1992^49^ | G1: Nonadherent, 30 G2: Hydrocolloid (Comfeel, Coloplast), 30 | 4-layer | 12 weeks | G1: 7 / 30 patients (23) G2: 13 / 30 patients (43) | G1: Ref G2: RR, 2.25 (CI, 0.88 to 5.75); P = 0.077 | NR
Nelson, 2007^29^ | G1: Knitted viscose, 27 G2: Hydrocolloid, 33 | 4-layer | 24 weeks | G1: 17 / 27 patients (63) G2: 20 / 33 (60) | G1: 127 days - median G2: 99 days - median; P > 0.05 | NR
Backhouse, 1987^43^ | G1: Compression, 28 G2: Hydrocolloid, 28 | Multilayer | 12 weeks | G1: 22 / 28 patients (78) G2: 21 / 28 patients (75); P > 0.05 | NR | G1: 20.5%/week G2: 18% / week; P > 0.05

* The studies did not report wound recurrence.

CI = 95% confidence interval; G = group; NR = not reported; Ref = reference group; RR = relative risk

##### Hydrocolloid Dressings Versus Other Types of Dressings

Four RCTs (total N=420) compared hydrocolloids with other types of dressings (Table 6).39, 48, 50, 53 Two of the trials measured percent changes in ulcer area over time and two trials measured area change per day. One trial that compared a hydrocolloid with impregnated gauze (with paraffin in the United States or Betadine^®^ in the United Kingdom) evaluated the number of ulcers healed but did not specifically report the number of ulcers in each group or the number of ulcers per patient.39 The mean percent reduction in ulcer area over 10 weeks was 71 percent (standard deviation [SD], 4.3) for the hydrocolloid versus 43 percent (SD, 7.1) for impregnated gauze (P>0.05 for this small study with a total of 70 patients).39 Complete healing occurred in 11 ulcers among 35 patients in the hydrocolloid group versus 14 ulcers among 35 patients in the impregnated gauze group (P>0.05).39 Another trial that compared hydrocolloids with impregnated gauze (magnesium sulfate paste and Vaseline^®^ with gauze) found a clinically important difference in mean healing rates per day (32 mm^2^ per day for hydrocolloids vs. 21 mm^2^ per day for impregnated gauze) (P=0.0001).48 The trial measured the followup period by the number of dressing changes, one through 10, and not over time.48 Ulcer healing occurred in three of 55 (5 percent) patients in the hydrocolloid group versus zero of 55 patients in the impregnated gauze group over the 10 dressing changes.48 Another small trial did not find much of a difference in healing rates when comparing hydrocolloids with alginates over 6 weeks.53 Two of 20 (10 percent) patients healed in the hydrocolloid group versus six of 20 (30 percent) patients healed in the alginate group.53 Lastly, a trial that compared hydrocolloids with Betadine^®^ and a contact layer over 4 months, taking into account the ulcer size at baseline, found no clinically important difference in healing rates (RR, 1.16, 95% CI, 0.8 to 1.8).50 However, a trial that evaluated the proportion of ulcers healed among ulcers with an initial measurement of greater than 4 cm saw a clinically important and statistically significant difference (12 of 35 [34 percent] patients healed in the hydrocolloid group vs. four of 39 [10 percent] patients healed in the Betadine^®^ plus contact layer group; P=0.02).50

Table 6 Summary of wound healing measures among patients with chronic venous ulcers comparing hydrocolloid dressings with other types of dressings

Author, Year | Intervention, N | Compression Used in Both Groups | Followup Time | Proportion of Ulcers Healed, n / N (%) | Time-to-Healing | Wound Healing Rates
Arnold, 1994 | G1: Impregnated gauze; paraffin in U.S., saline/Betadine® in U.K., 35 G2: Hydrocolloid, 35 | Unna boot gradient and zinc oxide paste | 10 weeks | G1: 14 ulcers G2: 11 ulcer, P>0.05 | G1: 8.2 (0.4) mean weeks (SE) G2: 7.09 (0.2) mean weeks (SE); P>0.05 | G1: 43% (7.1) mean decrease in area of ulcer (SD) G2: 71% (4.3) mean decrease in area of ulcer (SD); P>0.05
Greguric, 1994^48^ | G1: Impregnated gauze, 55 G2: Hydrocolloid, 55 | 2-layer compression | NR | G1: 0 (0) G2: 3 (5) | G1: 22 mm^2^/day G2: 32 mm^2^/day; P=0.0001 | G1: 21 mm^2^/day (mean) G2: 32 mm^2^/day (mean) (P=0.0001)
Scurr, 1994 53 | G1: Alginates, 20 G2: Hydrocolloid, 20 | Graduated elastic compression stocking | 6 weeks | G1: 6 (30) G2: 2 (10) | NR | G1: ≥ 40% increase in area: 2 / 20 (10%) ≥ 40% decrease in area: 14 / 20 (70%) G2: ≥ 40% increase in area: 8 / 20 (40%) ≥ 40% decrease in area: 9 / 20 (45%); P=0.258
Smith, 1992 Among those with initial ulcer size of 2-4 cm | G1: Betadine® and contact layer, 62 G2: Hydrocolloid, 64 | 2-layer compression, linear, graduated | 4 months | G1: 43 / 62 patients (69) G2: 38 / 64 patients (59); P=0.27 | G1: Reference G2: RR^†^ for time to complete healing, 1.16 (CI, 0.77 to 1.77) Treatment and ulcer area interaction, P=0.37 | G1: 0.062 cm^2^ per day (median) G2: 0.056 cm^2^ per day (median); P=0.40
Smith, 1992 Among those with initial ulcer size of > 4 cm | G1: Betadine® and contact layer, 39 G2: Hydrocolloid, 35 | 2-layer compression, linear, graduated | 4 months | G1:4 / 39 patients (10) G2:12 / 35 patients (34); P=0.02 | See above | G1: 0.017 cm^2^ per day (median) G2: 0.184 cm^2^ per day (median); P=0.09

† Reported for the entire sample

CI = 95% confidence interval; cm = centimeter; G = group; mm = millimeter; NR = not reported; RR = relative risk; SD = standard deviation; SE = standard error; U.K. = United Kingdom; U.S. = United States

#### Transparent Film Dressings

##### Transparent Film Dressings Plus Compression Versus Compression Systems Alone

Kucharzewski46 compared adequate compression under an Unna boot with adequate compression over a cellulose film in carefully selected venous ulcers (see Table 7). The compression was about 20 mmHg for both groups, though the mean of compression for each group was different. Healing rates at 11 weeks were 18 out of 27 patients (67 percent) treated with the film versus nine out of 27 patients (33 percent) treated with compression alone. All of the ulcers treated with the film were healed by 14 weeks, and all of the ulcers treated with compression alone were healed by 20 weeks. The study did not present data regarding healing rates in healed ulcers. Since the means of compression were quite different in the two treatment groups, it would have been impossible to avoid bias since the modes of therapy were so different to the patients and observers.

Table 7 Summary of the wound healing measures among patients with chronic venous ulcers comparing transparent film dressings with compression systems alone

Author,Year | Intervention | Compression Used in Both Groups | Followup Time | Proportion of Ulcers Healed, N / N (%) | Time-to-Healing
Kucharzewski, 2003^46^ | G1: Unna boot G2: (Bioprocess) Cellulose membrane | Unspecified compression | 11 weeks | G1: 9 / 27 patients (33) G2: 18 / 27 patients (67); P<0.05; RR, 0.5 (CI, 0.3 to 0.9) RD, -33% (CI, -58% to -8%) | G1: Time at complete closure in weeks, 20 G2: Time at complete closure in weeks, 14

CI = 95% confidence interval; G = group; RD = risk difference; RR = relative risk

##### Transparent Film Dressings Versus Other Types of Dressings

One small non-RCT trial (N=20) compared a transparent film with a foam as a secondary dressing over an alginate over 6 weeks.54 The study found that 80 percent of the ulcers treated with transparent film and 70 percent of the ulcers treated with foam had a 30 percent or more decrease in wound size at final evaluation, but this was not a statistically significant finding.

#### Alginate Dressings

##### Alginate Dressings Versus Other Alginate Dressings

Two RCTs compared different alginate dressings (Table 8).21, 35 In one small trial (N=19), Tegagen™ HG reduced wound area by 34 percent over 6 weeks compared with Sorbsan^®^ topical wound dressing that reduced wound area by 30 percent.35 This was not a statistically significant difference in healing rates (P=0.88).35 The other trial (N=82) compared Vulnamin^®^, an alginate with glycine, leucine, proline, lysine, and sodium hyaluronate, with another alginate without additives over 70 days and found a difference in healing rates.21 When clinicians treated ulcers with Vulnamin^®^ there was a mean decrease in area from 13.95 (SD, 4.5) cm^2^ to 3.04 (SD, 0.8) cm^2.21^ This is significant when compared with the other alginate without glycine, leucine, proline, lysine, and sodium hyaluronate, which resulted in a mean reduction in ulcer area from 15.14 (SD, 4.7) cm^2^ to 10.96 (SD, 3.8) cm^2^ (P<0.05).21

Table 8 Summary of the wound healing measures^*^ among patients with chronic venous ulcers comparing alginate dressings with other alginate dressings

Author, Year | Intervention, N | Compression Used in Both Groups | Followup Time | Proportion of Ulcers Healed, N / N (%) | Wound Healing Rate
Limova, 2003 | G1: Alginate (3M Tegagen™ HG), 10 G2: Alginate (Sorbsan Topical Wound Dressing), 9 | 2-layer compression | 6 weeks | G1: 0 / 10 (0%) G2: 2 / 9 (22%) | G1: 33.7% wound area reduction G2: 29.6% wound area reduction (P=0.88)
Maggio, 2011 | G1: Alginate, 26 G2: Alginate (Vulnamin^®^), 26 | Multilayer | 70 days | G1: 7 / 26 (27%) G2: 16 / 26 (61%); P = 0.01 | G1: 15.14 (SD, 4.7) cm^2^ to 10.96 (SD, 3.8) cm^2^ (mean) G2: 13.95 (SD, 4.5) cm^2^ to 3.04 (SD, 0.8) cm^2^ (mean); P<0.05

* None of the studies reported on time-to-healing or wound recurrence.

cm = centimeter; SD = standard deviation

##### Alginate Dressings Versus Other Types of Dressings

One prospective RCT of 113 patients compared a hydropolymer dressing with an alginate plus a secondary dressing of transparent film on moderate to heavily exuding wounds over 4 weeks.36 However, part way through the trial, the investigators changed the transparent film to a cotton gauze pad believing that the transparent film over the alginate was causing maceration or erythema. Therefore, the study evaluated three treatment groups: Hydropolymer, alginate plus transparent film, and alginate plus cotton gauze pads. The mean rate of reduction in ulcer area was 0.17 (SD, 0.31), 0.05 (SD, 0.29), and 0.00 (SD, 0.45) cm^2^ per day for the hydropolymer, alginate plus film, and alginate plus cotton gauze pad respectively. The difference between groups was not statistically significant.36 The proportion of ulcers healed did not differ between the groups.36

#### Foam Dressings

##### Foam Dressings Versus Other Foam Dressings

A foam dressing that released 112.5 mg of ibuprofen over 7 days in the presence of exudate was compared with the same foam dressing without ibuprofen.23 The difference in the average reduction in ulcer area over 42 days was not statistically significant between the groups (P=0.26) nor was the proportion of ulcers healed (15 percent healed in the foam dressing with ibuprofen vs. 17 percent in the foam dressing without ibuprofen, P>0.05) (Table 9).23 Preliminary results of another small, ongoing trial (N=18) found a greater reduction in average ulcer size over 16 weeks in the slightly adhesive hydroactive foam, Cutinova™, as compared with the nonadhesive foam dressing, Allevyn™; however, there was no formal statistical comparisons between groups.52 Franks28 noticed no difference in healing rates between two established foam products under appropriate aggressive compression (Table 9). This trial of 156 patients reported a 64 percent healing rate over 24 weeks.

Table 9 Summary of the wound healing measures^*^ among patients with chronic venous ulcers comparing foam dressings with other foam dressings

Author, Year | Intervention | Compression Used in Both Groups | Followup Time | Proportion of Ulcers Healed, N / N (%) | Time-to-Healing | Wound Healing Rates
Franks, 2007^28^ | G1: Foam (Allevyn™) G2: Foam (Mepilex^®^) | Short stretch or multilayer | 24 weeks | G1: 50 / 81 patients (62) G2: 50 / 75 patients (67); P>0.05 RR, 0.9 (CI, 0.7 to 1.2) RD, -4% (CI, -20% to 10%) | NR | NR
Gottrup, 2008^23^ | G1: Foam (Biatain^®^ Non-Adhesive, Coloplast A/S) G2: Foam, with ibuprofen (Biatain-Ibu^®^ Non-Adhesive, Coloplast A/S) | Kept a constant circumference at the ankle | 47 days | G1: 10/60 patients (16) G2: 9 / 62 patients (15); P>0.05 RR, 1.15 (CI, 0.5 to 2.6) RD, 2% (CI, -10% to 15%) | NR | G1: Average area reduction from 7.2 to 3.8 cm^2^ G2: Average area reduction from 11.2 to 7.9 cm^2^ (P=0.26)
Weiss, 1996^52^ | G1: Foam (Cutinova™ foam) G2:Foam (Allevyn™) | Jobst^®^ UlcerCare stocking | 16 weeks | G1: 8 / 10 patients (80) G2: 4 / 8 patients (50); P>0.05 RR, 1.6 (CI, 0.75 to 3.4) RD, 30% (CI, -13% to 72%) | G1: Mean weeks, 5.6 G2: Mean weeks, 6.5 | NR

* Wound recurrence was not reported.

CI = 95% confidence interval; G = group; NR = not reported; RD = risk difference; RR = relative risk

#### Collagen Dressings

##### Collagen Dressings Plus Compression Versus Compression Systems Alone

One multicenter U.S. trial examined small intestinal freeze-dried pig submucosa (OASIS^®^ Wound Matrix) as a therapy of venous ulcers (Table 10).32 Fifty-five percent (34 out of 62 patients) of venous ulcer patients who received small intestinal submucosa healed, compared with 34 percent (20 out of 58 patients) of patients who received standard compression therapy (P=0.02).32 Furthermore, after adjusting for baseline ulcer size, ulcers that received the test intervention were 3 times more likely to heal than those treated with standard compression (P=0.01). If clinicians performed an aggressive debridement before beginning therapy, the odds ratio for healing rose to 4. A Cox proportional hazards model estimated the probability of healing with the test material dressing was 64 percent and the probability of healing with standard therapy was 40 percent (P=0.02). At the end of the study, 54 patients had healed. Twenty-six out of 29 patients receiving the test material remained healed in contrast with seven out of 10 patients with standard therapy (P>0.05).32

Table 10 Summary of the wound healing measures^*^ among patients with chronic venous ulcers comparing collagen dressings with compression systems alone

Author, Year | Intervention, N | Compression Used in Both Groups | Followup Time | Proportion Ulcers Healed, N / N (%) | Wound Recurrence (%)
Mostow, 2005^32^ | G1: Standard compression therapy G2: Composite acellular or ECM | Multilayer Debridement | 6 months | G1: 20 / 58 (34) G2: 34 / 62 (55); P=0.02 G2: aOR^†^, 3.0; P=0.01 | G1: 3 / 10 (30) G2: 0 / 19 (0)

* The study did not report time to healing and wound healing rates.

† Adjusted for baseline ulcer size

Abbreviations: aOR = adjusted odds ratio; ECM = extracellular matrix

#### Acellular Human Skin Equivalent Dressings

##### Acellular Human Skin Equivalent Dressings Plus Compression Versus Compression Systems Alone

Preliminary results from a small nonrandomized trial of 24 patients evaluated the effect of fibrin sealant derived from snake venom plus essential fatty acids and compression versus a control group that received essential fatty acids plus compression over 8 weeks (Table 11).45 Patients in the fibrin sealant group had a higher percentage of deep wounds and cavities but five of the participants healed. However, there were no formal statistical comparisons.45 In a single-blinded RCT of 123 patients, there was no difference in healing rates between Amelogenin protein 30 milligrams per milliliter solution (Xelma^®^ extracellular matrix [ECM]) plus a soft silicone dressing versus control, 7 percent polypropylene glycol alginate plus soft silicone dressing over 12 weeks.30

Table 11 Summary of the wound healing measures among patients with chronic venous ulcers comparing acellular human skin equivalent dressings with other types of dressings

Author, Year | Intervention, N | Compression Used in Both Groups | Followup Time | Proportion of Ulcers Healed, N / N (%) | Wound Healing Rates
Gatti, 2011^45^ | G1: Fatty acids plus compression, 11 G2: Fibrin sealant derived from snake venom, fatty acids, compression, 13 | Unna boot | 8 weeks | G1: 5 / 11 (45%) G2: 7 / 13 (54%) | NR^*^
Vowden, 2008^30^ | G1: Amelogenin proteins (Xelmat) G2: Alginate | High-compression | 12 weeks | No difference | G1: 33.8% median percentage reduction in wound area G2: 25.6% median percentage reduction in wound area

* No studies reported on time-to-healing or wound recurrence.

#### Biological or Cellular Dressings

##### Biological or Cellular Dressings Plus Compression Versus Compression Systems Alone and Versus Cellular Skin Replacements

Dermagraft^®^ is a biodegradable mesh containing viable fibroblasts that produce growth factors. A study subjected a carefully selected group of 53 patients with venous ulcers (average age over 70, more females than males, and no extraneous complications), to a 2-week run-in period to eliminate patients who might heal on adequate compression alone (Table 12).47 The study randomized patients to four groups of 13. The first group received 12 weekly applications of Dermagraft^®^; the second, four applications over the 12 weeks; the third, one application at the beginning of the trial; and the fourth, only compression. Forty-seven patients completed the study and investigators analyzed the results by intention-to-treat. The authors reported having insufficient power to draw statistical conclusions from the trial. Ulcer healing occurred in five out of 13 patients (38 percent) receiving 12 applications, five out of 13 patients (38 percent) receiving four applications, one out of 13 patients (8 percent) receiving one application, and two out of 13 patients (15 percent) receiving only compression. A statistical analysis of healing rates as measured by percent of ulcer resurfaced by epithelium at 12 weeks showed no differences between groups.

Table 12 Summary of the wound healing measures^*^ among patients with chronic venous ulcers comparing biological or cellular dressings with compression alone

Author, Year | Intervention, N | Compression Used in Both Groups | Followup Time | Proportion Of Ulcers Healed, N / N (%) | Wound Healing Rate | Wound Recurrence
Krishnamoorthy, 2003^47^ | G1: Cellular skin substitute or ECM Dermagraft 12 pcs G2: Cellular skin substitute or ECM Dermagraft 4pc G3: Cellular skin substitute or ECM Dermagraft 1pc G4: Compression only | Multilayer Profore | 12 weeks | G1: 5 / 13 (38) G2: 5 / 13 (38) G3: 1 / 13 (8) G4: 2 / 13 (15); P>0.05 | NR | NR
Omar, 2004^34^ | G1: Compression only G2: human fibroblast derived dermal replacement, Dermagraft® | 4-layer | 12 weeks | NR | G1: 0.15 cm^2^ per week G2: 0.82 cm^2^ per week; P = 0.001 | NR
Falanga, 1998 38 | G1: Compression, 129 G2: Cellular skin substitute or ECM, 146 | Unna boot | 6 months | G1: 63 / 129 patients (49) G2: 92 / 146 patients (63); P=0.02 | G1: Median days, 181 (Range, 10 to 232) G2: Median days, 61 (Range, 9 to 233) RH of wound closure per unit time, 1.5 (CI, 1.3 to 1.9) | G1: 10 / 63 (16) G2: 11 / 92 (12); P=0.48
Vanscheidt, 2007^26^ | G1: Contact layer, 109 G2: Contact layer + cellular skin substitute or ECM, 116 | Short stretch | 182 days | G1: 24 / 109 patients (22) G2: 44 / 116 patients (38); P=0.0106 | G1: Median days, > 201 (CI, 201 to ∞) G2: Median days, 176 (CI, 114 to 184); P < 0.0001 | NR
Falanga,1999^51^ [Subgroup analysis from Falanga, 1998^38^ on ulcers > 1 year duration] | G1: Compression G2: Cellular skin substitute or ECM | Unna boot | 24 weeks | G1: 9 / 48 (19) G2: 34 / 72 (47) P<0.005 | G1: closure not attained G2: 181 days (P<0.005) | G1: 4 / 54 (7) at 6 months 12 / 54 (22) at 12 months G2: 6 / 72 (8) at 6 months 13 / 72 (18) at 12 months

* None of the studies reported on time-to-healing.

CI = 95% confidence interval; cm = centimeter; ECM = extracellular matrix; G = group; NR = not reported; RH = relative hazard

Another small prospective RCT of 18 patients compared healing rates of patients receiving human fibroblast derived dermal replacement, Dermagraft^®^, or compression alone over 12 weeks.34 The treatment group (N=10) received one piece of Dermagraft^®^ on day 0 and weeks 1, 4, and 8. The Dermagraft^®^ group had a significantly greater mean total ulcer area rate of healing than the compression group (0.82 cm^2^ per week vs. 0.15 cm^2^ per week respectively) (P=0.001) and a greater mean linear rate of healing than the compression group (0.14 cm per week vs. 0.033 cm per week) (P = 0.006).34 The reduction in wound surface area was greater in the Dermagraft^®^ group than in the compression-alone group (P=0.02).34

Another prospective, parallel group comparative trial (N=293) compared allogeneic cultured human skin equivalent with compression alone over 6 months in ulcers with a duration greater than 1 month that had not adequately responded to conventional therapy.38 Both groups received adequate compression. Patients received no more than five applications of human skin equivalent, and received no human skin equivalent after week 3. Human skin equivalent was more effective than compression therapy in median time to complete wound closure (61 vs. 181 days; P=0.003, log rank test) and median time to 75 percent wound closure (30 vs. 50 days, P=0.001).38 Human skin equivalent was more effective in healing than compression alone among the study population (P=0.02), large ulcers of over 1,000 mm surface area (P=0.02), deeper ulcers (P=0.003), and ulcers older than 6 months (P=0.001, log rank test). Researchers confirmed this throughout the treatment period by observing statistically significant decreases in days needed for healing of 50 percent (P=0.02) and 75 percent (P=0.01) in ulcer area. The human skin equivalent healed the ulcers with a similar recurrence rate of ulcers between the groups. In a subgroup analysis on hard-to-heal ulcers (those older than 1 year) over 6 months (N=120), 34 out of 72 (47 percent) patients in the human skin equivalent group achieved complete wound closure at 6 months versus nine out of 48 (19 percent) patients with compression alone (P<0.005).51 The median time to complete closure for human skin equivalent was significantly faster than the control group (P=0.005). Human skin equivalent had a 60 percent advantage over rates of wound closure in the comparison group (P=0.01). Recurrence rates did not differ between ulcers healed with human skin equivalent and ulcers healed with standard therapy).51

Addition of autologous living keratinocytes to nonhealing venous ulcers is a novel therapeutic approach. Vanscheidt et al.26 performed an open label RCT of 226 carefully selected patients.26 Autologous keratinocytes healed 38 percent of the ulcers compared with 22 percent of ulcers in the group of patients that received adequate compression alone (P=0.01). Furthermore, time-to-healing in the keratinocyte group was 176 days, compared with 201 days in the comparison group (P=0.0001). The experimental design included a 4-week run-in period with optimal conservative care and adequate compression, thereby maximizing selection of recalcitrant ulcers.26

##### Cellular Skin Replacement Dressings Versus Other Types of Dressings

Two RCTs compared the healing rates of cellular human skin equivalents with the healing rates of hydrocolloid dressings.33, 40 One trial (N=47) had an almost significant difference in ulcer size between the groups at baseline (P=0.07) and a significant number of withdrawals (N=9).40 Also, this trial treated patients for 6 weeks and then crossed over any unhealed ulcers to the alternate treatment.40 We evaluated data from the first 6 weeks of the trial. The other trial (N=178) evaluated a lyophilized human keratinocyte lysate added to a hydrocolloid preparation versus the hydrocolloid vehicle itself over 6 weeks.33 These investigators noted that ulcers that were increasing in size at the start of the trial demonstrated a statistically improved healing rate with the epidermal lysate (30 vs. 11 percent; P=0.02) which was even more marked in smaller ulcers (P=0.008). The study did not report data on recurrence.33

#### Antimicrobial Dressings

##### Antimicrobial Dressings Plus Compression Versus Compression Systems Alone

One crossover RCT (N=75) compared cadexomer iodine with saline wet to dry gauze dressings over 24 weeks (Table 13).42 Patients performed their own daily dressing cleaning and changes. Many patients withdrew or dropped out of the study (25 out of 75 patients) and the study only included 54 out of 75 patients in the statistical analysis.42 Additionally, baseline characteristics differed between the treatment and control groups. The cadexomer iodine group showed significantly greater mean ulcer area reduction per week than the gauze dressing group (0.95; standard error [SE], 0.12 cm^2^ per week versus 0.41; SE, 0.13 cm^2^ per week; P=0.003). After 12 weeks, the patients with unhealed ulcers had the opportunity to change to the alternate therapy.42 All 12 switched from the control group to the cadexomer iodine group. Five of these patients did not benefit, but seven of them showed healing of their ulcers. The trial did not conduct a formal statistical evaluation of this outcome.42

Table 13 Summary of the wound healing measures^*^ among patients with chronic venous ulcers comparing antimicrobial dressings with compression alone

Author, year | Intervention | Compression used in both groups | Followup time | Wound healing rate
Holloway, 1989^42^ | G1: Wet to dry saline gauze G2: Cadexomer iodine | Toe to knee elastic compression | 24 weeks | G1: Mean, 0.41 (SE, 0.13) cm^2^/week G2: Mean, 0.95 (SE, 0.12) cm^2^/week; P=0.0025
Beckert, 2005^31^ | G1: Vehicle + Jelonet™ G2: Pale sulfonated shale oil 10% + Jelonet™ | Short stretch | 20 weeks | G1: Relative mean change in ulcer area, -18.7% (SD, 68.1) G2: Relative mean change in ulcer area, -72.0% (SD, 37.2); P<0.0001

* Neither study reported on the proportion of ulcers healed, time-to-healing, or wound recurrence.

cm = centimeter; SD = standard deviation; SE = standard error

Another observer-blinded, multicenter RCT (N=119) showed a relative reduction in ulcer area with pale sulfonated shale oil 10 percent plus Jelonet™ compared with vehicle plus Jelonet™ over 20 weeks (-72 vs. -19 percent; P<0.0001).31

##### Antimicrobial Dressings Versus Other Antimicrobial Dressings

One RCT (N=281) compared Urgotul^®^ Silver with Aquacel^®^ Ag over 4 weeks (Table 14).20 The study randomized 145 patients to the Aquacel^®^ Ag group followed by Aquacel^®^ for another 4 weeks. The study randomized 136 patients to Urgotul^®^ Silver for 4 weeks then switched to Urgotul^®^ for another 4 weeks. This analysis included data over the first 4 weeks of the trial. The study found no significant difference in healing rates between groups.20

Table 14 Summary of wound healing measures^*^ among patients with chronic venous ulcers comparing antimicrobial dressings with other antimicrobial dressings

Author, year | Intervention | Compression used in both groups | Followup time | Wound healing rate
Harding, 2011^20^ | G1: Aquacel Ag G2: Urgotul Silver | Class III compression | 4 weeks | G1: Relative mean wound area reduction, 38.24% (SD, 40.63) G2: Relative mean wound area reduction, 32.47% (SD, 48.93)
Ormiston, 1985^44^ Ormiston, 1983^55^: interim data | G1: Gentian violet and Polyfax G2: Cadexomer iodine | Crepe then cotton crepe compression bandage | 12 weeks | G1: Mean, 0.46 (SEM, 0.1) cm^2^/week G2: Mean, 0.89 (SEM, 0.1) cm^2^/week; P=0.0001

* Neither study reported on the proportion of ulcers healed, time-to-healing, or wound recurrence.

cm = centimeter; SD = standard deviation; SEM = standard error of the mean

A randomized optional crossover trial compared cadexomer iodine with gentian violet and Polyfax ointment (standard treatment) over 24 weeks among 61 outpatients.44 However, the data discussed here pertains to the period prior to the cross-over at 12 weeks. At 12 weeks, the cadexomer iodine group healed at a rate of 0.89 cm^2^ per week versus 0.46 cm^2^ per week in standard treatment (P < 0.001).44

##### Antimicrobial Dressings Versus Other Types of Dressings

A large RCT recruited 213 patients to prospectively analyze healing rates at 12 weeks, 6 months, and 1 year, and time-to-healing between silver antimicrobial dressings (foams, specialty absorptives, alginates, and contact layers) and any nonantimicrobial dressing (including knitted viscose, foams, contact layers, and low adherent tulle) (Table 15).22 Investigators and nurses caring for patients could change the frequency of dressing changes. The choice of silver-donating dressings was up to the clinician. Likewise, the dressing choice for the nonsilver dressings was clinician-guided based on wound characteristics. The overall median time-to-healing was 67 (95% CI, 54 to 80) days for the antimicrobial dressings and 58 (95% CI, 43 to 73) days for the other dressings. This was not statistically significant (P=0.41). Large ulcers, those above 3 cm, healed significantly more slowly than small ulcers, those up to 3 cm. Significant predictors of healing at 12 weeks included patient location, ulcer size, and sex of patient.22

Table 15 Summary of the wound healing measures^*^ among patients with chronic venous ulcers comparing antimicrobial dressings versus other types of dressings

Author, year | Intervention, N | Compression used in both groups | Followup Time | Wound healing rate
Michaels, 2009^22^ | G1: Any nonantimicrobial dressing G2: Silver antimicrobial dressing | Multilayer | 12 months | G1: Median time-to-healing, 58 days (CI, 43 to 73) G2: Median time-to-healing, 67 days (CI, 54 to 80); P=0.51
Gethin, 2009^24^ | G1: Hydrogel, 54 G2: Manuka honey, 54 | Multilayer | 4 weeks | G1: 13% reduction to wound area G2: 34% reduction to wound area; P<0.001
Lammoglia-Ordiales, 2011 56 | G1: Hydrogel, 14 G2: Hydrogel plus Mimosa tenuiflora (M. tenuiflora) cortex extract, 18 | 2-layer compression | NR | G1: 5.85 cm^2^ mean area wound reduction (CI, 3.58 to 8.12 cm^2^) P=0.0001 G2: 6.29 cm^2^ mean area wound reduction (CI, 3.28 to 9.29 cm^2^), P=0.0001
Hansson, 1998^37^ | G1: Paraffin gauze G2: Cadexomer iodine G3: Hydrocolloid | Short stretch | 12 weeks | G1: Mean area reduction, 51 (SD, 53.2) G2: Mean area reduction, 66 (SD, 25.4); P=0.04 vs. G1 G3: Mean area reduction, 18 (SD, 51.6)

* None of the studies reported on the proportion of ulcers healed, time-to-healing, or wound recurrence.

CI = 95% confidence interval; cm = centimeter; G = group; SD = standard deviation

Another prospective, multicenter RCT (N=108) evaluated healing rates over 4 weeks using manuka honey compared with using hydrogel.24 The manuka honey group healed faster than the hydrogel group (34 percent reduction in median wound size vs. 13 percent reduction in wound size respectively) (P<0.001).24

A double-blind RCT of 41 patients compared hydrogel with hydrogel plus Mimosa tenuiflora (M. tenuiflora) cortex extract (MTC-2G), a substance with antiseptic properties.56 After 8 weeks, the mean area of wound reduction was significant in the MTC-2G group and the hydrogel group at 6.29 cm^2^ (95% CI, 3.28 to 9.29 cm^2^, P=0.0001) and 5.85 cm^2^ (95% CI, 3.58 to 8.12 cm^2^, P=0.0001), respectively. However, the study found no significant difference between the groups.56

Lastly, one RCT (N=153) compared cadexomer iodine with hydrocolloid and paraffin gauze over a duration of 12 weeks.37 During the course of the trial, 12 patients from the cadexomer iodine group, seven from the hydrocolloid group, and nine in the paraffin gauze group withdrew and researchers excluded them from the analyses. Of the patients treated for 12 weeks (N=51), the cadexomer iodine group had a 66 percent (SD, 25.4) mean ulcer area reduction from baseline and the hydrocolloid group had an 18 percent (SD, 51.6) mean ulcer area reduction (P=0.01). The paraffin gauze group had a 51 percent (SD, 53.2) mean ulcer area reduction, but this was not considered significant. The mean ulcer area reduction per week was significantly greater in the cadexomer iodine group compared with the paraffin gauze group (P=0.04).37

#### Other Types of Advanced Wound Dressings

We did not find any studies meeting our inclusion criteria that evaluated composite dressings, specialty absorptive dressings, contact layer dressings, hydrogel dressings, impregnated gauzes, or dressings with debriding agents in terms of wound healing.

#### Strength of Evidence

Because of their differing effects, we decided to grade the evidence separately for the different types of biological or cellular dressings. The three types of biological or cellular dressings are cryo-preserved human fibroblast derived dermal substitute, allogenic bilayered human skin equivalent, and autologous keratinocytes in a fibrin sealant.

Overall, we found moderate strength of evidence that allogenic bilayered cultured human skin equivalents have a moderate effect on wound healing when compared with compression systems alone (Table 16). We also found moderate strength of evidence that antimicrobial dressings had a small effect on wound healing rates when compared with other types of advanced wound dressings. The strength of the evidence comparing other advanced wound dressings in terms of wound healing was considered to be low or insufficient, generally due to a high risk of bias, inconsistent results, and/or imprecise estimates. These results could also be subjected to publication bias and selective outcome reporting.

Table 16 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and strength of evidence among studies comparing advanced wound dressings with either compression systems alone or other advanced wound dressings in terms of wound healing

Comparison | Number of Studies (Subjects) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect SOE^*^
| | Risk of Bias | Consistency | Directness | Precision
Hydrocolloids vs. compression | 3 (361) | Medium | Consistent | Direct | Imprecise | No effect Low SOE
Hydrocolloids vs. other dressings | 4 (420) | High | Inconsistent | Direct | Precise | Unclear effect Insufficient SOE
Transparent films vs. compression | 1 (54) | High | NA | Direct | Imprecise | Unclear effect Insufficient SOE
Transparent films vs. other dressings | 1 (20) | High | NA | Direct | Imprecise | Unclear effect Insufficient SOE
Alginates vs. alginates | 2 (101) | High | Inconsistent | Direct | Imprecise | Unclear effect Insufficient SOE
Alginates vs. other dressings | 1 (113) | High | NA | Direct | Imprecise | Unclear effect Insufficient SOE
Foam vs. foam | 3 (296) | High | Unknown - heterogeneity in interventions | Direct | Imprecise | Unclear effect Insufficient SOE
Collagen vs. compression | 1 (120) | Low | NA | Direct | Imprecise | Moderate effect Low SOE
Acellular HSE vs. compression | 3 (267) | High | Unknown - heterogeneity in interventions | Direct | Imprecise | Unclear effect Insufficient SOE
Cellular (cryo-preserved human fibroblast-derived dermal substitute) vs. compression | 2 (70) | Medium | Inconsistent | Indirect | Imprecise | Unclear effect Insufficient SOE
Cellular (allogenic bilayered cultured HSE) vs. compression | 1 (275) | Low | NA | Direct | Precise | Moderate effect Moderate SOE
Cellular (autologous keratinocytes in fibrin sealant) vs. compression | 1 (225) | Medium | NA | Direct | Precise | Small effect Low SOE
Cellular skin replacements vs. other dressings | 2 (225) | High | Consistent | Direct | Imprecise | Unclear effect Insufficient SOE
Antimicrobial dressings vs. compression | 2 (194) | High | Consistent | Direct | Imprecise | Unclear effect Insufficient SOE
Antimicrobial dressings vs. antimicrobial dressings | 2 (342) | Medium | Unknown -heterogeneity in interventions | Direct | Precise | Unclear effect Insufficient SOE
Antimicrobial dressings vs. other dressings | 4 (515) | Medium | Consistent | Direct | Precise | Small effect Moderate SOE

HSE = human skin equivalent; SOE = strength of evidence; vs. = versus

* We defined the strength of evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

### Mortality

We included 11 studies that reported on mortality.20, 22, 26, 28, 32, 33, 38, 44, 47, 49, 50 In most of these studies, deaths were rare, occurring in less than 5 percent of patients, and did not differ between intervention groups.

### Quality of Life

In this report, we classified QOL measures as either general health-related QOL (nonspecific measures) or ulcer-specific QOL (QOL associated with venous ulcers). One study evaluated health-related QOL using six validated QOL assessment tools.22 Three other studies used customized QOL assessment tools that were specific to each study and not validated.23, 39, 48Table 17 categorizes these QOL assessment tools into general health-related QOL and ulcer-specific QOL.

Table 17 Health-related quality of life assessment tools used in each category

Domain | Instrument | Range of Total Scores (High Scores Indication)
General health-related QOL | EuroQol 5D (EQ-5D) | -0.59 – 1 (better QOL)
General health-related QOL | Short Form 6D (SF-6D) | 0.29 – 1 (better QOL)
General health-related QOL | Customized for study | Varies
Ulcer-specific QOL | Customized for study | Varies

QOL = quality of life

#### Hydrocolloid Dressings

Two studies examined the comparative effectiveness of hydrocolloid dressings versus control dressings on general and ulcer-specific QOL in adults with venous leg ulcers (Table 18).39, 48 One study examined the comparative effectiveness of hydrocolloid dressings versus paraffin-impregnated gauze dressings using ulcer-specific QOL measures that assessed comfort, convenience, ease of use, and aesthetic appearance of the dressings.39 This study did not find a statistically significant difference in QOL between the two intervention arms.39 Another study examined the comparative effectiveness of hydrocolloid dressings versus conventional dressings using ulcer-specific QOL measures that assessed discomfort during dressing change (no discomfort, mild discomfort, moderate discomfort, severe discomfort, intolerable discomfort) and convenience while changing the dressing (most convenient, quite convenient, convenient, inconvenient, totally inconvenient).48 This study found that patients favored hydrocolloid dressings over conventional dressings for ulcer-specific QOL measures related to discomfort and convenience during dressing change.48

Table 18 Quality of life in hydrocolloid dressings versus controls

QOL Domain | Author, Year | Comparison (N) | Population | Difference in QOL Between Comparison Groups | Group Favored for QOL Measure
Custom^*^ | Arnold, 1994^39^ | Hydrocolloid dressings (35) vs. impregnated gauze (35) | 70 patients (mean age 65 years for hydrocolloid dressings and 60 years for control) with lower extremity venous ulcers | After 10 weeks of followup, 60% of the hydrocolloid-dressing group and 50% of the control group were satisfied with their treatment (score ≤ 2) based on comfort, ease of use, and aesthetics (P=0.3). | Neither
Custom^*^ | Greguric, 1994^48^ | Hydrocolloid dressings (55) vs. conventional dressing (55) | 110 patients (mean age 61 years for both groups) with venous leg ulcers | After 10 dressing changes of followup, hydrocolloid dressing caused less discomfort than control (P=0.003), and hydrocolloid was significantly more convenient than control (P=0.004). | Hydrocolloid dressing

QOL = quality of life; vs. = versus

* Ulcer-specific QOL measure. Custom patient satisfaction questionnaire used by Arnold et al. assessed comfort, convenience, ease of use, and aesthetic appearance of the treatment modality using a 10-point scale ranging from 0 to 10, with higher scores indicating discomfort and difficulty of use. Custom patient satisfaction questionnaire used by Greguric et al. assessed discomfort during dressing change (no discomfort, mild discomfort, moderate discomfort, severe discomfort, intolerable discomfort) and convenience while changing the dressing (most convenient, quite convenient, convenient, inconvenient, totally inconvenient). Numerical translation of these ratings was not provided.

#### Foam Dressings

One study examined the comparative effectiveness of a foam dressing with ibuprofen versus foam dressing without ibuprofen on general QOL in adults with venous leg ulcers (Table 19).23 The study questionnaire assessed changes in responses to four domains of the patients' activities of daily living, which included appetite, sleep, mood/feeling, and well-being.23 This study did not find a statistically significant difference in QOL between the two intervention arms.23

Table 19 Quality of life in foams versus controls

QOL Domain | Author, Year | Comparison | Population | Difference in QOL Between Comparison Groups | Group Favored for QOL Measure
Custom^*^ | Gottrup, 2008^23^ | Ibuprofen-foam (62) vs. foam alone (60) | 122 patients (mean age 66 years for Ibuprofen-foam, 70.0 years for control) with venous leg ulcers | After 6 weeks of followup, the two study groups had no statistically significant differences in four domains of the patients' ADL: appetite, sleep, mood/feeling, and well-being. | Neither

ADL = activities of daily living; QOL = quality of life

* General QOL measures. Custom questionnaire used by Gottrup et al. used three responses (improved, stayed the same, deteriorated) across four domains (appetite, sleep, mood/feeling, and well-being) and did not provide a standardized QOL measure on a numerical scale.

#### Antimicrobial Dressings

One study examined the comparative effectiveness of antibacterial dressings versus nonantibacterial control dressings on general and ulcer-specific QOL in adults with venous leg ulcers (Table 20).22 One study examined general QOL in adults with venous leg ulcers using EuroQoL 5D, and did not show a statistically significant difference in QOL between silver-releasing antibacterial dressings and nonantibacterial dressings in this population.22 This study also used the Short Form 6-Dimensions QOL measure, and did not find a statistically significant difference in QOL between the two intervention arms.22

Table 20 Quality of life in antibacterial dressings versus controls

QOL Domain | Author, Year | Comparison | Population | Difference in QOL Between Comparison Groups | Group Favored for QOL Measure
EQ-5D^*^ | Michaels, 2009^22^ | Silver (107) vs. nonsilver dressing (106) | 213 patients (mean age 69 years for silver, 72 years for nonsilver) with venous leg ulcers | After 12 months of followup, mean difference between silver (0.7526) and nonsilver groups (0.6752) was -0.0774 (P>0.05) | Neither
SF-6D^*^ | Michaels, 2009^22^ | Silver (107) vs. nonsilver dressing (106) | 213 patients (mean age 69 years for silver, 72 years for nonsilver) with venous leg ulcers | After 12 months of followup, mean difference between silver (0.7092) and nonsilver (0.6662) groups was -0.0430 (P>0.05) | Neither

EQ-5D = Euro Quality of Life 5-Dimensions; SF-6D = Short Form 6-Dimensions; QOL = quality of life

* General QOL measures. Total scores from EuroQol 5-Dimensions range from -0.59 to 1, with higher scores indicating better quality of life. Total scores from Short Form 6D range from 0.29 to 1, with higher scores indicating better quality of life.

#### Other Types of Advanced Wound Dressings

We did not find any studies that met our inclusion criteria and evaluated transparent film dressings, alginate dressings, composite dressings, specialty absorptive dressings, contact layer dressings, hydrogel dressings, collagen dressings, acellular human skin equivalent dressings, cellular human skin equivalent dressings, impregnated gauzes, and dressings with debriding agents in terms of QOL.

### Pain

#### Hydrocolloid Dressings

##### Hydrocolloid Dressings Versus Other Types of Dressings

One trial compared hydrocolloids with Betadine^®^ and a contact layer in terms of ulcer pain (moderate to severe) and dressing comfort (very to fairly comfortable) for the first month of treatment.50 The hydrocolloid group experienced less pain than the Betadine^®^ and contact layer group among small and large ulcers (P=0.02). Both groups experienced more pain with large ulcers (P<0.001). The treatments did not differ in their effect on dressing comfort, but large ulcers tended to be less comfortable (P=0.02).50

Another trial comparing hydrocolloid with impregnated gauze with magnesium sulfate and Vaseline^®^ found that patients had no discomfort at the fifth dressing change in the hydrocolloid group, but more than 20 percent of the patients experienced discomfort by dressing change 10 of the impregnated gauze group (P=0.0003).48

Another trial compared hydrocolloid with impregnated gauze containing paraffin or Betadine^®^. Patients rated their pain on a scale of 0 (minimal pain) to 10 (maximal pain).39 Patients in the hydrocolloid group reported less pain at followup as compared with patients in the impregnated gauze group. Additionally, 60 percent of the hydrocolloid group and 50 percent of the impregnated gauze group rated their treatment as very comfortable, but this difference was not statistically significant (P=0.3).39

Lastly, in the trial that compared a hydrocolloid with an alginate, the patients ranked their pain on a 4-point numeric scale as follows: 1 = painless, 2 = slight pain, 3 = painful, 4 = very painful.53 Wounds treated with the alginate dressing were less painful at week 0 (P=0.0004) than those treated with the hydrocolloid and remained that way at week 6 (P=0.03).53

Although these studies suggested that patients had less pain with use of hydrocolloid dressings than with other types of dressings, the strength of evidence was insufficient to support a firm conclusion because of the marked heterogeneity of the studies.

#### Transparent Film Dressings

##### Transparent Film Dressings Versus Other Types of Dressings

The trial comparing an alginate plus transparent film with an alginate plus foam evaluated pain on a 1 to 4 scale: 1 = painless, 2 = slightly painful, 3 = sufficiently painful to require analgesia, and 4 = painful enough to interfere with lifestyle and not relieved with high levels of analgesia.54 The alginate plus foam group experienced a 26 percent reduction of pain scores and the alginate plus transparent film group experienced an 18 percent reduction in pain scores, but the difference between groups was not statistically significant.54

#### Alginate Dressings

##### Alginate Dressings Versus Other Alginate Dressings

The trial comparing the alginates, Sorbsan^®^ with Tegagen™ HG, evaluated patient comfort during wear of the dressing and comfort during removal of the dressing on a scale of 1 to 5 (1 = very good and 5 = very poor).35 Patients in the Sorbsan alginate group experienced much more comfort during dressing wear (P=0.0005) and dressing removal (P=0.003).35

#### Specialty Absorptive Dressings

##### Specialty Absorptive Dressings Versus Other Types of Dressings

In a trial comparing a hydropolymer dressing with an alginate plus transparent film and an alginate plus cotton gauze pad, the investigators asked the patients to rate comfort on a scale of 1 to 5 (1 = poor comfort and 5 = good comfort).36 Patients rated the hydropolymer dressings higher in comfort (mean comfort score, 4.27) than the alginate plus transparent film (mean comfort score, 3.37) or the alginate plus cotton gauze pad (mean comfort score, 3.74; P<0.02).36

#### Acellular Human Skin Equivalent Dressings

##### Acellular Human Skin Equivalent Dressings Plus Compression Versus Compression Systems Alone

One trial evaluated pain on a scale of 0 to 10 comparing Amelogenin protein 30 milligrams per milliliter solution (Xelma^®^ ECM) plus a soft silicone dressing with a control dressing of 7 percent propylene glycol alginate.30 The mean baseline pain score for the treatment group was 4 compared with 3 for the control. Both groups had a pain score of 1 on the final visit. The trial did not show any statistical between-group comparisons.

#### Antimicrobial Dressings

##### Antimicrobial Dressings Plus Compression Versus Compression Systems Alone

A trial comparing cadexomer iodine to saline wet to dry dressings, reported pain but did not use a specific scale, making it difficult to interpret the findings.42 However, the investigators reported that there was no statistically significant difference in pain between the two groups.42 In another trial that compared pale sulfonated shale oil 10 percent plus Jelonet to vehicle plus Jelonet, pain was reported on a visual analog scale of 0 (no pain) to 10 (maximal pain).31 The investigators reported no significant difference in pain between groups.31

##### Antimicrobial Dressings Versus Other Antimicrobial Dressings

A randomized optional crossover trial compared cadexomer iodine to gentian violet and Polyfax™ ointment (standard treatment) over 24 weeks among 61 outpatients and evaluated pain on a linear scale of 0 to 100.^44^ The trial compared the change in pain per week and found no statistical significance.44

##### Antimicrobial Dressings Versus Other Types of Dressings

A trial comparing cadexomer iodine to a hydrocolloid dressing and a paraffin gauze dressing reported the percentage of wounds with pain at different time points.37 While 29 percent of the cadexomer iodine group, 57 percent of the hydrocolloid group, and 15 percent of the paraffin gauze group reported pain at week 12, the trial did not report the intensity of the pain nor did it make a statistical comparison between groups. It also did not use a specific pain scale.37

#### Other Types of Advanced Wound Dressings

We did not find any studies that evaluated how foam dressings, composite dressings, contact layer dressings, hydrogel dressings, collagen dressings, cellular human skin equivalent dressings, impregnated gauzes, or dressings with debriding agents affected pain.

### Condition of the Wound Bed

#### Transparent Film Dressings

##### Transparent Film Dressings Versus Other Types of Dressings

A trial comparing a transparent film with a foam as a secondary dressing over an alginate evaluated wound appearance on a scale of 1 to 4 (1 = healed; 2 = clean and epithelializing; 3 = clean and sloughy or mildly sloughy; and 4 = infected, very sloughy and odorous).53 While both groups started with a comparable number of wounds ranked as sloughy/infected, the transparent film group experienced a 32 percent reduction in total wound condition scores while the foam group experienced a 40 percent reduction in total wound condition scores. The trial made no statistical comparisons between groups.53

#### Alginate Dressings

##### Alginate Dressings Versus Other Alginate Dressings

A trial comparing the alginate dressings, Sorbsan^®^ and Tegagen™ HG evaluated the wound-bed condition for the amount of exudate, purulent or serosanguinous exudate, necrotic tissue, foul odor, and the need for debridement over 6 weeks.35 A medium to large amount of exudate was present in 86 percent of visits in the Sorbsan^®^ group and 72 percent of visits in the Tegagen™ group, but this difference was not significant (P=0.18). Likewise, purulent or serosanguinous exudate was present in 72 percent of visits in the Sorbsan^®^ group and 48 percent of visits in the Tegagen™ wounds (P=0.24). Necrotic tissue was present in 69 percent of the visits in the Sorbsan^®^ group and 60 percent of visits in the Tegagen™ group (P=0.57). A foul odor was present for 58 percent of visits in the Sorbsan^®^ group and 16 percent of visits in the Tegagen™ group. The trial found this significant between groups (P<0.02). Lastly, wounds in the Sorbsan^®^ group required debridement in 41 percent of the visits while wounds in the Tegagen™ group required debridement in 19 percent of visits (P=0.18).35

#### Specialty Absorptive Dressings

##### Specialty Absorptive Dressings Versus Other Types of Dressings

A trial, comparing a hydropolymer dressing with an alginate plus transparent film and an alginate plus cotton gauze pad, evaluated the wound bed for odor during 4 weeks in moderately to heavily exuding wounds.36 The investigators used a scale of 1 to 5 to evaluate odor (1 = poor odor control and 5 = good odor control). The investigators gave a higher control of odor score to the hydropolymer dressing (mean odor score, 4.24) than the alginate plus transparent film group (mean odor score, 2.95; P<0.001). The alginate plus cotton gauze pad received the same mean odor score as the hydropolymer dressing. The patients gave a higher control of odor score to the hydropolymer dressing (mean odor score 4.45) than alginate plus transparent film (mean odor score, 3.05) and the alginate plus cotton gauze pad (mean odor score, 3.96; P=0.001).36

#### Acellular Human Skin Equivalent Dressings

##### Acellular Human Skin Equivalent Dressings Plus Compression Versus Compression Systems Alone

An RCT, comparing amelogenin protein 30 milligrams per milliliter solution (Xelma^®^ ECM) plus a soft silicone dressing with a control dressing of 7 percent propylene glycol alginate, analyzed the wound bed for percent of viable tissue and amount of exudate expressed over time.30 The study extrapolated these data from figures within the published study using the software DigitizeIt 1.5 (ShareIt Inc., Koln, Germany). However, the trial made no statistical comparisons of the within- and between-group differences. The percent viable tissue in wound bed of amelogenin at baseline was 52 versus 77 percent for the comparison group. At the study end-point, the mean percentage of viable tissue in the wound bed of the amelogenin-treated group was 91 versus 92 percent for the comparison group. The study ranked 0 percent of the wounds in the amelogenin and comparison groups as having high exudate at baseline. At the final evaluation, 14 percent of the amelogenin group had high amounts of exudate versus 22 percent in the control group.30

#### Cellular Human Skin Equivalent Dressings

##### Cellular Human Skin Equivalent Dressings Plus Compression Versus Compression Systems Alone

A trial comparing Dermagraft^®^ 12 pieces over 12 weeks, versus four pieces over 12 weeks, versus one piece over 12 weeks evaluated the histology of the wound bed.47 A greater number of blood vessels formed in the wounds treated with four pieces of Dermagraft^®^ over 12 weeks (P=0.037). High numbers of blood vessels at week 0 (P=0.06) and week 6 (P=0.04) correlated with increased numbers of healed wounds at week 12 and a significant percentage reduction in wound area by week 12 (P=0.05). While Dermagraft^®^ had no significant influence on the number of blood vessels forming fibrin cuffs, a low percentage of blood vessels with fibrin cuffs in the granulation tissue near the ulcer surface at week 0 and 6 correlated with an increased percentage of healing at weeks 6 and 12 as well as with the number of patients healed.

Another trial, comparing the cellular human skin equivalent, Dermagraft^®^, with compression over 12 weeks, histologically evaluated wound beds by biopsy at the beginning of treatment and at week 6 (if the ulcer was not healed).34 While the Dermagraft^®^ group saw an increase in capillary count in the wound bed compared with compression, it was not statistically significant (P=0.36). Likewise, the 25 percent increase in skin blood flow by blood perfusion in the Dermagraft group versus 9 percent increase in the compression group was not statistically significant (P=0.55).34

#### Antimicrobial Dressings

##### Antimicrobial Dressings Plus Compression Versus Compression Systems Alone

A trial comparing cadexomer iodine with wet to dry saline gauze under compression over 24 weeks found no significant difference when the study evaluated wound beds for granulation tissue (P=0.16), exudate (P=0.96), and pus/debris (P=0.55).42 Likewise, a trial comparing pale sulfonated shale oil 10 percent plus Jelonet™ to vehicle plus Jelonet™ over 20 weeks, found no significant difference between groups when evaluating wound beds for fibrinous discharge and necrotic tissue.31

##### Antimicrobial Dressings Versus Other Types of Dressings

One trial compared cadexomer iodine versus hydrocolloid versus paraffin gauze over 12 weeks.37 Cadexomer iodine treatment resulted in less slough at 4 and 8 weeks than the paraffin gauze treatment group (P<0.05) and the hydrocolloid group had significantly less slough than the paraffin gauze group at week 4 only (P<0.05).37

Another trial that enrolled 32 patients compared hydrogel with hydrogel plus M. tenuiflora extract (MTC-2G), a substance with alleged antiseptic properties.56 The study evaluated the percentage of granulation tissue, fibrin, maceration, wound exudates, and necrosis and found no significant difference in the clinical condition of the wound beds after 8 weeks. However, the presence of epithelial islands was greater in the MTC-2G group (58 percent) than in the hydrogel only group (39 percent; P=0.02). Investigators took biopsies at the beginning and end of the trial to evaluate the wounds for necrosis, perivascular fibrosis, presence and type of inflammatory infiltrates, granulation tissue, and new vessel formation. Both groups had five patients with necrosis present in the biopsies taken at the beginning of the trial, but on final biopsy, the MTC-2G group had one patient versus four in the hydrogel group (P=0.035) that showed residual necrosis in the biopsy. In the end, the study only biopsied 21 patients as it was deemed unethical to obtain biopsies from patients with healed wounds or wounds that decreased to less than 5 millimeters. The study saw no difference between initial and final biopsies concerning fibrosis, vascular proliferation, granulation tissue, or perivascular fibrosis. However, the density of the lymphocytic and neutrophilic inflammatory infiltrates decreased in both groups on final biopsy. Moreover, the density of neutrophils decreased in the MTC-2G group compared with the hydrogel group after treatment (P=0.05).56 Measuring the density of inflammatory infiltrates by histological analysis is extremely difficult because of sampling variability.

##### Antimicrobial Dressings Versus Other Antimicrobial Dressings

A randomized optional crossover trial compared cadexomer iodine with gentian violet and Polyfax ointment (standard treatment) over 24 weeks among 61 outpatients and evaluated the condition of the wound bed based on the presence of granulation tissue, exudate pus, and debris.44 The study found no significant differences between the treatment groups.44

##### Other Types of Advanced Wound Dressings

We did not find any studies evaluating how hydrocolloid dressings, foam dressings, composite dressings, contact layer dressings, hydrogel dressings, collagen dressings, impregnated gauzes, or dressings with debriding agents affected the condition of the ulcer bed.

### Maceration

No study meeting our specified selection criteria evaluated the effect of the following dressings on maceration: hydrocolloid dressings, transparent films, alginates, foams, composites, specialty absorptive dressings, contact layer, hydrogels, collagen dressings, acellular human skin equivalents or extracellular matrices, cellular human skin equivalents or extracellular matrices, antibacterial dressings, impregnated gauzes, or biologic debriding agents.

### Infection

#### Hydrocolloid Dressings

##### Hydrocolloid Dressings Plus Compression Versus Compression Systems Alone

Four RCTs (that analyzed a total of 463 participants at 3 to 4 months of followup) compared a hydrocolloid dressing with a standard dressing in terms of the effects on wound infection rates.37, 43, 48, 50 Infection rates were similar across arms for all studies43, 48, 50 with the exception of the subgroup of participants with baseline ulcer size greater than 4 cm in Smith, 1992 et al.50 In this study, those receiving a hydrocolloid dressing (Biofilm powder plus Biofilm dressing) developed fewer infections at 4 months (one out of 35 patients; 3 percent) compared with the control group which received a Betadine^®^/Jelonet™ dressing (11 out of 39, 28 percent; P=0.004).50 Infection rates were similar in the participants with a baseline ulcer size of 2 to 4 cm regardless of study arm.50 Two studies did not provide definitions of infection,37, 43 and the two others used different definitions (“acute infection50” and “erysipelas48”) (Tables 21 and 22).

Table 21 Summary of infection rates as an adverse event among patients with chronic venous ulcers comparing hydrocolloid dressings with a standard dressing and compression system

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used in Both Groups | Followup Time | Infection Rate in Group 1, N / N (%) | Infection Rate in Group 2, N / N (%)
Backhouse, 1987^43^ | Nonadherent, nonocclusive dressing | Hydrocolloid - Granuflex (occlusive hydrocolloid) | Multilayer | 12 weeks | 3 / 28 (11) | 4 / 28 (14)
Greguric, 1994^48^ | Magnesium sulfate paste + Vaseline + gauze | Hydrocolloid - Varihesive E (hydrocolloid in adhesive elastomeric polymer matrix with outer film coated polyurethane foam) | 2-layer | NR | 0 / 55 (0) | 1 / 55 (2)
Smith, 1992^50^ Among those with initial ulcer size of 2–4 cm | Betadine/Jelonet | Hydrocolloid Biofilm powder + Biofilm dressing | 2-layer compression linear, graduated (Tubigrip or Venosan 2002) | 4 months | 1 / 62 (2) | 0 / 64 (0)
Smith, 1992^50^ Among those with initial ulcer size of > 4 cm | Betadine/Jelonet | Hydrocolloid Biofilm powder + Biofilm dressing | 2-layer compression linear, graduated (Tubigrip or Venosan 2002) | 4 months | 11 / 39 (28) | 1 / 35 (3); P=0.004
Hansson, 1998 37 | Jelonet paraffin gauze | Hydrocolloid Duoderm E | Comprilan short-stretch | 12 weeks | 4 / 49 (8) | 5 / 48 (10)

cm = centimeters; NR = not reported

Table 22 Definitions of wound infection reported in included studies

Author, year | Infection Definition
Gottrup, 2008^23^ | Coexistent presence of the classical signs of clinical infection: pain, erythema, edema, heat, and purulence
Mostow, 2005^32^ | Not further specified
Hansson, 1998^37^ | Not further specified
Falanga, 1998^38^ | Not further specified
Backhouse, 1987^43^ | Not further specified
Krishnamoorthy, 2003^47^ | Characterized as: local wound infection, cellulitis, or osteomyelitis
Greguric, 1994^48^ | Erysipelas cruis
Smith, 1992^50^ | Acute infection

#### Foam Dressings

##### Foam Dressings Versus Other Foam Dressings

In a single, multicenter European RCT of 122 patients with chronic venous ulcers comparing two types of foam dressings, infection rates were similar across arms.23 Two of 60 (3 percent) patients developed an infection in the foam without ibuprofen arm, and three of 62 (5 percent) patients developed an infection in the foam with ibuprofen arm.23 Both study arms used compression, and patients were likely followed for 42 days, although the study did not explicitly state this.23 The average duration of chronic venous ulcers was 20 to 23 months at baseline.23 Three of 60 participants (5 percent) withdrew consent in the foam without ibuprofen arm while seven of 62 participants (11 percent) withdrew (withdrew consent or investigators withdrew them from the study because of adverse events or protocol violations) from the foam plus ibuprofen arm.23 The study defined infection by the presence of several typical signs (Table 23).

Table 23 Summary of infection as an adverse event among patients with chronic venous ulcers comparing foam dressings to one another

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used in Both Groups | Followup Time | Infection^*^ Rate in Group 1, N / N (%) | Infection^*^ Rate in Group 2, N / N (%)
Gottrup, 2008^23^ | Foam WITHOUT ibuprofen (Biatain Non-Adhesive, Coloplast A/S) | Foam + ibuprofen (Biatain-Ibu Non-Adhesive foam dressing, Coloplast A/S) | Not specified; kept constant circumference at ankle | 42 days^†^ | 2 / 60 (3) | 3 / 62 (5)

* Definition included eczema, blisters, bullae, and urticaria.

† Presumed followup time but unclear

#### Acellular Human Skin Equivalent Dressings

##### Acellular Human Skin Equivalent Dressings Plus Compression Versus Compression Systems Alone

A single, multicenter RCT of 120 participants compared an extracellular matrix dressing with multilayer compression and reported five wound infections in the control arm and one in the active intervention arm at 12 weeks (P=0.10).32 The study did not provide a definition of infection (Table 24).

Table 24 Summary of wound infection as an adverse event among patients with chronic venous ulcers comparing acellular human skin equivalent dressings with compression systems alone

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used in Both Groups | Followup Time | Infection Rate in Group 1, N / N (%) | Infection Rate in Group 2, N / N (%)
Mostow, 2005^32^ | None | Composite acellular or extracellular matrix | Multilayer Debridement | 12 weeks | 5 events / 58 patients | 1 event / 62 patients; P=0.10

#### Biological Dressings

##### Cellular Human Skin Equivalent Dressings Plus Compression Versus Compression Systems Alone

Two RCTs (N=328) compared a cellular human skin equivalent with compression alone.38, 47 Wound infection rates were similar across cellular human skin equivalent and compression arms (Table 25).38, 47 Infection rates were very low in a study lasting 12 weeks with only a single infection occurring in one study arm.47 Similarly, infections occurred in 8 percent of participants in the RCT lasting 12 months.38 In this larger study of longer duration, dropout rates were substantial but similar across study arms (26 and 20 percent in the compression and intervention arms, respectively).38 One study included local wound infection, cellulitis, or osteomyelitis in its definition of infection47 while the other did not specify a definition.38

Table 25 Summary of wound infection as an adverse event among patients with chronic venous ulcers comparing cellular human skin equivalent dressings with compression systems alone

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used in Both Groups | Followup Time | Infection Rate in Group 1, N / N (%) | Infection Rate in Group 2, N / N (%)
Krishnamoorthy, 2003^47^ | None | Cellular human skin equivalent Dermagraft 12 pcs | Multilayer Profore | 12 weeks | 0 / 13 (0) | 0 / 13 (0)
Krishnamoorthy, 2003^47^ | None | Cellular human skin equivalent Dermagraft 4 pcs | Multilayer Profore | 12 weeks | 0 / 13 (0) | 1 / 13 (8)
Krishnamoorthy, 2003^47^ | None | Cellular human skin equivalent Dermagraft 1 pc | Multilayer Profore | 12 weeks | 0 / 13 (0) | 0 / 14 (0)
Falanga, 1998^38^ | None | Cellular human skin equivalent | Unna boot | 12 months | 10 / 129 (8) | 12 / 146 (8)

#### Antimicrobial Dressings

##### Antimicrobial Dressings Plus Compression Versus Compression Systems Alone

A single, multicenter RCT analyzing 105 participants compared a cadexomer iodine dressing with a paraffin gauze dressing plus compression and reported four wound infections in the control arm and one in the active intervention arm at 12 weeks.32 Participants in a third arm received a hydrocolloid dressing and five of 48 participants (10 percent) developed an infection (Table 26).37 The study did not provide a definition of infection (Table 22).

Table 26 Summary of infection as an adverse event among patients with chronic venous ulcers comparing antimicrobial dressings with standard dressings plus compression systems

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used in Both Groups | Followup Time | Infection Rate in Group 1, N / N (%) | Infection Rate in Group 2, N / N (%)
Hansson, 1998 37 | Jelonet paraffin gauze | Cadexomer iodine | Comprilan short-stretch | 12 weeks | 4 / 49 (8%) | 1 / 56 (2%)

#### Other Types of Advanced Wound Dressings

No study meeting our specified selection criteria evaluated the effect of the following dressings on wound infection rates: transparent films, alginates, composites, specialty absorptive dressings, contact layer, hydrogels, collagen dressings, impregnated gauzes, or biologic debriding agents.

### Contact Dermatitis

#### Hydrocolloid Dressings

##### Hydrocolloid Dressings Plus Compression Versus Compression Systems Alone

A single RCT of 110 patients with chronic venous ulcers in Croatia compared a standard dressing (gauze with magnesium sulfate paste and Vaseline^®^) with hydrocolloid Varihesive E^®^ (hydrocolloid in an adhesive elastomeric polymer matrix and coated with polyurethane foam). Both arms used two-layer compression (Table 27).48 No participant developed a contact dermatitis reaction in the control arm (zero out of 55, 0 percent), and a single participant developed contact dermatitis in the active intervention arm (one out of 55, 2 percent).48 The number of dressing changes required for complete wound healing dictated the maximum followup time with a maximum of 10 dressing changes allowed.48 The study anticipated dressing changes would occur every 5 days in the intervention arm and nearly daily in the control arm.48 The authors did not report followup time explicitly.48 On average, participants had chronic venous ulcers for 5 years at baseline.48

Table 27 Summary of contact dermatitis as an adverse event among patients with chronic venous ulcers comparing hydrocolloid dressings with a standard dressings and compression

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used in Both Groups | Followup Time | Contact Dermatitis Rate in Group 1^*^, N / N (%) | Contact Dermatitis Rate in Group 2^*^, N / N (%)
Greguric, 1994^48^ | Magnesium sulfate paste + Vaseline + gauze | Hydrocolloid Varihesive E (hydrocolloid in adhesive elastomeric polymer matrix with outer film coated with polyurethane foam) | 2-layer | NR^†^ | 0 / 55 (0) | 1 / 55 (2)

NR = not reported

* Defined as “bullous/erythematous reaction.”

† Maximum duration of followup was time to 10 dressings. Participants could have fewer than 10 dressings, and the time between dressings changes varied across participants and intervention arms.

#### Foams

##### Foam Dressings Versus Other Foam Dressings

In a single, multicenter European RCT of 122 patients with chronic venous ulcers comparing two types of foam dressings, rates of contact dermatitis were similar across study arms (Table 28).23 Four of 60 (7 percent) patients developed contact dermatitis in the foam without ibuprofen arm, and five of 62 (8 percent) patients developed contact dermatitis in the foam with ibuprofen arm.23 Both arms used compression, and likely followed patients for 42 days, although the study did not explicitly indicate the followup time.23 The average duration of chronic venous ulcers under study was 20 to 23 months at baseline.23 Three of 60 participants (5 percent) withdrew consent in the foam without ibuprofen arm while seven of 62 participants (11 percent) withdrew (withdrew consent or investigators withdrew them because of adverse events or protocol violations) from the foam plus ibuprofen arm.23

Table 28 Summary of contact dermatitis as an adverse event among patients with chronic venous ulcers comparing foam dressings to one another

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used in Both Groups | Followup Time | Contact Dermatitis Rate in Group 1^*^, N / N (%) | Contact Dermatitis Rate in Group 2^*^, N / N (%)
Gottrup, 2008^23^ | Foam WITHOUT ibuprofen (Biatain Non-Adhesive, Coloplast A/S) | Foam + ibuprofen (Biatain-Ibu Non-Adhesive foam dressing, Coloplast A/S) | Not specified, kept constant circumference at ankle | 42 days^†^ | 4 / 60 (7) | 5 / 62 (8)

* Definition included eczema, blisters, bullae, and urticaria.

† Presumed followup time but unclear

#### Other Types of Advanced Wound Dressings

No study meeting our specified selection criteria evaluated the effect of the following dressings on contact dermatitis: transparent films, alginates, composites, specialty absorptive dressings, contact layer, hydrogels, collagen dressings, acellular human skin equivalents or extracellular matrices, cellular human skin equivalents or extracellular matrices, antibacterial dressings, impregnated gauzes, or biologic debriding agents.

### Venous or Arterial Impairment

No study meeting our specified selection criteria evaluated the effect of the dressings of interest on venous or arterial impairment.

### Cellulitis

No study meeting our specified selection criteria evaluated the effect of dressings on cellulitis.

### Study Quality

The RCTs overall were at moderate risk of bias (Appendix D, Table 5). Studies tended to account for different lengths of followup and used appropriate statistical tests. Since dressing changes tended to occur in a clinical setting in most studies, we assumed reliable adherence to randomized interventions. We found numerous potential threats to internal validity in the RCTs evaluating the effect of advanced wound dressings. Many studies did not report on allocation concealment. Studies either did not attempt to mask or did not report on masking of outcome assessors. Also, studies did not report on prespecified analyses, and thus, selective reporting of results is a possibility. Most studies either did not account for or had substantial losses to followup. Finally, most studies did not provide specific definitions or details on ascertainment of adverse events.

## Key Question 2a For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with compression systems, what are the benefits and harms of using systemic antibiotics when compared with using solely compression systems?

## Key Question 2b For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components, what are the benefits and harms of using systemic antibiotics when compared with using dressings alone?

### Summary of Findings

Despite the widespread use of both local and systemic antimicrobials to treat nonhealing lower extremity ulcers in the setting of chronic venous stasis disease, we found only one RCT that addressed KQ 2a.57 This small study evaluated systemic oral antimicrobials, took place in Finland, and was published 18 years ago. The Finnish study57 enrolled 36 outpatients with chronic venous leg ulcers and randomized them to three treatment groups. The treatment groups were oral ciprofloxacin, trimethoprim, or placebo. All groups received adequate compression. The treatment assignment was double-blind, and the treatment period was 12 weeks. Final assessment for outcomes was at 16 weeks. The groups had similar ulcer size at baseline. After 16 weeks, the healing rate was 42 percent in the ciprofloxacin group, 33 percent in the trimethoprim group, and 30 percent in the placebo group. The differences in this underpowered study were not statistically significant. In patients treated with the antibiotics, emergence of resistant organisms was common and occurred in two-thirds of subjects treated with either ciprofloxacin or trimethoprim. This study did not report on the time to complete healing, wound recurrence, quality of life, pain, mortality, functional status, quality of the wound bed, and adverse events other than the emergence of resistant organisms.

### Strength of Evidence

The study that addressed KQ 2 had a high risk of bias, the most important being ascertainment bias. This study evaluated the microbiology of ulcers using methods that are now known to be inaccurate (swab culture) in a small number of subjects in a referral center. Furthermore, the sensitivity of culture technique was likely lower, as the study infrequently reported anaerobes. We cannot determine consistency since there was only one study. The study measured a direct effect. The results were imprecise, and were limited by both sample size and study design issues. These results could also be subjected to publication bias and selective outcome reporting. Thus, the strength of evidence addressing the effects of systemic antibiotics when compared with compression systems alone is insufficient.

The strength of the evidence evaluating the effects of systemic antibiotics when compared with advanced wound dressings (KQ 2b) is insufficient, as we did not find any studies addressing this comparison.

## Key Question 3a For patients with chronic venous leg ulcers, what are the benefits and harms of surgical procedures aimed at the underlying venous abnormalities when compared with using solely compression systems?

### Key Points

- Adding superficial vein surgery to compression therapy does not improve healing of chronic venous leg ulcers, but there may be a lower risk of recurrence. (Moderate strength of evidence)
- Adding minimally invasive surgical hemodynamic correction of reflux to compression therapy does not significantly affect the proportion of ulcers healed, but it may lower the risk of recurrence. (Low strength of evidence)
- Subfascial endoscopic perforator surgery (SEPS) with superficial vein surgery does not improve the rate of healing or the risk of recurrence of chronic venous leg ulcers in comparison with compression alone. (High strength of evidence)
- We were unable to draw a conclusion if sclerotherapy can improve the healing of chronic venous leg ulcers or lower the risk of occurrence when compared with compression therapy alone. (Insufficient strength of evidence)
- Insufficient evidence exists to determine whether the healing of chronic venous leg ulcers improves with the addition of radiofrequency ablation (RFA), endovenous laser therapy (EVLT), or deep venous surgery to compression therapy.

### Study Design Characteristics

We reviewed eight studies (nine publications) (Appendix D, Table 1).58-66 Two publications59, 60 reported on the same trial (Effect of Surgery and Compression on Healing and Recurrence [ESCHAR]). Barwell et al.60 reported the short-term results and Gohel et al.59 reported the long-term results.

These studies enrolled a total of 1,841 (range, 40 to 500) patients with chronic venous leg ulcers between 1988 and 2008. The studies screened an average of 596 patients, and enrolled an average of 145 patients. The enrollment rate was 13 to 93 percent, with an average of 33 percent. Six of the eight studies were RCTs,58-62, 64, 65 one was a cohort study,62 one was a retrospective cohort study,66 and one a non-RCT.63 The studies had 1 to 5 years of reported followup.

Four of the studies took place in the United Kingdom,58-60, 62, 64 one in Italy,61 one in the Netherlands,65 one in Italy,66 and one in Mexico.63 The clinic setting also varied; two studies recruited from specialist nurse-led venous ulcer clinics,58-60 one recruited from 12 centers across the Netherlands,65 one from an outpatient community base clinic,62 and four studies did not describe the source of the study population.61-64

All of these studies had at least one surgical arm: superficial vein surgery,59-62 SEPS,64, 65 and sclerotherapy58, 63, 66 (Appendix D, Table 2). All of the surgical patients had multilayer compression therapy. The comparison groups in these studies received compression therapy alone.

### Study Population Characteristics

Seven of the eight studies reported age with a median of 69 years58-60, 62-66 (Appendix D, Table 3). In studies that reported gender,59, 60, 62-66 most patients were female. The studies varied in how they factored diabetes into the study design. Diabetes was an exclusion criterion in three studies.61, 62, 64 One study58 excluded only patients with poorly controlled diabetes. The other three studies59, 60, 62, 65 included patients with diabetes, which was more prevalent in the compression group. Two studies63, 66 did not report diabetes status of the subjects.

For all patients, investigators conducted vascular evaluations using venous duplex ultrasound and arterial evaluations using the ankle brachial index. Investigators excluded patients with arterial insufficiency, defined in most studies by an ankle brachial index less than 0.8, except for two studies that used an ankle brachial index less than 0.85,^59, 60, 62^ and one study that used an ankle brachial index less than 0.9.^61^ None of the eight studies reported smoking status. Most of the publications did not describe the presence of other systemic diseases;58, 59, 61-66 only two publications reported on the prevalence of rheumatoid arthritis.60, 62

### Wound Healing

#### Superficial Vein Surgery Plus Compression Versus Compression

One RCT59, 60 and one prospective cohort study62 compared superficial vein surgery with compression alone, and reported on wound healing (Table 29 and Appendix D, Table 4). These two studies were too different to be combined in a meta-analysis.

Table 29 Summary of the proportion of ulcers healed among patients with chronic venous leg ulcers comparing superficial vein surgery with compression alone

Author, Year Study Design | Group 1 | Group 2 | Compression Used | Followup Period | Ulcer Healing in Group 1, N / N (%) | Ulcer Healing in Group 2, N / N (%) | Relative Risk Risk Difference
Gohel, 2007^59^ RCT | Compression alone | Superficial vein surgery plus compression | Multilayer | 48 months | 165 / 185 patients (89%) | 145 / 156 patients (93%); P=0.73 | RR, 0.96 (CI, 0.90 to 1.02) RD, -4% (CI, -10 to 2%)
Barwell, 2003^60^ RCT | Compression alone | Superficial vein surgery plus compression | Multilayer | 12 weeks | 141 / 185 patients (76%) | 128 / 156 patients (82%); P=0.85 | RR, 0.93 (CI, 0.83 to 1.04) RD, -6% (CI, -14% to 3%)
Barwell, 2000^62^ Prospective cohort | Compression alone | Superficial vein surgery plus compression | 4-layer | 24 weeks | 74% of limbs | 72% of limbs; P=0.67 | RR or RD not calculable

CI = 95% confidence interval; RCT = randomized controlled trial; RD = risk difference; RR = relative risk

Gohel et al.59 reported the short-term results, and Barwell et al.60 reported the long-term results of the ESCHAR trial, which compared compression alone with superficial vein surgery in addition to compression. ESCHAR was an RCT that enrolled 500 patients. It included 242 patients in the surgical intervention group and 258 patients in the compression-only group. Contamination of the defined groups after randomization limited the study--three patients in the comparison group requested surgery, and 47 patients in the surgical group refused surgery. The study performed analysis on an intention-to-treat basis. The study included patients with either a currently open ulcer (N=341) or recently healed ulcer (N=159). The average ulcer size was 2 cm^2^ (range, 1 to 5 cm^2^) and was similar in both groups. The chronicity of the ulcer was also similar in both groups, averaging 5 months (range, 3 to 11 months). All patients received arterial and venous ultrasound, and the study excluded them if they had arterial insufficiency (ankle brachial index less than 0.8) or deep venous obstruction. All randomized patients received multilayer compression dressings with graduated pressure of 40 mm Hg at the ankle to 17-20 mm Hg at the calf. The surgical arm patients underwent a surgical procedure tailored to their underlying level of superficial venous insufficiency as dictated by the venous duplex (disconnection of the saphenofemoral or sphenopopliteal junction and/or long saphenous vein striping plus varicosity avulsion if needed). The followup period was 4 years. The ulcer-healing rate was 89 percent in the compression group versus 93 percent in the surgical group (P =0.73).

The prospective nonrandomized cohort study took place in an outpatient clinic setting in England.62 Over a 4-year period (1995 to 1999), the study evaluated 669 patients (766 legs) with chronic venous leg ulcers. The study measured the ankle brachial index for all patients, and excluded 120 legs that had measured less than 0.85. All patients received 4-layer compression therapy and underwent venous duplex. The study excluded 410 legs with deep or mixed venous reflux. Only 236 legs (39 percent) had isolated superficial venous reflux and the study only offered those patients surgery. Only 56 percent of those patients accepted and underwent surgery (131 legs). The study compared the proportion of ulcers healed between the surgical group (131 legs) and the group with isolated superficial vein reflux that refused surgery (105 legs). Patient characteristics were similar in both groups, except for slightly older age and less mobility in the compression group. This study did not exclude patients with diabetes mellitus or rheumatoid arthritis. The study performed surgery on the long saphenous vein in 97 legs (74 percent), the short saphenous vein in 18 legs (14 percent), both the long and short saphenous veins in 12 legs (9 percent), and perforator veins in four legs (3 percent). Two patients received SEPS. Forty-four legs had concomitant perforator and saphenous reflux, but the study did not perform SEPS on these patients. The healing rate of ulcers was similar in both groups (72 percent in the surgical group compared with 74 percent in the medical group, P=0.67). The statistical analysis was limited in that the study treated each leg as an independent unit without adjusting for the fact that some patients had more than one ulcer in the study. Furthermore, the analysis did not account for the baseline differences between the surgical intervention and comparison groups, even though healthier and younger patients may have been biased toward having surgical intervention.

#### Minimally Invasive Ligation of Insufficient Saphenous Vein Tributaries Plus Compression Versus Compression Alone

Zamboni et al.61 compared compression alone with minimally invasive surgical hemodynamic correction of reflux (CHIVA) in addition to compression (Table 30). This was a randomized nonblinded trial that screened 80 patients and included 24 patients (with 24 ulcers) in the compression group and 21 patients (with 23 ulcers) in the surgical group. This study excluded patients if they were over the age of 80, were taking intravenous antibiotics, were nonambulatory, or had diabetes mellitus, a history of deep vein thrombosis, congenital angiodysplasia, or ankle brachial index less than 0.9. The study performed venous duplex ultrasound on all patients and excluded those with deep venous obstruction. The median ulcer size was similar in both groups (11 cm^2^ (range, 3 to 12 cm^2^) in the compression group vs. 10 cm^2^ (range, 2.6 to 11.8 cm^2^) in the surgical group). The study excluded patients with ulcers less than 2 or greater than 12 cm^2.^ This study did not report on age, gender, duration of ulcer, smoking status, or other co-morbidity. Clinical management varied across groups. Although all patients received 20 to 30 mm Hg compression dressings, some patients received additional foam or antibiotic dressings at the discretion of the treating physician. The principle of the surgical approach was to use intra-operative venous duplex ultrasound to identify and ligate (under local anesthesia) the insufficient saphenous tributaries that drain into the perforator veins. The mean followup was 3 years. The ulcer-healing rate was 96 percent in the compression group versus 100 percent in the surgical group (P>0.05).

Table 30 Summary of the proportion of ulcers healed among patients with chronic venous leg ulcers comparing CHIVA with compression therapy alone

Author, Year Study Design | Group 1 | Group 2 | Compression Used | Followup Time | Ulcer Healing in Group 1, N / N (%) | Ulcer Healing in Group 2, N / N (%) | Relative Risk, Risk Difference
Zamboni, 2003^61^ RCT | Compression + foam dressing | CHIVA | 20-30 mmHg elastic stocking | 36 months | 23 / 24 patients (96%) | 23 / 23 patients (100%); P>0.05 | RR, 0.96 (0.88 to 1.04) RD, -4% (-12% to 4%)

CHIVA = Conservative Hemodynamic treatment of Insufficiency of the Venous system in an Ambulatory setting; CI = 95% confidence interval; mmHg = millimeters of mercury; RCT = randomized controlled trial; RD = risk difference; RR = relative risk

#### Subfascial Endoscopic Perforator Surgery and Superficial Vein Surgery Plus Compression Versus Compression

Two studies included patients undergoing SEPS (Table 31).64, 65 Both studies were prospective RCTs.64, 65 The followup duration in these two studies was 24 weeks and 36 months. We did not perform a meta-analysis because of the differences between the two studies in their design, length of followup, and comparisons reported. One study used four layers of compression,64 and the other used two layers of compression.65 One study64 reported results per patient while the other65 reported results per limb.

Table 31 Summary of the proportion of ulcers healed among patients with chronic venous leg ulcers comparing SEPS with compression systems alone

Author, Year Study Design | Group 1 | Group 2 | Compression Used | Followup Time | Ulcer Healing in Group 1, N / N (%) | Ulcer Healing in Group 2, N / N (%) | Relative Risk, Risk Difference
Guest, 2003^64^ RCT | Compression alone | SEPS + compression | 4-layer | 26 weeks | 25 / 39 patients (64%) | 25 / 37 patients (68%); P=0.75 | RR, 0.95 (CI, 0.69 to 1.31) RD, -3% (CI, -25% to 18%)
Van Gent, 2006^65^ RCT | Compression alone | SEPS + compression | 2-layer | 36 months | 74 / 102 limbs (73%) | 78 / 94 limbs (83%); P=0.24 | RR or RD not calculable^*^

CI = 95% confidence interval; RCT = randomized controlled trial; RD = risk difference; RR = relative risk; SEPS = subfascial endoscopic perforator surgery

* Unable to calculate RR or RD because of lack of independency giving that some patients had two limbs included

One RCT screened 121 patients with chronic venous leg ulcers.64 The study excluded patients without superficial venous reflux or patients with diabetes mellitus, rheumatoid arthritis, vasculitis, arterial insufficiency (ankle brachial index less than 0.8), skin cancer, or trauma, and patients who were not appropriate for surgery. The study randomized 76 patients; 39 received four-layer compression and 37 patients received surgery in addition to compression. The mean duration of ulcer was similar in both groups (6 months). The median ulcer size was also similar in the groups: 10 cm^2^ in the compression group and 11 cm^2^ in the surgical group. All patients underwent venous duplex ultrasound, and all included patients had superficial venous reflux. In addition, several patients had concomitant deep venous or perforator reflux. The study tailored the surgical procedure to the underlying venous pathology (24 patients had long saphenous vein ligation and stripping, 13 had sequential avulsion, four had short saphenous vein ligation, and 24 had perforator surgery SEPS or ligation). The ulcer-healing rate at 26 weeks was 64 percent in the compression group compared with 68 percent in the surgical group (P=0.75).

Another RCT included 200 chronic venous leg ulcers in 170 patients in 12 centers in the Netherlands.65 Exclusion criteria included: ankle brachial index less than 0.8, partial or complete occlusion of a deep vein, prior SEPS procedure, and immobility. The randomization process allocated 97 ulcers to surgery in addition to two-layer compression, and 103 ulcers to two-layer compression alone. Patients had similar baseline characteristics except for diabetes mellitus, which was more prevalent in the compression group. All patients underwent venous duplex ultrasound, which helped determine the surgical procedure type: 40 patients had SEPS only (29 of them had prior superficial vein surgery), and 51 patients (59 percent) had SEPS and concomitant superficial vein surgery (ligation of long and/or short saphenous veins and stripping). The study lost four patients to followup (three in the surgical group prior to the procedure). Three patients did not undergo surgery after randomization (one due to a deep vein thrombosis, one due to a myocardial infarction, and one due to unrelated pathology). The ulcer-healing rate was 83 percent in the surgical group compared with 73 percent in the compression group (P=0.24). However, in a post hoc subgroup analysis, patients with a medial ulcer or ulcer greater than 2.5 cm^2^ had a greater proportion of healed ulcers with surgery than with compression therapy alone (P=0.04 for medial ulcer, P=0.01 for larger ulcers).

#### Sclerotherapy of Saphenous and Perforator Veins Plus Compression Versus Compression

Three studies compared sclerotherapy with compression in patients with chronic venous leg ulcers (Table 32).58, 63, 66 These three studies were too different to be combined in a meta-analysis.

Table 32 Summary of the proportion of ulcers healed among patients with chronic venous leg ulcers comparing sclerotherapy with compression systems alone

Author, Year Study Design | Group 1 | Group 2 | Compression Used | Followup Time | Ulcer Healing in Group 1, N / N (%) | Ulcer Healing in Group 2, N / N (%) | Relative Risk, Risk Difference
O'Hare, 2010^58^ RCT | Compression | Sclerotherapy - saphenous vein | Multilayer | 24 weeks | 17 / 20 (85%) | 12 / 13 (92%); P=0.72 | RR, 0.92 (CI, 0.72 to 1.17) RD, -7% (CI, -29% to 14%)
Rojas, 2009^63^ Unclear | Compression | Sclerotherapy -saphenous vein ± perforator | Multilayer + Unna boot, 20-30 mmHg | 21 weeks | 23 / 37 (62%) | 28 / 33 (85%); P=0.06 | RR, 0.73 (CI, 0.55 to 0.98) RD, -23% (CI, -43% to -3%)
Galimberti, 1988^66^ Retrospective cohort | Compression | Sclerotherapy- saphenous vein + perforator | Class 3, 40-50 mm Hg | 40 months | 46 / 46 (100%) | 72 / 72(100%) | RR, 1 RD, 0

CI = confidence interval; mmHg = millimeters of mercury; NR = not reported; RCT = randomized controlled trial; RD = risk difference; RR = relative risk

One was a prospective RCT that took place in a nurse-led clinic.58 The trial included 315 new patients and 11 followup patients. Inclusion criteria included patients with chronic venous leg ulcers with documented superficial venous incompetence without total deep vein incompetence on venous duplex. The study excluded patients with an ankle brachial index less than 0.8, poorly controlled diabetes mellitus, rheumatoid arthritis, malignancy, immobility, deep vein thrombosis, pulmonary embolism, or an inability to provide informed consent. The study randomized 40 patients. Twenty-two patients were in the four-layer compression group, and 18 patients were in the four-layer compression in addition to foam sclerotherapy group. Four patients withdrew and two patients in the sclerotherapy group did not meet inclusion criteria after randomization. One unrelated death occurred in the compression group (the study did not report the cause).The sclerotherapy was limited to the greater saphenous vein and its tributaries and did not address incompetent perforators. The followup at 24 weeks showed the healing rate of venous ulcers to be 85 percent in the compression group compared with 92 percent in the sclerotherapy group (P=0.72).

The second study compared sclerotherapy of saphenous and perforator veins with compression alone.63 The study measured ankle brachial index and performed venous ultrasound. Investigators excluded patients with an ankle brachial index less than 0.8. Thirty-seven patients were in the compression group and received compression at 20 to 30 mm Hg. Thirty-three patients were in the sclerotherapy group and received treatment to the saphenous vein as well as perforator veins if needed. The study did not describe how they allocated patients to the treatment groups or if randomization occurred. At 21 weeks of followup, the ulcer-healing rate was 62 percent in the compression group and 85 percent in the sclerotherapy group (P=0.06).

The third study, a retrospective study, compared sclerotherapy of the saphenous and perforator veins with compression alone.66 The study included patients from dermatology and vascular clinics. Forty-six patients received compression alone and 72 received sclerotherapy. All patients in both groups had ulcers that healed. The study lost one patient in the sclerotherapy group to followup.

#### Other Surgical Interventions Plus Compression Versus Compression

We did not find any data comparing RFA, EVLT, or deep venous surgery with compression therapy in terms of the healing of chronic venous leg ulcers.

### Time to Complete Ulcer Healing

#### Minimally Invasive Ligation of Insufficient Saphenous Vein Tributaries Plus Compression Versus Compression Alone

In addition to reporting on ulcer healing rates as indicated above, Zamboni et al. reported a median time to ulcer healing of 31 days (range, 17 to 53 days) in the CHIVA group versus 63 days (range, 21 to 180 days) in the compression group.61

#### Subfascial Endoscopic Perforator Surgery and Superficial Vein Surgery Plus Compression Versus Compression

In addition to reporting on ulcer-healing rates as indicated above, Guest et al.64 reported no statistically significant difference between the time-to-healing in the two treatment groups (P=0.41). The median time-to-healing was 83 days for surgery versus 98 days for compression. Even after adjusting for ulcer size and duration and prior history of deep vein thrombosis, the treatment groups did not differ in time-to-healing (adjusted hazard ratio [HR], 0.79, 95% CI, 0.45 to 1.39).

In addition to reporting on ulcer healing rates as indicated above, van Gent et al.65 reported a mean time to complete ulcer healing of 4.2 months for the surgical patients versus 5.7 months for the patients treated with compression. The median time was 11 and 15 months, respectively. This difference was not statistically significant.

#### Sclerotherapy of Saphenous and Perforator Veins Plus Compression Versus Compression

In addition to reporting on ulcer healing rates as indicated above, Rojas et al.63 reported a median of 8 weeks to complete wound healing in the surgical group compared with 20 weeks among patients in the control group.

In the Galimberti et al.66 study mentioned above, the time-to-healing for the compression-only group was a mean of 20 weeks, and for the sclerotherapy group a mean of 23 weeks.

#### Other Surgical Interventions Plus Compression Versus Compression

We did not find any data comparing RFA, EVLT, or deep venous surgery with compression therapy in terms of the time-to-healing.

### Ulcer Recurrence

#### Superficial Vein Surgery Plus Compression Versus Compression

The ESCHAR study mentioned above also evaluated ulcer recurrence in short-term59 and long-term followup (Table 33).60 As above, the study randomized 500 patients with either recently healed ulcers or chronic ulcers (average ulcer duration, 5 months; range, 3 to 11 months). For patients with healed ulcers at recruitment (73 in compression group, 86 in surgical group), or patients who healed their ulcers during the followup period (185 in compression group, 156 in surgical group), the recurrence rate varied base on the level of concomitant deep venous reflux involvement. For isolated superficial reflux, the 4-year recurrence rate was 51 percent in the compression group versus 27 percent in the surgical group (P<0.01). For patients with superficial and segmental deep venous reflux, the 3-year recurrence rate was 52 percent in the compression group versus 24 percent in the surgical group (P=0.04). For patients with superficial and total deep venous reflux, the 3-year recurrence rate was 46 percent in the compression group versus 32 percent in the surgical group (P=0.33). The proportion of ulcer-free time at 3-year followup was greater in the surgical group compared with the compression group (78 vs. 71 percent, P=0.007).

Table 33 Summary of ulcer recurrence rates among patients with chronic venous leg ulcers comparing superficial vein surgery with compression treatment alone

Author, Year Study Design | Followup Time | Ulcer Healing Compression Group, N / N (%) | Ulcer Healing Surgical Group, N / N (%) | Ulcer Recurrence in Compression Group (%) | Ulcer Recurrence in Surgical Group (%)
Gohel, 2007^59^ RCT | 48 months | 165 / 185 patients (89%) | 145 / 156 patients (93%); P =0.74 | 56% | 31%; P< 0.01
Barwell, 2004^60^ RCT | 12 weeks | 141 / 185 patients (76%) | 128 / 156 patients (82%); P =0.85 | 28% | 12%; P=0.85
Barwell, 2000^62^ RCT | 36 months | 74% of limbs | 72% of limbs; P =0.67 | 44% | 26%; P=0.03

RCT = randomized controlled trial

As mentioned in the previous section on wound healing, a prospective nonrandomized cohort study included 131 patients receiving superficial vein surgery and 105 patients receiving compression alone.62 In the surgical group, 23 patients had recently healed ulcers and 25 patients healed their ulcer while waiting for surgery. The recurrence rate at 3-year followup was better in the surgical group (26 percent) than in the compression group (44 percent; P=0.03). This was also seen at 1- and 2-year followup (14 vs. 28 percent, and 20 vs. 30 percent, respectively).

These two studies were too different to be combined in a meta-analysis.

#### Minimally Invasive Ligation of Insufficient Saphenous Vein Tributaries Plus Compression Versus Compression Alone

As reported above, one RCT61 compared compression alone with minimally invasive surgical hemodynamic correction of reflux (CHIVA) in addition to compression (Table 34). The recurrence rate at 3 years was 38 percent in the compression group compared with 9 percent in the surgical group (P<0.05).

Table 34 Summary of ulcer recurrence rates among patients with chronic venous leg ulcers comparing vein CHIVA with compression systems alone

Author, Year Study Design | Followup Time | Ulcer Healing Compression Group, N / N (%) | Ulcer Healing Surgical Group, N / N (%) | Ulcer Recurrence in Compression Group (%) | Ulcer Recurrence in Surgical Group (%)
Zamboni, 2003^61^ RCT | 36 months | 23 / 24 patients (96%) | 23 / 23 patients (100%); P<0.02 | 38% | 9%; P<0.05

CHIVA = Conservative Hemodynamic treatment of Insufficiency of the Venous system in an Ambulatory setting; RCT = randomized controlled trial

#### Subfascial Endoscopic Perforator Surgery and Superficial Vein Surgery Plus Compression Versus Compression

In the previously mentioned trial comparing SEPS with compression, the main study outcome was ulcer-free time during followup (Table 35).65 The mean followup time was 29 months in the surgical group and 26 months in the compression group. During this period, the percent of ulcer-free time was 72 percent in the surgical group compared with 53 percent in the compression group (P=0.11). Subgroup analysis showed a significant difference in ulcer-free time for patients with a medial ulcer (78 percent) versus a lateral ulcer (43 percent; P=0.02), first time ulcer (62 percent) versus recurrent ulcer (33 percent; P=0.02), and ulcers less than 4 months old (85 percent) versus ulcers more than 4 months old (39 percent; P < 0.001).

Table 35 Summary of ulcer recurrence rates among patients with chronic venous leg ulcers comparing SEPS with compression systems alone

Author, Year Study Design | Followup Time | Ulcer Healing Compression Group, N / N (%) | Ulcer Healing Surgical Group, N / N (%) | Ulcer Recurrence in Compression Group (%) | Ulcer Recurrence in Surgical Group (%)
Van Gent, 2006^65^ RCT | 36 months | 74 / 102 limbs (73%) | 78 / 94 limbs (83%); P=0.24 | 22% | 23%; P>0.05

RCT = randomized controlled trial

As shown in Table 35, the recurrence rate was similar in both groups. However, patients with first-time ulcers had a lower recurrence rate than recurrent ulcers (13 vs. 29 percent; P=0.01) regardless of the treatment group.

#### Sclerotherapy Plus Compression Versus Compression

One of the studies that evaluated this comparison reported on ulcer recurrence rates.66 Ulcer recurrence only occurred in the compression-only group with 21 patients (29 percent) reporting an ulcer recurrence (Table 36).

Table 36 Summary of ulcer recurrence rates among patients with chronic venous leg ulcers comparing sclerotherapy with compression systems alone

Author, Year Study Design | Followup Time | Ulcer Healing Compression Group, N / N (%) | Ulcer Healing Surgical Group, N / N (%) | Ulcer Recurrence in Compression, N / N Group (%) | Ulcer Recurrence in Surgical Group, N / N (%)
Galimberti, 1988^66^ | 40 months | 72 / 72 (100) | 46 / 46 (100) | 21 / 72 (29) | 0 / 46 (0); P<0.05

#### Other Surgical Interventions Versus Compression

We could not find any data comparing RFA, EVLT, or deep venous surgery with compression therapy in terms of ulcer recurrence.

### Quality of Life

Only two studies reported health-related QOL.61, 64 Zamboni et al.61 evaluated general health-related QOL using the Short Form-36 questionnaire with eight domains. They reported that patients who had surgery did better than patients who received compression alone (P<0.05). Guest et al.64 used the ulcer-specific Charing Cross Venous Ulcer Questionnaire, which showed no significant difference between the two groups at followup. However, this study also used the Short Form-36 and found that surgical patients scored better at followup in the domains of physical functioning and general health. The compression group patients scored better at followup in the domains of bodily pain and emotional role. We need to consider these results in the context of the nonblinded design, small sample size, and other bias issues that we previously mentioned.

### Mortality

None of the eight studies on KQ 3a reported any deaths related to the surgical procedure or compression therapy. During intermediate and long-term followup, several studies reported a few unrelated deaths with no difference between the treatment groups (Table 37).

Table 37 Summary of mortality rates among patients with chronic venous leg ulcers comparing surgical interventions with compression systems alone

Author, Year | Intervention, Group 1 | Intervention, Group 2 | Compression Used | Followup Time | Mortality Group 1, N / N (%) | Mortality Group 2, N / N (%)
Gohel, 2007^59^ RCT | Compression alone | Superficial vein surgery plus compression | Multilayer | 3 years | 49 / 258 (19) | 39 / 242 (16); P=0.25
Barwell, 2003^60^ RCT | Compression alone | Superficial vein surgery plus compression | Multilayer | 12 months | 26 / 258 (10) | 19 / 242 (8)
Barwell, 2000^62^ Prospective cohort | Compression alone | Superficial vein surgery plus compression | 4-layer | 24 weeks | 0^*^ | 0^*^
Guest, 2003^64^ RCT | Compression alone | SEPS + compression | 4-layer | 26 weeks | 0 / 39 (0) | 0 / 37 (0)
van Gent, 2006^65^ RCT | Compression alone | SEPS + compression | 2-layer | 36 months | 8 / 102 legs^†^ | 17 / 94 legs^†^
O'Hare, 2010^58^ RCT | Compression | Sclerotherapy - saphenous vein | Multilayer | 24 weeks | 1 / 21 (5) | 0 / 13 (0)

CHIVA = Conservative Hemodynamic treatment of Insufficiency of the Venous system in an Ambulatory setting; RCT = randomized controlled trial; SEPS = subfascial endoscopic perforator surgery

* Sixty-one patients died during the 4-year followup, but the authors did not report in which treatment arm these deaths occurred. The authors reported no postoperative deaths. The authors did not report the number of patients randomized to each treatment group.

† A total of 23 patients died during followup. Eight patients with a leg randomized to receive compression therapy and 17 patients with a leg randomized to receive surgery died. Two patients had one leg randomized to each treatment.

### Pain, Functional Status, and Quality of the Wound Bed

We did not include any studies comparing surgical techniques with compression therapy that reported on pain, functional status, or quality of the wound bed.

### Adverse Events

The authors reported very few adverse events, those reported were mostly minor wound complications. In the studies that reported on adverse events, the number of adverse events did not differ much between the treatment groups.

### Study Quality

Overall, the quality of the studies was fair (Appendix D, Table 5). Five of the eight studies were RCTs,58-61, 64, 65 but only one had adequate allocation concealment.58 None of the studies were blinded. Generally, the studies recruited intervention groups from the same population and time, and adequately reported demographic and baseline characteristics. Most studies did not report a statistical power calculation.

### Strength of Evidence

The strength of evidence is moderate that adding superficial vein surgery to compression therapy does not improve healing of chronic venous leg ulcers (Table 38). This is based on one RCT (with two publications) and one prospective cohort study. The body of evidence has a medium risk of bias. The data is direct, consistent, and precise.

Table 38 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and strength of evidence among studies comparing surgical interventions with compression systems alone in terms of wound healing or wound recurrence

Comparison / Outcome^*^ | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | Strength of Evidence^†^
| | Risk of Bias | Consistency | Directness | Precision
Superficial vein surgery vs. compression alone / wound healing | 1 RCT (500); 1 cohort (669) | Medium | Consistent | Direct | Precise | No effect Moderate SOE
CHIVA vs. compression alone / wound healing | 1 RCT (47) | Low | NA | Direct | Imprecise | No effect Low SOE
SEPS vs. compression alone / wound healing | 2 RCTs (246) | Low | Consistent | Direct | Precise | No effect High SOE
Sclerotherapy vs. compression alone / wound healing | 1 RCT (40) 2 cohorts (188) | High | Inconsistent | Direct | Imprecise | Unclear effect Insufficient SOE
Superficial vein surgery vs. compression alone / wound recurrence | 1 RCT (500); 1 cohort (669) | Medium | Consistent | Direct | Precise | Small effect Moderate SOE
CHIVA vs. compression alone / wound recurrence | 1 RCT (47) | Low | NA | Direct | Imprecise | Small effect Low SOE
SEPS vs. compression alone / wound recurrence | 1 RCT (170) | Low | NA | Direct | Precise | No effect High SOE
Sclerotherapy vs. compression alone / wound recurrence | 1 cohort (118) | High | NA | Direct | Imprecise | Unclear effect Insufficient SOE

CHIVA = Conservative Hemodynamic treatment of Insufficiency of the Venous system in an Ambulatory setting; EVLT = endovenous laser therapy; NA = not applicable; RFA = radiofrequency ablation; SEPS = subfascial endoscopic perforator surgery; SOE = strength of evidence; vs. = versus

* The strength of evidence for all comparisons not listed here were graded as insufficient because we did not find any studies addressing them.

† We defined the strength of evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

The strength of evidence is low that adding minimally invasive surgical hemodynamic correction of reflux (CHIVA) to compression therapy does not significantly affect the proportion of ulcers healed. This is based on one RCT with a small number of patients. Although this study had a low risk of bias, no other RCT exists that confirms the findings. The use of multiple interventions in the patients may also bias the results.

The strength of evidence was high that adding SEPS with superficial vein surgery to compression alone does not improve the healing rate of venous ulcers. This evidence came from two RCTs64, 65 with low risk of bias. The evidence is consistent between the two studies and is direct and precise.

The strength of evidence is insufficient that sclerotherapy is beneficial when added to compression therapy in healing chronic venous ulcers. This is based primarily on one RCT58 that failed to enroll enough patients to detect a statistically significant difference between the two groups. Power calculation called for 170 patients, but the study randomized only 40 patients. A second study was a prospective nonrandomized cohort that showed better healing rate in the sclerotherapy group compared with compression alone. The data from that study were inconsistent with the RCT and had a high risk of bias. There was one additional retrospective study that showed similar healing of venous ulcer when comparing sclerotherapy with compression.66

All of the above results are also subject to publication bias and selective outcome reporting.

The evidence is insufficient to determine the benefit of adding RFA, EVLT, or deep venous surgery to compression therapy to improve the healing rate of chronic venous leg ulcers.

## Key Question 3b For patients with chronic venous leg ulcers, what are the comparative benefits and harms of different surgical procedures for a given type of venous reflux and obstruction?

We divided the data for KQ 3b into two parts. Part 1 includes studies that compared two surgical interventions with each other, without a medical arm of compression treatment. Part 2 includes studies with no surgical or medical comparison at all. These were mostly case series. We included studies without a comparison group to address this question indirectly because we anticipated finding few, if any, comparative studies.

### Key Points

- The evidence generally is insufficient to determine the comparative benefits and harms of different surgical procedures for chronic venous leg ulcers associated with a given type of venous reflux. None of the studies provided precise estimates. We graded the evidence as insufficient because of the limited number and small size of relevant studies, and their high risk of bias.
- We did not find any studies evaluating surgical procedures for chronic venous leg ulcers associated with deep venous occlusion. (Insufficient strength of evidence)

### Study Design Characteristics

To address the comparative effectiveness and safety of surgical procedures for chronic venous leg ulcers associated with a given type of venous reflux or obstruction, we included studies that compared two surgical treatments with each other as well as studies (usually case series) with neither a surgical nor a medical comparison group. We included only those studies that had patients with documented chronic venous leg ulcers, as we described in the Methods section.

We found three studies that compared two surgical techniques (Appendix D, Table 1).67-69 Two studies were cohort studies.68, 69 The first68 took place in Egypt and Saudi Arabia, enrolled 36 patients, and followed them for 1 year. This cohort study compared isolated sapheno-femoral junction ligation with vein stripping. The second cohort study69 took place in Slovakia and followed patients for 5 years. It evaluated the open ligation of incompetent perforator veins (Linton procedure) with or without stripping compared with sclerotherapy or with an anti-reflux valvular procedure on the deep veins among 793 patients. The last study67 took place in the United States, had an unclear study design, and enrolled 46 patients with 76 treated limbs. This study compared four surgical procedures: perforator ligation plus saphenous vein stripping (PLSVS), PLSVS plus valvuloplasty, PLSVS plus vein transposition, and PLSVS plus valve transplantation.

We also found 11 studies that evaluated a surgical procedure for patients with chronic venous leg ulcers without a concurrent comparison group.14, 70-79

Five of these studies were case series.14, 70, 74-76 Five were cohort studies,71, 72, 77-79 and one had an unclear study design.73

Three of these studies took place in the United States,14, 72, 74 two took place in the United Kingdom,70, 71 two took place in Germany,78, 79 two in Australia,73, 77 one in Poland,75 and one in the Slovak Republic.76 The years of enrollment ranged from 1968 to 2010. The length of followup ranged from 1 to nearly 12 years. The median number of patients enrolled was 72 (range, 41 to 305).

Three studies evaluated venous valve surgery (Appendix D, Table 2),72, 73, 76 two evaluated RFA,14, 74 two evaluated SEPS,78, 79 two evaluated saphenous vein stripping and/or ligation,71, 75 one evaluated sclerotherapy,70 and one evaluated angioplasty/stenting.77

### Study Population Characteristics

None of the three studies with a comparison group67-69 reported baseline and demographic characteristics by study group (Appendix D, Table 3). The mean age of the patients, in the two studies that reported age, was 42 years68 and 59 years.69 Seventy-eight percent of the participants were women. Two studies68, 69 reported on the mean duration of ulcers at baseline, which ranged from 5 to 11 months. None of the studies reported smoking status, the percent of patients having diabetes mellitus or other systemic disease, or the percent of patients taking immunosuppressive medications.

Of the 11 studies without a comparison group, eight14, 71, 74-79 reported the average age of the subjects, which ranged from 54 to 74 years. Most of the participants in these studies were women, ranging from 42 to 78 percent in the nine studies reporting on patient sex.14, 70, 71, 74-79

All 11 studies reported the average duration of the ulcer at baseline. Three studies70, 71, 76 reported a median duration of 5 to 8 months (range, 3 to 420 months), while eight studies14, 72-75, 77-79 reported a mean duration of 8 to 100 months (range, 2 to 432 months). One study73 simply noted very long periods of conservative ulcer management, with 51 of 90 enrolled subjects reported as having more than 5 years of ulcer duration at baseline.

One study reported that 23 percent of the patients were smokers.75 In three studies, the percent of patients with diabetes ranged from 18 to 21 percent.14, 74, 79 In one study, two percent of the patients were taking immunosuppressives. None of the studies reported on the use of corticosteroids.14

### Part 1 Evidence From Studies That Compared Two Surgical Interventions

#### Wound Healing, Including Time to Wound Healing and Wound Recurrence

##### Perforator Ligation and Saphenous Vein Stripping Versus Perforator Ligation and Saphenous Vein Stripping Plus Valvular Surgery

One nonrandomized cohort study with 46 patients with recurrent chronic venous leg ulcers evaluated four groups: PLSVS, PLSVS plus valvuloplasty, PLSVS plus vein transposition, and PLSVS plus valve transplantation.67 The study reported wound-healing rates at 44 percent for PLSVS alone and 80 percent for PLSVS plus valvuloplasty, vein transposition, or valve transplantation (Appendix D, Table 4). In patients with incompetent deep venous valves and perforators, the disassociation of the superficial from the deep venous system (stripping) plus correction of the deep venous valvular incompetence (valvuloplasty, transposition, and valve transplant) produced superior rates of healing of chronic venous leg ulcers when compared with perforator ligation and saphenous vein stripping alone (P<0.005). The study did not report the time to complete wound healing. It followed patients for a mean of 37 months (range, 10 to 73 months). Wound recurrence was 56 percent for PLSVS, 20 percent for PLSVS plus valvuloplasty, 21 percent for PLSVS plus vein transposition, and 25 percent for PLSVS plus valve transplantation. The difference was not statistically significant between the four groups.

##### Isolated Sapheno-Femoral Junction Ligation Versus Vein Stripping

We found one cohort study that included 36 patients with chronic venous leg ulcers divided into two groups.68 Group I (10 patients) underwent isolated sapheno-femoral junction ligation, and group II (26 patients) underwent vein stripping. The baseline ulcer size and duration were similar in both groups. At 12-month followup, the wound healing rate was higher for group I (85 percent) than for group II (70 percent; P<0.05).

##### Sclerotherapy Versus Valvular Surgery

We included one nonrandomized retrospective cohort study that enrolled subjects from a single author's clinical experience (Table 39).69 The study evaluated four groups. Group I received a classical Linton procedure, vein stripping, and varicose vein extirpation. Group II received Linton SPS (small incision using a hook instrument), stripping, and varicose vein extirpation. Group III received compression sclerotherapy (Sigg's and Fegan's techniques). Group IV received an antireflux operation on the deep venous system including valvuloplasty and valve interposition. Since the Linton procedure is no longer used, we will only report on Groups III and IV. Group III (sclerotherapy) had the shortest time-to-healing with 95% of venous ulcers healed. The time-to-healing was significantly longer when clinicians documented femoral and popliteal vein insufficiency. In the group of patients with the shortest time-to-heal (up to 8 weeks), clinicians documented popliteal vein involvement in 55 percent of patients. However, the group that required more than 12 weeks to heal had 94 percent popliteal vein involvement.

Table 39 Summary of the time-to-heal and recurrence rates among patients with chronic venous leg ulcers reported in one cohort study

Group | Number of Patients | LOS (Days) | Time to Heal (Days) | Ulcer Recurrence | P
III – Compression sclerotherapy | 698 | 0 | 39±12 | 18% | NS
IV – Anti-reflux operation on deep venous system | 32 | 7 | 12-120 | Not reported | NS

LOS = hospital length of stay; NS = not significant

#### Mortality

None of the above three trials included under this section reported mortality rates.

#### Adverse Events

##### Isolated Sapheno-Femoral Junction Ligation Versus Vein Stripping

Patients who received isolated saphenofemoral ligation had less postoperative severe pain, hematoma, infection, and delayed wound healing, but had more limb swelling in comparison with saphenous vein stripping (Table 40).68

Table 40 Summary of the complication rates in patients with chronic venous leg ulcers treated with isolated sapheno-femoral junction ligation or vein stripping reported in one cohort study

Complications | Sapheno-Femoral Junction Ligation | Vein Stripping | P-Value
Severe pain | 42% | 70% | <0.05
Hematoma | 23% | 80% | <0.05
Limb swelling | 77% | 40% | <0.05
Wound infection | 15% | 30% | <0.05
Delay wound healing | 19% | 40% | <0.05

##### Sclerotherapy Versus Valvular Surgery

One cohort study reported similar complication rates (not further specified) among patients who received compression sclerotherapy compared with those who received an anti-reflux operation (Table 41).69

Table 41 Summary of the complication rate in patients with chronic venous leg ulcers treated with sclerotherapy or valvular surgery reported in one cohort study

Group | Number of Patients | Complication Rate | P-Value
III – Compression sclerotherapy | 698 | 7% | NS
IV – Anti-reflux operation on deep venous system | 32 | 6% | NS

#### Quality of Life, Pain, and Functional Status

None of the studies we reviewed reported QOL outcomes, pain measures, or functional status measures.

#### Intermediate Outcomes

We did not find any data on intermediate outcomes in these studies.

### Part 2 Evidence From Studies Without a Comparison Group

Part 2 includes 11 studies without a surgical or medical comparison group, most of which were case series.14, 70-79

#### Wound Healing, Including Time to Wound Healing and Wound Recurrence

##### Valvuloplasty, Valve Transposition, Valve Transplantation

Masuda et al. evaluated the long-term results of venous valve reconstruction.72 Forty-nine patients with chronic venous leg ulcers underwent direct femoral vein valve repair, transposition, or transplantation. Many patients had superficial and/or perforator venous insufficiency and received perforator ligation and/or saphenous vein stripping/ligation before, during, or after the primary procedure. The mean followup was 10.6 years. The 10-year cumulative clinical success rate, defined as mild or no symptoms with or without elastic compression, was 60 percent (by life-table analysis). Primary valvular insufficiency treated with valvuloplasty had far more superior clinical success than post-thrombotic valvular insufficiency treated with valve transplant or transposition (73 vs. 43 percent at 10 years, P=0.03). Significant postoperative complications included bleeding among 15 percent of patients. The recurrence rate was up to 39 percent during the followup period. Only one patient had deep vein occlusion after valve surgery at 16 years of followup.

Nash et al. reported on a retrospective analysis of 90 patients with chronic venous ulcers treated between 1979 and 1986.^73^ Investigators chose surgical procedures based on underlying venous pathology. Patients with valvular incompetence confined to perforating and superficial veins (N=42) had a 100 percent healing rate of their venous leg ulcers with one recurrence. Patients with additional but limited incompetence of deep veins (N=19) also achieved 100 percent ulcer healing, but three patients developed recurrent ulcers. Patients with extensive deep vein valvular incompetence, including popliteal valve incompetence (N=29), had the lowest healing and highest recurrence rates with 12 patients either failing to heal their ulcer or having a recurrence within 18 months.

Labas el al. reported on 56 patients with a mean age of 54 years (range, 24 to 84 years).76 Seventy-eight percent of the patients were women. These patients had venous ulceration that failed superficial vein surgery and compression therapy. Patients were treated with Fegan's technique, which consists of compression sclerotherapy combined with an anti-reflux operation (valve interposition and valvuloplasty). The healing rate was 95 percent (53 of 56 ulcers). The average time-to-healing was 39 days. The recurrence rate within 5 years was 18 percent.

##### Radiofrequency Ablation of Long Saphenous, Short Saphenous, and Perforator Veins

Harlander-Locke el al. evaluated the impact of radiofrequency endovenous ablation of incompetent superficial veins (long saphenous vein, small saphenous vein, posterior tibial perforator vein) on the healing rates of venous leg ulcers in patients that failed conventional compression therapy.74 The study performed 140 consecutive endovenous ablation procedures (74 on superficial veins and 66 on perforator veins) on 110 venous ulcers in 88 limbs. The mean ulcer duration prior to ablation was 71 months. After at least 6 months following ablation, 76 of 110 ulcers (76 percent) had healed. The mean time-to-healing was 142 days (SE, 14 days). Ulcers did not completely heal in 12 patients (26 ulcers): two patients died, six patients were still actively healing, and the study lost four patients to followup. The healing rate for all healed ulcers improved from 1.0 cm^2^/month (SE, 0.1 cm^2^/month) prior to ablation to -4.4 cm^2^/month (SE, 0.1 cm^2^/month; P<0.05) after ablation. Six of the healed ulcers (7.1 percent) recurred within 1 year.

Lawrence el al. evaluated patients who had chronic venous leg ulcers for longer than 3 months despite compression treatment.14 All patients underwent venous duplex ultrasound to assess incompetence of superficial, perforating, and deep veins. Patients with demonstrated perforator incompetence (greater than 3 mm) received vein ablation. All of these patients either had functional saphenous veins or had received saphenous vein ablation. The investigators first treated the perforator vein adjacent to the ulcer, and then treated additional incompetent veins if the ulcer didn't heal. They treated 45 patients with 75 ulcers and 86 associated incompetent perforating veins. The success rate was 58 percent for initial perforator vein ablation, and 90 percent for repeat ablation, for an overall success rate of 71 percent. No complications (skin necrosis, infection, or nerve injury) occurred. When perforator closure was successful, 90 percent of ulcers healed. The mean time-to-healing was 138 days (range, 60 to 365 days). On average, investigators ablated 1.5 incompetent perforator veins for ulcer healing.

##### Subcutaneous Paratibial Fasciotomy and SEPS

Sigala et al. described a single center study of paratibial fasciotomy and dissection of the posterior perforator veins (Hach procedure) for the treatment of patients with chronic venous leg ulcers.78 The study included 62 patients (65 percent women), with active venous ulcers. The center performed 67 subcutaneous paratibial fasciotomy procedures with saphenofemoral junction ligation and stripping in 43 limbs. The center used vacuum-assisted therapy in 28 ulcers for a median time of 8 days. The center performed autologous skin grafting in 22 patients with ulcers larger than 9 cm^2^. The cumulative ulcer-healing rate after fasciotomy was 97 percent in 1 year. Healing time was significantly related to ulcer size (P<0.001).

Wolters et al. reported a prospective observational study that evaluated endoscopic subfascial dissection of perforating veins in 74 patients with a followup of 21 months. The healing rate was 77 percent at 12 and 21 months.79

##### Sclerotherapy

Pang et al. evaluated ultrasound-guided foam sclerotherapy of superficial venous reflux in 130 consecutive patients (132 limbs) with healed and open chronic venous ulcers in terms of healing and recurrence rates.70 Eighty three of the patients had active ulcers. The study followed patients for a median of 16 months. At 1 month after the first treatment, 67 of 82 patients (82 percent) with active ulcers had healed. Among the 49 limbs with originally healed ulcers and 67 limbs that healed during the study period, five ulcers (5 percent) recurred after 2 years. This study reported a similar proportion of ulcers healed and recurrence rate as the studies that compared sclerotherapy with compression.

##### Superficial Vein Surgery

Bello et al. was a prospective study that examined how well superficial venous surgery heals venous leg ulcers.71 The study offered patients with isolated superficial venous incompetence saphenofemoral and/or saphenopopliteal surgery. None of the patients underwent perforator surgery or skin grafting. The study did not use postoperative compression hosiery or bandaging. The investigators performed superficial venous surgery on 122 legs with normal deep veins. Cumulative healing rates at 6, 12, and 18 months were 57, 74, and 82 percent, respectively. The ulcers healed in a median time of 18 weeks.

Taradaj et al. selected a group of patients that opted for surgery and another group that opted out of surgery. The study then randomly assigned these groups to one of five treatment groups: high-voltage stimulation, ultrasound, low-level laser therapy, compression stockings, and drug therapy. This study does not directly address our KQs, but it included a study arm that was treated with surgery and compression therapy. The healing rate at 7 weeks in the surgery and compression group was 53 percent, and was significantly higher than the healing rates in all of the other groups (range of healing rates in other groups, 11.4 to 37.3 percent). Ulcer recurrence rates at 2 years were lower in continued compression plus surgical treatment (18.7 percent) compared with other groups (range 25.9 to 37.5 percent).

These studies reported similar proportions of ulcers healed as the studies that compared superficial vein surgery with compression.

##### External Valvular Stenting

Lane et al. was a prospective nonrandomized study that included 41 patients with chronic venous leg ulcers that failed 6 months of medical management.77 To be included in this study, a patient had to have deep venous insufficiency involving the femoral and/or popliteal vein documented on venous duplex ultrasound and venography. The surgeons repaired 125 valves with external stenting in 42 limbs (2.98 valves per limb). The mean followup time was 7.9 years (range, 5.4 to 11.9 years). At 86 months of followup, 80 percent of ulcers healed. The ulcer areas decreased from a mean preoperative area of 12.9 cm^2^ to 1.2 cm^2^ at the same followup period. The number of stents related to an increased number of ulcers healed.

#### Mortality, Quality of Life, Functional Status, Pain, Quality of the Wound Bed, and Adverse Events

The studies included in this section did not report on these measures.

### Study Quality

Overall, the quality of the studies addressing KQ 3b was limited (Appendix D, Table 5). None of the studies were RCTs, and only three had a comparison group.67-69 Among the three studies with a comparison group, it was often difficult to determine the comparability of the different intervention groups because the studies often did not report baseline and demographic characteristics separately by group. Studies did not describe adjusting for confounding. One study recruited patients from different time periods.69 Most studies did not adequately account for loss to followup.

### Strength of Evidence

Our review of the surgical treatment of chronic venous leg ulcers did not find any RCTs that assessed the comparative benefits and harms of different surgical procedures for chronic venous leg ulcers associated with a given type of venous reflux, and did not find any studies that assessed surgical procedures for chronic venous leg ulcers associated with deep venous occlusion. The only studies we found were case series, retrospective cohort studies, and non-RCTs, often from a single institution. The populations were diverse and the studies did not describe them completely. Surgical interventions in some of the studies were patient-specific, which minimized generalizability. None of these studies included a nonsurgical comparison group, which severely limited our assessment of comparative effectiveness. We also found that the studies had a high risk of selection and publication bias, did not account for confounding or interaction effects, and were inconsistent. Due to the these limitations, we concluded that the strength of evidence generally was insufficient to estimate the comparative effectiveness of the different types of surgical interventions that could be performed for patients with chronic venous leg ulcers associated with any given type of venous reflux (see Table 42).

Table 42 Numbers of studies and subjects, strength of evidence domains, and strength of evidence among studies comparing surgical interventions for chronic venous leg ulcers, in terms of wound healing

Comparison | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | Strength of Evidence^*^
| | Risk of Bias | Consistency | Directness | Precision
PLSVS vs. PLSVS + valvuloplasty vs. PLSVS + vein transposition vs. PLSVS + valve transplantation | 1 (46) | High | NA | Direct | Imprecise | Unclear effect Insufficient SOE
Isolated sapheno-femoral junction ligation vs. vein stripping | 1 (36) | High | NA | Direct | Imprecise | Unclear effect Insufficient SOE
Sclerotherapy vs. valvular surgery | 1 (826) | High | NA | Direct | Imprecise | Unclear effect Insufficient SOE
Valvuloplasty, valve transposition, valve transplantation | 3 (195) | High | Consistent | Indirect | Imprecise | Unclear effect Insufficient SOE
RFA | 2 (unable to determine) | High | Consistent | Indirect | Imprecise | Unclear effect Insufficient SOE
Subcutaneous paratibial fasciotomy and SEPS | 2 (136) | High | Consistent | Indirect | Imprecise | Unclear effect Insufficient SOE
Sclerotherapy | 1 (82) | High | NA | Indirect | Imprecise | Unclear effect Insufficient SOE
Superficial vein surgery | 2 (153) | High | Unable to determine | Indirect | Imprecise | Unclear effect Insufficient SOE
External valvular stenting | 1 (41) | High | NA | Indirect | Imprecise | Unclear effect Insufficient SOE

NA = not applicable; PLSVS = perforator ligation and saphenous vein stripping; RFA = radiofrequency ablation; SEPS = subfascial endoscopic perforator surgery; vs. = versus

* We defined the strength of evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.