# References

1 Margolis DJ, Bilker W, Santanna J, et al. Venous leg ulcer: incidence and prevalence in the elderly. J Am Acad Dermatol. Mar. 2002;46(3):381-6. [pmid: 11862173].
2 Callam MJ, Harper DR, Dale JJ, et al. Chronic ulcer of the leg: clinical history. Br Med J (Clin Res Ed). May. 30. 1987;294(6584):1389-91. [pmid: 3109669].
3 Bergan JJ, Schmid-Schonbein GW, Smith PD, et al. Chronic venous disease. N Engl J Med. Aug. 3. 2006;355(5):488-98. [pmid: 16885552].
4 Min RJ, Khilnani NM, Golia P. Duplex ultrasound evaluation of lower extremity venous insufficiency. J Vasc Interv Radiol. Oct. 2003;14(10):1233-41. [pmid: 14551269].
5 O'Meara S, Cullum NA, Nelson EA. Compression for venous leg ulcers. Cochrane Database Syst Rev. 2009;(1):CD000265. [pmid: 19160178].
6 Sonnad S, Goldsack J, Mohr P, Whicher D. Methodological Recommendations for Comparative Effectiveness Research on the Treatment of Chronic Wounds. Version 2: Draft. 2011. Center for Medical Technology Policy. www.cmtpnet.org/news/treatmentofchronicwounds/.
7 Food and Drug Adminstration. Guidance for Industry: Chronic Cutaneous Ulcer and Burn Wounds - Developing Products for Treatment. US Dept of Health and Human Services, Clinical/Medical. June. 2006. www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/ucm071324.pdf.
8 Margolis DJ, Allen-Taylor L, Hoffstad O, et al. The accuracy of venous leg ulcer prognostic models in a wound care system. Wound Repair Regen. 2004;12(2):163-8. [pmid: 15086767].
9 Krasner DL, RG, Sibbald RG, Woo KY. Chronic Wound Care: A Clinical Source Book for Healthcare Professionals. Malvern, PA. HMP Communications. 2012;1. 5th ed.
10 Winter GD. Formation of the scab and the rate of epithelization of superficial wounds in the skin of the young domestic pig. Nature. Jan. 20. 1962;193:293-4. [pmid: 14007593].
11 Hinman CD, Maibach H. Effect of air exposure and occlusion on experimental human skin wounds. Nature. Oct. 26. 1963;200:377-8. [pmid: 14087904].
12 Landis SJ. Chronic wound infection and antimicrobial use. Adv Skin Wound Care. 2008;21(11):531-40. quiz 41-2. [pmid: 18981758].
13 Gloviczki P, Comerota AJ, Dalsing MC, et al. The care of patients with varicose veins and associated chronic venous diseases: clinical practice guidelines of the Society for Vascular Surgery and the American Venous Forum. J Vasc Surg. 2011;53(5 Suppl):2S-48S. [pmid: 21536172].
14 Lawrence PF, Alktaifi A, Rigberg D, et al. Endovenous ablation of incompetent perforating veins is effective treatment for recalcitrant venous ulcers. J. Vasc. Surg. 2011;54(3):737-42. [pmid: 21658887].
15 O'Meara S, Al-Kurdi D, Ologun Y, et al. Antibiotics and antiseptics for venous leg ulcers. Cochrane Database Syst Rev. 2010;(1):CD003557. [pmid: 20091548].
16 Palfreyman SJ, Nelson EA, Lochiel R, et al. Dressings for healing venous leg ulcers. Cochrane Database Syst Rev. 2006;3:CD001103. [pmid: 16855958].
17 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. Jun. 1998;52(6):377-84. [pmid: 9764259].
18 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. www.effectivehealthcare.ahrq.gov/methodsguide.cfm.
19 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Healthcare Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
20 Harding K, Gottrup F, Jawien A, et al. A prospective, multi-centre, randomised, open label, parallel, comparative study to evaluate effects of AQUACEL((R)) Ag and Urgotul((R)) Silver dressing on healing of chronic venous leg ulcers. Int Wound J. 2012;9(3):285-94. [pmid: 22066961].
21 Maggio G, Armenio A, Ruccia F, et al. A new protocol for the treatment of the chronic venous ulcers of the lower limb. Clin Exp Med. 2012;12(1):55-60. [pmid: 21559987].
22 Michaels JA, Campbell B, King B, et al. Randomized controlled trial and cost-effectiveness analysis of silver-donating antimicrobial dressings for venous leg ulcers (VULCAN trial). Br J Surg. 2009;96(10):1147-56. [pmid: 19787753].
23 Gottrup F, Jorgensen B, Karlsmark T, et al. Reducing wound pain in venous leg ulcers with Biatain Ibu: a randomized, controlled double-blind clinical investigation on the performance and safety. Wound Repair Regen. 2008;16(5):615-25. [pmid: 19128256].
24 Gethin G, Cowman S. Manuka honey vs. hydrogel--a prospective, open label, multicentre, randomised controlled trial to compare desloughing efficacy and healing outcomes in venous ulcers. J Clin Nurs. 2009;18(3):466-74. [pmid: 18752540].
25 Vowden P, Romanelli M, Price P. Effect of amelogenin extracellular matrix protein and compression on hard-to-heal venous leg ulcers. J Wound Care. 2007;16(5):189-95. [pmid: 17552400].
26 Vanscheidt W, Ukat A, Horak V, et al. Treatment of recalcitrant venous leg ulcers with autologous keratinocytes in fibrin sealant: a multinational randomized controlled clinical trial. Wound Repair Regen. 2007;15(3):308-15. [pmid: 17537117].
27 Gottrup F, Jorgensen B, Karlsmark T, et al. Less pain with Biatain-Ibu: initial findings from a randomised, controlled, double-blind clinical investigation on painful venous leg ulcers. Int Wound J. Suppl 1. 2007;4:24-34. [pmid: 17394627].
28 Franks PJ, Moody M, Moffatt CJ, et al. Randomized trial of two foam dressings in the management of chronic venous ulceration. Wound Repair Regen. 2007;15(2):197-202. [pmid: 17352751].
29 Nelson EA, Prescott RJ, Harper DR, et al. A factorial, randomized trial of pentoxifylline or placebo, four-layer or single-layer compression, and knitted viscose or hydrocolloid dressings for venous ulcers. J Vasc Surg. 2007;45(1):134-41. [pmid: 17210398].
30 Vowden P, Romanelli M, Peter R, et al. The effect of amelogenins (Xelma) on hard-to-heal venous leg ulcers. Wound Repair Regen. 2006;14(3):240-6. [pmid: 16808801].
31 Beckert S, Warnecke J, Zelenkova H, et al. Efficacy of topical pale sulfonated shale oil in the treatment of venous leg ulcers: a randomized, controlled, multicenter study. J Vasc Surg. 2006;43(1):94-100. [pmid: 16414395].
32 Mostow EN, Haraway GD, Dalsing M, et al. Effectiveness of an extracellular matrix graft (OASIS Wound Matrix) in the treatment of chronic leg ulcers: a randomized clinical trial. J Vasc Surg. 2005;41(5):837-43. [pmid: 15886669].
33 Harding KG, Krieg T, Eming SA, et al. Efficacy and safety of the freeze-dried cultured human keratinocyte lysate, LyphoDerm 0.9%, in the treatment of hard-to-heal venous leg ulcers. Wound Repair Regen. 2005;13(2):138-47. [pmid: 15828938].
34 Omar AA, Mavor AI, Jones AM, et al. Treatment of venous leg ulcers with Dermagraft. Eur J Vasc Endovasc Surg. 2004;27(6):666-72. [pmid: 15121121].
35 Limova M. Evaluation of two calcium alginate dressings in the management of venous ulcers. Ostomy Wound Manage. 2003;49(9):26-33. [pmid: 14581707].
36 Schulze HJ, Lane C, Charles H, et al. Evaluating a superabsorbent hydropolymer dressing for exuding venous leg ulcers. J Wound Care. 2001;10(1):511-8. [pmid: 12964233].
37 Hansson C. The effects of cadexomer iodine paste in the treatment of venous leg ulcers compared with hydrocolloid dressing and paraffin gauze dressing. Cadexomer Iodine Study Group. Int J Dermatol. 1998;37(5):390-6. [pmid: 9620490].
38 Falanga V, Margolis D, Alvarez O, et al. Rapid healing of venous ulcers and lack of clinical rejection with an allogeneic cultured human skin equivalent. Human Skin Equivalent Investigators Group. Arch Dermatol. 1998;134(3):293-300. [pmid: 9521027].
39 Arnold TE, Stanley JC, Fellows EP, et al. Prospective, multicenter study of managing lower extremity venous ulcers. Ann Vasc Surg. 1994;8(4):356-62. [pmid: 7947061].
40 Teepe RG, Roseeuw DI, Hermans J, et al. Randomized trial comparing cryopreserved cultured epidermal allografts with hydrocolloid dressings in healing chronic venous ulcers. J Am Acad Dermatol. 1993;29(6):982-8. [pmid: 8245265].
41 Pessenhofer H, Stangl M. The effect on wound healing of venous leg ulcers of a two-layered polyurethane foam wound dressing. Arzneimittelforschung. 1989;39(9):1173-7. [pmid: 2590272].
42 Holloway GA Jr., Johansen KH, Barnes RW, et al. Multicenter trial of cadexomer iodine to treat venous stasis ulcer. West J Med. 1989;151(1):35-8. [pmid: 2669345].
43 Backhouse CM, Blair SD, Savage AP, et al. Controlled trial of occlusive dressings in healing chronic venous ulcers. Br J Surg. 1987;74(7):626-7. [pmid: 3304523].
44 Ormiston MC, Seymour MT, Venn GE, et al. Controlled trial of Iodosorb in chronic venous ulcers. Br Med J (Clin Res Ed). 1985;291(6491):308-10. [pmid: 3926169].
45 Gatti MAN, Vieira LM, Barraviera B, et al. Treatment of venous ulcers with fibrin sealant derived from snake venom. J. Venomous Anim. Toxins Incl. Trop. Dis. 2011;17(2):226-9.
46 Kucharzewski M, Slezak A, Franek A. Topical treatment of non-healing venous leg ulcers by cellulose membrane. Phlebologie. 2003;32(6):147-51.
47 Krishnamoorthy L, Harding K, Griffiths D, et al. The clinical and histological effects of Dermagraft™ in the healing of chronic venous leg ulcers. Phlebology. 2003;18(1):12-22.
48 Greguric S, Budimcic D, Soldo-Belic A, et al. Hydrocolloid dressing versus a conventional dressing using magnesium sulphate paste in the management of venous leg ulcers. Acta Dermatolovenerol. Croat. 1994;2(2):65-71.
49 Moffatt CJ, Franks PJ, Oldroyd MI, et al. Randomized trial of an occlusive dressing in the treatment of chronic non-healing leg ulcers. Phlebology. 1992;7(3):105-7.
50 Smith JM, Dore CJ, Charlett A, et al. A randomized trial of biofilm dressing for venous leg ulcers. Phlebology. 1992;7(3):108-13.
51 Falanga V, Sabolinski M. A bilayered living skin construct (APLIGRAF(TM)) accelerates complete closure of hard-to-heal venous ulcers. Wound Repair & Regeneration. 1999;7(4):201-7. [pmid: 10781211].
52 Weiss RA, Weiss MA, Ford RW. Randomized comparative study of cutinova foam and allevyn with Jobst UlcerCare stockings for the treatment of venous stasis ulcers. Phlebology. 1996;11(SUPPL. 1):14-6.
53 Scurr JH, Wilson LA, Coleridge-Smith PD. A comparison of calcium alginate and hydrocolloid dressings in the management of chronic venous ulcers. Wounds: A Compendium of Clinical Research and Practice. 1994;6(1):1-8.
54 Scurr JH, Wilson LA, Coleridge Smith PD. A comparison of the effects of semipermeable foam and film secondary dressings over alginate dressings on the healing and management of venous ulcers. Wounds: A Compendium of Clinical Research and Practice. 1993;5(6):259-65.
55 Ormiston MC, Seymour MTJ, Venn GE, et al. A randomised comparison of cadexomer iodine and a standard treatment in out-patients with chronic venous ulcers. Cadexomer Iodine. 1983:63-9.
56 Lammoglia-Ordiales L, Vega-Memije ME, Herrera-Arellano A, et al. A randomised comparative trial on the use of a hydrogel with tepescohuite extract (Mimosa tenuiflora cortex extract-2G) in the treatment of venous leg ulcers. Int. Wound J. Aug. 2012;9(4):412-8. [pmid: 22128789].
57 Huovinen S, Kotilainen P, Jarvinen H, et al. Comparison of ciprofloxacin or trimethoprim therapy for venous leg ulcers: results of a pilot study. J Am Acad Dermatol. 1994;31(2 Pt 1):279-81. [pmid: 8040418].
58 O'Hare JL, Earnshaw JJ. Randomised clinical trial of foam sclerotherapy for patients with a venous leg ulcer. Eur J Vasc Endovasc Surg. 2010;39(4):495-9. [pmid: 20006528].
59 Gohel MS, Barwell JR, Taylor M, et al. Long term results of compression therapy alone versus compression plus surgery in chronic venous ulceration (ESCHAR): randomised controlled trial. BMJ. 2007;335(7610):83. [pmid: 17545185].
60 Barwell JR, Davies CE, Deacon J, et al. Comparison of surgery and compression with compression alone in chronic venous ulceration (ESCHAR study): randomised controlled trial. Lancet. 2004;363(9424):1854-9. [pmid: 15183623].
61 Zamboni P, Cisno C, Marchetti F, et al. Minimally invasive surgical management of primary venous ulcers vs. compression treatment: a randomized clinical trial. Eur J Vasc Endovasc Surg. 2003;25(4):313-8. [pmid: 12651168].
62 Barwell JR, Taylor M, Deacon J, et al. Surgical correction of isolated superficial venous reflux reduces long-term recurrence rate in chronic venous leg ulcers. Eur J Vasc Endovasc Surg. 2000;20(4):363-8. [pmid: 11035968].
63 Rojas JCM, Serrano Lozano JA, Nicolat NES, et al. Conservative treatment versus sclerotherapy treatment of saphenous and perforating venous ultrasound guided for the management of chronic venous ulcer. Tratamiento conservador versus escleroterapia segmentaria de vena safena y de venas perforantes guiada por ultrasonido para el manejo de la ulcera venosa cronica. Rev. Mex. Angiol. 2009;37(2):46-51.
64 Guest M, Smith JJ, Tripuraneni G, et al. Randomized clinical trial of varicose vein surgery with compression versus compression alone for the treatment of venous ulceration. Phlebology. 2003;18(3):130-6.
65 van Gent WB, Hop WC, van Praag MC, et al. Conservative versus surgical treatment of venous leg ulcers: a prospective, randomized, multicenter trial. J Vasc Surg. 2006;44(3):563-71. [pmid: 16950434].
66 Galimberti M, Bencini PL. Ulcus cruris: Sclerotherapy and compressive medication. Riforma Med. 1988;103(11):525-8.
67 Sottiurai VS. Surgical correction of recurrent venous ulcer. J Cardiovasc Surg (Torino). 1991;32(1):104-9. [pmid: 2010438].
68 El-Hafez EA, Seleem MI. Saphenofemoral ligation as a safe and effective alternative for the treatment of chronic venous leg ulcer. Saudi Med. J. 2004;25(2):172-6. [pmid: 14968212].
69 Cambal M, Labas P. Venous leg ulcers--a surgical treatment. Bratisl Lek Listy. 2008;109(9):391-5. [pmid: 19040144].
70 Pang KH, Bate GR, Darvall KA, et al. Healing and recurrence rates following ultrasound-guided foam sclerotherapy of superficial venous reflux in patients with chronic venous ulceration. Eur J Vasc Endovasc Surg. 2010;40(6):790-5. [pmid: 20875753].
71 Bello M, Scriven M, Hartshorne T, et al. Role of superficial venous surgery in the treatment of venous ulceration. Br J Surg. 1999;86(6):755-9. [pmid: 10383574].
72 Masuda EM, Kistner RL. Long-term results of venous valve reconstruction: a four- to twenty-one-year follow-up. J Vasc Surg. 1994;19(3):391-403. [pmid: 8126852].
73 Nash TP. Venous ulceration: factors influencing recurrence after standard surgical procedures. Med J Aust. 1991;154(1):48-50. [pmid: 1984586].
74 Harlander-Locke M, Lawrence PF, Alktaifi A, et al. The impact of ablation of incompetent superficial and perforator veins on ulcer healing rates. J Vasc Surg. Feb. 2012;55(2):458-64. [pmid: 22133452].
75 Taradaj J, Franek A, Cierpka L, et al. Early and long-term results of physical methods in the treatment of venous leg ulcers: randomized controlled trial. Phlebology. 2011;26(6):237-45. [pmid: 21478141].
76 Labas P, Cambal M. Autogenous venous valve construction. Int Angiol. 2009;28(2):147-50. [pmid: 19367245].
77 Lane RJ, Cuzzilla ML, McMahon CG. Intermediate to long-term results of repairing incompetent multiple deep venous valves using external valvular stenting. ANZ J Surg. 2003;73(5):267-74. [pmid: 12752280].
78 Sigala F, Hepp W, Menenakos C, et al. Paratibial fasciotomy with dissection of perforating veins: A surgical technique for the treatment of chronic venous ulcers. Paratibiale fasziotomie mit perforansdissektion: Ein behandlungsverfahren beim therapieresistenten ulcus cruris venosum. Phlebologie. 2007;36(5):260-4.
79 Wolters U, Schmitz-Rixen T. Endoscopic dissection in the therapy of incompetent perforating veins in ulcus cruris venosum. Die Behandlung insuffizienter Perforansvenen bei Ulcus cruris venosum durch endoskopische Dissektion. Phlebologie. 1997;26(3):92-4.
80 Sen CK, Gordillo GM, Roy S, et al. Human skin wounds: A major and snowballing threat to public health and the economy: Perspective article. Wound Repair Regen. 2009;17(6):763-71. [pmid: 19903300].
81 Kirsner R, Marston W, Snyder R, Lee T, Cargill D, Slade H. Spray-applied cell therapy with human allogeneic fibroblasts and keratinocytes for the treatment of chronic venous leg ulcers: a phase 2, multicentre, double-blind, randomised, placebo-controlled trial. Lancet. Sep. 15. 2012;380(9846):977-85. [pmid: 22863328].