# Introduction

## Background

Venous leg ulcers constitute a majority of all ulcers seen in United States, affecting between 500,000 to 2 million people annually.1 Individuals with venous leg ulcers tend to be older (over 60 years of age) and female. In the United Kingdom, where more comprehensive information is available, a 1987 study showed that the mean duration of ulcers was 9 months, 20 percent of ulcers had not healed within 2 years, and 66 percent of patients had a history of ulcerations lasting longer than 5 years.2 According to a 2006 study by Bergan et al., “chronic venous disease has been estimated to account for 1 to 3 percent of total health care budgets in countries with developed health care systems.”3

The factors that cause venous leg ulcers are elevated venous pressure, turbulent flow, and inadequate venous return. The latter can be due to venous occlusion or venous reflux. Risk factors for chronic venous disease include underlying illnesses where there is poor venous return (such as congestive heart failure and obesity), primary destruction of the venous system (such as prior history of deep venous thrombosis), recreational injected drug use (skin poppers), phlebitis, and venous valvular dysfunction.

Clinicians diagnose venous ulcers on the basis of anatomic location, morphology, and a series of characteristic skin changes. Clinicians confirm diagnosis using appropriate laboratory studies, which should include a functional assessment of the venous system. The “gold standard” for diagnosing venous disease is venography, however clinicians rarely use it because of expense, morbidity, and the availability of noninvasive tests. Today, clinicians most often use venous duplex ultrasound to diagnose venous abnormalities.4

The current standard clinical approach to therapy includes lower limb compression and debridement, which heals 40 to 60 percent of venous leg ulcers.3 O'Meara, in a 2009 Cochrane review, evaluated a total of 39 randomized controlled trials and concluded that there was reasonable evidence that compression healed venous ulcers more rapidly.5 Furthermore this review concluded that a minimum of two layers of compression, one being an elastic component, were necessary for effective therapy. Increasing the number of layers seemed to be more effective but comparisons between different compression systems was difficult. Clinicians must consider other therapies for the large number of patients for whom compression therapy and debridement fail. However, no consensus exists about which second-line treatment works best.

To evaluate the healing of venous leg ulcers with different therapies, investigators can use well-defined final health outcomes (see Figure 1), such as percentage of wounds healed based on intent to treat, and durability of healing over specified periods of time. These parameters have become the gold standards of evaluation, having gained acceptance by organizations such as the U.S. Food and Drug Administration and the Centers for Medicare and Medicaid Services.6, 7 More recently, researchers have proposed a valuable set of surrogates for complete healing. The most notable and best-confirmed surrogate is the rate of wound healing over a 4-week period of time.8 Clinicians can gauge the healing rate by tracing the wound margins and/or by using digital photography. This method mainly uses epithelialization (area reduction) to determine the healing rate. Clinicians can also determine healing rates using granulation (depth reduction) or vascularization. Other outcomes of interest include quality of life, pain, and cost-effectiveness.

Figure 1 Analytic framework for the treatment of chronic venous leg ulcers

See Tables A-C for possible interventions and comparisons

Abbreviations: DVT = deep vein thrombosis; KQ = Key Question; PICC = peripherally inserted central catheter

Figure 1 is the analytic framework diagram for the treatment of chronic venous ulcers. Chronic venous ulcers has an arrow pointing to a box with intermediate outcomes, then to a final health outcomes box. This arrow represents the key questions and treatment options. The arrow also offshoots to adverse effects of treatment and effect modifiers. The intermediate outcomes are: wound healing at four weeks, pain, and quality of wound bed (for example necrotic tissue, exudates). The final health outcomes are: time to complete wound closure, proportion of ulcers healed at twelve weeks, a wound recurrence at 24 weeks and one year, quality of life, mortality, and functional status. The adverse effects of treatment are in three columns: general, antibiotic specific, and surgery. The general adverse effects are maceration, infection, contact dermatitis, venous or arterial impairment, and cellulitis. The antibiotic-specific adverse effects are hypersensitivity, antibiotic resistance, systemic absorption, drug toxicity, C. difficile diarrhea, peripherally inserted line infection, and selection of resistant organisms. The surgery adverse effects are death, infection, bleeding, skin irritation and burning, deep vein thrombosis, and long-term recurrence reflux and ulceration. There is an arrow that runs from the key questions to the final health outcomes, and a box that comes from that line is effect modifiers. The effect modifiers are study setting, ulcer area and depth, duration of ulcer (short vs. long term), co-morbid conditions, and venous duplex testing.

Below is an overview of the three major types of interventions that clinicians currently use to manage chronic venous leg ulcers.

### Advanced Wound Dressings

Over the past 20 years, studies have generated much evidence to support the premise that a moist wound environment is essential for wound healing.9-11 This has caused a proliferation of expensive new wound dressings (see Figure 2 and Table 1), and has left wound care providers confused about when it is appropriate to use these expensive dressings.

Figure 2 Potential options for wound dressings with active chemical, enzymatic, or antimicrobial components for the treatment of chronic venous leg ulcers

Compression systems include the following elements:

- Debridement of necrotic tissue that may be by sharp, autolytic, enzymatic, mechanical (which includes pulse jet and ultrasound), or biologic debridement that leads to a clean wound base. Debridement will be classified, when possible, into wound bed debridement and excisional debridement.
- Simple dressings containing nonactive components such as moisturizers.
- At least moderate compression described either qualitatively or quantitatively (>20 mm), so that the leg does not swell significantly during the day.

Figure two is a decision tree figure for potential options for advanced wound dressings with active chemical, enzymatic, or antimicrobial components for the treatment of chronic venous ulcers. The first box is the chronic venous ulcer. This branches to two more boxes, labeled as key question one with dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components and compression systems, and the other box is compression systems. Nine boxes branch from advanced wound dressing, which are: dressings to increase moisture retention, exudates management, wound bed protection, dressings to enhance hydration, collagen dressings, skin substitutes and collagen matrixes, antimicrobial effect, impregnanted gauzes, and enhance further debridement.

Table 1 Functional categories, classifications, characteristics, and Healthcare Common Procedure Coding System classification of wound dressings with active chemical, enzymatic, biologic, or antimicrobial components

Functional Category | Classification | Characteristics | HCPS Classification
Dressings to enhance moisture retention | Hydrocolloids | - Adhesives and hydrophilic polymers (cellulose, gelatin, pectin) attached to a water-resistant polyurethane film or sheet; - Polymers form a gel on contact with wound exudate: allows for wound hydration and autolytic debridement | - Hydrocolloid dressing, wound cover, sterile
Dressings to enhance moisture retention | Transparent films | - Transparent sheets of polyurethane coated with an adhesive; - Act as a “blister roof” to provide a moist wound-healing environment, promotes autolysis, and protects the wound and peri-wound tissues from external trauma | - Transparent film, sterile
Exudate management | Alginates | - Derived from seaweed and spun into a rope or sheet dressing; - Fibrous and highly absorbent and can become gel-like when coming into contact with exudate to maintain a moist wound-healing environment | - Alginate or other fiber gelling dressing, wound cover; - Alginate or other fiber gelling dressing, wound filler
Exudate management | Foams | - Sterile, nonlinting, absorptive dressing made of open-cell, medical-grade expanded polymer; - It is nonadherent | - Foam dressing, wound cover, sterile (with/without adhesive border); - Foam dressing, wound filler, sterile
Exudate management | Composites | - Combine physically distinct components into a single dressing that provides multiple functions: (1) bacterial barrier; (2) absorptive layer other than an alginate, foam, hydrocolloid, or hydrogel; (3) either semi-adherent or nonadherent property; and (4) adhesive border | - Composite dressing, sterile with adhesive border
Exudate management | Special absorptive dressings | - Unitized, multilayer dressings that provide either a semiadherent quality or nonadherent layer and highly absorptive layers of fibers such as absorbent cellulose, cotton, or rayon | - Special absorptive dressing, wound cover, sterile with/without adhesive border
Wound bed protection | Contact layer | - Thin, nonadherent sheets placed directly on an open wound bed to protect the tissue from direct contact with other agents or dressings | - Contact layer, sterile
Dressings to enhance hydration | Hydrogels | - A polymer gel composed mostly of water in a complex network of fibers; - Water is released to keep the wound moist; - Can be hydrophilic | - Hydrogel dressing, wound cover, sterile with/without adhesive border; - Hydrogel dressing, wound filler
Collagen dressings | Sheets, wound filler gels or powder | - Freeze-dried bovine, porcine, or equine collagen; - Can contain cellulose or alginate for absorption; - Porcine small intestine submucosa extracellular matrix (Oasis^®^) | - Collagen-based wound filler, dry form; - Collagen-based wound filler, gel/paste; - Collagen dressing, sterile, pad
Biological dressings | Acellular | - Extracellular matrixes that support new tissue growth; - Three-dimensional porous matrix of cross-linked bovine tendon collagen and glycosaminoglycan (Integra™) | - Skin substitute
Biological dressings | Cellular | - Bioengineered, bi-layered, living cell-based skin substitute (Apligraf^®^); - Cryopreserved human fibroblast-derived dermal substitute (Dermagraft^®^); - Cryopreserved human skin allograft (TheraSkin^®^) | - Skin substitute
Antimicrobial effect | Alginates, foams, hydrocolloids, hydrogels, transparent films, absorptive specialty dressings, collagens | - See individual dressing characteristics; - Dressings containing silver, sodium chloride, polyhexamethylene biguanide, bismuth, manuka honey, gentian violet, polyvinyl alcohol with methylene blue, cadexomer iodine, and chlorhexidine | - HCPCS classifications as listed above
Gauzes | Impregnated | - Made of woven and nonwoven fibers of cotton, polyester, or a combination in which substances have been added such as: iodinated agents, petrolatum, zinc compounds, crystalline sodium chloride, chlorhexidine gluconate, bismuth tribromophenate, aqueous saline, hydrogel, and other agents | - Gauze, impregnated with other than water, normal saline, or hydrogel, sterile, pad; - Gauze, impregnated, water or normal saline, sterile, pad; - Gauze, impregnated, hydrogel, for direct wound contact, sterile, pad
Enhance further debridement | Biologic enzymatic debriding agent (collagenase Santyl^®^) | - Derived from fermentation by Clostridium histolyticum; - Sterile enzymatic debriding ointment that contains 250 collagenase units per gram of white petrolatum USP and that is able to digest collagen in necrotic tissue

Abbreviations: HCPCS = Healthcare Common Procedure Coding System; USP = United States Pharmacopeias

Advanced wound dressings regulate moisture found at the wound surface through moisture retention or exudate absorption, thereby protecting the wound base and tissue surrounding the wound. Additionally, maintaining a good moisture balance minimizes patient discomfort before, during, and after dressing changes. Many dressings inherently support autolytic debridement by providing added moisture, while others supply enzymatic debriding agents to rid the wound of necrotic tissue. Choice of dressings may change during the course of therapy concomitant with the changing nature of the wound base and exudate. Therefore, the selection of particular dressings requires training and expertise in wound care. Evaluating the efficacy of dressings in treating venous ulcer disease may have high relevance to morphologically similar ulcers found in patients with diabetes, arterial disease, pressure ulcers, postsurgical chronic wound ulcers, and ulcers consequent to internal diseases.

### Antibiotics

All chronic wounds become contaminated or colonized with bacteria, meaning that bacteria is present in the wound but not causing tissue damage.12 Infection occurs when the bacteria start to invade the tissue. Signs of infection include pain, redness, swelling, cellulitis, presence of exudates, and odor.

Antibiotic use is widely prevalent in the management of venous ulcers. Some experts believe that clinicians should only use antibiotics in patients that have symptoms or signs of an infected ulcer or adjacent cellulitis. However, many patients with chronic venous leg ulcers receive antibiotics in the absence of clinical symptoms or signs of infection. As shown in Figure 3 and Table 2, clinicians have many different options for adding antibiotic treatment to the management of venous ulcers. However, there is no clear guidance for the use of systemic or topical antibiotics. Clinicians must keep in mind that antibiotics have profound side effects including the development of resistant organisms, the growth of undesirable organisms, and iatrogenic disease. In addition, clinicians who use peripherally inserted central catheters to administer antibiotics for long periods of time, may put patients at risk for secondary infection complications. Furthermore, intravenous antibiotics are very costly (over $100 per day).

Figure 3 Potential systemic antibiotic treatment options for chronic venous leg ulcers

See Table 2 for a list of antibiotics.

Compression systems include the following elements:

- Debridement of necrotic tissue that may be by sharp, autolytic, enzymatic, mechanical (which includes pulse jet and ultrasound), or biologic debridement that leads to a clean wound base. Debridement will be classified, when possible, into wound bed debridement and excisional debridement.
- Simple dressings containing nonactive components such as moisturizers.
- At least moderate compression described either qualitatively or quantitatively (>20 mm), so that the leg does not swell significantly during the day.

Figure three is a decision tree figure for potential systemic antibiotic treatment options for chronic venous ulcers. The first box, chronic venous ulcer, has two branches which are compression systems and wound dressings. Each branch two additional boxes of systemic antibiotics and no systemic antibiotics. The systemic antibiotics that branches from conservative care, has three boxes branching from there, which are oral antimicrobials for Gram-positive activity, oral antimicrobials for Gram-negative activity, and intravenous antibiotic regimens. The three branches that come from the systemic antibiotics connected to advanced wound dressings are also oral antimicrobials for Gram-positive activity, oral antimicrobials for Gram-negative activity, and intravenous antibiotic regimens.

Table 2 Antibiotic treatments for chronic venous leg ulcers

Class | Indications | Drug Names | Benefits | Disadvantages
Oral antimicrobials (used primarily for Gram-positive activity) | Susceptible Staph (MSSA) and streptococci | cephalosporins (e.g., cephalexin); amoxicillin/clavulanate; dicloxacillin | Inexpensive | Usually require multiple doses/day; major adverse events include rash, intolerance, allergy
Oral antimicrobials (used primarily for Gram-positive activity) | MRSA | clindamycin | Also can treat anaerobes; allergy is rare; good bone and tissue penetration | Effective against only 50% of MRSA; requires multiple daily dosing; GI intolerance
Oral antimicrobials (used primarily for Gram-positive activity) | MRSA | trimethoprim/sulfamethoxazole | Inexpensive; good bone and tissue penetration | Interacts with warfarin; not effective against streptococci; high rate of allergy for sulfamethoxazole
Oral antimicrobials (used primarily for Gram-positive activity) | MRSA | linezolid | Effective against enterococci and streptococci; high bioavailability | Multiple contraindications (e.g., patients taking an SSRI); expensive; high rate of symptomatic side effects; thrombocytopenia
Oral drugs used for Gram-negative activity | Gram-negative organisms | quinolones (ciprofloxacin, levofloxacin, moxifloxacin) | Effective against most community acquired GNRs and Pseudomonas; rarely anaphylactoid reaction; can dose once daily; high bioavailability | GI intolerance; increased risk for C. diff; prolonged exposure can result in resistance
Oral drugs used for Gram-negative activity | Gram-negative organisms | beta lactams (amoxicillin/clavulanate, cefixime, cefpodoxime) | Usually effective first-round for community-acquired organisms | Requires multiple dosing
Intravenous antibiotic regimens | Gram-positive sensitive Staph (MSSA) | cefazolin, ampicillin/sulbactam | | Requires multiple dosing; requires prolonged IV access (usually PICC line); requires weekly monitoring
Intravenous antibiotic regimens | Gram-positive sensitive Staph (MSSA) | ceftriaxone | Can be dosed once daily | Requires prolonged IV access (usually PICC line); requires weekly monitoring
Intravenous antibiotic regimens | Gram-positive organisms (MRSA) | vancomycin | Inexpensive; effective against MRSA; can be dosed post-dialysis | Requires weekly monitoring for drug toxicity; requires frequent adjustment of dosing
Intravenous antibiotic regimens | Gram-positive organisms (MRSA) | daptomycin | Used when intolerant to vancomycin; dosed once daily; can be dosed post-dialysis | Expensive; toxicity is myositis; requires weekly CK monitoring
Intravenous antibiotic regimens | Gram-negative organisms (B-lactams) | ertapenem | Can be dosed once daily; broad spectrum for enteric Gram-negative bacteria and anaerobes; requires minimal monitoring | Not effective for Pseudomonas or many MDR organisms
Intravenous antibiotic regimens | Gram-negative organisms (B-lactams) | ceftriaxone | | No anaerobic activity
Intravenous antibiotic regimens | Pseudomonas | piperacillin/tazobactam, cefipime | Minimal toxicity profile | Requires multiple daily doses
Intravenous antibiotic regimens | Aminoglycosides | gentamicin, tobramycin, amikacin | Can be dosed once daily | Major renal toxicity; requires close monitoring of dose, drug levels, renal function

Abbreviations: C. diff = Clostridium difficile; CK = creatine kinase; GI = gastrointestinal; GNR = Gram-negative rods; IV = intravenous; MDR = multidrug resistant; MSSA = methicillin-sensitive Staphylococcus aureus; MRSA = methicillin-resistant Staphylococcus aureus; PICC = peripherally inserted central catheter; Staph = Staphylococcus; SSRI = selective serotonin reuptake inhibitor

### Surgical Interventions

Most patients with venous ulcers have significant reflux on duplex ultrasound. Clinicians define reflux as retrograde blood flow lasting greater than 0.5 seconds with the Valsalva maneuver in superficial, deep, or perforator veins. The superficial veins include the great or lesser saphenous veins while the deep veins include the femoral and popliteal veins. Obstructive venous disease is a less common cause of venous ulceration. If clinicians are considering surgery, they need duplex ultrasound (now routine in most vascular laboratories) to classify the underlying pathophysiology of a venous ulcer (see Figure 4). Clinicians perform invasive venography or measure ambulatory venous pressure when clinical and duplex ultrasound findings are insufficient to confirm the underlying pathophysiology.

Figure 4 Potential surgical treatment options for chronic venous leg ulcers

Abbreviations: KQ = Key Question; PTFE = polytetrafluoroethylene; RFA = radiofrequency ablation; SEPS = subfascial endoscopic perforator surgery

Figure 4 is a decision tree figure for potential surgical treatment options for chronic venous ulcers. The first box, venous duplex testing, branches to two more boxes labeled key question 3a as surgery and no surgery. The surgery box branches to four boxes, which are reflux in superficial system, perforator reflux, reflux in deep vein system, and obstructive reflux. Each of these branches to multiple boxes, all labeled as key question 3b. Reflux in superficial system has two branches which are vein stripping and minimally invasive procedures. Perforator reflux has four branches, which are open surgical ligation, subfascial endoscopic perforator surgery, duplex-guided radio frequency ablation, and sclerotherapy. Reflux in deep vein system has three branches which are valvuloplasty, valve transplantation, and valve transposition. Obstructive reflux has two branches which are angioplasty/stenting and bypass with vein versus polytetrafluoroethylene.

The current surgical practice is to eliminate documented reflux or obstruction in patients with chronic venous ulceration that have failed a 3-month period of compression dressing, debridement, and antibiotics.13, 14 As shown in Figure 4 and Table 3, the surgical options depend on the underlying type of reflux or obstruction. However, the indications for surgery are not standardized, and there is no consensus about which surgical option is the safest and most effective in healing the ulcer.

Table 3 Surgical treatments for chronic venous leg ulcers

Pathology | Treatment | Description
Superficial venous system | Ligation | - Sapheno-femoral junction/High saphenous ligation involves the ligation and division of the great saphenous vein at the junction with femoral vein.; - Sapheno-popliteal junction ligation involves the ligation and division of small saphenous vein at its junction with popliteal vein.; - Ligation of tributaries
Superficial venous system | Stripping | - Saphenous vein stripping involves the ligation and division of the sapheno-femoral junction, followed by stripping a segment of the great saphenous vein to just below the knee using an invagination or inversion catheter.
Superficial venous system | Stab / Micro phlebectomy | - Stab phlebectomy or micro phlebectomy of tributaries to great or lesser saphenous vein
Superficial venous system | Ablation | - Thermal ablation involves the closing of the great or small saphenous veins using high temperature generated by laser light (endovenous laser treatment [EVLT]) or radiofrequency energy (radiofrequency ablation [RFA]).; - Chemical ablation (sclerotherapy) involves injecting an irritant agent (such as sodium tetradecyl sulfate mixed with air or carbon dioxide) into the vein, which results in endothelial damage. Foam preparations increase the potency of sclerosing drug by increasing its surface area.
Perforator venous system | Ligation | - Perforator vein is directly ligated using ultrasound guidance.
Perforator venous system | Subfascial endoscopic perforator surgery (SEPS) | - Although rarely performed, this minimally invasive surgical procedure involves use of an endoscope through the unaffected area of skin and fascia. An elastic wrap is used to empty the leg veins of blood then a tourniquet is placed at the thigh. Clinicians insufflate the subfascial space with carbon dioxide. This creates a space for the endoscope to identify and ligate the Cockett's perforating veins in the lower calf.
Perforator venous system | Ablation | - Thermal ablation of perforator veins (radio frequency ablation); - Chemical ablation (sclerotherapy) of perforator veins
Perforator venous system | Hach procedure | - This procedure involves paratibial fasciotomy and dissection of the posterior perforator veins.
Deep venous system | Obstructive | - This involves bypassing the obstructive segment of deep vein using autogenous vein or polytetrafluoroethylene synthetic graft; - This involves balloon angioplasty with or without stenting of the stenotic area of the deep vein
Deep venous system | Reflux | - Valve replacement (transposition or transplant) involves the replacement of the affected deep venous valve with an autogenous vein valve from the upper extremity.; - Valvuloplasty involves repairing or reconstructing valves in the deep venous system of the lower limb.

EVLT = endovenous laser therapy; RFA = radiofrequency ablation; SEPS = subfascial endoscopic perforator surgery

## Scope of Review and Key Questions

The overall purpose of this evidence report is to provide a systematic review of the comparative effectiveness of the above described therapeutic approaches to the management of chronic venous leg ulcers. The scope of our report is more inclusive than previously published reviews,15, 16 and we plan to compare classes of therapeutic agents, as opposed to drawing distinctions between individual therapeutic agents. Figures 1–4 graphically depict the Key Questions (KQs) that we listed below. Tables 1–3 describe our classification schemes for the three major types of intervention: wound dressings, antibiotics, and vascular surgery.

Key Question 1. For patients with chronic venous leg ulcers, what are the benefits and harms of using dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components in conjunction with compression systems when compared with using solely compression systems?

Key Question 2a. For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with compression systems, what are the benefits and harms of using systemic antibiotics when compared with using solely compression systems?

Key Question 2b. For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components, what are the benefits and harms of using systemic antibiotics when compared with using dressings alone?

Key Question 3a. For patients with chronic venous leg ulcers, what are the benefits and harms of surgical procedures aimed at the underlying venous abnormalities when compared with using solely compression systems?

Key Question 3b. For patients with chronic venous leg ulcers, what are the comparative benefits and harms of different surgical procedures for a given type of venous reflux and obstruction?