# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Ellie J.C. Goldstein, M.D.
  David Geffen School of Medicine at UCLA
  Los Angeles, CA
- William B. Greenough III, M.D.
  Johns Hopkins University
  Baltimore, MD
- David Margolis, M.D., Ph.D.
  University of Pennsylvania
  Philadelphia, PA
- Simon Palfreyman, R.N., M.Sc., Ph.D.
  The University of Sheffield
  Sheffield, United Kingdom
- Jeff Richardson, M.D.
  Johns Hopkins University
  Baltimore, MD
- Jeffrey M. Robbins, D.P.M.
  Veterans Health Administration Central Office
  Washington, DC and Cleveland, OH
- Terry Treadwell, M.D., FACS
  Institute for Advanced Wound Care
  Montgomery, AL
- Dot Weir, R.N., CWON, CWS
  Osceola Regional Medical Center
  Kissimmee, FL