# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Adrian Barbul, M.D.
  Hackensack University Medical Center
  Hackensack, NJ
- Laura Bolton, Ph.D.
  Robert Wood Johnson University Medical School
  New Brunswick, NJ
- William B. Greenough III, M.D.
  Johns Hopkins University
  Baltimore, MD
- Diane Krasner, R.N., Ph.D.
  Rest Haven-York Rehabilitation and Nursing Center
  York, PA
- Robert Kirsner, M.D.
  University of Miami
  Miami, FL
- David Margolis, M.D., Ph.D.
  University of Pennsylvania
  Philadelphia, PA
- Jeff Richardson, M.D.
  Johns Hopkins University
  Baltimore, MD
- William Tiller
  Montgomery, AL