# Acknowledgments

The Evidence-based Practice Center wish to thank the Key Informants, the Technical Expert Panel, foreign language contributors Sarah Burke, Maria Casamassima, Saskia Nahrgang, Barbara Summerer, and Natalia Vlassova, reviewers Darcy Ward, Minxuan Huang, Alec Mkwamba, Ugo Ottih, and Adefemi Taiwo, and medical writer Eric Vohr.