# Discussion

## Key Findings and Strength of Evidence

Overall, the study team was struck by the paucity of evidence to guide decisions related to all of the Key Questions. For Each KQ, the available evidence was compromised by study designs that were often underpowered, and by a lack of standardized definitions or protocols for the wound interventions. The studies also lacked evidence on pain and quality of life assessments.

In terms of balancing benefit and harms, for KQ1, the major issue is whether the intervention results in benefit, as the dressings have minimal systemic or local toxicity (minimal harm). The lack of known benefit for many of these dressings is complicated by the wide price range of these interventions, which impacts both patients and payors. For KQ2, there are harms for both patient and society from antibiotic overuse, with few data to guide providers. For the surgical options explored in KQ3, there are both potential benefits and substantial harms related to the risk of surgery. Understanding the efficacy of surgical approaches is complicated by the lack of prospective clinical trial designs, and continued technical innovation. Technical innovation has led to less invasive and endovascular techniques.

Besides the efficacy questions, our review could not answer many of the practical aspects of caring for wounds, including the rapidity in return to function and the impact on family members, and aspects related to the delivery of care. For example, the impact of specific interventions may be altered if the care is delivered by a multidisciplinary wound clinic or a primary practice office. The studies did not compare the venues for delivery of care, yet this could be a major confounder.

### Key Question 1 Benefits and Harms of Advanced Wound Dressings

Minimal data existed to suggest that hydrocolloid dressings had no advantage over compression alone in the healing rates and ultimate wound healing of chronic venous leg ulcers (low strength of evidence). Many studies had nonsignificant results. Collagen dressings may improve the proportion of ulcers healed compared with compression alone (low strength of evidence). Antimicrobial dressings, such as those that contained cadexomer iodine, provided advantage in improved healing (moderate strength of evidence), but silver-based dressings had no advantage over nonsilver dressings (moderate strength of evidence).

For acellular skin equivalents, the strength of evidence was insufficient to support the use of freeze-dried intestinal pig mucosa. Allogenic bilayered human skin equivalents may promote more rapid healing, particularly among patients with long-standing ulcers (moderate strength of evidence). However, there was no effect on post-treatment recurrence, indicating the importance of treating the underlying disease and the necessity of continuing post-treatment compression. Table 43 summarizes our conclusions on the comparative benefits of advanced wound dressings in terms of wound healing.

Table 43 Summary of the comparative benefits of advanced wound dressings in terms of wound healing

Comparison (Number of Included Studies)^*^ | Strength of Evidence^†^ | Conclusions
Hydrocolloids vs. compression (3) | Low | Hydrocolloid dressings were not more effective than compression therapy alone in terms of the proportion of chronic venous ulcers healed. The results from the three studies addressing this comparison were imprecise and subject to some bias.
Hydrocolloids vs. other dressings (4) | Insufficient | We were unable to draw a conclusion.
Transparent films vs. compression (1) | Insufficient | We were unable to draw a conclusion.
Transparent films vs. other dressings (1) | Insufficient | We were unable to draw a conclusion.
Alginate dressings vs. compression (1) | Insufficient | We were unable to draw a conclusion.
Alginate dressings vs. alginate dressings (2) | Insufficient | We were unable to draw a conclusion.
Alginate dressings vs. other dressings (1) | Insufficient | We were unable to draw a conclusion.
Foam dressings vs. foam dressings (3) | Insufficient | We were unable to draw a conclusion.
Collagen dressings vs. compression (1) | Low | Collagen dressings healed a greater proportion of ulcers than compression alone.
Acellular human skin equivalent dressings vs. compression (3) | Insufficient | We were unable to draw a conclusion.
Cellular (cryo-preserved human fibroblast-derived dermal substitute) vs. compression (2) | Insufficient | We are unable to draw a conclusion.
Cellular human skin equivalents (allogenic bilayered cultured HSE) vs. compression (1) | Moderate | Studies of cellular human skin equivalent dressings in patients with chronic venous ulcers showed a higher proportion of ulcers healed and more rapid healing, especially those that had failed previous therapy and were present for over 1 year.
Cellular (autologous keratinocytes in a fibrin sealant) vs compressions (1) | Low | Autologous keratinocytes in fibrin sealant healed a greater proportion of ulcers and achieved a shorter median time to complete wound closure versus compression.
Cellular human skin equivalent dressings vs. other dressings (2) | Insufficient | We were unable to draw a conclusion.
Antimicrobial dressings vs. compression (2) | Insufficient | We were unable to draw a conclusion.
Antimicrobial dressings vs. antimicrobial dressings (2) | Insufficient | We were unable to draw a conclusion.
Antimicrobial containing dressings vs. other types of dressings (4) | Moderate | Some antimicrobial dressings improved wound area reduction by 20 percent or more as compared with other nonantimicrobial dressings. However, silver dressings did not improve wound healing as compared with nonsilver dressings.

* The strength of evidence for all comparisons not listed here were graded as insufficient because we did not find any studies addressing them or because we were unable to draw a conclusion from the evidence.

† We defined the strength of evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

There were minimal data on harms and quality of life measures and therefore we could not make any conclusions.

### Key Question 2a Benefits and Harms of Systemic Antibiotics Compared With Compression Systems

We found only one study that addressed this question, and it provided insufficient evidence to determine the benefits of systemic antibiotics compared with compression. There was no assessment of potential harms of this intervention in promoting the development of antimicrobial resistant organisms.

### Key Question 2b Benefits and Harms of Systemic Antibiotics Compared With Advanced Wound Dressings

We did not find any studies that addressed this question.

### Key Question 3a Benefits and Harms of Surgical Interventions Compared With Compression

We found low strength of evidence that minimally invasive surgical hemodynamic correction of reflux may decrease the time-to-healing of chronic venous leg ulcers compared with compression therapy alone, but it does not increase the proportion of ulcers healed. For other surgical interventions for chronic venous leg ulcers, the strength of evidence was moderate to high that healing may not be improved, but there could be a lower risk of recurrence when compared with compression alone. We found insufficient evidence about the benefits and harms, or quality of life measures of vein stripping, radiofrequency ablation or endovenous laser therapy for superficial vein reflux, or surgery for deep vein disease in patients with chronic venous leg ulcers.

Table 44 summarizes our conclusions on the comparative benefits of surgical interventions compared with compression therapy in terms of wound healing.

Table 44 Summary of the comparative benefits of surgical interventions compared with compression in terms of wound healing

Comparison (Number of Included Studies)^*^ | Strength of Evidence^†^ | Conclusions
Superficial vein surgery vs. compression alone (1 RCT, 1 cohort) | Moderate | Adding superficial vein surgery to compression therapy does not improve healing of chronic venous leg ulcers, but there may be a lower risk of recurrence.
CHIVA vs. compression alone (1 RCT) | Low | Adding minimally invasive surgical hemodynamic correction of reflux to compression therapy does not significantly affect the proportion of ulcers healed, but it may lower the risk of recurrence.
SEPS vs. compression alone (2 RCTs) | High | SEPS with superficial vein surgery does not improve the rate of healing or the risk of recurrence of chronic venous leg ulcers in comparison with compression alone.
Sclerotherapy vs. compression alone (1 RCT, 2 cohorts) | Insufficient | We were unable to draw a conclusion.
RFA vs. compression alone (0) EVLT vs. compression alone (0) Deep venous surgery vs. compression alone (0) | Insufficient | We were unable to draw a conclusion.

CHIVA = conservative hemodynamic treatment of insufficiency of the venous system in an ambulatory setting; EVLT = endovenous laser therapy; RCT = randomized controlled trial; RFA = radiofrequency ablation; SEPS = subfascial endoscopic perforator surgery

* The strength of evidence for all comparisons not listed here were graded as inconsistent because we did not find any studies addressing them or because we were unable to draw a conclusion from the evidence.

† We defined the strength of evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

### Key Question 3b Benefits and Harms of Surgical Interventions Compared With Other Surgical Interventions

The evidence was insufficient to determine the comparative benefits and harms, or impact on quality of life of different surgical procedures for chronic venous leg ulcers associated with a given type of venous reflux, due to the small number, small size, and poor quality of studies.

Table 45 summarizes our conclusions regarding the comparative benefits of surgical interventions in terms of wound healing.

Table 45 Summary of the comparative benefits of surgical interventions compared with other surgical interventions in terms of wound healing

Comparison (Number of Included Studies)^*^ | Strength of Evidence^†^ | Conclusions
PLSVS vs. PLSVS + valvuloplasty vs. PLSVS + vein transposition vs. PLSVS + valve transplantation (1) | Insufficient | We are unable to draw a conclusion.
Isolated sapheno-femoral junction ligation vs. vein stripping (1) | Insufficient | We are unable to draw a conclusion.
Sclerotherapy vs. valvular surgery (1) | Insufficient | We are unable to draw a conclusion.

PLSVS = perforator ligation and saphenous vein stripping;

* The strength of evidence for all comparisons not listed here were graded as inconsistent because we did not find any studies addressing them or because we were unable to draw a conclusion from the evidence.

† We defined the strength of evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

## Findings in Relationship to What is Already Known

Our findings are in concert with previous published large reviews and evidence-based practice guidelines. Previous reviews, albeit not as comprehensive as the one performed here, found a paucity of randomized or controlled clinical trials to support the use of any of the interventions described.

### Key Question 1 Benefits and Harms of Advanced Wound Dressings

Cochrane collaboration reviews16 have addressed the use of wound dressings and have found no data to support superiority of specific dressings. Our review of cadexomer iodine-containing dressings is consistent with that described in the Cochrane review, which indicated modest improvements in wound healing. The data on cellular equivalents are from recent well controlled clinical trials.

### Key Questions 2a and 2b Benefits and Harms of Systemic Antibiotics Compared With Compression Systems, and Benefits and Harms of Systemic Antibiotics Compared With Advanced Wound Dressings

There have been no previous comparative effectiveness reviews of the impact of systemic antibiotics on chronic venous ulcers. However, the limited findings of our review are in concert with the Infectious Diseases Society of America's policy statements on wound care.

### Key Questions 3a and 3b Benefits and Harms of Surgical Interventions Compared With Compression, and Benefits and Harms of Surgical Interventions Compared With Other Surgical Interventions

There have been no evidence-based reviews of studies with control groups to evaluate surgical outcomes in patients with chronic venous ulcers.

However, our review identified critical research needs which are in concert with a 2011 evaluation from the Center for Medical Technology Policy, which concluded that there was a paucity of evidence in wound care.6 Their major recommendations included developing an evidence base using multicenter randomized clinical trials (RCTs), blinding patient-reported outcomes to intervention, developing a consistent standard of care arm, standardizing protocols and protocol adherence, and standardizing outcome measures.

## Applicability

Studies generally did not report on the representativeness of their study populations. In most cases, we could not determine if the care received by study patients was similar to that received by other patients. The RCTs tended to include elderly patients similar in age to the population of patients with chronic venous leg ulcers, and most studies included at least a substantial minority of men. When studies reported the baseline mean duration of chronic venous ulcers, it was typically more than 12 months, and thus study results are more applicable to ulcers that are recalcitrant to prior treatment. Studies of advanced wound dressings were of short duration (4 months or less) and thus, the long-term effects are unclear.

## Limitations

### Limitations of the Review Process

Our review was comprehensive in scope, including studies in any language evaluating wound dressings, antibiotics, and surgical interventions. Although we designed our search to be as comprehensive as possible, it is plausible that we missed key studies. For articles that were not published in English, we tried to find suitable reviewers who were able to read the language. However, we were unable to find a reviewer for one article.

We excluded studies that were not peer-reviewed and could have potentially missed information that was published only in abstract form. Our results could be subjected to publication bias and selective outcome reporting.

In our review, we included studies only if the participants used at least a moderate level of compression (e.g., at least 20 mm Hg of pressure), excluding studies that either did not report the level of compression used or did not use an adequate level of compression. Although some experts recommend a higher pressure for compression therapy (at least 40 mm Hg), we did not want to exclude too many studies and therefore used 20 mm Hg as the minimum pressure based on the results of a previous systematic review conducted by the Cochrane Collaboration.3 However, we may have biased our results in favor of the advanced wound dressings and surgical procedures by including studies that allowed a lower level of compression therapy (i.e., between 20 and 40 mm Hg).

### Limitations of the Evidence Base

We reviewed the titles and abstracts of more than 10,000 published articles, but found few well-designed RCTs that addressed the comparative effectiveness of treatments for chronic venous leg ulcers. The RCTs generally did not report on allocation concealment, and did not mask patients or outcome assessors to treatment assignment. We expanded our review to include observational studies, but these studies were largely limited to convenience populations, which, by definition, carry with them a substantial risk of bias. Overall, the studies that addressed the topic were very heterogeneous and had major problems that limited our ability to make firm conclusions about the effectiveness and safety of treatments for chronic venous leg ulcers. Major limitations of the published data threatened both internal and external validity. These limitations included the lack of standard definitions of chronic venous leg ulcers, inconsistent outcome measures, suboptimal comparison groups, and inconsistent duration of interventions. Studies often had large losses to followup or did not report on this. Many of the studies also did not report statistical analyses beyond simple healing rates, stratification or adjustment to account for potential confounding variables, or sample size calculations. Most studies were very small and therefore had limited statistical power. Most of the studies evaluating wound dressings received industry support, which is associated with more favorable outcomes.

## Implications for Clinical Practice and Policy

Our findings have substantial implications for clinical practice and policies related to the care of chronic venous leg ulcers. With the exception of a few surgical interventions and the use of human skin equivalents under defined conditions, most interventions used in the management of chronic venous leg ulcers lack supporting evidence that they add any benefits to compression therapy alone. This negative finding does not necessarily mean that the interventions are ineffective, but rather that we need better studies to demonstrate their clinical impact.

These findings therefore have impact on policy, especially for agencies and payers in providing reimbursement and identifying critical research needs. Since the prevalence of chronic venous stasis disease is increasing,80 and will likely continue to increase for the foreseeable future, health care payers, regulatory agencies, and other policymakers will require strong evidence on outcomes that can better guide the treatment of patients with chronic venous leg ulcers. We need high quality data on the comparative effectiveness of the treatment options to develop efficient algorithms for guiding therapy, and to better understand which therapeutic interventions have value to ensure appropriate reimbursement in an increasingly constrained health care environment.

## Research Gaps

Our research identified several areas to consider for future research. We were unable to make strong conclusions regarding the efficacy of most interventions because of a lack of high quality RCTs. Promising areas to consider for future research include cellular human skin equivalents, collagen dressings, dressings that enhance debridement, antibiotic treatments, and surgical techniques. The results from a recent phase 2 RCT are promising and warrant future research on the effects of a spray cell therapy containing growth arrested allogeneic neonatal keratinocytes and fibroblasts plus a foam dressing.81

Few studies addressed quality of life measures, and no studies assessed quality of life using standard or validated scales. Since chronic wounds have substantial impact on the patient and his/her family, quality of life measures are critical in evaluating overall wound treatment efficacy. Studies also did not adequately address or describe potential harms in interventions. This substantially differs from the studies of regulated pharmaceuticals, which carefully record adverse events.

### Need for Harmonization

Our review demonstrated that studies of interventions for chronic venous leg ulcers take place in many different practice and cultural settings involving a variety of disciplines, including nursing, dermatology, vascular surgery, and internal medicine. This heterogeneity was associated with the excessive variety of methods we saw in these studies.

To adequately address this problem, clinical researchers, government regulators, payers, and other stakeholders from academic and clinical communities and industry should establish a consensus regarding how to harmonize studies in this area. The objective would be to develop better standards for disease definition, interventions, comparison groups, and outcome measures, including intermediate outcomes, pain, and quality of life. These experts could help to develop templates for study designs that better demonstrate efficacy. Similar recommendations were made in a report published by the Center for Medical Technology and Policy, “Methodological Recommendations for Comparative Effectiveness Research on the Treatment of Chronic Wounds.”6

One of the major issues we need to address is the limitation in study design. The nature of the interventions, and the difficulty in many cases of developing placebo or sham conditions, makes implementing traditional double-blinded, or even single-blinded randomized trials difficult, if not impossible. We believe that implementation of appropriate, well-designed clinical trials will require substantial clinical patient management and recruitment resources. Furthermore, the trials must be large enough to have sufficient statistical power for determining the comparative effectiveness and safety of the therapeutic options. Since future research is likely to depend on funding from a number of different sources, including manufacturers of products and devices, investigators will need to develop appropriate policies for managing potential conflict-of-interest issues. We suggest that a long-term solution to this would be the development and implementation of a clinical trials network that would have a broad recruiting base, specialized centers that adhere to case definitions, and a commitment to long-term followup.

## Conclusions

Chronic wounds due to venous hypertension are emerging as a major clinical care and public health challenge, with rapidly increasing costs and morbidity. Following an iterative process, and consulting with AHRQ and stakeholders, we developed three Key Questions to help guide our review of the effectiveness of treatment options for chronic venous leg ulcers. We performed an extensive review of the literature, and graded the evidence, which included review by content experts. We found a paucity of well-designed well-controlled studies, as well as a lack of a standard case definitions, or approaches to managing confounders and interactions. Most studies were not blinded, and the results are therefore subject to reporting and ascertainment bias. We found that advanced wound dressings had no impact on wound healing when compared with compression therapy alone, with the exception of cellular skin equivalents. We found no evidence to support antimicrobial therapy for chronic venous leg ulcers, in the absence of symptoms or signs of infection, due to a general lack of data. Although a substantial literature exists on venous surgical approaches, the vast majority of these were uncontrolled case series or studies that did not measure ulcer outcomes. We found minimal, if any, benefit for surgical interventions in managing this disease. However, more recent data suggest that surgical interventions may impact recurrence rates, and therefore there is a need to validate these findings.

Future research should focus on developing a strong evidence base to evaluate the efficacy and effectiveness of current and newly developed products and interventions. These include standardizing case definition, clarifying the study outcomes to be used in clinical trials, and developing a network of centers that have the capacity to implement clinical effectiveness research for this condition.