# Evidence Tables

Table D-1 Study design characteristics of studies evaluating treatments for chronic venous ulcers

Table D-2 Study population characteristics of studies evaluating treatments for chronic venous ulcers

Table D-3a Intervention characteristics of studies evaluating advanced wound dressings for the treatment of chronic venous ulcers

Table D-3b Intervention characteristics of studies evaluating antibiotics for the treatment chronic venous ulcers

Table D-3c Intervention characteristics of studies evaluating surgery for the treatment chronic venous ulcers

Table D-4a Reported outcomes of studies evaluating advanced wound dressings as treatment for chronic venous ulcers

Table D-4b Outcomes reported for studies evaluating antibiotics for treatment of chronic venous ulcers

Table D-4c Outcomes reported for studies evaluating surgery as treatment of chronic venous ulcers (KQ3a)

Table D-4d Outcomes reported for studies evaluating surgery as treatment of chronic venous ulcers (KQ3b)

Table D-5a Study quality evaluations for studies evaluating the treatment of chronic venous ulcers, reporting

Table D-5b Study quality evaluations for studies evaluating the treatment of chronic venous ulcers, external validity, power, and conflict of interest

Table D-5c Study quality evaluations for studies evaluating the treatment of chronic venous ulcers, internal validity-bias

Table D-5d Study quality evaluations for studies evaluating the treatment of chronic venous ulcers, internal validity-confounding and selection bias