# Excluded Articles

Management of infections in chronic wounds: hydroactive dressing instead of antiseptics?. Krankenpfl J. 98;36(11):454. No original data. [pmid: 10095546].
UrgoClean: a new wound dressing features high absorption and uptake of fibrous deposits. Pflege Z. 2011;64(11):698. No original data. [pmid: 22097412].
Controlled trial of Iodosorb in chronic venous ulcers. Br Med J (Clin Res Ed). 85;291(6499):902. No original data.
Adam DJ, Bello M, Hartshorne T, London NJ. Role of superficial venous surgery in patients with combined superficial and segmental deep venous reflux. Eur J Vasc Endovasc Surg. 2003;25(5):469-72. Different levels of compression used. [pmid: 12713788].
Akesson H, Bjellerup M. Leg ulcers: report on a multidisciplinary approach. Acta Derm Venereol. 95;75(2):133-5. No separate analysis of CVU. [pmid: 7604642].
Akesson H, Brudin L, Cwikiel W, Ohlin P, Plate G. Does the correction of insufficient superficial and perforating veins improve venous function in patients with deep venous insufficiency?. PHLEBOLOGY. 90;5(2):113-123. Case series with <10.
Alhabouni S, Hingorani A, Ascher E, Marks N, Shiferson A, Patel N, Gopal K, Jacob T. Iliac venous stenting for lower extremity venous stasis disease. J. Vasc. Surg. 2009;49(5):40S. No separate analysis of CVU.
Alikhanov VP, Keshokov RK. Laser therapy in the combined treatment of the trophic disorders in the postthrombophlebitis syndrome. Lazernaia terapiia v kompleksnom lechenii troficheskikh narushenii pri posttromboflebiticheskom sindrome. Med Sestra. 89;48(9):24-25. No original data; no separate analysis of CVU. [pmid: 2593785].
Almeida JI, Kaufman J, Gockeritz O, Chopra P, Evans MT, Hoheim DF, Makhoul RG, Richards T, Wenzel C, Raines JK. Radiofrequency endovenous ClosureFAST versus laser ablation for the treatment of great saphenous reflux: a multicenter, single-blinded, randomized study (RECOVERY study). J Vasc Interv Radiol. 2009;20(6):752-9. No separate analysis of CVU. [pmid: 19395275].
Ananthakrishnan N, Parkash S, Banerjee SN. A new technique for chronic venous ulcers of the lower limb: modified Felder-Rob procedure. Aust N Z J Surg. 89;59(2):157-60. No KQ. [pmid: 2645862].
Andersen KE, Franken CPM, Gad P, Larsen AM, Larsen JR, van Neer PAFA, et al. A randomized, controlled study to compare the effectiveness of two foam dressings in the management of lower leg ulcers. Ostomy Wound Management. 2002;48(8):34-41. Different levels of compression used.
Askerkhanov RP. Some aspects of the pathology, clinical picture, and treatment of occlusive and valvular venous circulatory insufficiency in the lower extremities. KARDIOLOGIYA. 80;20(2):67-71. No intervention of interest.
Askerov NG, Zhukov AO, Malinina VN. Comparative analysis of horizontal venous reflux surgical correction by large trophic lower leg ulcers. Khirurgiia (Mosk). 2009;(10):29-32. No separate analysis of CVU. [pmid: 20032933].
Aydin C, Inan B, Teker ME. Venous ulcer treatment methods. Heart Surg. Forum. 2011;14:S40. Other.
Azoubel R, Torres Gde V, da Silva LW, Gomes FV, dos Reis LA. Effects of the decongestive physiotherapy in the healing of venous ulcers. Rev Esc Enferm USP. 2010;44(4):1085-92. No intervention of interest. [pmid: 21337794].
B MG, Bazzigaluppi F, Fano M, Moschin AM, Toscani P, Cervone C, Cavoni A, Abate G, Cesarano P, Colombo R, Donadio D, Stefani E, Di Vito C, Leigheb G, Leone C, Molisso A, Martinotti A, Murgiano GA, Conte M, et al. Cadexomer iodine in the treatment of cutaneous ulcers. Open, multicentric trial. Gazzetta Medica Italiana Archivio per le Scienze Mediche. 1991;150(11):471-480. No concurrent comparison group.
Bahr S, Mustafi N, Hattig P, Piatkowski A, Mosti G, Reimann K, Abel M, Dini V, Restelli J, Babadagi-Hardt Z, Abbritti F, Eberlein T, Wild T, Bandl K. Clinical efficacy of a new monofilament fibre-containing wound debridement product. J Wound Care. 2011;20(5):242-8. No separate analysis of CVU. [pmid: 21647069].
Baier PM, Daopulos A, Miszczak ZT, Konig N. Indications, results and experiences with endoscopic subfascial dissection of perforating veins (ESDP). A prospective study. Indikationen, ergebnisse und erfahrungen mit der endoskopisch subfaszialen perforantendissektion (ESDP). Eine prospektive studie. Gefasschirurgie. 2007;12(1):33-42. No original data.
Baker PG, Haig G. Metronidazole in the treatment of chronic pressure sores and ulcers. A comparison with standard treatments in general practice. Practioner. 81;225(1354):569-573. No separate analysis of CVU.
Banerjee AK, Levy DW, Rawlinson D. Leg ulcers - a comparative study of Synthaderm and conventional dressings. Care of the Elderly. 90;2(3):123-5. Different levels of compression used.
Banks V, Bale S, Harding K, Harding EF. Evaluation of a new polyurethane foam dressing. J Wound Care. 97;6(6):266-9. No separate analysis of CVU. [pmid: 9274262].
Barendse-Hofmann MG, van Doorn LP, Oskam J, Steenvoorde P. Extracellular matrix prevents split-skin grafting in selected cases. J Wound Care. 2007;16(10):455-8. No separate analysis of CVU. [pmid: 18065022].
Baron HC, Saber AA, Wayne M. Endoscopic subfascial surgery for incompetent perforator veins in patients with active venous ulceration. Surg Endosc. 2001;15(1):38-40. No separate analysis of CVU. [pmid: 11178759].
Baron HC, Wayne MG, Santiago CA, Grossi R. Endoscopic subfascial perforator vein surgery for patients with severe, chronic venous insufficiency. Vasc Endovascular Surg. 2004;38(5):439-42. No separate analysis of CVU. [pmid: 15490041].
Baron HC, Wayne MG, Santiago C, Lown I, Castellano M, Cioroiu M, Grossi R. Treatment of severe chronic venous insufficiency using the subfascial endoscopic perforator vein procedure. Surg Endosc. 2005;19(1):126-9. No separate analysis of CVU. [pmid: 15531974].
Barwell JR, Ghauri ASK, Taylor M, Deacon J, Wakely C, Poskitt KR, Whyman MR. Risk factors for healing and recurrence of chronic venous leg ulcers. Phlebology. 2000;15(2):49-52. No concurrent comparison group.
Baxter H. A comparison of two hydrocolloid sheet dressings. Br J Community Nurs. 574. 576. 2000;5(11):572-7. No original data. [pmid: 12066057].
Beele H, Meuleneire F, Nahuys M, Percival SL. A prospective randomised open label study to evaluate the potential of a new silver alginate/carboxymethylcellulose antimicrobial wound dressing to promote wound healing. Int Wound J. 2010;7(4):262-70. No separate analysis of CVU. [pmid: 20529142].
Belacek J, Vician M. Compression therapy of leg ulcers. Kompresivna liecba vredov predkolenia. Rozhl Chir. 2000;79(10):492-494. Case series with <10. [pmid: 11192796].
Belcaro G, Marelli C. Treatment of venous lipodermatosclerosis and ulceration in venous hypertension by elastic compression and fibrinolytic enhancement with defibrotide. PHLEBOLOGY. 89;4(2):91-106. No intervention of interest.
Belcaro G, Cesarone MR, Errichi BM, Ricci A, Dugall M, Pellegrini L, Ledda A, Grossi MG. Venous and diabetic ulcerations: management with topical multivalent silver oxide ointment. Panminerva Med. 2010;52(2 Suppl 1):37-42. No intervention of interest. [pmid: 20657533].
Belcaro G, Cesarone MR, Nicolaides AN, De Sanctis MT, Incandela L, Geroulakos G. Treatment of venous ulcers with pentoxifylline: a 6-month randomized, double-blind, placebo controlled trial. Angiology. Suppl 1. 2002;53:S45-7. No intervention of interest. [pmid: 11865836].
Belcaro G, Dugall M, Vasdekis S, Christopoulos D, Laurora G, Nicolaides AN, Cesarone Mr, De Sanctis Mt, Incandela L, Ricci A. Comparison between endovascular sclerotheraphy, surgery and surgery plus sclerotheraphy in the treatment of superficial vein insufficiency. A randomized study on 10 years follow-up. Comparaison entre la sclerothrapie endovasculaire, la chirurgie et la chirurgie associee a la sclerotherapie dans le traitement de l'incontinence des veines superficielles. Une etude randomisee sur 10 ans de suivi. Angeiologie. 98;50(1):57-61. No separate analysis of CVU.
Bello AM, Wheatley C, Scriven M, London NJM. Recurrent venous ulceration after superficial surgery or compression bandaging: a prospective comparison. Royal Society of Medicine Venous Forum. 1999, 16 April. Leeds, UK. 99. Other.
Bello AM, Scriven M, Naylor AR, Bell PR, London NJ. Vascular surgical society of great britain and ireland: role of superficial vein surgery in treatment of venous ulceration. Br J Surg. 99;86(5):701-2. No original data. [pmid: 10361335].
Bender E. Local treatment in varicous ulcus cruris with sulfadiazine-silver in out-patients. DIE LOKALE BEHANDLUNG VON UNTERSCHENKELGESCHWUREN MIT SULFADIAZIN-SILBER IN DER AMBULANTEN PRAXIS. FORTSCHR. MED. 82;100(29):1372-1373. No original data. [pmid: 6751957].
Berard P, Montandon S, Jedynak D, Saubier EC. Trial of a hydrocolloid in occlusive dressings in the treatment of skin wounds, Duoderm. Rev Enferm. 86;9(1):17-20. No original data. [pmid: 3633609].
Bergan JJ. Saphenous vein stripping and quality of outcome. BR. J. SURG. 96;83(8):1025-1027. No original data.
Bergan J, Pascarella L, Mekenas L. Venous disorders: treatment with sclerosant foam. J Cardiovasc Surg (Torino). 2006;47(1):9-18. No separate analysis of CVU.
Biaunie G, Kalis B. Ulcers of the leg. ULCERE DE JAMBE. REV. PRAT. 93;43(20):2699-2707. No original data. [pmid: 8146573].
Bihari I, Mester AR. The biostimulative effect of low level laser therapy of long-standing crural ulcers using helium neon laser, helium neon plus infrared lasers, and noncoherent light: Preliminary report of a randomized double blind comparative study. LASER THER. 89;1(2):97-98. No intervention of interest.
Bini I, Jankovi A, Jankovi D, Jankovi I, Vrucini Z. Evaluation of healing and antimicrobiological effects of herbal therapy on venous leg ulcer: pilot study. Phytotherapy research : PTR. 2010;24(2):277-82. Different levels of compression used. [pmid: 19610037].
Bishop JB, Phillips LG, Mustoe TA, VanderZee AJ, Wiersema L, Roach DE, Heggers JP, Hill DP Jr, Taylor EL, Robson MC. A prospective randomized evaluator-blinded trial of two potential wound healing agents for the treatment of venous stasis ulcers. J Vasc Surg. 92;16(2):251-7. No intervention of interest. [pmid: 1495150].
Blaszczak E, Franek A, Taradaj J, Dolibog P. Evaluation of healing process dynamics of the leg venous ulcers treated by means of selected physical methods. Ocena dynamiki procesu gojenia owrzodzen zylnych leczonych za pomoca wybranych metod fizykalnych. Fizjoterapia. 2007;15(1):3-16. No concurrent comparison group.
Bolton L. Are silver products safe and effective for chronic wound management?. J Wound Ostomy Continence Nurs. 2006;33(5):469-77. No original data. [pmid: 17133133].
Bolton L, McNees P, van Rijswijk L, de Leon J, Lyder C, Kobza L, Edman K, Scheurich A, Shannon R, Toth M. Wound-healing outcomes using standardized assessment and care in clinical practice. J Wound Ostomy Continence Nurs. 2004;31(2):65-71. No intervention of interest. [pmid: 15209428].
Bondt G, Durani AK, Gerecht K. Treatment of leg ulcer: Clinical study with Iruxol(registered trademark) and Cutinova(registered trademark) hydro. Behandlung eines Ulcus cruris Anwendungsbeobachtung mit Iruxol(registered trademark) und Cutinova(registered trademark) hydro. Z. ALLG.MED. 97;73(19):1058-1061. No original data.
Bongiovanni CM, Hughes MD, Bomengen RW. Accelerated wound healing: multidisciplinary advances in the care of venous leg ulcers. Angiology. 2006;57(2):139-44. No intervention of interest. [pmid: 16518520].
Bosatra M, Jucci A, Olliaro P. Simultaneous use of oral catechine and laser treatment in post-phlebitic ulcers. A clinical and electron microscope study. L'IMPIEGO DELLA CATECHINA PER OS E DELLA LASER-TERAPIA He-Ne NELLE ULCERE POST-FLEBITICHE. STUDIO CLINICO ED ELETTROMICROSCOPICO. ANN. ITAL. DERMATOL. CLIN. SPER. 83;37(2):189-197. No intervention of interest.
Bradbury AW, Ruckley CV. Foot volumetry can predict recurrent ulceration after subfascial ligation of perforators and saphenous ligation. J Vasc Surg. 93;18(5):789-95. No separate analysis of CVU. [pmid: 8230565].
Brandi C, Grimaldi L, Nisi G, Brafa A, Campa A, Calabro M, Campana M, D'Aniello C. The role of carbon dioxide therapy in the treatment of chronic wounds. In Vivo. 2010;24(2):223-6. No intervention of interest. [pmid: 20363999].
Brandrup F, Menne T, Agren MS, Stromberg HE, Holst R, Frisen M. A randomized trial of two occlusive dressings in the treatment of leg ulcers. Acta Derm Venereol. 90;70(3):231-5. No separate analysis of CVU. [pmid: 1972837].
Brantigan CO, Senkowsky FJ, Yim D. The effect of systemic antibiotics on the bacterial flora of chronic wounds. Wounds: A Compendium of Clinical Research &amp; Practice. 96;8(4):118-124. No separate analysis of CVU.
Breu FX, Wollmann JCGR. Clinical and technical follow-up after sclerotherapy. Dermatol. Surg. 2010;36(SUPPL. 2):1004-1009. No original data. [pmid: 20590707].
Brigido SA. The use of an acellular dermal regenerative tissue matrix in the treatment of lower extremity wounds: a prospective 16-week pilot study. Int Wound J. 2006;3(3):181-7. No separate analysis of CVU. [pmid: 16984575].
Bull RH, Andersen KE, Larsen AM, Leigh IM. A comparative study on two alginate dressings: Kaltostat and Comfeel: alginate dressing for exudating venous leg ulcers. Proceedings of the 5th European Conference on Advances in Wound Management. 1995, 21-24 November. Harrogate, UK. 96. 273. Other.
Bull RH, Leigh IM. Alginate dressings for exudating leg ulcers: a randomized study of Comfeel: alginate dressing vs Kaltostat. 5th Annual Meeting of the European Tissue Repair Society. 1995, August 30-September 2. Padova, Italy. 95:362. Other.
Burenko HV, Suprun IuO, Halyha TM, Kobzar AIa. Varicose vein surgery complicated by trophic ulcers. Klin Khir. 2002;(11-12):14-5. No original data. [pmid: 12549257].
Burgess B. An investigation of hydrocolloids. Prof Nurse. 93;8(7):suppl 3-6. Other.
Burgess B, Robinson B. Wound care. Comparative benefits. Nurs Times. 93;89(13):90-2. Other. [pmid: 8474914].
Alfano C, Angelisanti M, Calzoni C, Somma F, Chiummariello S. Treatment of ulcer and difficult wounds of the lower limbs: our experience. Ann Ital Chir. 2012;83(2):135-41. No separate analysis of CVU. [pmid: 22462334].
Caetano KS, Frade MA, Minatel DG, Santana LA, Enwemeka CS. Phototherapy improves healing of chronic venous ulcers. Photomed Laser Surg. 2009;27(1):111-8. No separate analysis of CVU. [pmid: 19196110].
Callam MJ, Harper DR, Dale JJ. A controlled trial of weekly ultrasound therapy in chronic leg ulceration. LANCET. 87;2(8552):204-205+206. No intervention of interest. [pmid: 2885650].
Callam MJ, Harper DR, Dale JJ, Brown D, Gibson B, Prescott RJ, Ruckley CV. Lothian and Forth Valley leg ulcer healing trial. Part 2: Knitted viscose dressing versus a hydrocellular dressing in the treatment of chronic leg ulceration. PHLEBOLOGY. 92;7(4):142-145. No concurrent comparison group.
Cameron J, Hoffman D, Wilson J, Cherry G. Comparison of two peri-wound skin protectants in venous leg ulcers: a randomised controlled trial. J Wound Care. 2005;14(5):233-6. No outcome of interest. [pmid: 15909441].
Camilli S, Guarnera G. External banding valvuloplasty of the superficial femoral vein in the treatment of primary deep valvular incompetence. INT. ANGIOL. 94;13(3):218-222. No separate analysis of CVU. [pmid: 7822897].
Campolmi P, Lotti T, Bonan P, Tsampau D, Palleschi GM, Andreassi L. CO2 Laser in the treatment of leg ulcers. Preliminary results. IL LASER CO2 DEFOCALIZZATO NELLA TERAPIA DELLE ULCERE DEGLI ARTI INFERIORI. RISULTATI PRELIMINARI. G. ITAL. DERMATOL. VENEREOL. 89;124(6):317-319. No original data. [pmid: 2517123].
Canonico S, Campitiello F, Della Corte A, Fattopace A. The use of a dermal substitute and thin skin grafts in the cure of &quot;complex&quot; leg ulcers. Dermatol Surg. 2009;35(2):195-200. No separate analysis of CVU; No concurrent comparison group. [pmid: 19215255].
Capillas Perez R, Cabre Aguilar V, Gil Colome AM, Gaitano Garcia A, Torra i. Bou JE. Comparison of the effectiveness and cost of treatment with humid environment as compared to traditional cure. Clinical trial on primary care patients with venous leg ulcers and pressure ulcers. Rev Enferm. 2000;23(1):17-24. No original data; no separate analysis of CVU. [pmid: 10788945].
Carabelli A, Contos S, Bertani E, De Bernardi M. Collagen effectiveness on patients with inferior extremitas ulcers and cutaneous tolerability. VALIDITA DI UN NUOVO COLLAGENE FELTRI IN PAZIENTI AFFETTI DA ULCERE DEGLI ARTI INFERIORI E TOLLERABILITA CUTANEA. ACTA TOXICOL. THER. 91;12(2):133-145. No concurrent comparison group; case series with <10.
Carandina S, Mari C, De Palma M, Marcellino MG, Cisno C, Legnaro A, Liboni A, Zamboni P. Varicose vein stripping vs haemodynamic correction (CHIVA): a long term randomised trial. Eur J Vasc Endovasc Surg. 2008;35(2):230-7. No separate analysis of CVU; case series with <10. [pmid: 17964822].
Cariati A, Piromalli E, Cariati P. Effects of compression therapy and antibiotics on lymphatic flow and chronic venous leg ulceration. Arch Dermatol Res. 2012. No original data.
Carradice D, Mekako AI, Mazari FA, Samuel N, Hatfield J, Chetter IC. Randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg. 2011;98(4):501-10. No separate analysis of CVU. [pmid: 21283981].
Cesarone MR, Belcaro G, Geroulakos G, Ricci A, Laurora G, Nicolaides AN, De Sanctis MT, Incandela L, Marelli C. Fibrinolytic enhancement with defibrotide in the treatment of venous ulceration: Activation fibrinolytique par le defibrotide dans le traitement des ulceres veineux. Angeiologie. 97;49(5):10-14. No KQ.
Chabbarov RG, Gavrilov VA, Piatnitskii AG, Khvorostukhin VS. Radiofrequency ablation of the great saphenous vein in lower-limb varicose disease. Angiol Sosud Khir. 2009;15(2):65-8. No separate analysis of CVU. [pmid: 19806942].
Chaloner D. A Comparative Study of Two Silver Containing Dressings, Acticoat 7 and Avance in the treatment of Chronic Venous Ulcers. 2nd World Union of Wound Healing Societies Meeting. 2004 ,8-13 July. Paris. 2004. 134. Other.
Chaloner DM, Milward PA, Skitt PJ. A community-based clinical trial of three dressings in the treatment of leg ulceration. 1st European Conference on Advances in Wound Management. 1991, 4-6 September. Cardiff, UK. 92:148-9. Other.
Chang GQ, Yin HH, Li XX, Chen L, Ye RY, Wang SM. Potential causes and optimal treatment strategy of recurrent venous ulceration in lower limb. Zhonghua Wai Ke Za Zhi. 2011;49(6):500-2. Case series does not assess ulcer healing; case series does not provide demographics. [pmid: 21914296].
Chang JB, Stein TA. Management of varicose veins from chronic venous insufficiency. Int. J. Angiol. 2002;11(4):234-237. Case series does not provide demographics.
Chaparro M, Alvarez de los Heros F, Novo E, Rodriguez-Alvarez J, Stolle D, Losada A. Effectiveness of topical treatment of chronic varicose ulcers with sterile single-dose ciprofloxacin ampoules versus physiologic serum. Revista Espanola de Geriatria y Gerontologia. 2003;38(3):145-152. < 4 weeks followup duration.
Charles H, Callicott C, Mathurin D, Ballard K, Hart J. A randomised, comparative study of a recently introduced hydroactive foam dressing versus two well established hydrocolloid dressings in the treatment of venous leg ulcers using short-stretch compression bandages. Fourth Australian Wound Management Association Conference. 2002, 7-10 March. Adelaide, South Australia. 2002. 31. Other.
Charles H, Callicot C, Mathurin D, Ballard K, Hart J. Randomised, comparative study of three primary dressings for the treatment of venous ulcers. Br J Community Nurs. 2002;7(6 Suppl):48-54. Other. [pmid: 12066081].
Chen CJ, Guo SG, Luo D, Huang YQ. Full-valve annuloplasty in treatment of primary deep venous valvular incompetence of the lower extremities. Chin Med J (Engl). 92;105(3):256-9. Case series does not provide demographics. [pmid: 1395848].
Cherry GW, Ryan T, McGibbon D. Trial of a new dressing in venous leg ulcers. Practitioner. 84;228(1398):1175-8. No concurrent comparison group; different levels of compression used. [pmid: 6390412].
Christenson JT. Postthrombotic or non-postthrombotic severe venous insufficiency: impact of removal of superficial venous reflux with or without subcutaneous fasciotomy. J Vasc Surg. 2007;46(2):316-21. No separate analysis of CVU. [pmid: 17664106].
Ciostek P, Myrcha P, Noszczyk W. Ten years experience with subfascial endoscopic perforator vein surgery. Ann Vasc Surg. 2002;16(4):480-7. Different levels of compression used. [pmid: 12098018].
Clarke TF, Braithwaite BD. Radiofrequency ablation of the great saphenous vein: resistive versus segmental techniques. Vasc Endovascular Surg. 2011;45(5):474. No separate analysis of CVU; case series with <10. [pmid: 21719553].
Clarke-Moloney M, Keane N, Kavanagh E. Changes in leg ulcer management practice following training in an Irish community setting. J Wound Care. 118. 2008;17(3):116-21. No intervention of interest. [pmid: 18376653].
Coccheri S, Scondotto G, Agnelli G, Aloisi D, Palazzini E, Zamboni V. Randomised, double blind, multicentre, placebo controlled study of sulodexide in the treatment of venous leg ulcers. Thromb Haemost. 2002;87(6):947-52. No intervention of interest. [pmid: 12083500].
Collier J. A moist, odour-free environment. A multicentred trial of a foamed gel and a hydrocolloid dressing. Prof Nurse. 92;7(12):804. 806. 808. No separate analysis of CVU; no outcome of interest. [pmid: 1513833].
Colombo P, Contos S, De Bernardi M. Evaluation of the therapeutic efficacy and tolerability of 5% amikacin gel. ACTA TOXICOL. THER. 91;12(3):229-239. No separate analysis of CVU.
Corcos L, Peruzzi GP, Romeo V, Procacci T. Preliminary results of external valvuloplasty in saphenofemoral junction insufficiency. PHLEBOLOGY. 89;4(3):197-202. No concurrent comparison group; different levels of compression used.
Costante F, Panero D, Lanati I, Giordano O. Subfascial endoscopic perforating surgery. Personal experience. La chirurgia endoscopica sottofasciale delle perforanti. La nostra esperienza. Minerva Chir. 2003;58(4):557-562. Case series with <10. [pmid: 14603169].
Covo L. Sclerotherapy and varices: at what stage?. Sclerotherapie et maladie variqueuse: a quel stade?. Phlebologie. 91;44(1):221-225. No original data; no outcome of interest. [pmid: 1946648].
Creutzig A, Caspary L, Von Der Lieth H, Alexander K. Changes of tcPO2 and laser-doppler-flowmetry in patients with primary varicosis before and after varix exeresis. VERANDERUNGEN DES TCPO2 UND LDF BEI PATIENTEN MIT PRIMARER VARIKOSE VOR UND NACH VARIZENEXHAIRESE. VASA J. VASC. DIS. 88;17(SUPPL. 23):57-58. < 4 weeks followup duration; case series with <10.
Curran MP, Plosker GL. Bilayered bioengineered skin substitute (Apligraf): a review of its use in the treatment of venous leg ulcers and diabetic foot ulcers. BioDrugs. 2002;16(6):439-55. No original data. [pmid: 12463767].
Da Costa RM, Ribeiro Jesus FM, Aniceto C, Mendes M. Randomized, double-blind, placebo-controlled, dose- ranging study of granulocyte-macrophage colony stimulating factor in patients with chronic venous leg ulcers. Wound Repair Regen. 1999;7(1):17-25. No intervention of interest. [pmid: 10231502].
Dale JJ, Ruckley CV, Harper DR, Gibson B, Nelson EA, Prescott RJ. Randomised, double blind placebo controlled trial of pentoxifylline in the treatment of venous leg ulcers. BMJ. 99;319(7214):875-8. No intervention of interest.
Danielsen L, Madsen SM, Henriksen L. Healing of venous leg ulcers. A randomized prospective study of a long-stretch versus short-stretch compression bandage. Ugeskr Laeger. 99;161(44):6042-5. No intervention of interest. [pmid: 10778338].
Darke SG, Penfold C. Venous ulceration and saphenous ligation. Eur J Vasc Surg. 92;6(1):4-9. Different levels of compression used. [pmid: 1555668].
Darke SG. Incompetent perforating vein ligation in the treatment of venous ulceration. Ann R Coll Surg Engl. 87;69(1):43. Case series does not provide demographics. [pmid: 3566121].
Darvall KA, Bate GR, Adam DJ, Silverman SH, Bradbury AW. Ultrasound-guided foam sclerotherapy for the treatment of chronic venous ulceration: a preliminary study. Eur J Vasc Endovasc Surg. 2009;38(6):764-9. Case series with <10. [pmid: 19616975].
Darwood RJ, Theivacumar N, Dellagrammaticas D, Mavor AI, Gough MJ. Randomized clinical trial comparing endovenous laser ablation with surgery for the treatment of primary great saphenous varicose veins. Br J Surg. 2008;95(3):294-301. No separate analysis of CVU. [pmid: 18278775].
Davis LB, McCulloch JM, Neal MB. The effectiveness of Unna Boot and semipermeable film vs. Unna Boot alone in the healing of venous ulcers. A pilot report. Ostomy Wound Manage. 92;38(1):19-21. Case series with <10. [pmid: 1605824].
De Rijcke PAR, Hop WCJ, Wirtens CHA. Subfascial endoscopic perforating vein surgery as treatment for lateral perforating vein incompetence and venous ulceration. J. Vasc. Surg. 2003;38(4):799-803. Case series with <10. [pmid: 14560233].
De Sanctis MT, Belcaro G, Cesarone MR, Ippolito E, Nicolaides AN, Incandela L, Geroulakos G. Treatment of venous ulcers with pentoxifylline: a 12-month, double-blind, placebo controlled trial. Microcirculation and healing. Angiology. Suppl 1. 2002;53:S49-51. No intervention of interest. [pmid: 11865837].
de Souza GG, Pereira AH, Costa LF, Silva JC, Burihan E. Hemodynamic results of femoral vein valve repair. Cardiovasc Surg. 2001;9(2):127-32. No outcome of interestCase series with <10. [pmid: 11250174].
DePalma RG, Kowallek DL. Venous ulceration: a cross-over study from nonoperative to operative treatment. J Vasc Surg. 96;24(5):788-92. No intervention of interest. [pmid: 8918325].
Dix FP, Picton A, McCollum CN. Effect of superficial venous surgery on venous function in chronic venous insufficiency. Ann Vasc Surg. 2005;19(5):678-85. No separate analysis of CVU; case series with <10. [pmid: 16096860].
Dmochowska M, Prokop J, Bielecka S, Urasinska K, Krolicki A, Nagaj E, et al. A randomized, controlled, parallel group clinical trial of a polyurethane foam dressing versus a calcium alginate dressing in the treatment of moderately to heavily exuding venous leg ulcers. Wounds: A Compendium of Clinical Research and Practice. 99;11(1):21-8. Other.
Doblas M, Gutierrez Romero R, Fontcuberta J, Orgaz A, Lopez Beret P. Endoscopic subfascial ligature of perforating veins. Ligadura subfascial endoscopia de venas perforantes. An. Cir. Cardiaca Vasc. 2005;11(1):38-44. No original data.
Dommann SNW, Serbes B, Dommann-Scherrer CC, Kung EE. Debridement of leg ulcers with the CO2 laser; results of a pilot study with ten patients. WUNDREINIGUNG VON ULCERA CRURIS MIT HILFE DES CO2-LASERS; ERFAHRUNGENSBERICHT ANHAND EINER PILOTSTUDIE MIT 10 PATIENTEN. AKTUEL. DERMATOL. 95;21(8):232-236. Case series with <10.
Driuk NF, Fadeev SG, Guch AA. Surgical reconstruction of the valves of the deep veins in the femoro-popliteal segment. Klin Khir. 88;(7):49-52. No original data.
Driuk NF, Fadeev SG, Polishchuk IE, Soroka AM. Surgical correction and reconstruction of the valves of the femoro-popliteal segment of deep veins. Khirurgicheskaia korrektsiia i rekonstruktsiia klapanov bedrenno-podkolennogo segmenta glubokikh ven. Vestn. Khir. Im. I. I. Grek. 88;140(6):134-137. No separate analysis of CVU; case series does not assess ulcer healing. [pmid: 3065999].
Driuk NF, Fadeev SG, Polishchuk IuE, Soroka AM. Surgical correction and reconstruction of the valves of the femoro-popliteal segment of deep veins. Vestn Khir Im I I Grek. 88;140(6):134-7. No original data. [pmid: 3065999].
Driver VR, Park NJ, Ogbonna J, Dinnall K, Powers K. The Effective Use of Negative Pressure Wound Therapy. Podiatry Management. 2012;31(5):165-174. No original data; no intervention of interest.
Dumville JC, Worthy G, Bland JM, Cullum N, Dowson C, Iglesias C, Mitchell JL, Nelson EA, Soares MO, Torgerson DJ. Larval therapy for leg ulcers (VenUS II): randomised controlled trial. BMJ. 2009;338:b773. No separate analysis of CVU; no intervention of interest. [pmid: 19304577].
Dumville JC, Worthy G, Soares MO, Bland JM, Cullum N, Dowson C, Iglesias C, McCaughan D, Mitchell JL, Nelson EA, Torgerson DJ. VenUS II: A randomised controlled trial of larval therapy in the management of leg ulcers. Health Technol. Assess. 2009;13(55):1-182. No outcome of interest. [pmid: 19925723].
Dunn JM, Kernick VFM, Cosford EJ, Campbell WB. Surgical treatment for venous ulcers: Is it worthwhile?. ANN. R. COLL. SURG. ENGL. 95;77(6):421-424. No original data; case series does not provide demographics. [pmid: 8540660].
Dunn RM, Fudem GM, Walton RL, Anderson FA Jr, Malhotra R. Free flap valvular transplantation for refractory venous ulceration. J Vasc Surg. 94;19(3):525-31. Case series with <10. [pmid: 8126867].
Duran V, Matic M, Jovanovc M, Mimica N, Gajinov Z, Poljacki M, Boza P. Results of the clinical examination of an ointment with marigold (Calendula officinalis) extract in the treatment of venous leg ulcers. Int J Tissue React. 2005;27(3):101-6. Different levels of compression used; < 4 weeks followup duration. [pmid: 16372475].
Duhra P, Blight A, Mountford E, Cheshire I, Withers A, Ilchyshyn A. A randomized controlled trial of cultured keratinocyte allografts for chronic venous ulcers. J Dermatol Treat. 1992;3(4):189-191. Inconsistent compression.
Ebner H, Zaraca F, Ebner JA, Stringari C. Leg ulcer: proposal of a new method for comparing different wound dressings. Chir Ital. 2008;60(4):563-6. No intervention of interest. [pmid: 18837258].
Edmonds M. Early use of antibiotics should not be ruled out. Diabetic Foot Journal. 99;2(4):135-138. No original data; no separate analysis of CVU.
Edwards H, Courtney M, Finlayson K, Shuter P, Lindsay E. A randomised controlled trial of a community nursing intervention: improved quality of life and healing for clients with chronic leg ulcers. J Clin Nurs. 2009;18(11):1541-9. No intervention of interest. [pmid: 19490293].
Egemen O, Ozkaya O, Ozturk MB, Aksan T, Orman C, Akan M. Effective use of negative pressure wound therapy provides quick wound-bed preparation and complete graft take in the management of chronic venous ulcers. Int Wound J. 2011. No concurrent comparison group.
Ehresmann U, Bischoff B, Warnat S, Krunes U, Holzapfel R. Ulcer healing after varicose surgery - Results after five years. Ulkusheilung nach varizen-OP - Ergebnisse nach funf jahren. Phlebologie. 99;28(4):118-121. Does not describe sampling frame.
Eriksson G. Comparative study of hydrocolloid dressings and double layer bandage in treatment of venous stasis ulceration. An Environment for Healing : The Role of Occlusion. 84:111-3. No original data.
Eriksson G. Comparison of two occlusive bandages in the treatment of venous leg ulcers. Br J Dermatol. 86;114(2):227-30. No intervention of interest. [pmid: 3511944].
Eriksson G, Eklund AE, Liden S, Zetterquist S. Comparison of different treatments of venous leg ulcers: A controlled study using stereophotogrammetry. CURR. THER. RES. CLIN. EXP. 84;35(4):678-684. Different levels of compression used.
Eriksson I, Almgren B. Surgical reconstruction of incompetent deep vein valves. Ups J Med Sci. 88;93(2):139-43. No original dataNo separate analysis of CVU. [pmid: 3206725].
Eriksson I. Reconstructive surgery for deep vein valve incompetence in the lower limb. Eur J Vasc Surg. 90;4(3):211-8. No original data. [pmid: 2191873].
Etienne G, Constantin JM, Hevia M. Cryo-stripping: an advance in the treatment of varicose veins. 3811 operated limbs. Presse Med. 95;24(22):1017-20. No separate analysis of CVU; no concurrent comparison group. [pmid: 7667227].
Falanga V. Apligraf treatment of venous ulcers and other chronic wounds. J Dermatol. 98;25(12):812-7. No original data. [pmid: 9990774].
Falanga V, Fujitani RM, Diaz C, Hunter G, Jorizzo J, Lawrence PF, Lee BY, Menzoian JO, Tretbar LL, Holloway GA, Hoballah J, Seabrook GR, McMillan DE, Wolf W. Systemic treatment of venous leg ulcers with high doses of pentoxifylline: efficacy in a randomized, placebo-controlled trial. Wound Repair Regen. 99;7(4):208-13. No intervention of interest. [pmid: 10781212].
Fernandez CF, Roizental M, Carvallo J. Combined endovenous laser therapy and microphlebectomy in the treatment of varicose veins: Efficacy and complications of a large single-center experience. J. Vasc. Surg. 2008;48(4):947-952. No separate analysis of CVU; no outcome of interest. [pmid: 18692346].
Ferrara F, Meli F, Raimondi F, Amato C, Bonura F, Mule G, Novo G, Novo SS. The treatment of venous leg ulcers: a new therapeutic use of iloprost. Ann Surg. 2007;246(5):860-5. No intervention of interest. [pmid: 17968180].
Ferris EB, Kistner RL. Femoral vein reconstruction in the management of chronic venous insufficiency. A 14-year experience. Arch Surg. 82;117(12):1571-9. No separate analysis of CVU. [pmid: 7149977].
Figueiredo M, Araujo S, Barros N Jr., Miranda F Jr. Results of Surgical Treatment Compared with Ultrasound-Guided Foam Sclerotherapy in Patients with Varicose Veins: A Prospective Randomised Study. Eur. J. Vasc. Endovasc. Surg. 2009;38(6):758-763. No separate analysis of CVU; case series with <10. [pmid: 19744867].
Fischer H, Gilliet F, Hornemann M, Leyh F, Lindemayr H, Stegmann W, Welke S. Enzymatic debridement in venous ulcus cruris. Report of a multicenter clinical comparative study with various enzyme preparations. Fortschritte der Medizin. 84;102(10):281-3. No intervention of interest; different levels of compression used; no outcome of interest. [pmid: 6325313].
Foote M. Inhibiting bacterial growth in venous ulcers using an antimicrobial foam dressing.. including commentary by Cuttino C. Ostomy Wound Management. 2009:18-19. No concurrent comparison group.
Forschner A, Schippert W, Rassner G, Breuninger H. Stripping operations of the parva and magna saphenous veins. Long-term study in relation to pre- and postoperative dysfunction. Hautarzt. 2001;52(9):797-802. No separate analysis of CVU. [pmid: 11572071].
Franks PJ, Moody M, Moffatt CJ. Randomised trial of a soft silicone dressing a foam dressing in patients with chronic venous ulceration [Abstract]. 13th Conference of the European Wound Management Association. 2003, 22-24 May. Pisa, Italy. 2003. 51. Other.
Franks PJ, Bosanquet N, Brown D, Straub J, Harper DR, Ruckley CV. Perceived health in a randomised trial of treatment for chronic venous ulceration. Eur J Vasc Endovasc Surg. 99;17(2):155-9. Different levels of compression used. [pmid: 10063412].
Franks PJ, Moody M, Moffatt CJ, Patton J, Bradley L, Chaloner D, Stevens J, Stevens J, Lewis C. Quality of life in a trial of short stretch versus four-layer bandaging in the management of chronic venous ulceration. Phlebology. 2004;19(2):87-91. No outcome of interest.
Frantsuzov VN, Krylov NL, Kalinin VP, Pomelov AV. The basic trends in the combined treatment of trophic ulcers of the lower extremities. Osnovnye napravleniia kompleksnogo lecheniia troficheskikh iazv nizhnikh konechnostei. Voen Med Zh. 93;(9):44-45. 80. No separate analysis of CVU.
Freak L, Simon D, Edwards AT, McCollum CN. Comparative study of three primary dressings in the healing of chronic venous ulcers. British Journal of Surgery. 92;79(11):1235. Other.
Friedman SJ, Su WP. Management of leg ulcers with hydrocolloid occlusive dressing. Arch Dermatol. 84;120(10):1329-36. No concurrent comparison group; different levels of compression used. [pmid: 6486846].
Fromantin I, Seyer D. Biofilm and leg ulcers. Soins. 2012;(762):53. Other. [pmid: 22489433].
G M, Alamari MG, Albanesi M, et al. Multicentre trial of cadexomer iodine and standard therapy in the treatment of chronic venous ulcers of the lower limbs. Minerva Angiol. 1990;15:171-179. Different levels of compression used.
Gale SS, Lee JN, Walsh ME, Wojnarowski DL, Comerota AJ. A randomized, controlled trial of endovenous thermal ablation using the 810-nm wavelength laser and the ClosurePLUS radiofrequency ablation methods for superficial venous insufficiency of the great saphenous vein. J Vasc Surg. 2010;52(3):645-50. No separate analysis of CVU. [pmid: 20638231].
Galimzianov FV. Laser and electromagnetolaser therapy in trophic ulcers of the lower extremities in chronic venous insufficiency. Lazernaia i elektromagnitolazerbaia terapiia troficheskikh iazv nizhnikh konechnostei pri khronicheskoi venoznoi nedostatochnosti. Vestn. Khir. Im. I. I. Grek. 94;152(5-6):70-72. No original data; no intervention of interest. [pmid: 7740698].
Gamborg Nielsen P, Munk Madsen S, Stromberg L. Treatment of chronic leg ulcers with a hydrocolloid dressing. Acta Derm Venereol Suppl (Stockh). 89;152:1-12. No separate analysis of CVU; no concurrent comparison group. [pmid: 2618526].
Garrido GH, Rosado CR, Rivas MJ, et al. The effect on the reparation process of dextranomer (Debrisan(Reg.trademark)) in perimalleolar ulcers due to chronic venous insufficiency. CLIN TRIALS J. 84;21(3):121-134. Other.
Geske T, Hachmann E, Effendy I. Wound treatment with ethacridine lactate in venous leg ulcers: A prospective, randomized, placebo-controlled, single-blind study. Wundbehandlung mit ethacridinlactat bei ulcus cruris venosum: Eine prospektive, randomisierte, placebokontrollierte, einfachblinde studie. Vasomed. 2005;17(3):99-103. No intervention of interest.
Gethin G, Cowman S. Bacteriological changes in sloughy venous leg ulcers treated with manuka honey or hydrogel: an RCT. J Wound Care. 2008;17(6):241-4. 246. 7. No outcome of interest. [pmid: 18666717].
Gibbs S, van den Hoogenband HM, Kirtschig G, Richters CD, Spiekstra SW, Breetveld M, Scheper RJ, de Boer EM. Autologous full-thickness skin substitute for healing chronic wounds. Br J Dermatol. 2006;155(2):267-74. No concurrent comparison group. [pmid: 16882162].
Gloviczki P. Subfascial endoscopic perforator vein surgery: indications and results. Vasc Med. 99;4(3):173-80. No original data. [pmid: 10512597].
Gloviczki P. The Rationale for the Treatment of Perforating Veins in Advanced Chronic Venous Insufficiency. Dis. Mon. 2010;56(11):658-662. No original data. [pmid: 21081197].
Gloviczki P, Bergan JJ, Rhodes JM, Canton LG, Harmsen S, Ilstrup DM. Mid-term results of endoscopic perforator vein interruption for chronic venous insufficiency: lessons learned from the North American subfascial endoscopic perforator surgery registry. The North American Study Group. J Vasc Surg. 99;29(3):489-502. Different levels of compression used. [pmid: 10069914].
Gloviczki P, Cambria RA, Rhee RY, Canton LG, McKusick MA. Surgical technique and preliminary results of endoscopic subfascial division of perforating veins. J Vasc Surg. 96;23(3):517-23. Case series with <10. [pmid: 8601897].
Gloviczki P, Merrell SW, Bower TC. Femoral vein valve repair under direct vision without venotomy: a modified technique with use of angioscopy. J Vasc Surg. 91;14(5):645-8. No original data; no separate analysis of CVU. [pmid: 1942373].
Gohel MS, Barwell JR, Earnshaw JJ, Heather BP, Mitchell DC, Whyman MR, Poskitt KR. Randomized clinical trial of compression plus surgery versus compression alone in chronic venous ulceration (ESCHAR study)--haemodynamic and anatomical changes. Br J Surg. 2005;92(3):291-7. No separate analysis of CVU. [pmid: 15584055].
Gohel MS, Barwell JR, Heather BP, Earnshaw JJ, Mitchell DC, Whyman MR, Poskitt KR. The predictive value of haemodynamic assessment in chronic venous leg ulceration. Eur J Vasc Endovasc Surg. 2007;33(6):742-6. No intervention of interest; no KQ. [pmid: 17275361].
Gohel MS, Barwell JR, Wakely C, Minor J, Harvey K, Earnshaw JJ, Heather BP, Whyman MR, Poskitt KR. The influence of superficial venous surgery and compression on incompetent calf perforators in chronic venous leg ulceration. Eur J Vasc Endovasc Surg. 2005;29(1):78-82. No separate analysis of CVU. [pmid: 15570276].
Gonzalez-Zeh R, Armisen R, Barahona S. Endovenous laser and echo-guided foam ablation in great saphenous vein reflux: one-year follow-up results. J. Vasc. Surg. 2008;48(4):940-946. No separate analysis of CVU; case series with <10. [pmid: 18639418].
Goor W. The sclerotherapy for venous ulcers. DIE VERODUNGSBEHANDLUNG BEIM ULCUS CRURIS VARICOSUM. THER. UMSCH. 84;41(12):869-872. No original data. [pmid: 6523425].
Greger B, Habig H, Sonnefeld R. Critical analysis of the value of endoscopic subfascial dissection of perforating veins (ESDP) in the surgical treatment of primary varicosis. Kritische prufung des stellenwerts der ESDP bei der operativen therapie der primaren varikosis. Vasomed. 2002;14(4):136-143. No separate analysis of CVU.
Guarnera G, DeRosa A, Camerini R. The effect of thymosin treatment of venous ulcers. Ann N Y Acad Sci. 2010;1194:207-12. No intervention of interest. [pmid: 20536470].
Guest MG, Smith JJ, Greenhalgh RM, Davies AH. A randomised controlled trial of 4 layer bandaging and simple venous surgery for venous ulceration. Phlebology. 2000;15(2):93. No original data.
Guest MG, Smith JJ, Greenhalgh RM, Davies AH. A randomised controlled trial of 4-layer bandaging and simple venous surgery for venous surgery for venous ulceration. Annual Meeting of the Venous Forum of the Royal Society of Medicine. 2000, 13 October. Chester, England. 2000. 93. No original data.
Guinan S. Tullamore puts silver to the test. Nursing in the Community. 2002;3(8):10-13. No original data.
Gulla P, Pieretti C. Surgical therapy of recurring varices in the lower extremities. TERAPIA CHIRURGICA DELLE VARICI RECIDIVE DEGLI ARTI INFERIORI. MINERVA CHIR. 84;39(13-14):1035-1039. No original data; no separate analysis of CVU. [pmid: 6504348].
Haeger K. Prevention of venous leg ulcer recurrence by a simplified procedure of perforator ligation in ambulant practice. Vasa. 84;13(3):248-50. No separate analysis of CVU; case series does not provide demographics. [pmid: 6485528].
Handfield-Jones SE, Grattan CE, Simpson RA, Kennedy CT. Comparison of a hydrocolloid dressing and paraffin gauze in the treatment of venous ulcers. Br J Dermatol. 88;118(3):425-7. < 4 weeks followup duration. [pmid: 3128320].
Hansson C, Faergemann J, Swanbeck G. Fungal infections occurring under bandages in leg ulcer patients. Acta Derm Venereol. 87;67(4):341-5. No intervention of interest. [pmid: 2445155].
Harlander-Locke M, Lawrence P, Jimenez JC, Rigberg D, Derubertis B, Gelabert H. Combined treatment with compression therapy and ablation of incompetent superficial and perforating veins reduces ulcer recurrence in patients with CEAP 5 venous disease. J Vasc Surg. 2011. No separate analysis of CVU; no outcome of interest; case series with <10.
Harrison MB, Vandenkerkhof EG, Hopman WM, Graham ID, Carley ME, Nelson EA. The Canadian Bandaging Trial: Evidence-informed leg ulcer care and the effectiveness of two compression technologies. BMC Nurs. 2011;10(1):20. No intervention of interest. [pmid: 21995267].
Hart J, Charles H, Callicot C, Mathurin D, Ballard C, Harding KG. A randomised comparative study of a new hydroactive foam dressing versus two hydrocolloid dressings in the treatment of venous ulcers. 8th Annual Meeting of the European Tissue Repair Society. 1998, August 27-30. Copenhagen, Denmark. 98;6(5):A469. Other.
Hart J, Charles H, Callicot C, Mathurin D, Ballard K, Bale S, et al. Randomised, comparative study of Cutinova foam versus Comfeel and Granuflex (improved formulation) in the treatment of venous leg ulcers - interim results. 7th Annual Meeting European Tissue Repair Society. 1997, 23-26 August. Koln, Germany. 97. 5. Other.
Hartmann A, Quist J, Hamm H, Brocker EB, Friedl P. Transplantation of autologous keratinocyte suspension in fibrin matrix to chronic venous leg ulcers: improved long-term healing after removal of the fibrin carrier. Dermatol Surg. 2008;34(7):922-9. No concurrent comparison group. [pmid: 18384617].
He Q, Wu G, Yu B, Zhang T, Wang W, Gu Q. A prospective study on wound-healing hydrogel in treating chronic venous ulcer of lower extremities. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2008;22(3):311-3. < 4 weeks followup duration. [pmid: 18396709].
Helaly P, Vogt E, Schneider G. Wound healing disorders and their enzymatic therapy--a multicenter double-blind study. Wundheilungsstorungen und ihre enzymatische Therapie--eine multizentrische Doppelblindstudie. Schweiz. Rundsch. Med. Prax. 88;77(52):1428-1434. < 4 weeks followup duration. [pmid: 2851160].
Hertzman PA, Owens R. Sustained healing of chronic venous ulcers, one and two years following ultrasound-guided endovenous chemical ablation of the great saphenous vein. Phlebology. 2008;23:9. No separate analysis of CVU; no intervention of interest; no outcome of interest.
Hillstrom L. Iodosorb compared to standard treatment in chronic venous leg ulcers--a multicenter study. Acta Chir Scand Suppl. 88;544:53-6. Different levels of compression used. [pmid: 3051826].
Hingorani AP, Ascher E, Marks N, Shiferson A, Patel N, Gopal K, Jacob T. Predictive factors of success following radio-frequency stylet (RFS) ablation of incompetent perforating veins (IPV). J Vasc Surg. 2009;50(4):844-8. Other. [pmid: 19576715].
Hinz J, Hautzinger H, Stahl KW. Rationale for and results from a randomised, double-blind trial of tetrachlorodecaoxygen anion complex in wound healing. Lancet. 86;1(8485):825-8. Different levels of compression used; < 4 weeks followup duration. [pmid: 2870315].
Hjerppe A, Sane M, Huhtala H, Vaalasti A. Pinch grafting of chronic leg ulcers: a retrospective analysis of 104 patients with 169 ulcers. J Wound Care. 2010;19(1):37-40. No intervention of interest. [pmid: 20081572].
Hogue RS, Schul MW, Dando CF, Erdman BE. The effect of nitroglycerin ointment on great saphenous vein targeted venous access site diameter with endovenous laser treatment. Phlebology. 2008;23(5):222-6. No separate analysis of CVU; no intervention of interest. [pmid: 18806204].
Hokkam E, El-Labban G, Shams M, Rifaat S, El-Mezaien M. The use of topical phenytoin for healing of chronic venous ulcerations. Int J Surg. 2011;9(4):335-8. Different levels of compression used. [pmid: 21338720].
Holme TC, Negus D. The treatment of venous ulceration by surgery and elastic compression hosiery; A long-term review. PHLEBOLOGY. 90;5(2):125-128. No concurrent comparison group; case series does not provide demographics.
Hordegen KM. Healing course of leg ulcers: The significance of systemic antibiotic therapy. HEULUNGSVERLAUF BEI BEINULZERA. BEDEUTUNG EINER SYSTEMISCHEN ANTIBIOTISCHEN THERAPIE. THERAPIEWOCHE SCHWEIZ. 93;9(6):369-376. No concurrent comparison group.
Hordegen KM. Leg ulcers - Ambulatory treatment and results. ULCUS CRURIS - AMBULANTE BEHANDLUNG UND ERGEBNISSE. SCHWEIZ. MED. WOCHENSCHR. 89;119(37):1264-1269. No intervention of interest. [pmid: 2799339].
Hubner K. Acceleration of healing of chronic therapy-resistant leg venous ulcers by sclerotherapy of periulcerous varices. Beschleunigung der abheilung des chronischen, therapieresistenten ulcus cruris venosum durch die sklerotherapie periulzeroser varizen: Eine studie bei 171 ulkus-patienten. Vasomed. 2001;13(5):191-195. No separate analysis of CVU.
Humphreys G, Lee GL, Percival SL, McBain AJ. Combinatorial activities of ionic silver and sodium hexametaphosphate against microorganisms associated with chronic wounds. J Antimicrob Chemother. 2011;66(11):2556-61. No separate analysis of CVU. [pmid: 21873289].
Hyde GL, Litton TC, Hull DA. Long term results of subfascial vein ligation for venous stasis disease. Surg Gynecol Obstet. 81;153(5):683-6. No intervention of interest; different levels of compression used. [pmid: 7292267].
Hessler I, Panfil EM. Ulcus curis venosum: topical drugs and dressings in evaluation. How effective are the measures in terms of pain management?. Pflege Z. 2011;64(10):616-7. No original data. [pmid: 22032037].
Wong IK, Andriessen A, Lee DT, Thompson D, Wong LY, Chao DV, So WK, Abel M. Randomized controlled trial comparing treatment outcome of two compression bandaging systems and standard care without compression in patients with venous leg ulcers. J Vasc Surg. 2012;55(5):1376-85. No intervention of interest; different levels of compression used. [pmid: 22429451].
Wong IK, Andriessen A, Charles HE, Thompson D, Lee DT, So WK, Abel M. Randomized controlled trial comparing treatment outcome of two compression bandaging systems and standard care without compression in patients with venous leg ulcers. J Eur Acad Dermatol Venereol. 2012;26(1):102-10. No intervention of interest; different levels of compression used. [pmid: 22077933].
Iafrati MD, Pare GJ, O'Donnell TF, Estes J. Is the nihilistic approach to surgical reduction of superficial and perforator vein incompetence for venous ulcer justified?. J Vasc Surg. 2002;36(6):1167-74. Case series with <10. [pmid: 12469048].
Iafrati MD, Welch HJ, O'Donnell TF Jr. Subfascial endoscopic perforator ligation: An analysis of early clinical outcomes and cost. J. VASC. SURG. 97;25(6):995-1001. No concurrent comparison group; case series with <10. [pmid: 9201159].
Isenberg JS. Additional follow-up with microvascular transfer in the treatment of chronic venous stasis ulcers. J. Reconstr. Microsurg. 2001;17(8):603-605. Different levels of compression used; < 4 weeks followup duration. [pmid: 11740655].
Iupatov SI, Smotrin SM, Anufrik SS. Use of laser irradiation in the treatment of trophic ulcers of the lower limbs. Primenenie lazernogo izlucheniia pri lechenii troficheskikh iazv nizhnikh konechnostei. Vestn. Khir. Im. I. I. Grek. 82;129(12):64-66. No intervention of interest. [pmid: 7168117].
Iupatov SI, Smotrin SM, Gavcrilik BL, Sten'ko VG. Treatment of trophic ulcers of the lower extremities in elderly patients. Lechenie troficheskikh iazv nizhnikh konechnostei u lits pozhilogo vozrasta. Khirurgiia (Mosk). 90;(5):105-108. No intervention of interest; different levels of compression used.
Ivanovic N, Panfil EM. Compression in varicose ulcer. What is the effect of this measure?. Pflege Z. 2011;64(7):412. No original data; no intervention of interest. [pmid: 21845897].
Ivins N, Harding KG, Price P, Jurgensen B, Lohmann M, Gottrup F, et al. Safety and efficacy in long-term use of a sustained silver-releasing foam dressing: a randomized, controlled trial on venous leg ulcers. SAWC. 2006; April 30 - May 3, 2006. San Antonio, Texas. 2006. Poster 12. Other.
Jain P, Perakath B, Jesudason MR, Nayak S. The effect of autologous bone marrow-derived cells on healing chronic lower extremity wounds: results of a randomized controlled study. Ostomy Wound Manage. 2011;57(7):38-44. No intervention of interest. [pmid: 21904014].
Jain SK, Gupta A, Murti Kaza RC. Use of ultrasonic scalpel in subfascial endoscopic perforator vein surgery: a novel approach. J Laparoendosc Adv Surg Tech A. 2008;18(2):244-7. No intervention of interest; different levels of compression used. [pmid: 18373451].
Jamieson WG, DeRose G, Harris KA. Management of venous stasis ulcer: long-term follow-up. Can J Surg. 90;33(3):222-3. Case series does not provide demographics. [pmid: 2350746].
Jankicevic J, Vesic S, Vukicevic J, Gajic M, Adamic M, Pavlovic MD. Contact sensitivity in patients with venous leg ulcers in Serbia: comparison with contact dermatitis patients and relationship to ulcer duration. Contact Dermatitis. 2008;58(1):32-6. Other. [pmid: 18154556].
Jankunas V, Bagdonas R, Samsanavicius D, Rimdeika R. The influence of surgical treatment for chronic leg ulcers on the quality dynamics of the patient's life. Acta Chir Belg. 2007;107(4):386-96. No intervention of interest; case series does not assess ulcer healing. [pmid: 17966531].
Jean SE, Moreau L. Contact dermatitis in leg ulcer patients. J Cutan Med Surg. Suppl 1. 2009;13:S38-41. No original data. [pmid: 19480751].
Jimenez Cossio JA. Topical treatment of ulcers of venous origin with semi-synthetic hydrocolloid occlusive bandages. Angiologia. 86;38(2):106-14. No original data; no intervention of interest. [pmid: 3706811].
Johnson M. Healing determinants in older people with leg ulcers. Res Nurs Health. 95;18(5):393-403. No intervention of interest; no outcome of interest. [pmid: 7676073].
Johnson WC, O'Hara ET, Corey C. Venous stasis ulceration: Effectiveness of subfascial ligation. ARCH. SURG. 85;120(7):797-800. Different levels of compression used. [pmid: 4015369].
Johnson WC, O'Hara ET, Corey C, Widrich WC, Nabseth DC. Venous stasis ulceration. Effectiveness of subfascial ligation. Arch Surg. 85;120(7):797-800. Case series does not assess ulcer healing. [pmid: 4015369].
Jones V. Comparison of the new multilayer composite wound dressing Versiva with Allevyn hydrocellular for managing venous leg ulcers: results of an international multicentre randomised trial [Abstract]. 13th Conference of the European Wound Management Association. 2003, 22-24 May. Pisa, Italy. 2003. 217. No original data.
Jones V. Comparison of the new multilayer composite wound dressing Versiva with Tielle Plus for managing venous leg ulcers: results of an international multicentre randomised trial [Abstract]. 13th Conference of the European Wound Management Association. 2003, 22-24 May. Pisa, Italy. 2003. 218. Other.
Jorgensen B, Sulcaite R, Vilkevicius G, Bech-Thomsen N, Rimdeika R, Gottrup F. A randomised, controlled trial on safety and performance of a new foam dressing on venous leg ulcers. EWMA Journal. 2008;8(2 (Supp)):138. Abstract no. P69. No original data.
Jørgensen B, Karlsmark T, Vogensen H, Haase L, Lundquist R. A Pilot Study to Evaluate the Safety and Clinical Performance of Leucopatch, an Autologous, Additive-Free, Platelet-Rich Fibrin for the Treatment of Recalcitrant Chronic Wounds. International Journal of Lower Extremity Wounds. 2011;10(4):218-223. No separate analysis of CVU; no intervention of interest; no concurrent comparison group. [pmid: 22009148].
Jorgensen B, Friis GJ, Gottrup F. Pain and quality of life for patients with venous leg ulcers: proof of concept of the efficacy of Biatain-Ibu, a new pain reducing wound dressing. Wound Repair Regen. 2006;14(3):233-9. No concurrent comparison group< 4 weeks followup duration. [pmid: 16808800].
Jorgensen B, Price P, Andersen KE, Gottrup F, Bech-Thomsen N, Scanlon E, Kirsner R, Rheinen H, Roed-Petersen J, Romanelli M, Jemec G, Leaper DJ, Neumann MH, Veraart J, Coerper S, Agerslev RH, Bendz SH, Larsen JR, Sibbald RG. The silver-releasing foam dressing, Contreet Foam, promotes faster healing of critically colonised venous leg ulcers: a randomised, controlled trial. Int Wound J. 2005;2(1):64-73. No separate analysis of CVU. [pmid: 16722854].
Joyce DH. Radiofrequency ablation of incompetent perforator veins. Initial experience: The first 683 ablations. Phlebology. 2008;23:6. No KQ.
Judy D, Burton C, Johnson J, Yates S. Silver impregnated dressings: Do they help chronic venous ulcers heal?. J. Am. Acad. Dermatol. 2010;62(3):AB150. No original data.
Jugenheimer M, Junginger T. Endoscopic subfascial sectioning of incompetent perforating veins in treatment of primary varicosis. World J Surg. 92;16(5):971-5. No separate analysis of CVU; case series with <10. [pmid: 1462640].
Jugenheimer M, Mayer W, Uckele M. Endoscopic subfascial dissection of the perforating veins: treatment results. Surg Technol Int. 2003;11:202-5. No original data; no separate analysis of CVU. [pmid: 12931302].
Jull A, Walker N, Parag V, Molan P, Rodgers A. Randomized clinical trial of honey-impregnated dressings for venous leg ulcers. Br J Surg. 2008;95(2):175-82. No separate analysis of CVU. [pmid: 18161896].
Jull A, Walker N, Parag V, Molan P, Rodgers A. Venous ulcer management in New Zealand: usual care versus guideline recommendations. N Z Med J. 2009;122(1295):9-18. No intervention of interest. [pmid: 19648982].
Junger M, Zuder D, Steins A, Hahn M, Klyscz T. Treatment of venous leg ulcers with low frequency pulsed direct current (Dermapulse(registered trademark)): Effects on cutaneous microcirculation. Behandlung von venosen ulzera mit niederfrequentem gepulstem strom (Dermapulse): Effekte auf die kutane mikrozirkulation. Hautarzt. 97;48(12):897-903. Case series with <10. [pmid: 9486361].
Kabbani L, Escobar GA, Mansour F, Wakefield TW, Henke PK. Longevity and outcomes of axillary valve transplantation for severe lower extremity chronic venous insufficiency. Ann Vasc Surg. 2011;25(4):496-501. No original data; no separate analysis of CVU; no intervention of interest. [pmid: 21549918].
Kahle B. Foam sclerotherapy of ulcus cruris venosum. Stellenwert der schaumsklerosierung in der behandlung des ulcus cruris venosum. Med. Welt. 2010;61(6):313-316. No outcome of interest.
Kalodiki E, Ellis M, Kakkos SK, Williams A, Davies AH, Geroulakos G. Immediate hemodynamic effect of the additional use of the SCD EXPRESS Compression System in patients with venous ulcers treated with the four-layer compression bandaging system. Eur J Vasc Endovasc Surg. 2007;33(4):483-7. Intermittent compression. [pmid: 17224283].
Kammerlander G, Afarideh R, Baumgartner A, Berger M, Fischelmayer K, Hirschberger G, Hangler W, Huber A. Clinical experiences of using a silver hydroalginate dressing in Austria, Switzerland and Germany. Journal of Wound Care. 2008;17(9):384. No separate analysis of CVU; no concurrent comparison group. [pmid: 18833896].
Karlsmark T, Hahn TW, Thomsen JK, Gottrup F. Hydrocapillary dressing to manage exudate in venous leg ulcers. Br J Nurs. 2004;13(6 Suppl):S29-35. No concurrent comparison group. [pmid: 15126973].
Karr JC. Retrospective comparison of diabetic foot ulcer and venous stasis ulcer healing outcome between a dermal repair scaffold (PriMatrix) and a bilayered living cell therapy (Apligraf). Adv Skin Wound Care. 2011;24(3):119-25. Other. [pmid: 21326023].
Katelaris PM, Fletcher JP, Little JM, McEntyre RJ, Jeffcoate KW. Electrical stimulation in the treatment of chronic venous ulceration. Aust N Z J Surg. 87;57(9):605-7. No intervention of interest. [pmid: 3689247].
Kenkre JE, Hobbs FD, Carter YH, Holder RL, Holmes EP. A randomized controlled trial of electromagnetic therapy in the primary care management of venous leg ulceration. Fam Pract. 96;13(3):236-41. No intervention of interest; no outcome of interest. [pmid: 8671131].
Kerihuel JC. Effect of activated charcoal dressings on healing outcomes of chronic wounds. J Wound Care. 210. 2010;19(5):208-2. 214. 5. No separate analysis of CVU. [pmid: 20505594].
Kerner J, Schultz-Ehrenburg U. Functional meaning of different injection levels in the course of sclerotherapy. PHLEBOLOGY. 89;4(2):123-131. Different levels of compression usedCase series with <10.
Kero M, Tarvainen K, Hollmen A, Pekanmaki K. A comparison of cadexomer iodine with dextranomer in the treatment of venous leg ulcers. CURR. THER. RES. CLIN. EXP. 87;42(5):761-767. No separate analysis of CVU.
Kerstein MD, Gahtan V. Outcomes of venous ulcer care: results of a longitudinal study. Ostomy Wound Manage. 2000;46(6):22-6. 28. 9. No outcome of interest. [pmid: 11029932].
Kharfi M, Zeglaoui F, Ben Slimene M, Ezzeddine M, Kamoun MR. Elastic compression bandaged in the management of leg ulcer of venous origin. Tunis Med. 97;75(12):910-1. No original data; no outcome of interest. [pmid: 9507318].
Kianifard B, Holdstock J, Allen C, Smith C, Price B, Whiteley MS. Randomized clinical trial of the effect of adding subfascial endoscopic perforator surgery to standard great saphenous vein stripping. Br J Surg. 2007;94(9):1075-80. No separate analysis of CVU; case series with <10. [pmid: 17701962].
Kikta MJ, Schuler JJ, Meyer JP, Durham JR, Eldrup-Jorgensen J, Schwarcz TH, Flanigan DP. A prospective, randomized trial of Unna's boots versus hydroactive dressing in the treatment of venous stasis ulcers. J Vasc Surg. 88;7(3):478-83. Different levels of compression used. [pmid: 3279235].
King T. Preliminary experience with concomitant ultrasound-guided foam sclerotherapy and endovenous laser ablation: A series of 1000 consecutive cases. Phlebology. 2008;23(5):241-242. No original data.
King T, Coulomb G, Goldman A, Sheen V, McWilliams S, Guptan RC. Experience with concomitant ultrasound-guided foam sclerotherapy and endovenous laser treatment in chronic venous disorder and its influence on Health Related Quality of Life: interim analysis of more than 1000 consecutive procedures. Int Angiol. 2009;28(4):289-97. No separate analysis of CVU. [pmid: 19648872].
Kingston R, Smith K. Synthaderm treatment for varicose ulcers in mobile district practice patients. Br J Clin Pract. 86;40(8):331-5. Different levels of compression used; case series with <10. [pmid: 3741753].
Kirsner RS, Fastenau J, Falabella A, Valencia I, Long R, Eaglstein WH. Clinical and economic outcomes with graftskin for hard-to-heal venous leg ulcers: a single-center experience. Dermatol Surg. 2002;28(1):81-2. No original data; no concurrent comparison group. [pmid: 11991277].
Kirsner RS, Marson W, Snyder R, Lee T, Cargill D, Slade H. Spray-applied cell therapy with human allogeneic fibroblasts and keratinocytes for the treatment of chronic venous leg ulcers: a phase 2, multicenter, double-blind, randomized, placebo-controlled trial. Lancet. 2012. Epub August 3, 2012. No intervention of interest.
Kokol R, Berger C, Haas J, Kopera D. 685-nm low level laser therapy of venous leg ulcers. No improvement of wound healing with 685-nm low level laser therapy. Randomised, placebo-controlled, double-blind study. Hautarzt. 2005;56(6):570-5. No intervention of interest. [pmid: 15580451].
Kokol R, Berger C, Haas J, Kopera D. Venous leg ulcers: no improvement of wound healing with 685-nm low level laser therapy. Randomised, placebo-controlled, double-blind study. Hautarzt. 2005;56(6):570-5. No intervention of interest. [pmid: 15580451].
Koksal C, Bozkurt AK. Combination of hydrocolloid dressing and medical compression stockings versus Unna's boot for the treatment of venous leg ulcers. Swiss Med Wkly. 2003;133(25-26):364-8. No concurrent comparison group; different levels of compression used. [pmid: 12947533].
Kolvenbach R, Ramadan H, Schwierz E. Redone endoscopic perforator surgery: feasibility and failure analysis. J Vasc Surg. 99;30(4):720-6. No separate analysis of CVU; case series does not assess ulcer healing. [pmid: 10514211].
Konig M, Vanscheidt W, Augustin M, Kapp H. Enzymatic versus autolytic debridement of chronic leg ulcers: a prospective randomised trial. J Wound Care. 2005;14(7):320-3. No outcome of interest. [pmid: 16048218].
Kopera D, Kokol R, Berger C, Haas J. Low level laser: does it influence wound healing in venous leg ulcers? A randomized, placebo-controlled, double-blind study. Br J Dermatol. 2005;152(6):1368-70. Case series does not provide demographics. [pmid: 15949018].
Korber A, Franckson T, Grabbe S, Dissemond J. Vacuum assisted closure device improves the take of mesh grafts in chronic leg ulcer patients. Dermatology. 2008;216(3):250-6. No intervention of interest. [pmid: 18204263].
Korber A, Weindorf M, Dissemond J. Exudate capacity of modern wound dressings during compression therapy for chronic venous leg ulcers. Hautarzt. 2008;59(11):904-11. Not human. [pmid: 18815760].
Kotz P, Fisher J, McCluskey P, Hartwell SD, Dharma H. Use of a new silver barrier dressing, ALLEVYNparallelogram open Ag in exuding chronic wounds. Int. Wound J. 2009;6(3):186-194. No concurrent comparison group; no outcome of interest. [pmid: 19538192].
Kremer K, Sandmann W. Surgery of chronic venous insufficiency (varicose veins). Chirurgische Therapie der chronisch-venosen Insuffizienz (Krampfadern). Dtsch. Med. Wochenschr. 80;105(5):150-151. No original data. [pmid: 7351201].
Krupski WC, Reilly LM, Perez S, Moss KM, Crombleholme PA, Rapp JH. A prospective randomized trial of autologous platelet-derived wound healing factors for treatment of chronic nonhealing wounds: a preliminary report. J Vasc Surg. 91;14(4):526-32. discussion 532-6. No intervention of interest. [pmid: 1920650].
Kulkarni SR, Barwell JR, Gohel MS, Bulbulia RA, Whyman MR, Poskitt KR. Residual venous reflux after superficial venous surgery does not predict ulcer recurrence. Eur J Vasc Endovasc Surg. 2007;34(1):107-11. No concurrent comparison group; no outcome of interest. [pmid: 17408990].
Kulkarni SR, Gohel MS, Wakely C, Minor J, Poskitt KR, Whyman MR. The Ulcerated Leg Severity Assessment score for prediction of venous leg ulcer healing. Br J Surg. 2007;94(2):189-93. No intervention of interest. [pmid: 17205494].
Kumar A, Agarwal PN, Garg PK. Evaluation of subfascial endoscopic perforator vein surgery (SEPS) using harmonic scalpel in varicose veins: an observational study. Int J Surg. 2009;7(3):253-6. Case series with <10. [pmid: 19393778].
Kurdal AT, Cerrahoglu M, Iskesen I, Eserdag M, Sirin H. Subfascial endoscopic perforator surgery ameliorates the symptoms of chronic venous ulcer (C6) patiens. Int. Angiol. 2010;29(1):70-74. Case series with <10. [pmid: 20224536].
Kuruenko AI, Bogdanets LI, Bogachev VIu, Zhuravleva OV. Results of an open comparative study on efficacy and safety of Voscopran bandages used for local treatment of venous ulcers in the II and III stages of wound healing. Khirurgiia (Mosk). 2003;(9):38-40. < 4 weeks followup duration. [pmid: 14533380].
Kuznetsov NA, Barinov VE, Teleshov BV, Trepilets VE, Zheltikov AN. Surgical technologies in the treatment of varicose veins of the lower extremities complicated with trophic ulcer. Khirurgiia (Mosk). 2005;(4):37-41. No original data; no separate analysis of CVU. [pmid: 15940178].
Kuznetsov NA, Rodoman GV, Nikitin VG, Karev MA, Shalaeva TI. The use of current bandages in the treatment of patients with venous trophic ulcers of the skin: clinical and economic aspects. Khirurgiia (Mosk). 2009;(11):63-9. No concurrent comparison group; < 4 weeks followup duration.
Bilan L, Hurlimann F, Goor W, Korner WF, Kundig A, Madar G, Widmer LK, Ziegler WJ. Treatment of venous ulcers. A multi-center randomized double-blind study. VASA. 1985;14(4):383-9. No separate analysis of CVU; no intervention of interest; no concurrent comparison group. [pmid: 4072377].
Labas P, Ohradka B, Cambal M, Martinicky D. The treatment of venous leg ulcers by compression sclerotherapy. Bratisl Lek Listy. 2002;103(11):442-6. Case series does not provide demographics. [pmid: 12585364].
Labas P, Ohradka B, Cambal M, Ringelband R. The results of compression sclerotherapy: Comparative study of two techniques and two sclerosants. Die ergebnisse der kompressionssklerotherapie - Vergleichende studie zu zwei techniken und zwei sklerosierungsmitteln. Phlebologie. 2000;29(5):137-141. No intervention of interest; case series does not provide demographics.
Lacroix H, Smeets A, Nevelsteen A, Suy R. Classic versus endoscopic perforating vein surgery: a retrospective study. Acta Chir Belg. 98;98(2):71-5. No separate analysis of CVU; case series with <10. [pmid: 9615161].
Lafferty B, Wood L, Davis P. Improved care and reduced costs with advanced wound dressings. Wounds UK. 2011;7(1):14-23. No concurrent comparison group.
Lagan KM, McKenna T, Witherow A, Johns J, McDonough SM, Baxter GD. Low-intensity laser therapy/combined phototherapy in the management of chronic venous ulceration: a placebo-controlled study. J Clin Laser Med Surg. 2002;20(3):109-16. No outcome of interest; case series with <10. [pmid: 12165122].
Lammoglia L, Contreras-Ruiz J, Vega-Memije ME. Effectiveness of MTC-2G (Mimosa tenuiflora cortex extract) in venous leg ulcers treatment. Wound Repair Regen. 2010;18(2):A25. No original data.
Landau Z, Migdal M, Lipovsky A, Lubart R. Visible light-induced healing of diabetic or venous foot ulcers: a placebo-controlled double-blind study. Photomed Laser Surg. 2011;29(6):399-404. No intervention of interest. [pmid: 21214497].
Landsman AS, Cook J, Cook E, Landsman AR, Garrett P, Yoon J, Kirkwood A, Desman E. A retrospective clinical study of 188 consecutive patients to examine the effectiveness of a biologically active cryopreserved human skin allograft (TheraSkin(R)) on the treatment of diabetic foot ulcers and venous leg ulcers. Foot Ankle Spec. 2011;4(1):29-41. No separate analysis of CVU. [pmid: 21135263].
Larsen AM, Franken K, Vuerstaek J, Wuite J, van Neer PAFA, Andersen KE, et al. A randomised comparative study on performance and safety of biatain non-adhesive dressing versus allevyn hydrocellular dressing on venous leg ulcers [Abstract]. 11th Conference of the European Wound Management Association. 2001 17-19 May. Dublin, Ireland. 2001. 71. Other.
Larsen AM, Ulrik D, Madsen SM. Randomised study on Comfeel: alginate dressing vs Kaltostat on exudating venous leg ulcers. 5th Annual Meeting of the European Tissue Repair Society. 1995, August 30-September 2. Padova, Italy. 95. Other.
Larsen AM, Vogensen H, Haase L, et al. Evaluation of a foam dressing with a new soft adherent layer. European Wound Management Association. 1998. November. Harrogate, UK. 2005; Posterabstracts P197 293. No original data.
Laudanska H, Gustavson B. In-patient treatment of chronic varicose venous ulcers. A randomized trial of cadexomer iodine versus standard dressings. J Int Med Res. 88;16(6):428-35. Different levels of compression used. [pmid: 2466712].
Lawrence PF, Harlander-Locke M, Alktaifi A, Farley S, Rigberg D, Jimenez JC, DeRubertis BG, Gelabert H. The impact of ablation of incompetent veins on ulcer healing. J. Vasc. Surg. 2011;53(6):109S-110S. Other.
Lazareth I, Meaume S, Sigal Grinberg ML, Combemale P, Le Guyadec T, Zagnoli A, et al. The role of a silver releasing lipido-colloid contact layer in venous leg ulcers presenting inflammatory signs suggesting heavy bacterial colonization: results of a randomized controlled study. Wounds: A Compendium of Clinical Research and Practice. 2008;20(6):158-66. Different levels of compression used.
Leach MJ, Pincombe J, Foster G. Clinical efficacy of horsechestnut seed extract in the treatment of venous ulceration. J Wound Care. 2006;15(4):159-67. No intervention of interest; case series with <10. [pmid: 16620045].
Leaper DJ, Stewart AJ. A comparative trial of Sherisorb gel and cadexomer iodine: problems of community-based trials involving chronic leg ulcers. Advances in Wound Management. 86:121-6. No outcome of interest.
Leaper DJ, Cameron S, Hewitt H, Winter A, Lucarotti ME. A community- and hospital-based comparative evaluation of Comfeel ulcer dressing for chronic leg ulcers. J. DERMATOL. TREAT. 91;2(3):103-106. Other.
Leclere FM, Puechguiral IR, Rotteleur G, Thomas P, Mordon SR. A prospective randomized study of 980 nm diode laser-assisted venous ulcer healing on 34 patients. Wound Repair Regen. 2010;18(6):580-5. No intervention of interest; different levels of compression used. [pmid: 20958856].
Lee DW, Chan AC, Lam YH, Wong SK, Fung TM, Mui LM, Ng EK, Chung SC. Early clinical outcomes after subfascial endoscopic perforator surgery (SEPS) and saphenous vein surgery in chronic venous insufficiency. Surg Endosc. 2001;15(7):737-40. Case series with <10; case series does not provide demographics. [pmid: 11591980].
Lee DW, Lam YH, Chan AC, Chung SC. Subfascial endoscopic perforator surgery for venous ulcers. Hong Kong Med J. 2003;9(4):279-82. Case series with <10. [pmid: 12904616].
Lehtola A, Oinonen A, Sugano N, Alback A, Lepantalo M. Deep venous reconstructions: long-term outcome in patients with primary or post-thrombotic deep venous incompetence. Eur J Vasc Endovasc Surg. 2008;35(4):487-93. Case series with <10. [pmid: 17983771].
Lekovic I, Misovic S, Bjelanovic Z, Draskovic M, Tomic A. Subcutaneous paratibial fasciotomy in the treatment of chronic venous ulcer. Primena supkutane paratibijalne fasciotomije u lecenju hronicnog venskog ulkusa. Vojnosanit. Pregl. 2011;68(5):430-435. No intervention of interest. [pmid: 21744653].
Lerman B, Oldenbrook L, Eichstadt SL, Ryu J, Fong KD, Schubart PJ. Evaluation of chronic wound treatment with the SNaP wound care system versus modern dressing protocols. Plast Reconstr Surg. 2010;126(4):1253-61. No outcome of interest. [pmid: 20885246].
Levy E, Levy P. Venous leg ulcer: A costly disease for French society. Results from a prospective medicoeconomic observational study. Phlebolymphology. 2001;(35):11-15. No intervention of interest; no concurrent comparison group.
Li XX, Wu ZM, Wang SM. Subfascial endoscopic perforator vein surgery in treatment of varicose of lower limb. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2002;16(6):374-5. No original data; case series does not provide demographics. [pmid: 12508423].
Ligresti C, Delemont M, Ruscalla L, Zan S. Surgical treatment of venous ulcer of the leg. Minerva Chir. 90;45(6):401-4. No concurrent comparison group; case series does not provide demographics. [pmid: 2348919].
Lim KS, Tang MB, Goon AT, Leow YH. Contact sensitization in patients with chronic venous leg ulcers in Singapore. Contact Dermatitis. 2007;56(2):94-8. No intervention of interest; no outcome of interest. [pmid: 17244077].
Limova M, Troyer-Caudle J. Controlled, randomized clinical trial of 2 hydrocolloid dressings in the management of venous insufficiency ulcers. J Vasc Nurs. 2002;20(1):22-32. quiz 33-4. No separate analysis of CVU. [pmid: 11938346].
Lin SM, Zhang ZH, Yao YD, Xiao JB. Experience of endovenous radiofrequency combined with TriVex in treatment of chronic venous insufficiency in lower extremity. Zhonghua Wai Ke Za Zhi. 2009;47(4):271-4. No outcome of interest. [pmid: 19570389].
Lindgren C, Marcusson JA, Toftgard R. Treatment of venous leg ulcers with cryopreserved cultured allogeneic keratinocytes: a prospective open controlled study. Br J Dermatol. 98;139(2):271-5. No intervention of interest. [pmid: 9767241].
Liron A. Compression is indispensable for venous ulcers. Soins. 2006;(706):42-3. No original dataNo intervention of interest. [pmid: 16821407].
Lisbona C, Perez P, Segura Olle J, Puncernau X. Laser surgery of varicose veins: Personal endolaser vein ablation technique. Cirugia laser de las varices: ELAV tecnica personal. An. Cir. Cardiaca Vasc. 2003;9(4):215-219. No outcome of interest; case series with <10.
Loftus S. A longitudinal, quality of life study comparing four layer bandaging and superficial venous surgery for the treatment of venous leg ulcers. J Tissue Viability. 2001;11(1):14-9. Case series with <10. [pmid: 11949305].
Loiterman DA, Byers PH. Effect of a hydrocellular polyurethane dressing on chronic venous ulcer healing. Wounds: A Compendium of Clinical Research and Practice. 91;3(5):178-81. Other.
Long RE, Falabella AF, Valencia I, Eaglstein WH, Kirsner RS. Treatment of refractory, atypical lower extremity ulcers with tissue-engineered skin (Apligraf). Arch Dermatol. 2001;137(12):1660-1. No original data; case series with <10. [pmid: 11735729].
Longhini A, Borelli P, Franzini M, Kazemian AR, Munarini G, Marcolli G. Combination of endovenous laser treatment and a surgical approach for venous disease. Chir Ital. 2007;59(4):475-9. No separate analysis of CVU. [pmid: 17966767].
Lurie F, Kistner RL. Trends in patient reported outcomes of conservative and surgical treatment of primary chronic venous disease contradict current practices. Ann Surg. 2011;254(2):363-7. No separate analysis of CVU; case series does not assess ulcer healing. [pmid: 21532467].
Luzzani L, Bellosta R, Carugati C, Sarcina A. Isolated short saphenous vein insufficiency and lateral venous ulcer. Insufficienza isolata della vena piccola safena ed ulcere perimalleolari esterne. G. Ital. Chir. Vasc. 2002;9(4):381-387. Case series with <10.
Machynska-Bucko Z, Mankowski B, Slowinski K. Surgical treatment of chronic venous ulcers. Chirurgische therapie chronischer ulzera. Vasomed. 2004;16(2):49-51. Case series with <10.
Magnusson MB, Nelzen O, Volkmann R. Leg ulcer recurrence and its risk factors: a duplex ultrasound study before and after vein surgery. Eur J Vasc Endovasc Surg. 2006;32(4):453-61. No separate analysis of CVU. [pmid: 16750919].
Mahajan R, Mosley JG. Use of a semipermeable polyamide dressing over skin grafts to venous leg ulcers. Br J Surg. 95;82(10):1359-60. No intervention of interest. [pmid: 7489164].
Malm M, Lundeberg T. Effect of low power gallium arsenide laser on healing of venous ulcers. Scand J Plast Reconstr Surg Hand Surg. 91;25(3):249-51. No intervention of interest. [pmid: 1780722].
Mancini S, Tani F. Treatment of ulcers of the lower limbs. Experience at the Pabisch Interdisciplinary Center of Phlebology Sclerotherapy and Elasto-compression, University of Sienna. Traitement des ulceres des membres inferieurs. Experience du Centre Interdisciplinaire &quot;W. Pabisch&quot; de phlebologie, sclerotherapie et elasto-compression de l'Universite de Sienne. Phlebologie. 87;40(3):759-765. No original data. [pmid: 2446340].
Marot L, Lachapelle JM. The treatment of leg ulcers, using new types of dressings. LE TRAITEMENT DES ULCERES DE JAMBE PERSPECTIVES OFFERTES PAR L'EMPLOI DE NOUVEAUX TYPES DE PANSEMENTS. LOUVAIN MED. 90;109(3):197-201. No original data.
Marques-Vidal P, Imsand D, Kayoumi A, Kern P, Mazzolai L, Depairon M. Quality of life in patients traited for primary superficial venous insufficiency. Praxis. 2012;101(10):645-650. No concurrent comparison group. [pmid: 22565555].
Marston WA, Farber MA, Bryant J, Burns J, Keagy BA. Management of lower extremity venous stasis ulcers in a comprehensive wound care clinic. N C Med J. 98;59(2):128-31. No original data. [pmid: 9558904].
Marzin L, Rouveix B. An evaluation of collagen gel in chronic leg ulcers. Schweiz Rundsch Med Prax. 82;71(36):1373-8. No separate analysis of CVU. [pmid: 7134186].
Mayall RC, Mayall ACDC, Dias Garcia Mayall LC, Rocha HC, Narques LCB. The treatment of trophic ulcers of the limbs with a new skin substitute. REV. BRAS. CIR. 90;80(4):257-283. No concurrent comparison group.
Mayer W, Jochmann W, Partsch H. Varicose ulcer: healing in conservative therapy. A prospective study. Wien Med Wochenschr. 94;144(10-11):250-2. No intervention of interestNo outcome of interest. [pmid: 7856198].
McDaniel HB, Marston WA, Farber MA, Mendes RR, Owens LV, Young ML, Daniel PF, Keagy BA. Recurrence of chronic venous ulcers on the basis of clinical, etiologic, anatomic, and pathophysiologic criteria and air plethysmography. J Vasc Surg. 2002;35(4):723-8. No intervention of interest. [pmid: 11932670].
Meaume S, Schmutz JL, Dompmartin A, Fays S, Ourabah Z, Thirion V, et al. Management of venous leg ulcers with two active wound dressings. Results of a randomized clinical trial. 3rd Congress of the World Union of Wound Healing Societies Meeting. 2008, 4-8 June. Toronto, Canada. 2008. Abstract no. OR047. No original data.
Meaume S, Senet P, Pannier M, Bohbot S. Efficacy and tolerance of a contact layer and hydrocolloid dressing in the treatment of venous and mixed leg ulcers: results of randomized clinical study. Journal of Wound, Ostomy and Continence Nursing. 2008;35(3S: Suppl):S8. No original data.
Meaume S, Ourabah Z, Romanelli M, Manopulo R, De Vathaire F, Salomon D, Saurat JH. Efficacy and tolerance of a hydrocolloid dressing containing hyaluronic acid for the treatment of leg ulcers of venous or mixed origin. Curr Med Res Opin. 2008;24(10):2729-39. No separate analysis of CVU. [pmid: 18713490].
Meaume S, Vallet D, Morere MN, Teot L. Evaluation of a silver-releasing hydroalginate dressing in chronic wounds with signs of local infection. J Wound Care. 2005;14(9):411-9. No concurrent comparison group. [pmid: 16240620].
Meaume S, Vallet D, Morere MN, Teot L. Evaluation of a silver-releasing hydroalginate dressing in chronic wounds with signs of local infection. Evaluation einer silberionen-freisetzenden hydroalginat-wundauflage bei chronischen wunden mit anzeichen einer lokalen infektion. Z. Wundheilung. 2006;11(5):236-245. No separate analysis of CVU.
Mehtar S, Fox D. A double-blind comparative study with mupirocin vs placebo base in the treatment of chronic leg ulcers. Br J Clin Pract. 88;42(8):324-8. No separate analysis of CVU; different levels of compression used< 4 weeks followup duration. [pmid: 3145003].
Mermet I, Pottier N, Sainthillier JM, Malugani C, Cairey-Remonnay S, Maddens S, Riethmuller D, Tiberghien P, Humbert P, Aubin F. Use of amniotic membrane transplantation in the treatment of venous leg ulcers. Wound Repair Regen. 2007;15(4):459-64. No original data; no concurrent comparison group. [pmid: 17650088].
Miguens C, Ingles F, Seco AJ. Use of honey products in lower limb lymphoedema and recalcitrant wounds. Wounds UK. 2011;7(3):88-90. No concurrent comparison group.
Milic DJ, Zivic SS, Bogdanovic DC, Jovanovic MM, Jankovic RJ, Milosevic ZD, Stamenkovic DM, Trenkic MS. The influence of different sub-bandage pressure values on venous leg ulcers healing when treated with compression therapy. J Vasc Surg. 2010;51(3):655-61. No intervention of interest. [pmid: 20045611].
Milic DJ, Zivic SS, Bogdanovic DC, Karanovic ND, Golubovic ZV. Risk factors related to the failure of venous leg ulcers to heal with compression treatment. J Vasc Surg. 2009;49(5):1242-7. No separate analysis of CVU; no intervention of interest. [pmid: 19233601].
Miller CN, Carville K, Newall N, Kapp S, Lewin G, Karimi L, Santamaria N. Assessing bacterial burden in wounds: comparing clinical observation and wound swabs. Int Wound J. 2011;8(1):45-55. No KQ. [pmid: 21078131].
Miller CN, Newall N, Kapp SE, Lewin G, Karimi L, Carville K, Gliddon T, Santamaria NM. A randomized-controlled trial comparing cadexomer iodine and nanocrystalline silver on the healing of leg ulcers. Wound Repair Regen. 2010;18(4):359-67. No separate analysis of CVU. [pmid: 20636550].
Milward P. Comparing treatments for leg ulcers. Nurs Times. 91;87(13):70. 72. No outcome of interest.
Mizaushev BA, Kosenkov AN, Aslanov AD, Tsarenko IA, Zhirikov AV. Surgical treatment of patients with chronic lower limb venous insufficiency and trophic disorders. Khirurgiia (Mosk). 2005;(10):24-7. No separate analysis of CVU. [pmid: 16247403].
Moffatt CJ, Franks PJ, Oldroyd MI, Greenhalgh RM. A randomized trial of an occlusive dressing to treat chronic non-healing venous ulcers. 2nd European Conference on Advances in Wound Management. 1992, 20-23 October. Harrogate, UK. 93:210-1. Other.
Moffatt CJ, McCullagh L, O'Connor T, Doherty DC, Hourican C, Lewis C, et al. Randomised trial comparing four layer with two layer high compression bandaging in the management of chronic leg ulceration. 12th Conference of the European Wound Management Association. 2002, 23-25 May. Granada, Spain. 2002. No intervention of interest.
Moffatt CJ, Edwards L, Collier M, Treadwell T, Miller M, Shafer L, Sibbald G, Brassard A, McIntosh A, Reyzelman A, Price P, Kraus SM, Walters SA, Harding K. A randomised controlled 8-week crossover clinical evaluation of the 3M Coban 2 Layer Compression System versus Profore to evaluate the product performance in patients with venous leg ulcers. Int Wound J. 2008;5(2):267-79. No intervention of interest; different levels of compression used. [pmid: 18494632].
Moffat CJ, Oldroyd MI, Franks PJ. Assessing a calcium alginate dressing for venous ulcers of the leg. Journal of Wound Care. 1992;1(4):22-4. Ulcers < 4 weeks in duration.
Moglia RM. A prospective randomized trial of Unna's boots versus hydroactive dressing in the treatment of venous stasis ulcer. J Vasc Surg. 89;9(3):508. No original data. [pmid: 2921800].
Mol MA, Nanninga PB, van Eendenburg JP, Westerhof W, Mekkes JR, van Ginkel CJ. Grafting of venous leg ulcers. An intraindividual comparison between cultured skin equivalents and full-thickness skin punch grafts. J Am Acad Dermatol. 91;24(1):77-82. No intervention of interest; no outcome of interest. [pmid: 1999536].
Moody M. Comparison of Rosidal K and SurePress in the treatment of venous leg ulcers. Br J Nurs. 99;8(6):345-55. No intervention of interest. [pmid: 10409957].
Moody M. Tissue viability. Calcium alginate: a dressing trial. Nurs Stand Spec Suppl. 91;(13):3-6. Other.
Moore RA, Liedl DA, Jenkins S, Andrews KL. Using a silver-coated polymeric substrate for the management of chronic ulcerations: the initial Mayo Clinic experience. Adv Skin Wound Care. 2008;21(11):517-20. No concurrent comparison group. [pmid: 18981754].
Morris WT, Lamb AM. The Auckland Hospital varicose veins and venous ulcer clinic: a report on six years work. N Z Med J. 81;93(684):350-2. No original data; no intervention of interest; different levels of compression used. [pmid: 6942298].
Moss C, Taylow A, Shuster S. Comparative study of cadexomer iodine and dextranomer in chronic leg ulcers. Scottish Medical Journal. 84;25:54. No intervention of interest; different levels of compression used.
Motolese A, Capriata S, Simonelli M. Contact sensitivity to ‘advanced’ wound dressings in 116 patients with leg ulcers. Contact Dermatitis. 2009;60(2):107. No original dataNo concurrent comparison group. [pmid: 19207384].
Moues CM, Vos MC, van den Bemd GJ, Stijnen T, Hovius SE. Bacterial load in relation to vacuum-assisted closure wound therapy: a prospective randomized trial. Wound Repair Regen. 2004;12(1):11-7. No separate analysis of CVU; no intervention of interestNo outcome of interest. [pmid: 14974959].
Mouton WG, Klippert K, Wenning AS, Naef M, Wagner HE. Truncular vascular malformations in a varicose vein surgery patient cohort. Vasa J. Vasc. Dis. 2010;39(1):54-58. No separate analysis of CVU; no intervention of interest.
Mulder GD, Como A, Seeley J, Peak Andrews K. A randomised clinical study to evaluate and compare the performance of Allevyn hydrocellular dressing and Kaltostat alginate dressing in the treatment of venous ulcers. Proceedings of the 4th European Conference on Advances in Wound Management. 1994, September 6-9. Copenhagen, Denmark. 95. 199. Other.
Murray JD, Bergan JJ, Riffenburgh RH. Development of open-scope subfascial perforating vein surgery: lessons learned from the first 67 cases. Ann Vasc Surg. 99;13(4):372-7. Case series does not provide demographics. [pmid: 10398733].
Myers KA, Jolley D. Outcome of endovenous laser therapy for saphenous reflux and varicose veins: medium-term results assessed by ultrasound surveillance. Eur J Vasc Endovasc Surg. 2009;37(2):239-45. No separate analysis of CVU; case series with <10. [pmid: 18993093].
Nachbur B, Blanchard M, Rothlisberger H. The treatment of rebellious venous stasis ulcers. Correlation of outcome with extension of deep venous damage. Die Behandlung des rebellischen Ulcus cruris venosum. Bedeutung des Ausmasses des tiefen Venenschadens. Zentralbl. Chir. 99;124(6):520-524. No separate analysis of CVU. [pmid: 10436510].
Nagl M, Nguyen VA, Gottardi W, Ulmer H, Hopfl R. Tolerability and efficacy of N-chlorotaurine in comparison with chloramine T for the treatment of chronic leg ulcers with a purulent coating: a randomized phase II study. Br J Dermatol. 2003;149(3):590-7. < 4 weeks followup duration. [pmid: 14510994].
Nagovitsyn ES, Baliasnikov NP. Prevention of complications of endoscopic correction of the crural venous blood flow. Profilaktika oslozheniii endoskopicheskoi korrektsii venoznogo krovotoka na goleni. Vestn. Khir. Im. I. I. Grek. 89;142(3):113-115. No original data; no intervention of interest. [pmid: 2749983].
Nagovitsyn ES, Baliasnikov NP, Antropova NV, Dubov SB. Endoscopic correction of crural venous blood flow. Vestn Khir Im I I Grek. 86;137(11):48-51. No separate analysis of CVU. [pmid: 3824784].
Nayeri F, Forsberg P, Sundqvist T, Olsson H, Peterson C, Soderstrom C, Brudin L. Hepatocyte growth factor in chronic leg ulcers--no biological activity--no improvement. J Dermatol Sci. 2005;39(1):62-4. No intervention of interest; no concurrent comparison group. [pmid: 15894463].
Neglen P, Raju S. Venous reflux repair with cryopreserved vein valves. J Vasc Surg. 2003;37(3):552-7. No separate analysis of CVU; case series with <10. [pmid: 12618691].
Neglen P, Hollis KC, Raju S. Combined saphenous ablation and iliac stent placement for complex severe chronic venous disease. J Vasc Surg. 2006;44(4):828-33. No separate analysis of CVU; no concurrent comparison group. [pmid: 17012006].
Negus D, Friedgood A. The effective management of venous ulceration. Br J Surg. 83;70(10):623-7. No outcome of interest; no KQ. [pmid: 6626924].
Nelson EA, Ruckley CV, Harper DR, Gibson B, Dale JJ, Prescott RJ. A randomised trial of a knitted viscose dressing and a hydrocolloid dressings in the treatment of chronic venous ulceration. Phlebology. 95;(Suppl 1):913-4. Other.
Nelzen O, Fransson I. Early results from a randomized trial of saphenous surgery with or without subfascial endoscopic perforator surgery in patients with a venous ulcer. Br J Surg. 2011;98(4):495-500. Different levels of compression used; no outcome of interest. [pmid: 21656715].
Nelzen O, Fransson I. True long-term healing and recurrence of venous leg ulcers following SEPS combined with superficial venous surgery: a prospective study. Eur J Vasc Endovasc Surg. 2007;34(5):605-12. Case series does not provide demographics. [pmid: 17716932].
Nelzen O. Prospective study of safety, patient satisfaction and leg ulcer healing following saphenous and subfascial endoscopic perforator surgery. Br J Surg. 2000;87(1):86-91. Different levels of compression used. [pmid: 10606916].
Nikolovska S, Pavlova L, Petrova N, Gocev G, Ivanovski M. Pentoxifylline--efficient in the treatment of venous ulcers in the absence of compression?. Acta Dermatovenerol Croat. 2002;10(1):9-13. No intervention of interest. [pmid: 12137725].
Nordon IM, Hinchliffe RJ, Brar R, Moxey P, Black SA, Thompson MM, Loftus IM. A prospective double-blind randomized controlled trial of radiofrequency versus laser treatment of the great saphenous vein in patients with varicose veins. Ann Surg. 2011;254(6):876-81. No separate analysis of CVU. [pmid: 21934487].
Norkus A, Dargis V, Thomsen JK, Harding KG, Ivins N, Serra N, Torres de Castro OG, Galindo A, Andersen KE, Roed-Petersen J, Gottrup F, Blanco JL, de Mena MA, Hauschild A, Moll I, Svensson A, Carter K. Use of a hydrocapillary dressing in the management of highly exuding ulcers: a comparative study. J Wound Care. 2005;14(9):429-32. Different levels of compression used. [pmid: 16240623].
Nowak A, Bowszyc P, Blaszczyk M. A randomised, controlled, parallel group clinical trial of a new polyurethane foam dressings versus calcium alginate dressing in the treatment of moderately to heavily exuding venous ulcers. Proceedings of the 5th European Conference on Advances in Wound Management. 1995, 21-24 November. Harrogate, UK. 96. Other.
Obermayer A, Gostl K, Partsch H, Benesch T. Venous reflux surgery promotes venous leg ulcer healing despite reduced ankle brachial pressure index. Int Angiol. 2008;27(3):239-46. No separate analysis of CVUNo intervention of interest. [pmid: 18506127].
Obermayer A, Gostl K, Walli G, Benesch T. Chronic venous leg ulcers benefit from surgery: long-term results from 173 legs. J Vasc Surg. 2006;44(3):572-9. No concurrent comparison group. [pmid: 16950436].
O'Donnell TF Jr., Mackey WC, Shepard AD, Callow AD. Clinical, hemodynamic, and anatomic follow-up of direct venous reconstruction. ARCH. SURG. 87;122(4):474-482. Case series with <10. [pmid: 3566530].
Ogrin R, Darzins P, Khalil Z. The use of sensory nerve stimulation and compression bandaging to improve sensory nerve function and healing of chronic venous leg ulcers. Curr Aging Sci. 2009;2(1):72-80. No separate analysis of CVU; no intervention of interest. [pmid: 20021401].
Ohlsson P, Larsson K, Lindholm C, Moller M. A cost-effectiveness study of leg ulcer treatment in primary care. Comparison of saline-gauze and hydrocolloid treatment in a prospective, randomized study. Scand J Prim Health Care. 94;12(4):295-9. No separate analysis of CVU. [pmid: 7863149].
Olofsson B, Ljunghall K, Nordin-Bjorklund K, Sorensen S, Leppert J. Two therapeutic models in venous leg ulcers are compared: better results with optimized compression. Lakartidningen. 96;93(51-52):4752-4. No intervention of interest. [pmid: 9011730].
O'Shaughnessy M, Rahall E, Walsh TN, Given HF. Surgery in the treatment of varicose veins. Ir Med J. 89;82(2):54-5. No separate analysis of CVU; No KQ. [pmid: 2759820].
Ouvry PA. Silver sulfadiazine in the local treatment of venous ulcer. ESSAI DE LA SULFADIAZINE ARGENTIQUE DANS LE TRAITEMENT LOCAL DE L'ULCERE VEINEUX. PHLEBOLOGIE. 89;42(4):673-679. No original data; no separate analysis of CVU. [pmid: 2626487].
Padberg FT Jr, Pappas PJ, Araki CT, Back TL, Hobson RW 2nd. Hemodynamic and clinical improvement after superficial vein ablation in primary combined venous insufficiency with ulceration. J Vasc Surg. 96;24(5):711-8. Case series with <10. [pmid: 8918313].
Palmieri B, Magri M. A new formulation of collagenase ointment (Iruxol(registered trademark) mono) in the treatment of ulcers of the lower extremities. A randomised, placebo-controlled, double-blind study. Clin. Drug Invest. 98;15(5):381-387. < 4 weeks followup duration.
Pang KH, Bate GR, Darvall KAL, Adam DJ, Bradbury AW. Ultrasound-guided foam sclerotherapy of superficial venous reflux in patients with chronic venous ulceration provides sustained ulcer healing in the medium-term. Phlebology. 2011;26(6):269. Other.
Panknin HT, Reith B. Local therapy of infected and chronic wounds at risk for infection with silver containing dressings. Kinderkrankenschwester. 2009;28(9):373-9. Other. [pmid: 19795685].
Pannier F, Rabe E. Endovenous laser treatment with the 980 nm diode-laser in patients with venous leg ulcers. Endovenose lasertherapie mit dem 980-nm-diodenlaser bei ulcus cruris venosum. Phlebologie. 2007;36(4):179-185. No separate analysis of CVUNo outcome of interest.
Paraskeva PA, Cheshire N, Stansby G, Darzi AW. Endoscopic subfascial division of incompetent perforating calf veins. BR. J. SURG. 96;83(8):1105-1106. Case series with <10. [pmid: 8869316].
Pardes JB, Carson PA, Eaglstein WH, Falanga V. Mupirocin treatment of exudative venous ulcers. J. AM. ACAD. DERMATOL. 93;29(3):497-498. No original data. [pmid: 8349875].
Perkowski P, Ravi R, Gowda RC, Olsen D, Ramaiah V, Rodriguez-Lopez JA, Diethrich EB. Endovenous laser ablation of the saphenous vein for treatment of venous insufficiency and varicose veins: early results from a large single-center experience. J Endovasc Ther. 2004;11(2):132-8. No KQ. [pmid: 15056020].
Perrin M. Criteria of the verification of the efficacy of surgery in venous disorders. Criteres de controle d'efficacite de la chirurgie dans les affections veineuses. Phlebologie. 90;43(4):689-694. No original data. [pmid: 2093926].
Perrin M. Surgery of the perforating veins in chronic venous diseases of the lower limbs. La chirurgie des perforantes dans les affections veineuses chroniques des membres inferieurs. Phlebologie. 87;40(3):655-672. No original data. [pmid: 2960992].
Perrin M. Technic and results of valvuloplasty in reflux syndromes of the deep sub-inguinal venous network. Technique et resultats de la valvuloplastie dans les syndromes de reflux du reseau veineux profond a l'etage sous-inguinal. Phlebologie. 91;44(1):173-179. No separate analysis of CVU; case series with <10. [pmid: 1946641].
Perrin M. Valvuloplasty for treating deep venous reflux. An. Cir. Cardiaca Cir. Vasc. 2001;7(4):320-322. No original data.
Perrin M, Becker F, Hiltbrand B. Surgery in postphlebitic disease. Apropos of 157 surgical interventions. La chirurgie dans la maladie post-phlebitique. A propos de 157 interventions chirurgicales. Phlebologie. 84;37(4):515-526. No original data; no concurrent comparison group; different levels of compression used. [pmid: 6514802].
Peschen M, Weichenthal M, Schopf E, Vanscheidt W. Low-frequency ultrasound treatment of chronic venous leg ulcers in an outpatient therapy. Acta Derm Venereol. 97;77(4):311-4. No intervention of interest; case series with <10. [pmid: 9228227].
Pfeffer F, Von Dobschutz E, Coerper S, Jekov M, Riediger H, Hopt UT. Influence of different dressings on chronic wound healing velocity - An analysis of 6958 wounds treated within the Wundnetz e. V. Einfluss unterschiedlicher wundauflagen auf die abheilgeschwindigkeit chronischer wunden: Eine analyse von 6958 wunden aus dem Wundnetz e. V. Z. Wundheilung. 2005;10(1):12-15. No separate analysis of CVU.
Phillips TJ, Provan A, Colbert DA. A comparative trial of a vented adhesive two part dressing with a hydrocolloid in the treatment of chronic leg ulcers. Wounds: A Compendium of Clinical Research and Practice. 93;5(2):57-61. No outcome of interest< 4 weeks followup duration.
Pien FD, Kistner RL, Partsch B, Kusumawati L, Osako T, Galagan RC. Retrospective study of hospitalized patients with chronic leg ulcers in Hawaii. J Foot Ankle Surg. 94;33(6):546-50. No intervention of interest. [pmid: 7894399].
Pierard-Franchimont C, Paquet P, Arrese JE, Pierard GE. Healing rate and bacterial necrotizing vasculitis in venous leg ulcers. Dermatology. 97;194(4):383-7. Other. [pmid: 9252771].
Pierik EG, van Urk H, Hop WC, Wittens CH. Endoscopic versus open subfascial division of incompetent perforating veins in the treatment of venous leg ulceration: a randomized trial. J Vasc Surg. 97;26(6):1049-54. Other. [pmid: 9423722].
Pierik EG, Wittens CH, van Urk H. Subfascial endoscopic ligation in the treatment of incompetent perforating veins. Eur J Vasc Endovasc Surg. 95;9(1):38-41. Different levels of compression used. [pmid: 7664009].
Polignano R, Turrini P, Andreissen A. The effect of microcirculation in leg ulcers comparing traditional vs MWH dressings - a pilot study. 11th European Tissue Repair Society Annual Conference. 2001 5-8 September. Cardiff, Wales. 2001. 44. No original data.
Polignano R, Terriaca P, Pavanelli A, Forma O, De Ponti I, Sparavigna A. Evaluation of the efficacy of a cream with purified omental lipids (P.O.L.) in the management of peri-lesional skin in chronic vascular ulcers. Valutazione dell'efficacia di una crema a base di lipidi purificati di omento (P.O.L.) nella gestione della cute peri-lesionale dette ulcere croniche di origine vascolare. J. Plast. Dermatol. 2010;6(3):235-244. No original data.
Popandopulo AG. Dermal equivalent as an inductor of the lower extremities ulcer healing. Klin Khir. 2005;(6):27-9. No original data. [pmid: 16255195].
Porter JM, Griffiths RW, McNeill DC. The surgical management of intractable venous ulceration in the lower limbs: excision, decompression of the limb and split-skin grafting. Br J Plast Surg. 84;37(2):179-83. Case series with <10. [pmid: 6370368].
Poskitt KR, James AH, Lloyd-Davies ER, Walton J, McCollum C. Pinch skin grafting or porcine dermis in venous ulcers: a randomised clinical trial. Br Med J (Clin Res Ed). 87;294(6573):674-6. No intervention of interest.
Prescott RJ, Nelson EA, Dale JJ, Harper DR, Ruckley CV. Design of randomized controlled trials in the treatment of leg ulcers: More answers with fewer patients. Phlebology. 98;13(3):107-112. Other.
Price PE, Fagervik-Morton H, Mudge EJ, Beele H, Ruiz JC, Nystrom TH, Lindholm C, Maume S, Melby-Ostergaard B, Peter Y, Romanelli M, Seppanen S, Serena TE, Sibbald G, Soriano JV, White W, Wollina U, Woo KY, Wyndham-White C, Harding KG. Dressing-related pain in patients with chronic wounds: an international patient perspective. Int Wound J. 2008;5(2):159-71. No intervention of interest. [pmid: 18494622].
Procaccini E, Ruggiero R, Scuderi V, Mandato M, De Martino A, Perrotta S. Role of the subfascial endoscopic perforator vein surgery in the treatment of venous ulcers. Minerva Chir. 2001;56(3):273-82. Case series with <10. [pmid: 11423794].
Procaccini E, Ruggiero R, Scuderi V, Mandato M, De Martino A, Perrotta S. Role of the subfascial endoscopic perforator veins surgery in the treatment of venous ulcerations. Surgical techniques. Ruolo della interruzione sottofasciale delle vene perforanti per via endoscopica nella terapia delle ulcere flebostatiche: Tecnica chirurgica. Minerva Chir. 2001;56(3):273-282. No original data. [pmid: 11423794].
Proebstle TM, Weisel G, Voit C, Peter RU. Endoscopic fasciotomy and subfascial perforator division for chronic stasis ulcers. Hautarzt. 99;50(8):566-71. Case series with <10. [pmid: 10460300].
Pronk P, Gauw SA, Mooij MC, Gaastra MT, Lawson JA, van Goethem AR, van Vlijmen-van Keulen CJ. Randomised controlled trial comparing sapheno-femoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anaesthesia: one year results. Eur J Vasc Endovasc Surg. 2010;40(5):649-56. No separate analysis of CVU. [pmid: 20888274].
Psathakis D, Psathakis N. Popliteal valvular construction using a silastic sling (Technique II) for deep venous insufficiency of the lower limb. PHLEBOLOGY. 92;7(4):158-165. No separate analysis of CVU; no outcome of interest.
Psathakis ND, Psathakis DN. Further experience with the substitute valve operation by technique II in postthrombotic syndrome. INT. ANGIOL. 85;4(4 SUPPL.):95-97. No separate analysis of CVU; case series with <10.
Puggioni A, Marks N, Hingorani A, Shiferson A, Alhalbouni S, Ascher E. The safety of radiofrequency ablation of the great saphenous vein in patients with previous venous thrombosis. J Vasc Surg. 2009;49(5):1248-55. No separate analysis of CVU. [pmid: 19307089].
Queen D, Coutts P, Fierheller M, Sibbald RG. The use of a novel oxygenating hydrogel dressing in the treatment of different chronic wounds. Adv Skin Wound Care. 2007;20(4):200. 202. 204. 206. No original data. [pmid: 17415028].
Queral LA, Criado FJ, Lilly MP, Rudolphi D. The role of sclerotherapy as an adjunct to Unna's boot for treating venous ulcers: a prospective study. J Vasc Surg. 90;11(4):572-5. Other. [pmid: 2325217].
Rainey J. A comparison of two dressings in the treatment of heavily exuding leg ulcers. Journal of Wound Care. 93;2(4):199-200. Different levels of compression used.
Raju S, Neglen P. Percutaneous recanalization of total occlusions of the iliac vein. J Vasc Surg. 2009;50(2):360-8. No separate analysis of CVU; different levels of compression used. [pmid: 19446993].
Raju S, Berry MA, Neglen P. Transcommissural valvuloplasty: technique and results. J Vasc Surg. 2000;32(5):969-76. No separate analysis of CVU; case series does not provide demographics. [pmid: 11054229].
Raju S, Darcey R, Neglen P. Iliac-caval stenting in the obese. J Vasc Surg. 2009;50(5):1114-20. No intervention of interest. [pmid: 19878789].
Raju S, Darcey R, Neglen P. Unexpected major role for venous stenting in reflux disease: Symptom relief with partial correction of pathology. J. Vasc. Surg. 2009;49(5):5S. No separate analysis of CVU.
Raju S, Fredericks RK, Neglen PN, Bass JD. Durability of venous valve reconstruction techniques for &quot;primary&quot; and postthrombotic reflux. J Vasc Surg. 96;23(2):357-66. discussion 366-7. No outcome of interest. [pmid: 8637114].
Raju S, Owen S Jr, Neglen P. The clinical impact of iliac venous stents in the management of chronic venous insufficiency. J Vasc Surg. 2002;35(1):8-15. No outcome of interest. [pmid: 11802127].
Ramelet AA. Ambulatory treatment of chronic venous insufficiency. Traitement ambulatoire de l'insuffisance veineuse chronique. Rev Med Suisse Romande. 91;111(11):989-992. No original data. [pmid: 1749898].
Reeder SWI, De Roos KP, De Maeseneer M, Sommer A, Neumann HAM. Hospital admission for venous ulcers: What is it worth?. Phlebology. 2010;25(6):309-310. No intervention of interest.
Reich-Schupke S, Murmann F, Altmeyer P, Stucker M. Quality of life and patients' view of compression therapy. Int Angiol. 2009;28(5):385-93. No intervention of interest. [pmid: 19935593].
Renner R, Renner R, Simon JC, Wetzig T. Modern therapeutic surgical options of venous leg ulcers. MMW Fortschr Med. 2009;151(10):34-6. No original data. [pmid: 19472665].
Rhodes JM, Gloviczki P, Canton LG, Rooke T, Lewis BD, Lindsey JR. Factors affecting clinical outcome following endoscopic perforator vein ablation. Am J Surg. 98;176(2):162-7. Case series with <10. [pmid: 9737624].
Rivera-Arce E, Chavez-Soto MA, Herrera-Arellano A, Arzate S, Aguero J, Feria-Romero IA, Cruz-Guzman A, Lozoya X. Therapeutic effectiveness of a Mimosa tenuiflora cortex extract in venous leg ulceration treatment. J Ethnopharmacol. 2007;109(3):523-8. Different levels of compression used. [pmid: 17088036].
Robinson C, Santilli SM. Warm-Up Active Wound Therapy: a novel approach to the management of chronic venous stasis ulcers. J Vasc Nurs. 98;16(2):38-42. Case series with <10. [pmid: 9735735].
Robson MC, Phillip LG, Cooper DM, Lyle WG, Robson LE, Odom L, Hill DP, Hanham AF, Ksander GA. Safety and effect of transforming growth factor-beta(2) for treatment of venous stasis ulcers. Wound Repair Regen. 95;3(2):157-67. No intervention of interest. [pmid: 17173644].
Robson MC, Phillips TJ, Falanga V, Odenheimer DJ, Parish LC, Jensen JL, Steed DL. Randomized trial of topically applied repifermin (recombinant human keratinocyte growth factor-2) to accelerate wound healing in venous ulcers. Wound Repair Regen. 2001;9(5):347-52. Different levels of compression used. [pmid: 11896977].
Robson V, Dodd S, Thomas S. Standardized antibacterial honey (Medihoney(trademark)) with standard therapy in wound care: Randomized clinical trial. J. Adv. Nurs. 2009;65(3):565-575. No separate analysis of CVU. [pmid: 19222654].
Roddy SP. A randomized, controlled trial of endovenous thermal ablation using the 810-nm wavelength laser and the ClosurePLUS radiofrequency ablation methods for superficial venous insufficiency of the great saphenous vein. J. Vasc. Surg. 2010;52(3):796. No separate analysis of CVU.
Romanelli M, Vowden P, Price P. An open, randomised, comparative, parallel group, multi-centre clinical trial of amelogenin extracellular matrix therapy in the treatment of hard-to-heal venous leg ulcers: Follow-up data. 3rd Congress of the World Union of Wound Healing Societies Meeting. 2008, 4-8 June. Toronto, Canada. 2008. Abstract no. OR100. No original data.
Romanelli M, Dini V, Barbanera S, Bertone MS. Evaluation of the efficacy and tolerability of a solution containing propyl betaine and polihexanide for wound irrigation. Skin Pharmacol Physiol. Suppl. 2010;23:41-4. No intervention of interest. [pmid: 20829661].
Romanelli M, Dini V, Polignano R, Bonadeo P, Maggio G. Ibuprofen slow-release foam dressing reduces wound pain in painful exuding wounds: preliminary findings from an international real-life study. J Dermatolog Treat. 2009;20(1):19-26. < 4 weeks followup duration. [pmid: 18622878].
Rosen SA. Comparison of CMS/Alginate dressing with antimicrobial silver with hydrofiber dressing with silver. 39th Annual Wound, Ostomy and Continence Nurses Annual Conference. Journal of Wound, Ostomy &amp; Continence Nursing. 2007;34(3S):S36. Other.
Rosenthal D, Dickson C, Rodriguez FJ, Blackshear WM Jr., Clark MD, Lamis PA, Pallos LL, Gregory RT. Infrainguinal endovascular in situ saphenous vein bypass: Ongoing results. J. VASC. SURG. 94;20(3):389-395. No separate analysis of CVU; no outcome of interest. [pmid: 8084031].
Rowland J. Intermittent pump versus compression bandages in the treatment of venous leg ulcers. Aust N Z J Surg. 2000;70(2):110-3. Intermittent compression. [pmid: 10711472].
Roztocil K, Stvrtinova V, Strejcek J. Efficacy of a 6-month treatment with Daflon 500 mg in patients with venous leg ulcers associated with chronic venous insufficiency. Int Angiol. 2003;22(1):24-31. No intervention of interest. [pmid: 12771852].
Rubin JR, Alexander J, Plecha EJ, Marman C. Unna's boot vs polyurethane foam dressings for the treatment of venous ulceration. A randomized prospective study. Arch Surg. 90;125(4):489-90. Different levels of compression used. [pmid: 2181975].
Rubin SB, Rubin BG. Radiofrequency ablation as treatment for chronic venous insufficiency. JAAPA. 47. 2011;24(3):44-8. 50. 1. No original data. [pmid: 21434499].
Ruffieux P, Hommel L, Saurat JH. Long-term assessment of chronic leg ulcer treatment by autologous skin grafts. Dermatology. 97;195(1):77-80. No intervention of interest. [pmid: 9267750].
Russo A. Multi-layer versus two-layer bandage system in the treatment of venous leg ulcers A comparative study. 9th European Conference on Advances in Wound Management. 1999, 9-11 November. Harrogate UK. 99. 16. Other.
Rusyn VI, Levchak IA, Rusyn AV. Surgical treatment of chronic venous insufficiency. Khirurhichne likuvannia khronichnoi venoznoi nedostatnosti. Klin Khir. 2003;(12):21-23. No original data; no separate analysis of CVU. [pmid: 15074208].
Rutgers PH, Kitslaar PJEHM, Webster MW. Randomized trial of stripping versus high ligation combined with sclerotherapy in the treatment of the incompetent greater saphenous vein. AM. J. SURG. 94;168(4):311-315. No separate analysis of CVU; no outcome of interest; no KQ. [pmid: 7943585].
Saharay M, Scurr JH. Minimally invasive surgery for perforator vein incompetence. Cardiovasc Surg. 96;4(6):701-5. No original data. [pmid: 9012995].
Salim AS. Role of sulphydryl-containing agents in the management of venous (varicose) ulceration. A new approach. Clin Exp Dermatol. 92;17(6):427-32. No intervention of interest. [pmid: 1486710].
Santoianni P, Monfrecola G, Martellotta D, Ayala F. Inadequate effect of helium-neon laser on venous leg ulcers. Photodermatol. 84;1(5):245-9. No intervention of interest. [pmid: 6531303].
Sato DT, Goff CD, Gregory RT, Walter BF, Gayle RG, Parent FN 3rd, DeMasi RJ, Meier GH, Wheeler JR. Subfascial perforator vein ablation: comparison of open versus endoscopic techniques. J Endovasc Surg. 99;6(2):147-54. Case series with <10. [pmid: 10473332].
Sattler G. Subfascial endoscopic perforator surgery. Curr Probl Dermatol. 99;27:190-4. No original data. [pmid: 10547746].
Scanlon E, Karlsmark T, Leaper DJ, Carter K, Poulsen PB, Hart-Hansen K, Hahn TW. Cost-effective faster wound healing with a sustained silver-releasing foam dressing in delayed healing leg ulcers--a health-economic analysis. Int Wound J. 2005;2(2):150-60. Other. [pmid: 16722864].
Schadeck M. Reflux in healthy valves of the great saphenous vein. Le reflux sur valvules saines en grande saphene. Phlebologie. 91;44(3):603. 610. discussion 610-613. No separate analysis of CVU. [pmid: 1792250].
Schmutz JL, Meaume S, Fays S, Ourabah Z, Guillot B, Thirion V, Collier M, Barrett S, Smith J, Bohbot S, Dompmartin A. Evaluation of the nano-oligosaccharide factor lipido-colloid matrix in the local management of venous leg ulcers: results of a randomised, controlled trial. Int Wound J. 2008;5(2):172-82. Different levels of compression used. [pmid: 18494623].
Schulze HJ. Clinical evaluation of TIELLE* Plus dressing in the management of exuding chronic wounds. Br J Community Nurs. 2003;8(11 Suppl):18-22. No separate analysis of CVU. [pmid: 15115220].
Schumann H, Calow T, Weckesser S, Muller ML, Hoffmann G. Water-filtered infrared A for the treatment of chronic venous stasis ulcers of the lower legs at home: a randomized controlled blinded study. Br J Dermatol. 2011;165(3):541-51. No intervention of interest. [pmid: 21574975].
Scriven JM, Hartshorne T, Thrush AJ, Bell PR, Naylor AR, London NJ. Role of saphenous vein surgery in the treatment of venous ulceration. Br J Surg. 98;85(6):781-4. Different levels of compression used; case series with <10 No KQ. [pmid: 9667707].
Senet P, Bon FX, Benbunan M, Bussel A, Traineau R, Calvo F, Dubertret L, Dosquet C. Randomized trial and local biological effect of autologous platelets used as adjuvant therapy for chronic venous leg ulcers. J Vasc Surg. 2003;38(6):1342-8. No intervention of interest. [pmid: 14681639].
Senet P, Vicaut E, Beneton N, Debure C, Lok C, Chosidow O. Topical treatment of hypertensive leg ulcers with platelet-derived growth factor-BB: a randomized controlled trial. Arch Dermatol. 2011;147(8):926-30. Different levels of compression used. [pmid: 21482863].
Serra N, Palomar F, Fornes B, Capillas R, Berenguer M, Aranda J, Sanchez J, Ruiz P, Reina T, Marinel.lo Roura J. Effectiveness of the association of multilayer compression therapy and periwound protection with Cavilon(registered trademark) (no sting barrier film) in the treatment of venous leg ulcers. Efectividad del tratamiento de las ulceras venosas con vendaje compresivo multicapa asociado a proteccion de la piel perilesional con Cavilon(registered trademark) (pelicula barrera no irritante). Gerokomos. 2010;21(3):124-130. No intervention of interest.
Serra R, Buffone G, de Franciscis A, Mastrangelo D, Vitagliano T, Greco M, de Franciscis S. Skin Grafting Followed by Low-Molecular-Weight Heparin Long-Term Therapy in Chronic Venous Leg Ulcers. Ann Vasc Surg. 2011. No intervention of interest.
Serra R, Buffone G, de Franciscis A, Mastrangelo D, Vitagliano T, Greco M, de Franciscis S. Skin grafting followed by low-molecular-weight heparin long-term therapy in chronic venous leg ulcers. Ann Vasc Surg. 2012;26(2):190-7. No intervention of interest. [pmid: 22018697].
Shun A, Ramsey-Stewart G. Human amnion in the treatment of chronic ulceration of the legs. Med J Aust. 83;2(6):279-83. No separate analysis of CVU. [pmid: 6646039].
Shuttleworth GJ, Mayho GV. Controlled trial of Iodosorb in chronic venous ulcers. Br Med J (Clin Res Ed). 85;291(6495):605-6. No original data.
Sibbald RG, Coutts P, Woo KY. Reduction of bacterial burden and pain in chronic wounds using a new polyhexamethylene biguanide antimicrobial foam dressing-clinical trial results. Advances in skin &amp; wound care. 2011;24(2):78-84. No separate analysis of CVU; no intervention of interest; no outcome of interest. [pmid: 21242737].
Sibbald RG. Apligraf living skin equivalent for healing venous and chronic wounds. J Cutan Med Surg. Suppl 1. 98;3:S1-24-8. No original data. [pmid: 10082604].
Sibbald RG, Contreras-Ruiz J, Coutts P, Fierheller M, Rothman A, Woo K. Bacteriology, inflammation, and healing: a study of nanocrystalline silver dressings in chronic venous leg ulcers. Adv Skin Wound Care. 2007;20(10):549-58. No separate analysis of CVU; no concurrent comparison group. [pmid: 17906429].
Skog E, Arnesjo B, Troeng T, Gjores JE, Bergljung L, Gundersen J, Hallbook T, Hessman Y, Hillstrom L, Mansson T, Eilard U, Ekloff B, Plate G, Norgren L. A randomized trial comparing cadexomer iodine and standard treatment in the out-patient management of chronic venous ulcers. Br J Dermatol. 83;109(1):77-83. No concurrent comparison group. [pmid: 6344906].
Slim FJ, Kulkarni SR, Emerson LG, Davies C, Bulbulia RA, Whyman MR, Poskitt A. The long-term effect of foam sclerotherapy on chronic venous leg ulcers with superficial venous reflux. Journal of Vascular Surgery. 2012;55(1):297. No separate analysis of CVU.
Smeets R, Ulrich D, Unglaub F, Woltje M, Pallua N. Effect of oxidised regenerated cellulose/collagen matrix on proteases in wound exudate of patients with chronic venous ulceration. Int Wound J. 2008;5(2):195-203. No outcome of interest. [pmid: 18494625].
Smith BA. The dressing makes the difference. Trial of two modern dressings on venous ulcers. Prof Nurse. 350. 94;9(5):348-2. Different levels of compression used. [pmid: 8140111].
Sotnichenko BA, Makarov VI, Kalinin AV, Fefelov EA, Stepura AP, Di AIu. Endoscopic dissection of perforating veins: surgical and pharamacoeconomic aspects. Angiol Sosud Khir. 2008;14(2):85-9. No separate analysis of CVU. [pmid: 19156056].
Sottiurai VS. Comparison of surgical modalities in the treatment of recurrent venous ulcer. Int Angiol. 90;9(4):231-5. intermittent compression. [pmid: 2099954].
Sottiurai VS. Technique in direct venous valvuloplasty. J Vasc Surg. 88;8(5):646-8. No original data; no separate analysis of CVU. [pmid: 3054176].
Sparks SR, Ballard JL, Bergan JJ, Killeen JD. Early benefits of subfascial endoscopic perforator surgery (SEPS) in healing venous ulcers. Ann Vasc Surg. 97;11(4):367-73. Case series with <10. [pmid: 9236992].
Stacey MC, Jopp-Mckay AG, Rashid P, Hoskin SE, Thompson PJ. The influence of dressings on venous ulcer healing--a randomised trial. Eur J Vasc Endovasc Surg. 97;13(2):174-9. Other. [pmid: 9091151].
Stacey MC, Mata SD, Trengove NJ, Mather CA. Randomised double-blind placebo controlled trial of topical autologous platelet lysate in venous ulcer healing. Eur J Vasc Endovasc Surg. 2000;20(3):296-301. Other. [pmid: 10986030].
Stegmann W. The treatment of leg ulcers with polarised light soft-laser. BEHANDLUNG DES ULCUS CRURIS MIT POLARISIERTEM LICHT. PHLEBOL. PROKTOL. 85;14(1):96-97. No original data; no outcome of interest.
Stewart AJ, Leaper DJ. Treatment of chronic leg ulcers in the community: a comparative trial of Scherisorb and Iodosorb. Phlebology. 87;2:115-121. No separate analysis of CVU; different levels of compression used.
Stone PA, Armstrong PA, Shames ML, Back MR, Johnson BL, Flaherty SK, Bandyk DF. Impact of postoperative duplex surveillance after radiofrequency ablation of the greater saphenous vein. J. Vasc. Ultrasound. 2006;30(2):65-68. No separate analysis of CVU.
Strand L, Madsen HC. Subfascial endoscopic supplementary surgery of perforating veins. Experiences with the first 100 procedures. Ugeskr Laeger. 2001;163(6):747-9. No original data; case series with <10. [pmid: 11228801].
Stryga W, Trusinski W, Jasinski G, Malinski B, Zalewski J. Treatment of varicose ulcers with Codogard of Polish production. Polim Med. 84;14(1-4):55-60. No original data. [pmid: 6533636].
Stuart WP, Adam DJ, Bradbury AW, Ruckley CV. Subfascial endoscopic perforator surgery is associated with significantly less morbidity and shorter hospital stay than open operation (Linton's procedure). Br J Surg. 97;84(10):1364-5. No original data; case series with <10. [pmid: 9361589].
Sun S, Yao Y, Li Y, Huang X, Ma X, Jiang Y. Mechanism and curative effect of vacuum sealing technique in treatment of wide chronic ulcer in the lower limbs in 24 cases. Chin. J. Clin. Rehab. 2003;7(4):577-578. No original data; no intervention of interest.
Sybrandy JE, van Gent WB, Pierik EG, Wittens CH. Endoscopic versus open subfascial division of incompetent perforating veins in the treatment of venous leg ulceration: long-term follow-up. J Vasc Surg. 2001;33(5):1028-32. Case series does not provide demographics. [pmid: 11331845].
Szewczyk MT, Jawien A, Migdalski A, Piotrowicz R, Grzela T, Brazis P. Predicting time to healing by anatomical assessment of venous pathology. Med Sci Monit. 2009;15(2):CR74-81. No intervention of interest. [pmid: 19179971].
Taddeucci P, Pianigiani E, Colletta V, Torasso F, Andreassi L, Andreassi A. An evaluation of Hyalofill-F plus compression bandaging in the treatment of chronic venous ulcers. J Wound Care. 2004;13(5):202-4. Different levels of compression used. [pmid: 15160576].
Taradaj J, Franek A, Brzezinska-Wcislo L, Cierpka L, Dolibog P, Chmielewska D, Blaszczak E, Kusz D. The use of therapeutic ultrasound in venous leg ulcers: a randomized, controlled clinical trial. Phlebology. 2008;23(4):178-83. No intervention of interest. [pmid: 18663117].
Taradaj J, Franek A, Cierpka L, Krol P, Blaszczak E, Dolibog P, Kusz D. Failure of low-level laser therapy to boost healing of venous leg ulcers in surgically and conservatively treated patients. Phlebologie. 2008;37(5):241-246. No intervention of interest.
Tarvainen K. Cadexomer iodine (Iodosorb) compared with dextranomer (Debrisan) in the treatment of chronic leg ulcers. Acta Chir Scand Suppl. 88;544:57-9. No intervention of interestNo outcome of interest. [pmid: 2459870].
Tauro LF, Ravikrishnan J, Rao BSS, Shenoy HD, Shetty SR, Menezes LT. A comparative study of the efficacy of topical negative pressure moist dressings and conventional moist dressings in chronic wounds. Indian Journal of Plastic Surgery. 2007;40(2):133-40. < 4 weeks followup duration.
Teo TK, Tay KH, Lin SE, Tan SG, Lo RH, Taneja M, Irani FG, Sebastien MG, Lim KH, Tan BS. Endovenous laser therapy in the treatment of lower-limb venous ulcers. J Vasc Interv Radiol. 2010;21(5):657-62. No concurrent comparison group; case series does not provide demographics. [pmid: 20430295].
Ternovoi KS, Zhila IS, Bulakh AD. Use of helium-neon laser in diseases and sequelae of injuries of the musculoskeletal system. Primenenie izluchenii gelii-neonovogo lazera pri zabolevaniiakh i posledstviiakh travm oporno-dvigatel'nogo apparata. Vopr Kurortol Fizioter Lech Fiz Kult. 84;(2):46-51. No original data; no intervention of interest.
Thomas AM, Tomlinson PJ, Boggon RP. Incompetent perforating vein ligation in the treatment of venous ulceration. Ann R Coll Surg Engl. 86;68(4):214-5. Case series does not provide demographics. [pmid: 3789608].
Thomas S, Banks V, Bale S, Fear-Price M, Hagelstein S, Harding KG, Orpin J, Thomas N. A comparison of two dressings in the management of chronic wounds. J Wound Care. 97;6(8):383-6. Other. [pmid: 9341430].
Ting ACW, Cheng SWK, Ho P, Poon JTC, Wu LLH, Cheung GCY. Surgical treatment for advanced chronic venous insufficiency in Hong Kong. Ann. Coll. Surg. Hong Kong. 2004;8(4):135-140. No original data.
Ting AC, Cheng SW, Ho P, Wu LL, Cheung GC. Clinical outcomes and changes in venous hemodynamics after subfascial endoscopic perforating vein surgery. Surg Endosc. 2003;17(8):1314-8. No separate analysis of CVU. [pmid: 12799891].
Trevivian AJ, Jamieson WG. Air plethysmography (APG) changes that occur following valve reconstruction for chronic venous insufficiency. J. VASC. TECHNOL. 96;20(1):23-24. Case series with <10.
Trial C, Darbas H, Lavigne JP, Sotto A, Simoneau G, Tillet Y, Teot L. Assessment of the antimicrobial effectiveness of a new silver alginate wound dressing: a RCT. J Wound Care. 2010;19(1):20-6. No separate analysis of CVU. [pmid: 20081570].
Tripathi R, Ktenidis KD. Trapdoor internal valvuloplasty--a new technique for primary deep vein valvular incompetence. Eur J Vasc Endovasc Surg. 2001;22(1):86-9. Case series with <10. [pmid: 11461109].
Trividic-Rumeau M, Bouyssou-Gauthier ML, Mounier M, Sparsa A, Blaise S, Bedane C, Bonnetblanc JM. Methicilline-sensitive and methicilline-resistant Staphylococcus aureus related morbidity in chronic wounds: A prospective study. Etude prospective comparative de la morbidite des Staphylococcus aureus metisensibles et metiresistants dans les plaies chroniques. Ann. Dermatol. Venereol. 2003;130(6-7):601-605. No separate analysis of CVU; no intervention of interest; different levels of compression. [pmid: 13679695].
Usik VS. Use of the helium-neon laser in the treatment of crural varicose ulcers. Vestn Khir Im I I Grek. 84;132(1):69-71. No intervention of interest. [pmid: 6538714].
Valenzuela AR, Perucho NS. The effectiveness of a 0.1% polyhexanide gel. Rev Enferm. 2008;31(4):7-12. No original data. [pmid: 18564781].
Valtonen V, Karppinen L, Kariniemi AL. A comparative study of ciprofloxacin and conventional therapy in the treatment of patients with chronic lower leg ulcers infected with Pseudomonas aeruginosa or other gram-negative rods. Scandinavian journal of infectious diseases. Supplementum. 89;60:79-83. No separate analysis of CVU. [pmid: 2547245].
Van Damme H, Quaniers J, Lambert J, Limet R. Resurgence of vein perforation surgery: SEPS (subfacial endoscopic perforator surgery). Rev Med Liege. 2001;56(7):511-20. Case series with <10. [pmid: 11523303].
Van Damme H, Quaniers J, Lambert J, Limet R. Resurgence of vein perforation surgery: SEPS (subfacial endoscopic perforator surgery). Resurgence de la chirurgie des veines perforantes: CEPS (chirurgie endoscopique des perforantes sous-fasciales). Rev Med Liege. 2001;56(7):511-520. Case series with <10. [pmid: 11523303].
Vandenbulcke K, Horvat LI, De Mil M, Slegers G, Beele H. Evaluation of the antibacterial activity and toxicity of 2 new hydrogels: a pilot study. Int J Low Extrem Wounds. 2006;5(2):109-14. No separate analysis of CVU; no concurrent comparison group. [pmid: 16698915].
Vanni L, Cerbone V, La Manna S, Fresini A, Lavorgna B, Grasso M, Papaleo D, Apicella G, Abate S. Efficacy of SEPS in chronic venous leg ulcers (Personal series). Efficacia della SEPS nel trattamento delle ulcere venose croniche della gamba: Esperienza personale. Chirurgia. 2009;22(3):151-154. Case series does not provide demographics.
Vanscheidt W, Bertalanffy C, Wenz W, Schopf E. Paratibial fasciotomy. Vasa Suppl. 91;32:471-8. No original data; no concurrent comparison group. [pmid: 1771560].
Vanscheidt W, Harding K, Teot L, Siebert J. Effectiveness and tissue compatibility of a 12-week treatment of chronic venous leg ulcers with an octenidine based antiseptic - a randomized, double-blind controlled study. Int. Wound. J. 2011. No intervention of interest.
Vanscheidt W, Sibbald RG, Eager CA. Comparing a foam composite to a hydrocellular foam dressing in the management of venous leg ulcers: a controlled clinical study. Ostomy Wound Manage. 2004;50(11):42-55. Other. [pmid: 15545697].
Vas J, Modesto M, Mendez C, Perea-Milla E, Aguilar I, Carrasco-Lozano JM, Faus V, Martos F. Effectiveness of acupuncture, special dressings and simple, low-adherence dressings for healing venous leg ulcers in primary healthcare: study protocol for a cluster-randomized open-labeled trial. BMC Complement Altern Med. 2008;8:29. Different levels of compression used; no outcome of interest. [pmid: 18547419].
Veraart JCJM, Neumann HAM, Hulsmans RFHJ, van den Broek MBJ. A comparative study on the characteristics of Comfeel Extra Absorbing Dressing in terms of healing, effects on periulcer skin, and patient comfort in care of leg ulcers [abstract]. 4th European Tissue Repair Society Meeting. 1994, 25-28 August. Oxford, England. 94. Other.
Vertyanov VA, Khanin AG. Treatment of trophic ulcers and delayed wound healing with laser beams. KHIRURGIYA. 82;58(8):19-22. No separate analysis of CVU.
Viarengo LM, Poterio-Filho J, Poterio GM, Menezes FH, Meirelles GV. Endovenous laser treatment for varicose veins in patients with active ulcers: measurement of intravenous and perivenous temperatures during the procedure. Dermatol Surg. 2007;33(10):1234-42. discussion 1241-2. Case series with <10. [pmid: 17903157].
Vin F, Teot L, Meaume S. The healing properties of Promogran in venous leg ulcers. J Wound Care. 2002;11(9):335-41. Different levels of compression used. [pmid: 12430368].
von Felbert V, Schumann H, Mercer JB, Strasser W, Daeschlein G, Hoffmann G. Therapy of chronic wounds with water-filtered infrared-A (wIRA). GMS Krankenhhyg Interdiszip. 2008;2(2):Doc52. No intervention of interest. [pmid: 20204086].
Vuerstaek JD, Vainas T, Wuite J, Nelemans P, Neumann MH, Veraart JC. State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (V.A.C.) with modern wound dressings. J Vasc Surg. 2006;44(5):1029-37. discussion 1038. No intervention of interest; different levels of compression used. [pmid: 17000077].
Vuylsteke ME, Vandekerckhove PJ, De Bo T, Moons P, Mordon S. Use of a new endovenous laser device: results of the 1,500 nm laser. Ann Vasc Surg. 2010;24(2):205-11. No separate analysis of CVU. [pmid: 19748212].
Wang J, Smith J, Babidge W, Maddern G. Silver dressings versus other dressings for chronic wounds in a community care setting. J Wound Care. 2007;16(8):352-6. No concurrent comparison group; no outcome of interest; case series with <10. [pmid: 17927082].
Wang MH, Jin X, Zhang SY, Wu XJ, Zhong ZY, Wang M, Dong DN, Yuan H. Lateral subfascial endoscopic perforating vein surgery as treatment for lateral perforating vein incompetence and venous ulceration. World J Surg. 2009;33(5):1093-8. Different levels of compression used. [pmid: 19189173].
Wang S, Li X, Wu Z, Huang X, Ye Y. External valvuloplasty for deep venous valve insufficiency of legs. Zhonghua Wai Ke Za Zhi. 99;37(1):38-40. Case series with <10. [pmid: 11829775].
Watson JM, Kang'ombe AR, Soares MO, Chuang LH, Worthy G, Bland JM, Iglesias C, Cullum N, Torgerson D, Nelson EA. Use of weekly, low dose, high frequency ultrasound for hard to heal venous leg ulcers: the VenUS III randomised controlled trial. BMJ. 2011;342:d1092. No intervention of interest. [pmid: 21385806].
Warburg FE, Danielsen L, Madsen SM, Raaschou HO, Munkvad S, Jensen R, Siersen HE. Vein surgery with or without skin grafting versus conservative treatment for leg ulcers. A randomized prospective study. Acta Derm Venerol. 1994;74:307-9. No intervention of interest. [pmid: 7976095].
Watson JM, Kang'ombe AR, Soares MO, Chuang LH, Worthy G, Bland JM, Iglesias C, Cullum N, Torgerson D, Nelson EA. VenUS III: a randomised controlled trial of therapeutic ultrasound in the management of venous leg ulcers. Health Technol Assess. 2011;15(13):1-192. No intervention of interest.
Wechselberger G, Aefel L, Schwabegger A, Papp C. Plastic surgery treatment of chronic venous ulcera cruris. Plastisch-chirurgische Behandlung chronisch venoser Ulcera cruris. Chirurg. 95;66(3):216-219. Case series with <10. [pmid: 7750393].
Weindorf M, Korber A, Klode J, Dissemond J. Non-interventional study to investigate the efficacy and safety of Tegaderm Matrix in the treatment of patients with therapy-refractory chronic wounds. J Dtsch Dermatol Ges. 2011. No separate analysis of CVU; no concurrent comparison group.
Weller CD, Evans S, Reid CM, Wolfe R, McNeil J. Protocol for a pilot randomised controlled clinical trial to compare the effectiveness of a graduated three layer straight tubular bandaging system when compared to a standard short stretch compression bandaging system in the management of people with venous ulceration: 3VSS2008. Trials. 2010;11:26. No intervention of interest; different levels of compression used. [pmid: 20214822].
Werdin F, Sinis N, Schaller HE, Coerper S. Recurrence rates of venous leg ulcers and the special importance of its surgical treatment. Handchir Mikrochir Plast Chir. 2008;40(2):94-9. No intervention of interest. [pmid: 18437667].
Weston-Davies WH. Controlled trial of occlusive dressings in healing chronic venous ulcers. Br J Surg. 88;75(2):189. No original data. [pmid: 3349320].
Whiteley MS, Smith JJ, Galland RB. Tibial nerve damage during subfascial endoscopic perforator vein surgery. Br J Surg. 97;84(4):512. No intervention of interest; no outcome of interest; case series with <10. [pmid: 9112904].
Wild T, Eberlein T, Andriessen A. Wound cleansing efficacy of two cellulose-based dressings. Wounds UK. 2010;6(3):14-21. Different levels of compression used.
Wilkinson GE Jr, Maclaren IF. Long term review of procedures for venous perforator insufficiency. Surg Gynecol Obstet. 86;163(2):117-20. No original data; no separate analysis of CVU. [pmid: 3738709].
Wollina U, Schmidt WD, Kronert C, Nelskamp C, Scheibe A, Fassler D. Some effects of a topical collagen-based matrix on the microcirculation and wound healing in patients with chronic venous leg ulcers: preliminary observations. Int J Low Extrem Wounds. 2005;4(4):214-24. < 4 weeks followup duration. [pmid: 16286373].
Wolters U, Schmitz-Rixen T, Erasmi H, Lynch J. Endoscopic dissection of incompetent perforating veins in the treatment of chronic venous leg ulcers. VASC. SURG. 96;30(6):481-487. No separate analysis of CVU; case series with <10.
Wong IKY. A prospective, randomized-controlled, multi-centre comparison study on 180 leg ulcer patients: modern wound management (MWM) alone versus compression bandages + MWM. 16th Conference of the European Wound Management Association. 2006, 18-20 May. Prague, Czech Republic. 2006. 49, Abstract no.032. Different levels of compression used.
Wong IK, Andriessen A, Charles HE, Thompson D, Lee DT, So WK, Abel M. Randomized controlled trial comparing treatment outcome of two compression bandaging systems and standard care without compression in patients with venous leg ulcers. J Eur Acad Dermatol Venereol. 2011. Different levels of compression used.
Wu P, Nelson EA, Reid WH, Ruckley CV, Gaylor JD. Water vapour transmission rates in burns and chronic leg ulcers: influence of wound dressings and comparison with in vitro evaluation. Biomaterials. 96;17(14):1373-7. No outcome of interest. [pmid: 8830962].
Wunderlich U, Orfanos CE. Treatment of venous ulcera cruris with dry wound dressings. Phase overlapping use of silver impregnated activated charcoal xerodressing. Hautarzt. 91;42(7):446-50. No original data. [pmid: 1938398].
Yao K, Nie W, Lu L, Huang F, Liu X. Treatment for chronic venous ulcerlation of the leg by subfascial endoscopic perforator vein surgery. J. Cent. South Univ. Med. Sci. 2009;34(8):830-833. No original data; case series does not provide demographics.
Zamboni P, Cisno C, Marchetti F, Mazza P, Fogato L, Carandina S, De Palma M, Liboni A. Haemodynamic CHIVA correction surgery versus compression for primary venous ulcers: First year results. Phlebology. 2004;19(1):28-34. No intervention of interest.
Zhiruev MS, Kozlov KL, El'sinovskii VI, Liashko VV. Complex management of lower extremity venous ulcers in elderly patients. Adv Gerontol. 2009;22(3):483-7. No original data; no intervention of interest. [pmid: 20210200].
Ziegler UE, Schmidt K, Keller HP, Thiede A. Treatment of chronic wounds with an alginate dressing containing calcium, zinc and manganese. MMW Fortschr Med. 2003;145(13):47. No original data; no concurrent comparison group. [pmid: 15101534].
Zuccarelli F. A comparative study of the hydrocellular dressing Allevyn and the hydrocolloid dressing Duoderm in the local treatment of leg ulcers. Phlebologie. 92;45(4):529-33. Different levels of compression used. [pmid: 1302331].