# Forms

Title review form

The title review form is shown from the Distiller SR online software program. A title and its authors are displayed with the choice of yes or no in a radio checkbox to the question "Is this article potentially relevant to our review (i.e. evaluates wound dressings, antibiotics, or surgical interventions for patients with chronic venous ulcers)?

Abstract review form

The abstract review form is shown from the Distiller SR online software program. The abstract, title, and authors are displayed. Next to them are exclusion and inclusion criteria to checkbox, as well as unclear, pull for handsearch, mark if foreign language, and a comment box.

Article review form

The article review form is shown from the Distiller SR online software program. The abstract, title, and authors are displayed and a hyperlink to the pdf. Next to them are exclusion and inclusion criteria to checkbox, as well as unclear, pull for handsearch, mark if foreign language, and a comment box.

Study design form

The study design form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe the study design of the article being reviewed.

Population Characteristics Form

The population characteristics form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe the population characteristics of the article being reviewed. All groups are on a single form.

Interventions Form

The interventions form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe interventions presented in the article being reviewed. All groups are on a single form.

Outcomes Form

The population characteristics form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe the study design of the article being reviewed. One outcomes form is filled out per outcome and timepoint.

Study Quality Form

The study quality form is shown from the Distiller SR online software program for data abstraction. The form is an adaptation of the Downs and Black Checklist for Measuring Study quality.