# Detailed Electronic Database Search Strategies

Advanced Wound Dressings PubMed Strategy

Search | String | # Hits
#1 | “Leg ulcer”[mh] | 15937
#2 | “Varicose ulcer”[mh] | 3520
#3 | “chronic leg”[tiab] | 738
#4 | “chronic venous”[tiab] | 3133
#5 | “lower extremity”[tiab] OR “lower extremeties”[tiab] OR “lower limb”[tiab] OR “lower limbs”[tiab] | 45746
#6 | Ulcer[tiab] OR ulcers[tiab] OR ulceration[tiab] | 110973
#7 | (#3 OR #4 OR #5) AND #6 | 3415
#8 | “leg ulcer”[tiab] OR “leg ulcers”[tiab] OR “leg ulceration”[tiab] | 4576
#9 | “venous ulcer”[tiab] OR “venous ulcers”[tiab] OR “venous ulceration”[tiab] | 1576
#10 | “venous stasis ulcer”[tiab] OR “venous stasis ulcers”[tiab] OR “venous stasis ulceration”[tiab] | 181
#11 | “chronic wound”[tiab] OR “chronic wounds”[tiab] | 2416
#12 | #1 OR #2 OR #7 OR #8 OR #9 OR #10 OR #11 | 19852
#13 | Bandages[mh] | 17853
#14 | “Bandages, hydrocolloid”[mh] | 546
#15 | “Iodine compounds”[mh] | 14763
#16 | “Iodine/therapeutic use”[mh] | 3596
#17 | Iodophors[mh] | 2401
#18 | Collagen[mh] | 90149
#19 | “Skin, artificial”[mh] | 1628
#20 | Dressing*[tiab] or bandag*[tiab] | 16767
#21 | Hydrocolloid*[tiab] | 1178
#22 | Film*[tiab] | 94974
#23 | Alginate*[tiab] | 8261
#24 | Foam*[tiab] | 15060
#25 | Composite*[tiab] | 69266
#26 | Absorb*[tiab] OR absorpt*[tiab] | 260534
#27 | Gauze*[tiab] | 2741
#28 | Antibacterial*[tiab] | 37842
#29 | iodine*[tiab] | 33619
#30 | “silver”[tiab] | 37082
#31 | “polyhexamethylene biguanide”[tiab] | 189
#32 | “bismuth”[tiab] | 5315
#33 | honey[tiab] | 4835
#34 | collagen*[tiab] | 144270
#35 | oasis*[tiab] | 1738
#36 | “extracellular matrix”[tiab] | 55940
#37 | Iodosorb[tiab] | 18
#38 | Polyurethanes[mh] | 6685
#39 | Allograft*[tiab] | 47819
#40 | Bilayer*[tiab] OR bi-layer*[tiab] | 31836
#41 | Bioengineer*[tiab] OR bio-engineer*[tiab] | 3100
#42 | Biological*[tiab] | 440724
#43 | #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 | 1266975
#44 | (animal[mh] NOT human [mh]) | 3686454
#45 | Addresses[pt] OR Autobiography[pt] OR Bibliography[pt] OR Biography[pt] OR “Case Reports”[pt] OR “Classical Article”[pt] OR “Clinical Conference”[pt] OR “Collected Works”[pt] OR Comment[pt] OR Congresses[pt] OR “Consensus Development Conference”[pt] OR “Consensus Development Conference, NIH”[pt] OR Dictionary[pt] OR Directory[pt] OR Editorial[pt] OR “Legal Cases”[pt] OR Legislation[pt] OR News[pt] OR “Newspaper Article”[pt] OR Portraits[pt] | 2699284
#46 | (#12 AND #43) NOT #44 NOT #45 AND PUBLICATION DATE LIMIT OF 1980/01/01 | 3138

Advanced Wound Dressings EMBASE Strategy

Search | String | # Hits
#1 | ‘Leg ulcer’/exp | 12005
#2 | “chronic leg”:ti,ab | 942
#3 | “chronic venous”:ti,ab | 4676
#4 | “lower extremity”:ti,ab OR “lower extremities”:ti,ab OR “lower limb”:ti,ab OR “lower limbs”:ti,ab | 79717
#5 | Ulcer:ti,ab OR ulcers:ti,ab OR ulceration:ti,ab | 140840
#6 | (#2 OR #3 OR #4) AND #5 | 5457
#7 | “leg ulcer”:ti,ab OR “leg ulcers”:ti,ab OR “leg ulceration”:ti,ab | 6143
#8 | “venous ulcer”:ti,ab OR “venous ulcers”:ti,ab OR “venous ulceration”:ti,ab | 2187
#9 | “venous stasis ulcer”:ti,ab OR “venous stasis ulcers”:ti,ab OR “venous stasis ulceration”:ti,ab | 236
#10 | “chronic wound”:ti,ab OR “chronic wounds”:ti,ab | 3509
#11 | #1 OR #6 OR #7 OR #8 OR #9 OR #10 | 19217
#12 | ‘wound dressing’/exp | 8225
#13 | ‘foam dressing’/exp | 205
#14 | ‘hydrocolloid dressing’/exp | 542
#15 | ‘polyethylene derivative’/exp | 3752
#16 | ‘Polyurethane’/exp | 9419
#17 | ‘silver derivative’/exp | 1870
#18 | Dressing*:ti,ab or bandag*:ti,ab | 21839
#19 | Hydrocolloid*:ti,ab | 1456
#20 | Film*:ti,ab | 98285
#21 | Alginate*:ti,ab | 11321
#22 | Foam*:ti,ab | 20001
#23 | Composite*:ti,ab | 84026
#24 | Absorb*:ti,ab OR absorpt*:ti,ab | 300653
#25 | Gauze*:ti,ab | 3594
#26 | Antibacterial*:ti,ab | 52023
#27 | iodine*:ti,ab | 41353
#28 | “silver”:ti,ab | 41454
#29 | “polyhexamethylene biguanide”:ti,ab | 224
#30 | “bismuth”:ti,ab | 6004
#31 | honey:ti,ab | 6301
#32 | collagen*:ti,ab | 178128
#33 | oasis*:ti,ab | 2210
#34 | “extracellular matrix”:ti,ab | 67720
#35 | Iodosorb:ti,ab | 25
#36 | Allograft*:ti,ab | 62289
#37 | Bilayer*:ti,ab OR bi-layer:ti,ab OR bi-layered:ti,ab OR bi-layers:ti,ab | 34372
#38 | Bioengineer*:ti,ab OR bio-engineer:ti,ab OR bio-engineered:ti,ab OR bio-engineering:ti,ab | 4835
#39 | Biological*:ti,ab | 564888
#40 | #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 | 1504879
#41 | #11 AND #40 | 3917
#42 | ([animals]/lim NOT [humans]/lim) | 4592309
#43 | ‘conference abstracts’:it OR ‘conference paper’:it OR ‘conference reviews’:it OR editorial:it OR erratum:it OR letter:it OR note:it | 2567814
#44 | #41 NOT #42 NOT #43 | 3484

Advanced Wound Dressings Cochrane Strategy

Search | String | # Hits
#1 | “chronic leg”:ti,ab,kw | 125
#2 | “chronic venous”:ti,ab,kw | 491
#3 | “lower extremity”:ti,ab,kw OR “lower extremities”:ti,ab,kw OR “lower limb”:ti,ab,kw OR “lower limbs”:ti,ab,kw | 3950
#4 | Ulcer:ti,ab,kw OR ulcers:ti,ab,kw OR ulceration:ti,ab,kw | 12129
#5 | (#1 OR #2 OR #3) AND #4 | 495
#6 | “leg ulcer”:ti,ab,kw OR “leg ulcers”:ti,ab,kw OR “leg ulceration”:ti,ab,kw | 1004
#7 | “venous ulcer”:ti,ab,kw OR “venous ulcers”:ti,ab,kw OR “venous ulceration”:ti,ab,kw | 374
#8 | “venous stasis ulcer”:ti,ab,kw OR “venous stasis ulcers”:ti,ab,kw OR “venous stasis ulceration”:ti,ab,kw | 26
#9 | “chronic wound”:ti,ab,kw OR “chronic wounds”:ti,ab,kw | 188
#10 | #5 OR #6 OR #7 OR #8 OR #9 | 1520
#11 | Dressing*:ti,ab,kw or bandag*:ti,ab,kw | 3561
#12 | Hydrocolloid*:ti,ab,kw | 333
#13 | Film*:ti,ab,kw | 1937
#14 | Alginate*:ti,ab,kw | 356
#15 | Foam*:ti,ab,kw | 888
#16 | Composite*:ti,ab,kw | 5323
#17 | Absorb*:ti,ab,kw OR absorpt*:ti,ab,kw | 14289
#18 | Gauze*:ti,ab,kw | 445
#19 | Antibacterial*:ti,ab,kw | 1374
#20 | iodine*:ti,ab,kw | 2246
#21 | “silver”:ti,ab,kw | 862
#22 | “polyhexamethylene biguanide”:ti,ab,kw | 27
#23 | “bismuth”:ti,ab,kw | 916
#24 | honey:ti,ab,kw | 169
#25 | collagen*:ti,ab,kw | 3365
#26 | oasis*:ti,ab,kw | 82
#27 | “extracellular matrix”:ti,ab,kw | 229
#28 | Iodosorb:ti,ab,kw | 11
#29 | Allograft*:ti,ab,kw | 1767
#30 | Bilayer*:ti,ab,kw OR bi-layer:ti,ab,kw OR bi-layered:ti,ab,kw OR bi-layers:ti,ab,kw | 73
#31 | Bioengineer*:ti,ab,kw OR bio-engineer:ti,ab,kw OR bio-engineered:ti,ab,kw OR bio-engineering:ti,ab,kw | 78
#32 | Biological*:ti,ab,kw | 17855
#33 | #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 | 49768
#34 | (#10 AND #33), from 1980 to 2011 | 602

Advanced Wound Dressings CINAHL Strategy

Search | String | # Hits
S1 | (MH “Leg Ulcer+”) | 7248
S2 | TX “chronic leg” | 462
S3 | TX “chronic venous” | 558
S4 | TX “lower extremity” OR TX “lower extremities” OR TX “lower limb” OR TX “lower limbs” | 11938
S5 | TX Ulcer OR TX ulcers OR TX ulceration | 18750
S6 | (S2 OR S3 OR S4) AND S5 | 1369
S7 | TX “leg ulcer” OR TX “leg ulcers” OR TX “leg ulceration” | 2795
S8 | TX “venous ulcer” OR TX “venous ulcers” OR TX “venous ulceration” | 1845
S9 | TX “venous stasis ulcer” OR TX “venous stasis ulcers” OR TX “venous stasis ulceration” | 98
S10 | TX “chronic wound” OR TX “chronic wounds” | 2652
S11 | S1 OR S6 OR S7 OR S8 OR S9 OR S10 | 9620
S12 | (MH “Bandages and dressings+”) | 7737
S13 | TX Dressing* OR TX bandag* | 10651
S14 | TX Hydrocolloid* | 565
S15 | TX Film* | 3747
S16 | TX Alginate* | 597
S17 | TX Foam* | 1686
S18 | TX Composite* | 6400
S19 | TX Absorb* OR TX absorpt* | 9217
S20 | TX Gauze* | 669
S21 | TX Antibacterial* | 1448
S22 | TX iodine* | 2082
S23 | TX “silver” | 4274
S24 | TX “polyhexamethylene biguanide” | 25
S25 | TX “bismuth” | 139
S26 | TX honey | 852
S27 | TX collagen* | 5402
S28 | TX oasis* | 607
S29 | TX “extracellular matrix” | 1239
S30 | TX Iodosorb | 8
S31 | TX Allograft* | 3253
S32 | TX Bilayer* OR TX bi-layer OR TX bi-layered OR TX bi-layers | 135
S33 | TX Bioengineer* OR TX bio-engineer OR TX bio-engineered OR TX bio-engineering | 947
S34 | TX Biological* | 53531
S35 | S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 | 97168
S36 | S11 AND S35 | 2976
S37 | Limiters - Publication Type: Abstract, Accreditation, Algorithm, Anecdote, Audiovisual, Bibliography, Biography, Book, Book Chapter, Book Review, Brief Item, Care Plan, Cartoon, Case Study, CEU, Clinical Innovations, Code of Ethics, Commentary, Computer Program, Consumer/Patient Teaching Materials, Corrected Article, Critical Path, Diagnostic Images, Directories, Doctoral Dissertation, Drugs, Editorial, Equations & Formulas, Exam Questions, Forms, Games, Glossary, Historical Material, Interview, Legal Cases, Letter, Listservs, Masters Thesis, Nurse Practice Acts, Nursing Diagnoses, Nursing Interventions, Obituary, Pamphlet, Pamphlet Chapter, Pictorial, Poetry, Practice Acts, Proceedings, Protocol, Questions and Answers, Response, Software, Standards, Statistics, Tables/Charts, Teaching Materials, Tracings, Website | 0
S38 | S36 NOT S37 | 541

Antimicrobials PubMed Strategy

Search | String | # Hits
#1 | “Leg ulcer”[mh: noexp] | 7117
#2 | “Varicose ulcer”[mh] | 3580
#3 | “chronic leg”[tiab] | 739
#4 | “chronic venous”[tiab] | 3133
#5 | “lower extremity”[tiab] OR “lower extremities”[tiab] OR “lower limb”[tiab] OR “lower limbs”[tiab] | 59033
#6 | Ulcer[tiab] OR ulcers[tiab] OR ulceration[tiab] | 110990
#7 | (#3 OR #4 OR #5) AND #6 | 3863
#8 | “leg ulcer”[tiab] OR “leg ulcers”[tiab] OR “leg ulceration”[tiab] | 4577
#9 | “venous ulcer”[tiab] OR “venous ulcers”[tiab] OR “venous ulceration”[tiab] | 1577
#10 | “venous stasis ulcer”[tiab] OR “venous stasis ulcers”[tiab] OR “venous stasis ulceration”[tiab] | 181
#11 | “chronic wound”[tiab] OR “chronic wounds”[tiab] | 2416
#12 | #1 OR #2 OR #7 OR #8 OR #9 OR #10 OR #11 | 14928
#13 | “Anti-infective agents”[mh] | 455226
#14 | “beta-Lactams”[mh] | 102689
#15 | Clindamycin[mh] | 4618
#16 | “Trimethoprim-Sulfamethoxazole Combination”[mh] | 5341
#17 | Oxazolidinones[mh] | 5645
#18 | Quinolones[mh] | 32034
#19 | Lactams[mh] | 10814
#20 | Vancomycin[mh] | 9108
#21 | Daptomycin[mh] | 977
#22 | Gentamicins[mh] | 16315
#23 | Tobramycin[mh] | 3543
#24 | Tetracyclines[mh] | 38254
#25 | Metronidazole[mh] | 10154
#26 | Antibiotic*[tiab] OR anti-biotic*[tiab] OR antimicrobial*[tiab] OR anti-microbial*[tiab] OR antibacterial*[tiab] OR anti-bacterial*[tiab] | 291474
#27 | Cephalosporin*[tiab] | 16075
#28 | Cephalexin*[tiab] OR Cefalexin*[tiab] | 2304
#29 | Amoxicillin*[tiab] OR Clavulanate*[tiab] | 10002
#30 | Linezolid*[tiab] | 2718
#31 | Dicloxacillin*[tiab] | 590
#32 | Clindamycin*[tiab] | 7305
#33 | Trimethoprim*[tiab] OR sulfamethoxazole*[tiab] | 12639
#34 | Quinolone*[tiab] | 9509
#35 | Levofloxacin*[tiab] | 4079
#36 | Moxifloxacin*[tiab] | 2393
#37 | “Beta lactam”[tiab] OR “beta lactam”[tiab] OR beta-lactam*[tiab] | 27026
#38 | Augmentin*[tiab] | 7922
#39 | Cefixime*[tiab] | 1116
#40 | Cefpodoxime*[tiab] | 617
#41 | Cefazolin*[tiab] | 3101
#42 | Ceftriaxone*[tiab] | 6475
#43 | Vancomycin*[tiab] OR Daptomycin*[tiab] | 16477
#44 | Ertapenem*[tiab] | 604
#45 | Piperacillin*[tiab] OR tazobactam*[tiab] OR cefipime*[tiab] | 4608
#46 | Gentamicin*[tiab] OR tobramycin*[tiab] OR amikacin*[tiab] | 25125
#47 | aminoglycoside*[tiab] | 13881
#48 | Neomycin*[tiab] | 8115
#49 | Tetracycline*[tiab] OR doxycycline*[tiab] OR minocycline*[tiab] | 35085
#50 | Metronidazole*[tiab] | 10967
#51 | Cefuroxime*[tiab] | 3317
#52 | #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 | 745663
#53 | #12 AND #52 | 1231
#54 | (animal[mh] NOT human [mh]) | 3687258
#55 | Addresses[pt] OR Autobiography[pt] OR Bibliography[pt] OR Biography[pt] OR “Case Reports”[pt] OR “Classical Article”[pt] OR “Clinical Conference”[pt] OR “Collected Works”[pt] OR Comment[pt] OR Congresses[pt] OR “Consensus Development Conference”[pt] OR “Consensus Development Conference, NIH”[pt] OR Dictionary[pt] OR Directory[pt] OR Editorial[pt] OR “Legal Cases”[pt] OR Legislation[pt] OR News[pt] OR “Newspaper Article”[pt] OR Portraits[pt] | 2699639
#56 | #53 NOT #54 NOT #55 | 897
#57 | #56 WITH PUBLICATION DATE LIMIT OF 1980 | 703

Antimicrobials EMBASE Strategy

Search | String | # Hits
#1 | ‘Leg ulcer’/exp | 11779
#2 | “chronic leg”:ti,ab | 920
#3 | “chronic venous”:ti,ab | 4552
#4 | “lower extremity”:ti,ab OR “lower extremities”:ti,ab OR “lower limb”:ti,ab OR “lower limbs”:ti,ab | 76614
#5 | Ulcer:ti,ab OR ulcers:ti,ab OR ulceration:ti,ab | 137892
#6 | (#2 OR #3 OR #4) AND #5 | 5245
#7 | “leg ulcer”:ti,ab OR “leg ulcers”:ti,ab OR “leg ulceration”:ti,ab | 6018
#8 | “venous ulcer”:ti,ab OR “venous ulcers”:ti,ab OR “venous ulceration”:ti,ab | 2121
#9 | “venous stasis ulcer”:ti,ab OR “venous stasis ulcers”:ti,ab OR “venous stasis ulceration”:ti,ab | 225
#10 | “chronic wound”:ti,ab OR “chronic wounds”:ti,ab | 3124
#11 | #1 OR #6 OR #7 OR #8 OR #9 OR #10 | 18595
#12 | ‘antiinfective agent’/exp | 1990306
#13 | ‘beta lactam’/exp | 314212
#14 | ‘quinolone’/exp | 98780
#15 | Antibiotic*:ti,ab OR “anti-biotic”:ti,ab OR antimicrobial*:ti,ab OR “anti-microbial”:ti,ab OR antibacterial*:ti,ab OR “anti-bacterial”:ti,ab | 368749
#16 | Cephalosporin*:ti,ab | 21317
#17 | Cephalexin*:ti,ab OR Cefalexin*:ti,ab | 2983
#18 | Amoxicillin*:ti,ab OR Clavulanate*:ti,ab | 13527
#19 | Linezolid*:ti,ab | 3658
#20 | Dicloxacillin*:ti,ab | 734
#21 | Clindamycin*:ti,ab | 9061
#22 | Trimethoprim*:ti,ab OR sulfamethoxazole*:ti,ab | 15465
#23 | Quinolone*:ti,ab | 12843
#24 | Levofloxacin*:ti,ab | 5714
#25 | Moxifloxacin*:ti,ab | 3167
#26 | “Beta lactam”:ti,ab OR “beta lactams”:ti,ab OR “beta-lactam”:ti,ab OR “beta-lactams”:ti,ab | 5338
#27 | Augmentin*:ti,ab | 9500
#28 | Cefixime*:ti,ab | 1670
#29 | Cefpodoxime*:ti,ab | 901
#30 | Cefazolin*:ti,ab | 3907
#31 | Ceftriaxone*:ti,ab | 8687
#32 | Vancomycin*:ti,ab OR Daptomycin*:ti,ab | 21081
#33 | Ertapenem*:ti,ab | 896
#34 | Piperacillin*:ti,ab OR tazobactam*:ti,ab OR cefipime*:ti,ab | 6499
#35 | Gentamicin*:ti,ab OR tobramycin*:ti,ab OR amikacin*:ti,ab | 32032
#36 | aminoglycoside*:ti,ab | 17357
#37 | Neomycin*:ti,ab | 8829
#38 | Tetracycline*:ti,ab OR doxycycline*:ti,ab OR minocycline*:ti,ab | 41515
#39 | Metronidazole*:ti,ab | 1400
#40 | Cefuroxime*:ti,ab | 4442
#41 | #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 | 2107091
#42 | #11 AND #41 | 3130
#43 | ([animals]/lim NOT [humans]/lim) | 4415955
#44 | ‘conference abstracts’:it OR ‘conference paper’:it OR ‘conference reviews’:it OR editorial:it OR erratum:it OR letter:it OR note:it | 2506412
#45 | #42 NOT #43 NOT #44 | 2806
#46 | #45 WITH PUBLICATION DATE LIMIT OF 1980 | 2626

Antimicrobials Cochrane Strategy

Search | String | # Hits
#1 | “chronic leg”:ti,ab,kw | 125
#2 | “chronic venous”:ti,ab,kw | 491
#3 | “lower extremity”:ti,ab,kw OR “lower extremities”:ti,ab,kw OR “lower limb”:ti,ab,kw OR “lower limbs”:ti,ab,kw | 3950
#4 | Ulcer:ti,ab,kw OR ulcers:ti,ab,kw OR ulceration:ti,ab,kw | 12129
#5 | (#1 OR #2 OR #3) AND #4 | 68
#6 | “leg ulcer”:ti,ab,kw OR “leg ulcers”:ti,ab,kw OR “leg ulceration”:ti,ab,kw | 1004
#7 | “venous ulcer”:ti,ab,kw OR “venous ulcers”:ti,ab,kw OR “venous ulceration”:ti,ab,kw | 374
#8 | “venous stasis ulcer”:ti,ab,kw OR “venous stasis ulcers”:ti,ab,kw OR “venous stasis ulceration”:ti,ab,kw | 26
#9 | “chronic wound”:ti,ab,kw OR “chronic wounds”:ti,ab,kw | 188
#10 | #5 OR #6 OR #7 OR #8 OR #9 | 1437
#11 | Antibiotic*:ti,ab,kw OR “anti-biotic”:ti,ab,kw OR antimicrobial*:ti,ab,kw OR “anti-microbial”:ti,ab,kw OR antibacterial*:ti,ab,kw OR “anti-bacterial”:ti,ab,kw | 19305
#12 | Cephalosporin*:ti,ab,kw | 1930
#13 | Cephalexin*:ti,ab,kw OR Cefalexin*:ti,ab,kw | 417
#14 | Amoxicillin*:ti,ab,kw OR Clavulanate*:ti,ab,kw | 3113
#15 | Linezolid*:ti,ab,kw | 127
#16 | Dicloxacillin*:ti,ab,kw | 59
#17 | Clindamycin*:ti,ab,kw | 1030
#18 | Trimethoprim*:ti,ab,kw OR sulfamethoxazole*:ti,ab,kw | 1470
#19 | Quinolone*:ti,ab,kw | 891
#20 | Levofloxacin*:ti,ab,kw | 537
#21 | Moxifloxacin*:ti,ab,kw | 378
#22 | “Beta lactam”:ti,ab,kw OR “beta lactams”:ti,ab,kw OR “beta-lactam”:ti,ab,kw OR “beta-lactams”:ti,ab,kw | 421
#23 | Augmentin*:ti,ab,kw | 504
#24 | Cefixime*:ti,ab,kw | 247
#25 | Cefpodoxime*:ti,ab,kw | 122
#26 | Cefazolin*:ti,ab,kw | 569
#27 | Ceftriaxone*:ti,ab,kw | 934
#28 | Vancomycin*:ti,ab,kw OR Daptomycin*:ti,ab,kw | 723
#29 | Ertapenem*:ti,ab,kw | 53
#30 | Piperacillin*:ti,ab,kw OR tazobactam*:ti,ab,kw OR cefipime*:ti,ab,kw | 539
#31 | Gentamicin*:ti,ab,kw OR tobramycin*:ti,ab,kw OR amikacin*:ti,ab,kw | 2688
#32 | aminoglycoside*:ti,ab,kw | 632
#33 | Neomycin*:ti,ab,kw | 504
#34 | Tetracycline*:ti,ab,kw OR doxycycline*:ti,ab,kw OR minocycline*:ti,ab,kw | 2650
#35 | Metronidazole*:ti,ab,kw | 2570
#36 | Cefuroxime*:ti,ab,kw | 713
#37 | #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 | 28126
#38 | (#10 AND #37) from 1980 to 2011 | 70

Antimicrobials CINAHL Strategy

Search | String | # Hits
S1 | (MH “Leg Ulcer+”) | 7248
S2 | TX “chronic leg” | 462
S3 | TX “chronic venous” | 558
S4 | TX “lower extremity” OR TX “lower extremities” OR TX “lower limb” OR TX “lower limbs” | 11938
S5 | TX Ulcer OR TX ulcers OR TX ulceration | 18750
S6 | (S2 OR S3 OR S4) AND S5 | 1369
S7 | TX “leg ulcer” OR TX “leg ulcers” OR TX “leg ulceration” | 2797
S8 | TX “venous ulcer” OR TX “venous ulcers” OR TX “venous ulceration” | 1845
S9 | TX “venous stasis ulcer” OR TX “venous stasis ulcers” OR TX “venous stasis ulceration” | 98
S10 | TX “chronic wound” OR TX “chronic wounds” | 2652
S11 | S1 OR S6 OR S7 OR S8 OR S9 OR S10 | 9620
S12 | (MH “Antiinfective agents+”) | 29109
S13 | TX Antibiotic* OR TX “Anti-biotic” OR TX antimicrobial* OR TX “anti-microbial” OR TX antibacterial* OR TX “anti-bacterial” | 1119
S14 | TX Cephalosporin* | 99
S15 | TX Cephalexin* OR TX Cefalexin* | 1088
S16 | TX Amoxicillin* OR TX Clavulanate* | 306
S17 | TX Linezolid* | 10
S18 | TX Dicloxacillin* | 620
S19 | TX Clindamycin* | 889
S20 | TX Trimethoprim* OR TX sulfamethoxazole* | 792
S21 | TX Quinolone* | 348
S22 | TX Levofloxacin* | 254
S23 | TX Moxifloxacin* | 411
S24 | TX “Beta lactam” OR TX “beta lactams” OR TX “beta-lactam” OR TX “beta-lactams” | 537
S25 | TX Augmentin* | 47
S26 | TX Cefixime* | 40
S27 | TX Cefpodoxime* | 198
S28 | TX Cefazolin* | 574
S29 | TX Ceftriaxone* | 2440
S30 | TX Vancomycin* OR Daptomycin* | 61
S31 | TX Ertapenem* | 235
S32 | TX Piperacillin* OR TX tazobactam* OR TX cefipime* | 1280
S33 | TX Gentamicin* OR TX tobramycin* OR TX amikacin* | 1011
S34 | TX aminoglycoside* | 153
S35 | TX Neomycin* | 1677
S36 | TX Tetracycline* OR TX doxycycline* OR TX minocycline* | 996
S37 | TX Metronidazole* | 233
S38 | TX Cefuroxime* | 5512
S39 | S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 | 37572
S40 | S11 AND S39 | 801
S41 | Limiters - Publication Type: Abstract, Accreditation, Algorithm, Anecdote, Audiovisual, Bibliography, Biography, Book, Book Chapter, Book Review, Brief Item, Care Plan, Cartoon, Case Study, CEU, Clinical Innovations, Code of Ethics, Commentary, Computer Program, Consumer/Patient Teaching Materials, Corrected Article, Critical Path, Diagnostic Images, Directories, Doctoral Dissertation, Drugs, Editorial, Equations & Formulas, Exam Questions, Forms, Games, Glossary, Historical Material, Interview, Legal Cases, Letter, Listservs, Masters Thesis, Nurse Practice Acts, Nursing Diagnoses, Nursing Interventions, Obituary, Pamphlet, Pamphlet Chapter, Pictorial, Poetry, Practice Acts, Proceedings, Protocol, Questions and Answers, Response, Software, Standards, Statistics, Tables/Charts, Teaching Materials, Tracings, Website | 1
S42 | S40 NOT S41 | 801
S43 | S40 NOT S41 publication date limited 1980 to 2012 | 814

Surgical PubMed Strategy

Search | String | # Hits
#1 | “Leg ulcer”[mh: noexp] | 7117
#2 | “Varicose ulcer”[mh] | 3520
#3 | “chronic leg”[tiab] | 739
#4 | “chronic venous”[tiab] | 3133
#5 | “lower extremity”[tiab] OR “lower extremities”[tiab] OR “lower limb”[tiab] OR “lower limbs”[tiab] | 59033
#6 | Ulcer[tiab] OR ulcers[tiab] OR ulceration[tiab] | 110990
#7 | (#3 OR #4 OR #5) AND #6 | 3863
#8 | “leg ulcer”[tiab] OR “leg ulcers”[tiab] OR “leg ulceration”[tiab] | 4577
#9 | “venous ulcer”[tiab] OR “venous ulcers”[tiab] OR “venous ulceration”[tiab] | 1577
#10 | “venous stasis ulcer”[tiab] OR “venous stasis ulcers”[tiab] OR “venous stasis ulceration”[tiab] | 181
#11 | “chronic wound”[tiab] OR “chronic wounds”[tiab] | 1160
#12 | “Venous Insufficiency/Surgery”[mh] | 15788
#13 | #1 OR #2 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 | 231557
#14 | Endoscopy[mh] | 17747
#15 | “Catheter ablation”[mh] | 45571
#16 | “Laser therapy”[mh] | 45571
#17 | “Balloon dilation”[mh] | 57915
#18 | Ligation[mh] | 16709
#19 | Sclerotherapy[mh] | 3985
#20 | Thrombectomy[mh] | 2663
#21 | Angioplasty[mh] | 50543
#22 | Endoscop*[tiab] | 124799
#23 | Stripping[tiab] | 7623
#24 | Ablat*[tiab] | 59141
#25 | Ligat*[tiab] | 66926
#26 | Laser*[tiab] | 164238
#27 | Valvuloplast*[tiab] | 3490
#28 | Valve*[tiab] | 91443
#29 | Sclerotherap*[tiab] | 5111
#30 | Thrombolys*[tiab] | 15531
#31 | Thrombectom*[tiab] | 3962
#32 | Angioplast*[tiab] | 34805
#33 | Stent*[tiab] | 551282
#34 | (Vein[tiab] OR venous[tiab]) AND (surgery[tiab] OR surgeries[tiab]) | 28014
#35 | #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 | 792514
#36 | #13 AND #35 | 2013
#37 | (animal[mh] NOT human [mh]) | 3687258
#38 | Addresses[pt] OR Autobiography[pt] OR Bibliography[pt] OR Biography[pt] OR “Classical Article”[pt] OR “Clinical Conference”[pt] OR “Collected Works”[pt] OR Comment[pt] OR Congresses[pt] OR “Consensus Development Conference”[pt] OR “Consensus Development Conference, NIH”[pt] OR Dictionary[pt] OR Directory[pt] OR Editorial[pt] OR “Legal Cases”[pt] OR Legislation[pt] OR News[pt] OR “Newspaper Article”[pt] OR Portraits[pt] | 1148100
#39 | #36 NOT #37 NOT #38 | 1914
#40 | #39 WITH PUBLICATION DATE LIMIT OF 1980. | 1848

Surgical EMBASE Strategy

Search | String | # of hits
#1 | ‘Leg ulcer’/exp | 12201
#2 | “chronic leg”:ti,ab | 963
#3 | “chronic venous”:ti,ab | 4764
#4 | “lower extremity”:ti,ab OR “lower extremities”:ti,ab OR “lower limb”:ti,ab OR “lower limbs”:ti,ab | 81416
#5 | Ulcer:ti,ab OR ulcers:ti,ab OR ulceration:ti,ab | 143251
#6 | (#2 OR #3 OR #4) AND #5 | 5569
#7 | “leg ulcer”:ti,ab OR “leg ulcers”:ti,ab OR “leg ulceration”:ti,ab | 6253
#8 | “venous ulcer”:ti,ab OR “venous ulcers”:ti,ab OR “venous ulceration”:ti,ab | 2220
#9 | “venous stasis ulcer”:ti,ab OR “venous stasis ulcers”:ti,ab OR “venous stasis ulceration”:ti,ab | 238
#10 | “chronic wound”:ti,ab OR “chronic wounds”:ti,ab | 3580
#11 | ‘vein insufficiency’/exp | 8401
#12 | #1 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 | 26150
#13 | ‘endoscopic surgery’/exp | 139183
#14 | ‘vein surgery’/exp | 10760
#15 | ‘radiofrequency ablation’/exp OR ‘sclerotherapy’/exp OR ‘vein transplantation’/exp | 40067
#16 | Endoscop*:ti,ab | 183402
#17 | Stripping:ti,ab | 10723
#18 | Ablat*:ti,ab | 84509
#19 | Ligat*:ti,ab | 83442
#20 | Laser*:ti,ab | 170434
#21 | Valvuloplast*:ti,ab | 4729
#22 | Valve*:ti,ab | 121023
#23 | Sclerotherap*:ti,ab | 7260
#24 | Thrombolys*:ti,ab | 22560
#25 | Thrombectom*:ti,ab | 5940
#26 | Angioplast*:ti,ab | 45775
#27 | Stent*:ti,ab | 85953
#28 | (Vein:ti,ab OR venous:ti,ab) AND (surgery:ti,ab OR surgeries:ti,ab) | 42433
#29 | #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 | 893507
#30 | #12 AND #29 | 4231
#31 | ([animals]/lim NOT [humans]/lim) | 4639462
#32 | ‘conference abstracts’:it OR ‘conference paper’:it OR ‘conference reviews’:it OR editorial:it OR erratum:it OR letter:it OR note:it | 2615920
#33 | #30 NOT #31 NOT #32 | 3726
#34 | #33 AND [1980-2012]/py | 3585

Surgical Cochrane Strategy

Search | String | # of hits
#1 | “chronic leg”:ti,ab,kw | 125
#2 | “chronic venous”:ti,ab,kw | 491
#3 | “lower extremity”:ti,ab,kw OR “lower extremities”:ti,ab,kw OR “lower limb”:ti,ab,kw OR “lower limbs”:ti,ab,kw | 3950
#4 | Ulcer:ti,ab,kw OR ulcers:ti,ab,kw OR ulceration:ti,ab,kw | 12129
#5 | (#1 OR #2 OR #3) AND #4 | 495
#6 | “leg ulcer”:ti,ab,kw OR “leg ulcers”:ti,ab,kw OR “leg ulceration”:ti,ab,kw | 1004
#7 | “venous ulcer”:ti,ab,kw OR “venous ulcers”:ti,ab,kw OR “venous ulceration”:ti,ab,kw | 374
#8 | “venous stasis ulcer”:ti,ab,kw OR “venous stasis ulcers”:ti,ab,kw OR “venous stasis ulceration”:ti,ab,kw | 26
#9 | “chronic wound”:ti,ab,kw OR “chronic wounds”:ti,ab,kw | 188
#10 | #5 OR #6 OR #7 OR #8 OR #9 | 1520
#11 | Endoscop*:ti,ab,kw | 9764
#12 | Stripping:ti,ab,kw | 1033
#13 | Ablat*:ti,ab,kw | 2470
#14 | Ligat*:ti,ab,kw | 1280
#15 | Laser*:ti,ab,kw | 7633
#16 | Valvuloplast*:ti,ab,kw | 67
#17 | Valve*:ti,ab,kw | 2786
#18 | Sclerotherap*:ti,ab,kw | 1031
#19 | Thrombolys*:ti,ab,kw | 2084
#20 | Thrombectom*:ti,ab,kw | 165
#21 | Angioplast*:ti,ab,kw | 5472
#22 | Stent*:ti,ab,kw | 4278
#23 | (Vein:ti,ab,kw OR venous:ti,ab,kw) AND (surgery:ti,ab,kw OR surgeries:ti,ab,kw) | 4381
#24 | #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 | 36210
#25 | #10 AND #24 | 169
#26 | #25 – clinical trials and limit 1980-2012 | 155