# Abbreviations

ABI: ankle brachial index
AHRQ: Agency for Healthcare Research and Quality
CHIVA: Conservative Hemodynamic treatment of Insufficiency of the Venous system in an Ambulatory setting
CVU: chronic venous ulcers
DVT: deep vein thrombosis
ECM: extracellular matrix
EPC: Evidence-based Practice Center
ESCHAR: Effect of Surgery and Compression on Healing and Recurrence
EVLT: endovenous laser therapy
HCPS: Healthcare Common Procedure Coding System
HR: hazard ratio
HSE: human skin equivalent
KQ: Key Question
Mm: millimeters
mm Hg: millimeters of mercury
MTC-2g: Mimosa tenuiflora
NOSF: nano-oligosaccharide factor lipido-colloid
PLSVS: perforator ligation plus saphenous vein stripping
QOL: quality of life
RCT: randomized controlled trial
RFA: radiofrequency ablation
SD: standard deviation
SEPS: subfascial endoscopic perforator surgery