# References

1 van Kimmenade RR, Januzzi JL Jr., Ellinor PT, et al. Utility of amino-terminal pro-brain natriuretic peptide, galectin-3, and apelin for the evaluation of patients with acute heart failure. J Am Coll Cardiol. 2006;48(6):1217-24. [pmid: 16979009].
2 Januzzi JL, van Kimmenade R, Lainchbury J, et al. NT-proBNP testing for diagnosis and short-term prognosis in acute destabilized heart failure: An international pooled analysis of 1256 patients: The International Collaborative of NT-proBNP Study. Eur Heart J. 2006;27(3):330-7. [pmid: 16293638].
3 Maisel A, Mueller C, Nowak R, et al. Mid-region pro-hormone markers for diagnosis and prognosis in acute dyspnea: Results from the BACH (Biomarkers in Acute Heart Failure) trial. J Am Coll Cardiol. 2010;55(19):2062-76. [pmid: 20447528].
4 Berger R, Moertl D, Peter S, et al. N-terminal pro-B-type natriuretic peptide-guided, intensive patient management in addition to multidisciplinary care in chronic heart failure a 3-arm, prospective, randomized pilot study. J Am Coll Cardiol. 2010;55(7):645-53. [pmid: 20170790].
5 Persson H, Erntell H, Eriksson B, et al. Improved pharmacological therapy of chronic heart failure in primary care: A randomized Study of NT-proBNP guided management of heart failure - SIGNAL-HF (Swedish intervention study - Guidelines and NT-proBNP analysis in heart failure). Eur J Heart Fail. 2010;12(12):1300-8. [pmid: 20876734].
6 Greenland P, Alpert JS, Beller GA, et al. 2010 ACCF/AHA guideline for assessment of cardiovascular risk in asymptomatic adults. J Am Coll Cardiol. 2010;56(25):e50-e103. [pmid: 21144964].
7 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart disease and stroke statistics--2011 update: a report from the American Heart Association. Circ Cardiovasc Qual Outcomes. 2011;123(4):e18-e209. [pmid: 21160056].
8 U.S.Census Bureau. U.S. and Population Clocks. www.census.gov/main/www/popclock.html.
9 Ziskoven D, Forssmann WG, Holthausen U, et al. Calcium calmodulinantagonists influences the release of cardiodilatin/ANP from atrial cardiocytes. Kaufmann W, Wambach G, editors. Handbook Endocrinology of the Heart. Verlag, Berlin, Heidelberg, New York. Springer. 1989.
10 Jessup M. Focused update: ACCF/AHA guidelines for the diagnosis and management of heart failure in adults. J Am Coll Cardiol. 2009;53(15):1343-82.
11 McKelvie RS, Moe GW, Ezekowitz JA, et al. The 2012 Canadian Cardiovascular Society heart failure management guidelines update: focus on acute and chronic heart failure. Can J Cardiol. 2013;29(2):168-81. [pmid: 23201056].
12 McMurray JJV, Adamopoulos C, Anker S, et al. ESC Guidelines for the diagnosis and treatment of acute and chronic heart failure. Eur Heart J. 2012;33:1787-847. www.escardio.org/guidelines-surveys/esc-guidelines/Pages/acute-chronic-heart-failure.aspx. [pmid: 22611136].
13 Pang PS, Komajda M, Gheorghiade M. The current and future management of acute heart failure syndromes. Eur Heart J. 2010;31(7):784-93. [pmid: 20207624].
14 Metra M, Ponikowski P, Dickstein K, et al. Advanced chronic heart failure: A position statement from the Study Group on Advanced Heart Failure of the Heart Failure Association of the European Society of Cardiology. Eur J Heart Fail. 2007;9(6-7):684-94. [pmid: 17481947].
15 Heart Failure Society of America. The 2010 Heart Failure Society of America comprehensive heart failure practice guidelines. J Card Fail. 2010;16(6):e1-e194. [pmid: 20610207].
16 Felker GM, Adams KF Jr., Konstam MA, et al. The problem of decompensated heart failure: Nomenclature, classification, and risk stratification. Am Heart J. 2003;145(2 Suppl):S18-S25. [pmid: 12594448].
17 Arnold LM, Crouch MA, Carroll NV, et al. Outcomes associated with vasoactive therapy in patients with acute decompensated heart failure. Pharmacotherapy. 2006;26(8):1078-85. [pmid: 16863484].
18 Scottish Intercollegiate Guidelines Network (SIGN). Risk estimation and the prevention of cardiovascular disease. A national clinical guideline. SIGN publication no.97. www.sign.ac.uk/pdf/sign97.pdf. April 23, 2013.
19 Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: meta-analysis of test performance when there is a “gold standard”. J Gen Intern Med. Suppl 1. 2012;27:S56-S66. [pmid: 22648676].
20 Balion C, Santaguida PL, Hill S, et al. Testing for BNP and NT-proBNP in the diagnosis and prognosis of heart failure. Evid Rep Technol Assess. 2006;(142):1-147. [pmid: 17764210].
21 Doust JA, Glasziou PP, Pietrzak E, et al. A systematic review of the diagnostic accuracy of natriuretic peptides for heart failure. Arch Intern Med. 2004;164(18):1978-84. [pmid: 15477431].
22 de Lemos JA, McGuire DK, Khera A, et al. Screening the population for left ventricular hypertrophy and left ventricular systolic dysfunction using natriuretic peptides: Results from the Dallas Heart Study. Am Heart J. 2009;157(4):746-53. [pmid: 19332205].
23 Betti I, Castelli G, Barchielli A, et al. The role of N-terminal PRO-brain natriuretic peptide and echocardiography for screening asymptomatic left ventricular dysfunction in a population at high risk for heart failure. The PROBE-HF study. J Card Fail. 2009;15(5):377-84. [pmid: 19477397].
24 Zuber M, Cuculi F, Attenhofer Jost CH, et al. Value of brain natriuretic peptides in primary care patients with the clinical diagnosis of chronic heart failure. Scand Cardiovasc J. 2009;43(5):324-9. [pmid: 19247872].
25 Rogers RK, Collins SP, Kontos MC, et al. Diagnosis and characterization of left ventricular hypertrophy by computerized acoustic cardiography, brain natriuretic peptide, and electrocardiography. J Electrocardiol. 2008;41(6):518-25. [pmid: 18804784].
26 Behnes M, Brueckmann M, Ahmad-Nejad P, et al. Diagnostic performance and cost effectiveness of measurements of plasma N-terminal pro brain natriuretic peptide in patients presenting with acute dyspnea or peripheral edema. Int J Cardiol. 2009;135(2):165-74. [pmid: 18603317].
27 Rutten JH, Steyerberg EW, Boomsma F, et al. N-terminal pro-brain natriuretic peptide testing in the emergency department: beneficial effects on hospitalization, costs, and outcome. Am Heart J. 2008;156(1):71-7. [pmid: 18585499].
28 Kosowsky JM, Weiner C, Aronson AA, et al. Impact of point-of-care B-type natriuretic peptide (BNP) measurement on medical decision-making for older emergency department patients with dyspnea. J Emerg Med. 2006;31(2):147-50. [pmid: 17044575].
29 National Clinical Guideline Centre. NICE. Clinical Guideline 108: Chronic heart failure: Management of chronic heart failure in adults in primary and secondary care. http://guidance.nice.org.uk/CG108/Guidance/pdf/English.
30 Di Angelantonio E, Chowdhury R, Sarwar N, et al. B-type natriuretic peptides and cardiovascular risk: Systematic review and meta-analysis of 40 prospective studies. Circ Cardiovasc Qual Outcomes. 2009;120(22):2177-87.
31 Doust JA, Pietrzak E, Dobson A, et al. How well does B-type natriuretic peptide predict death and cardiac events in patients with heart failure: Systematic review. BMJ. 2005;330(7492):625-7. [pmid: 15774989].
32 Vesbianu D, Vesbianu C, Bernstein P, et al. Plasma brain natriuretic peptide - An independent predictor of mortality and rehospitalization in congestive heart failure - A meta-analysis. World Heart J. 2008;1(4):349-54.
33 Oremus M, Raina PS, Santaguida P, et al. A systematic review of BNP as a predictor of prognosis in persons with coronary artery disease. Clin Biochem. 2008;41(4-5):260-5. [pmid: 17949703].
34 Balion CM, McKelvie RS, Reichert S, et al. Monitoring the response to pharmacologic therapy in patients with stable chronic heart failure: Is BNP or NT-proBNP a useful assessment tool?. Clin Biochem. 2008;41(4-5):266-76. [pmid: 17991434].
35 Porapakkham P, Porapakkham P, Zimmet H, et al. B-type natriuretic peptide-guided heart failure therapy: A meta-analysis. Arch Intern Med. 2010;170(6):507-14. [pmid: 20308637].
36 Richards AM. B-type natriuretic peptide-guided therapy for chronic heart failure reduces all-cause mortality compared with usual care but does not affect all-cause hospitalisation or survival free of hospitalisation. Evid Based Med. 2010;15(5):137-8. [pmid: 20688847].
37 Schou M, Gustafsson F, Nielsen PH, et al. Unexplained week-to-week variation in BNP and NT-proBNP is low in chronic heart failure patients during steady state. Eur J Heart Fail. 2007;9(1):68-74. [pmid: 16829184].
38 Schou M, Gustafsson F, Kjaer A, et al. Long-term clinical variation of NT-proBNP in stable chronic heart failure patients. Eur Heart J. 2007;28(2):177-82. [pmid: 17218450].
39 Wu AH. Serial testing of B-type natriuretic peptide and NTpro-BNP for monitoring therapy of heart failure: The role of biologic variation in the interpretation of results. Am Heart J. 2006;152(5):828-34. [pmid: 17070141].
40 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
41 Agency for Healthcare Research and Quality. Methods guide for medical test reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
42 American Academy of Family Physicians. Primary care. www.aafp.org/online/en/home/policy/policies/p/primarycare.html#Parsys0002. April 23, 2012.
43 Bouwmeester W, Zuithoff NP, Mallett S, et al. Reporting and methods in clinical prediction research: a systematic review. PLoS Med. 2012;9(5):1-12. [pmid: 22629234].
44 Hlatky MA, Greenland P, Arnett DK, et al. Criteria for evaluation of novel markers of cardiovascular risk: a scientific statement from the American Heart Association. Circ Cardiovasc Qual Outcomes. 2009;119(17):2408-16. [pmid: 19364974].
45 Cook NR. Use and misuse of the receiver operating characteristic curve in risk prediction. Circ Cardiovasc Qual Outcomes. 2007;115(7):928-35. [pmid: 17309939].
46 Cook NR. Statistical evaluation of prognostic versus diagnostic models: beyond the ROC curve. Clin Chem. 2008;54(1):17-23. [pmid: 18024533].
47 Pencina MJ, D'Agostino RB Sr., Steyerberg EW. Extensions of net reclassification improvement calculations to measure usefulness of new biomarkers. Stat Med. 2011;30(1):11-21. [pmid: 21204120].
48 Grund B, Sabin C. Analysis of biomarker data: Logs, odds ratios, and receiver operating characteristic curves. Curr Opin HIV AIDS. 2010;5(6):473-9. [pmid: 20978390].
49 Pencina MJ, D'Agostino RB Sr., D'Agostino RB Jr., et al. Evaluating the added predictive ability of a new marker: From area under the ROC curve to reclassification and beyond. Stat Med. 2008;27(2):157-72. [pmid: 17569110].
50 Hlatky MAH. The year in epidemiology, health services research, and outcomes research. J Am Coll Cardiol. 2011;57(19):1859-66. [pmid: 21545941].
51 Vignon-Zellweger N, Relle K, Kienlen E, et al. Endothelin-1 overexpression restores diastolic function in eNOS knockout mice. J Hypertens. 2011;29(5):961-70. [pmid: 21451422].
52 Hosmer DW, Lemeshow S. Goodness of fit tests for the multiple logistic regression model. Commun Stat Theory Meth. 1980;9(10):1043-69.
53 Pfisterer M, Buser P, Rickli H, et al. BNP-guided vs symptom-guided heart failure therapy: the Trial of Intensified vs Standard Medical Therapy in Elderly Patients With Congestive Heart Failure (TIME-CHF) randomized trial. JAMA. 2009;301(4):383-92. [pmid: 19176440].
54 The Criteria Committee of the New York Heart Association. Nomenclature and Criteria for Diagnosis of Diseases of the Heart and Great Vessels. 9. Boston. Little, Brown and Co. 1994.
55 Levy WC, Mozaffarian D, Linker DT, et al. The Seattle Heart Failure Model: Prediction of survival in heart failure. Circ Cardiovasc Qual Outcomes. 2006;113(11):1424-33. [pmid: 16534009].
56 Kannel WB, D'Agostino RB, Silbershatz H, et al. Profile for estimating risk of heart failure. Arch Intern Med. 1999;159(11):1197-204. [pmid: 10371227].
57 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
58 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. 2006;144(6):427-37. [pmid: 16549855].
59 National Institute for Health and Clinical Excellence. The Guidelines Manual: Appendix J: Methodology checklist: Prognostic Studies. London. National Institute for Health and Clinical Excellence. 2009.
60 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
61 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: A generalized linear mixed model approach. J Clin Epidemiol. 2006;59(12):1331-2. [pmid: 17098577].
62 Van Houwelingen HC, Arends LR, Stijnen T. Advanced methods in meta-analysis: multivariate approach and meta-regression. Stat Med. 2002;21(4):589-624. [pmid: 11836738].
63 Van Houwelingen HC, Zwinderman KH, Stijnen T. A bivariate approach to meta-analysis. Stat Med. 1993;12(24):2273-84. [pmid: 7907813].
64 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58(10):982-90. [pmid: 16168343].
65 Deeks JJ, Macaskill P, Irwig L. The performance of tests of publication bias and other sample size effects in systematic reviews of diagnostic test accuracy was assessed. J Clin Epidemiol. 2005;58(9):882-93. [pmid: 16085191].
66 Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. Higgins JP, Green S. 2011. The Cochrane Collaboration.
67 Zamora J, Abraira V, Muriel A, et al. Meta-DiSc: A software for meta-analysis of test accuracy data. BMC Med Res Methodol. 2006;6:31. [pmid: 16836745].
68 Hanley JA, McNeil BJ. The meaning and use of the area under a receiver operating characteristic (ROC) curve. Radiology. 1982;143(1):29-36. [pmid: 7063747].
69 Macaskill P. Empirical Bayes estimates generated in a hierarchical summary ROC analysis agreed closely with those of a full Bayesian analysis. J Clin Epidemiol. 2004;57(9):925-32. [pmid: 15504635].
70 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Ann Intern Med. 2009;151(4):264-9. W64. [pmid: 19622511].
71 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate healthcare interventions: Explanation and elaboration. BMJ. 2009;339:b2700. [pmid: 19622552].
72 Barcarse E, Kazanegra R, Chen A, et al. Combination of B-type natriuretic peptide levels and non-invasive hemodynamic parameters in diagnosing congestive heart failure in the emergency department. Congest Heart Fail. 2004;10(4):171-6. [pmid: 15314474].
73 Maisel AS, Clopton P, Krishnaswamy P, et al. Impact of age, race, and sex on the ability of B-type natriuretic peptide to aid in the emergency diagnosis of heart failure: Results from the Breathing Not Properly (BNP) multinational study. Am Heart J. 2004;147(6):1078-84. [pmid: 15199359].
74 Knudsen CW, Riis JS, Finsen AV, et al. Diagnostic value of a rapid test for B-type natriuretic peptide in patients presenting with acute dyspnoe: Effect of age and gender. Eur J Heart Fail. 2004;6(1):55-62. [pmid: 15012919].
75 Knudsen CW, Omland T, Clopton P, et al. Diagnostic value of B-Type natriuretic peptide and chest radiographic findings in patients with acute dyspnea. Am J Med. 2004;116(6):363-8. [pmid: 15006584].
76 Maisel AS, McCord J, Nowak RM, et al. Bedside B-Type natriuretic peptide in the emergency diagnosis of heart failure with reduced or preserved ejection fraction. Results from the Breathing Not Properly Multinational Study. J Am Coll Cardiol. 2003;41(11):2010-7. [pmid: 12798574].
77 McCullough PA, Hollander JE, Nowak RM, et al. Uncovering heart failure in patients with a history of pulmonary disease: Rationale for the early use of B-type natriuretic peptide in the emergency department. Acad Emerg Med. 2003;10(3):198-204. [pmid: 12615582].
78 Villacorta H, Duarte A, Duarte NM, et al. The role of B-type natriuretic peptide in the diagnosis of congestive heart failure in patients presenting to an emergency department with dyspnea. Arq Bras Cardiol. 2002;79(6):569-72. [pmid: 12532240].
79 Logeart D, Saudubray C, Beyne P, et al. Comparative value of Doppler echocardiography and B-type natriuretic peptide assay in the etiologic diagnosis of acute dyspnea. J Am Coll Cardiol. 2002;40(10):1794-800. [pmid: 12446063].
80 McCullough PA, Nowak RM, McCord J, et al. B-type natriuretic peptide and clinical judgment in emergency diagnosis of heart failure: Analysis from Breathing Not Properly (BNP) Multinational Study. Circ Cardiovasc Qual Outcomes. 2002;106(4):416-22.
81 Maisel AS, Krishnaswamy P, Nowak RM, et al. Rapid measurement of B-type natriuretic peptide in the emergency diagnosis of heart failure. N Engl J Med. 2002;347(3):161-7. [pmid: 12124404].
82 Morrison LK, Harrison A, Krishnaswamy P, et al. Utility of a rapid B-natriuretic peptide assay in differentiating congestive heart failure from lung disease in patients presenting with dyspnea. J Am Coll Cardiol. 2002;39(2):202-9. [pmid: 11788208].
83 Dao Q, Krishnaswamy P, Kazanegra R, et al. Utility of B-type natriuretic peptide in the diagnosis of congestive heart failure in an urgent-care setting. J Am Coll Cardiol. 2001;37(2):379-85. [pmid: 11216950].
84 Wu AH, Omland T, Duc P, et al. The effect of diabetes on B-type natriuretic peptide concentrations in patients with acute dyspnea: An analysis from the Breathing Not Properly Multinational Study. Diabetes Care. 2004;27(10):2398-404. [pmid: 15451907].
85 Ray P, Arthaud M, Lefort Y, et al. Usefulness of B-type natriuretic peptide in elderly patients with acute dyspnea. Intensive Care Med. 2004;30(12):2230-6. [pmid: 15502931].
86 Choi S, Park D, Lee S, et al. Cut-off values of B-type natriuretic peptide for the diagnosis of congestive heart failure in patients with dyspnoea visiting emergency departments: A study on Korean patients visiting emergency departments. Emerg Med J. 2007;24(5):343-7. [pmid: 17452702].
87 Coste J, Jourdain P, Pouchot J. A gray zone assigned to inconclusive results of quantitative diagnostic tests: Application to the use of brain natriuretic peptide for diagnosis of heart failure in acute dyspneic patients. Clin Chem. 2006;52(12):2229-35. [pmid: 17053156].
88 Sanz MP, Borque L, Rus A, et al. Comparison of BNP and NT-proBNP assays in the approach to the emergency diagnosis of acute dyspnea. J Clin Lab Anal. 2006;20(6):227-32. [pmid: 17115420].
89 Chung T, Sindone A, Foo F, et al. Influence of history of heart failure on diagnostic performance and utility of B-type natriuretic peptide testing for acute dyspnea in the emergency department. Am Heart J. 2006;152(5):949-55. [pmid: 17070166].
90 Collins SP, Lindsell CJ, Peacock WF, et al. The combined utility of an S3 heart sound and B-type natriuretic peptide levels in emergency department patients with dyspnea. J Card Fail. 2006;12(4):286-92. [pmid: 16679262].
91 Daniels LB, Clopton P, Bhalla V, et al. How obesity affects the cut-points for B-type natriuretic peptide in the diagnosis of acute heart failure. Results from the Breathing Not Properly Multinational Study. Am Heart J. 2006;151(5):999-1005. [pmid: 16644321].
92 Knudsen CW, Omland T, Clopton P, et al. Impact of atrial fibrillation on the diagnostic performance of B-type natriuretic peptide concentration in dyspneic patients: An analysis from the breathing not properly multinational study. J Am Coll Cardiol. 2005;46(5):838-44. [pmid: 16139134].
93 Steg PG, Joubin L, McCord J, et al. B-type natriuretic peptide and echocardiographic determination of ejection fraction in the diagnosis of congestive heart failure in patients with acute dyspnea. Chest. 2005;128(1):21-9. [pmid: 16002911].
94 Arques S, Roux E, Sbragia P, et al. Usefulness of bedside tissue Doppler echocardiography and B-type natriuretic peptide (BNP) in differentiating congestive heart failure from noncardiac cause of acute dyspnea in elderly patients with a normal left ventricular ejection fraction and permanent, nonvalvular atrial fibrillation: Insights from a prospective, monocenter study. Echocardiograph. 2007;24(5):499-507.
95 Wang HK, Tsai MS, Chang JH, et al. Cardiac ultrasound helps for differentiating the causes of acute dyspnea with available B-type natriuretic peptide tests. Am J Emerg Med. 2010;28(9):987-93. [pmid: 20825928].
96 Boldanova T, Noveanu M, Breidthardt T, et al. Impact of history of heart failure on diagnostic and prognostic value of BNP: Results from the B-type Natriuretic Peptide for Acute Shortness of Breath Evaluation (BASEL) study. Int J Cardiol. 2010;142(3):265-72. [pmid: 19185372].
97 Lokuge A, Lam L, Cameron P, et al. B-type natriuretic peptide testing and the accuracy of heart failure diagnosis in the emergency department. Circulation. 2010;3(1):104-10. [pmid: 19933409].
98 Kevin RR, Stehlik J, Stoddard GJ, et al. Adjusting for clinical covariates improves the ability of B-type natriuretic peptide to distinguish cardiac from non-cardiac dyspnoea: A sub-study of HEARD-IT. Eur J Heart Fail. 2009;11(11):1043-9. [pmid: 19812054].
99 Pahle AS, Sorli D, Omland T, et al. Impact of systemic hypertension on the diagnostic performance of B-type natriuretic peptide in patients with acute dyspnea. Am J Cardiol. 2009;104(7):966-71. [pmid: 19766765].
100 Dieplinger B, Gegenhuber A, Haltmayer M, et al. Evaluation of novel biomarkers for the diagnosis of acute destabilised heart failure in patients with shortness of breath. Heart. 2009;95(18):1508-13. [pmid: 19525245].
101 Rogers RK, Stoddard GJ, Greene T, et al. Usefulness of adjusting for clinical covariates to improve the ability of B-type natriuretic peptide to distinguish cardiac from noncardiac dyspnea. Am J Cardiol. 2009;104(5):689-94. [pmid: 19699346].
102 Noveanu M, Breidthardt T, Cayir S, et al. B-type natriuretic peptide-guided management and outcome in patients with obesity and dyspnea--Results from the BASEL study. Am Heart J. 2009;158(3):488-95. [pmid: 19699875].
103 Gruson D, Thys F, Ketelslegers JM, et al. Multimarker panel in patients admitted to emergency department: a comparison with reference methods. Clin Biochem. 2009;42(3):185-8. [pmid: 18793629].
104 Parrinello G, Paterna S, Di Pasquale P, et al. The usefulness of bioelectrical impedance analysis in differentiating dyspnea due to decompensated heart failure. J Card Fail. 2008;14(8):676-86. [pmid: 18926440].
105 Havelka EG, Rzechula KH, Bryant TO, et al. Correlation between impedance cardiography and B-type natriuretic peptide levels in dyspneic patients. J Emerg Med. 2011;40(2):146-50. [pmid: 18790589].
106 Arenja N, Reichlin T, Drexler B, et al. Sensitive cardiac troponin in the diagnosis and risk stratification of acute heart failure. J Intern Med. 2012;271(6):598-607. [pmid: 21988283].
107 Ro R, Thode HC Jr., Taylor M, et al. Comparison of the diagnostic characteristics of two B-type natriuretic peptide point-of-care devices. J Emerg Med. 2011;41(6):661-7. [pmid: 21620610].
108 Lainchbury JG, Campbell E, Frampton CM, et al. Brain natriuretic peptide and n-terminal brain natriuretic peptide in the diagnosis of heart failure in patients with acute shortness of breath. J Am Coll Cardiol. 2003;42(4):728-35. [pmid: 12932611].
109 Chenevier-Gobeaux C, Claessens YE, Voyer S, et al. Influence of renal function on N-terminal pro-brain natriuretic peptide (NT-proBNP) in patients admitted for dyspnoea in the Emergency Department: Comparison with brain natriuretic peptide (BNP). Clin Chim Acta. 2005;361(1-2):167-75. [pmid: 15993397].
110 Mueller T, Gegenhuber A, Poelz W, et al. Diagnostic accuracy of B type natriuretic peptide and amino terminal proBNP in the emergency diagnosis of heart failure. Heart. 2005;91(5):606-12. [pmid: 15831643].
111 Ray P, Arthaud M, Birolleau S, et al. Comparison of brain natriuretic peptide and probrain natriuretic peptide in the diagnosis of cardiogenic pulmonary edema in patients aged 65 and older. J Am Geriatr Soc. 2005;53(4):643-8. [pmid: 15817011].
112 Alibay Y, Beauchet A, El Mahmoud R, et al. Plasma N-terminal pro-brain natriuretic peptide and brain natriuretic peptide in assessment of acute dyspnea. Biomed Pharmacother. 2005;59(1-2):20-4. [pmid: 15740931].
113 Gorissen C, Baumgarten R, De Groot M, et al. Analytical and clinical performance of three natriuretic peptide tests in the emergency room. Clin Chem Lab Med. 2007;45(5):678-84. [pmid: 17484634].
114 Chenevier-Gobeaux C, Guerin S, Andre S, et al. Midregional pro-atrial natriuretic peptide for the diagnosis of cardiac-related dyspnea according to renal function in the emergency department: A comparison with B-type natriuretic peptide (BNP) and N-terminal proBNP. Clin Chem. 2010;56(11):1708-17. [pmid: 20813917].
115 Potocki M, Breidthardt T, Reichlin T, et al. Comparison of midregional pro-atrial natriuretic peptide with N-terminal pro-B-type natriuretic peptide in the diagnosis of heart failure. J Intern Med. 2010;267(1):119-29. [pmid: 19570053].
116 Shah KB, Kop WJ, Christenson RH, et al. Natriuretic peptides and echocardiography in acute dyspnoea: Implication of elevated levels with normal systolic function. Eur J Heart Fail. 2009;11(7):659-67. [pmid: 19515720].
117 Shah KB, Kop WJ, Christenson RH, et al. Lack of diagnostic and prognostic utility of circulating plasma myeloperoxidase concentrations in patients presenting with dyspnea. Clin Chem. 2009;55(1):59-67. [pmid: 18988754].
118 Gruson D, Rousseau MF, Ahn S, et al. Accuracy of N-terminal-pro-atrial natriuretic peptide in patients admitted to emergency department. Scand J Clin Lab Invest. 2008;68(5):410-4. [pmid: 19172697].
119 Chenevier-Gobeaux C, Delerme S, Allo JC, et al. B-type natriuretic peptides for the diagnosis of congestive heart failure in dyspneic oldest-old patients. Clin Biochem. 2008;41(13):1049-54. [pmid: 18573245].
120 deFilippi CR, Seliger SL, Maynard S, et al. Impact of renal disease on natriuretic peptide testing for diagnosing decompensated heart failure and predicting mortality. Clin Chem. 2007;53(8):1511-9. [pmid: 17586595].
121 Gruson D, Ketelslegers JM, Verschuren F, et al. Head-to-head comparison of the prohormone proBNP1-108 with BNP and Nt-proBNP in patients admitted to emergency department. Clin Biochem. 2012;45(3):249-52. [pmid: 22209994].
122 Shaikh K, Ahmad M. Diagnostic significance of NT-proBNP estimation in patients with acute dyspnea. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan. 2011;21(10):584-8. [pmid: 22015116].
123 McKie PM, Burnett JC Jr. B-type natriuretic peptide as a biomarker beyond heart failure: Speculations and opportunities. Mayo Clin Proc. 2005;80(8):1029-36. [pmid: 16092582].
124 Bayes-Genis A, Santalo-Bel M, Zapico-Muniz E, et al. N-terminal probrain natriuretic peptide (NT-proBNP) in the emergency diagnosis and in-hospital monitoring of patients with dyspnoea and ventricular dysfunction. Eur J Heart Fail. 2004;6(3):301-8. [pmid: 14987580].
125 Moe GW, Howlett J, Januzzi JL, et al. N-terminal pro-B-type natriuretic peptide testing improves the management of patients with suspected acute heart failure: Primary results of the Canadian prospective randomized multicenter IMPROVE-CHF study. Circ Cardiovasc Qual Outcomes. 2007;115(24):3103-10.
126 Bayes-Genis A, Lloyd-Jones DM, van Kimmenade RR, et al. Effect of body mass index on diagnostic and prognostic usefulness of amino-terminal pro-brain natriuretic peptide in patients with acute dyspnea. Arch Intern Med. 2007;167(4):400-7. [pmid: 17325303].
127 Krauser DG, Chen AA, Tung R, et al. Neither race nor gender influences the usefulness of amino-terminal pro-brain natriuretic peptide testing in dyspneic subjects: A ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) substudy. J Card Fail. 2006;12(6):452-7. [pmid: 16911912].
128 Tung RH, Camargo CA Jr., Krauser D, et al. Amino-terminal pro-brain natriuretic peptide for the diagnosis of acute heart failure in patients with previous obstructive airway disease. Ann Emerg Med. 2006;48(1):66-74. [pmid: 16781921].
129 Berdague P, Caffin PY, Barazer I, et al. Use of N-terminal prohormone brain natriuretic peptide assay for etiologic diagnosis of acute dyspnea in elderly patients. Am Heart J. 2006;151(3):690-8. [pmid: 16504634].
130 Anwaruddin S, Lloyd-Jones DM, Baggish A, et al. Renal function, congestive heart failure, and amino-terminal pro-brain natriuretic peptide measurement: Results from the ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) Study. J Am Coll Cardiol. 2006;47(1):91-7. [pmid: 16386670].
131 Zaninotto M, Mion M, Altinier S, et al. NT-proBNP in the differential diagnosis of acute dyspnea in the emergency department. Clin Biochem. 2005;38(11):1041-4. [pmid: 16143322].
132 Sakhuja R, Chen AA, Anwaruddin S, et al. Combined use of amino terminal-pro-brain natriuretic peptide levels and QRS duration to predict left ventricular systolic dysfunction in patients with dyspnea. Am J Cardiol. 2005;96(2):263-6. [pmid: 16018854].
133 Januzzi JL Jr., Camargo CA, Anwaruddin S, et al. The N-terminal Pro-BNP investigation of dyspnea in the emergency department (PRIDE) study. Am J Cardiol. 2005;95(8):948-54. [pmid: 15820160].
134 Martinez-Rumayor AA, Vazquez J, Rehman SU, et al. Relative value of amino-terminal pro-B-type natriuretic peptide testing and radiographic standards for the diagnostic evaluation of heart failure in acutely dyspneic subjects. Biomarkers. 2010;15(2):175-82. [pmid: 19911943].
135 Nazerian P, Vanni S, Zanobetti M, et al. Diagnostic accuracy of emergency Doppler echocardiography for identification of acute left ventricular heart failure in patients with acute dyspnea: Comparison with Boston criteria and N-terminal prohormone brain natriuretic peptide. Acad Emerg Med. 2010;17(1):18-26. [pmid: 20078435].
136 Steinhart B, Thorpe KE, Bayoumi AM, et al. Improving the diagnosis of acute heart failure using a validated prediction model. J Am Coll Cardiol. 2009;54(16):1515-21. [pmid: 19815122].
137 Oh J, Kang SM, Hong N, et al. Relation between red cell distribution width with echocardiographic parameters in patients with acute heart failure. J Card Fail. 2009;15(6):517-22. [pmid: 19643363].
138 Liteplo AS, Marill KA, Villen T, et al. Emergency thoracic ultrasound in the differentiation of the etiology of shortness of breath (ETUDES): Sonographic B-lines and N-terminal pro-brain-type natriuretic peptide in diagnosing congestive heart failure. Acad Emerg Med. 2009;16(3):201-10. [pmid: 19183402].
139 Green SM, Martinez-Rumayor A, Gregory SA, et al. Clinical uncertainty, diagnostic accuracy, and outcomes in emergency department patients presenting with dyspnea. Arch Intern Med. 2008;168(7):741-8. [pmid: 18413557].
140 O'Donoghue M, Kenney P, Oestreicher E, et al. Usefulness of aminoterminal pro-brain natriuretic peptide testing for the diagnostic and prognostic evaluation of dyspneic patients with diabetes mellitus seen in the emergency department (from the PRIDE Study). Am J Cardiol. 2007;100(9):1336-40. [pmid: 17950786].
141 Robaei D, Koe L, Bais R, et al. Effect of NT-proBNP testing on diagnostic certainty in patients admitted to the emergency department with possible heart failure. Ann Clin Biochem. 2011;48(Pt 3):212-7. [pmid: 21398433].
142 Behnes M, Hoffmann U, Lang S, et al. Transforming growth factor beta 1 (TGF-beta 1) in atrial fibrillation and acute congestive heart failure. Clin Res Cardiol. 2011;100(4):335-42. [pmid: 21069358].
143 Prosen G, Klemen P, Štrnad M, et al. Combination of lung ultrasound (a comet-tail sign) and N-terminal pro-brain natriuretic peptide in differentiating acute heart failure from chronic obstructive pulmonary disease and asthma as cause of acute dyspnea in prehospital emergency setting. Crit Care. 2011;15(2):R114. [pmid: 21492424].
144 Suttner S, Lang K, Piper SN, et al. Continuous intra- and postoperative thoracic epidural analgesia attenuates brain natriuretic peptide release after major abdominal surgery. Anesth Analg. 101(3):896-903. [pmid: 16116011].
145 Blatt A, Svirski R, Morawsky G, et al. Short and long-term outcome of pregnant women with preexisting dilated cardiomypathy: An NTproBNP and echocardiography-guided study. Isr Med Assoc J. 2010;12(10):613-6. [pmid: 21090518].
146 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: A tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
147 Provan S, Angel K, Semb AG, et al. NT-proBNP predicts mortality in patients with rheumatoid arthritis: results from 10-year follow-up of the EURIDISS study. Ann Rheum Dis. 2010;69(11):1946-50. [pmid: 20525846].
148 Aspromonte N, Feola M, Scardovi AB, et al. Early diagnosis of congestive heart failure: Clinical utility of B-type natriuretic peptide testing associated with Doppler echocardiography. J Cardiovasc Med. 2006;7(6):406-13.
149 Arques S, Roux E, Sbragia P, et al. Accuracy of tissue Doppler echocardiography in the emergency diagnosis of decompensated heart failure with preserved left ventricular systolic function: Comparison with B-type natriuretic peptide measurement. Echocardiograph. 2005;22(8):657-64.
150 Jeyaseelan S, Goudie BM, Pringle SD, et al. A critical re-appraisal of different ways of selecting ambulatory patients with suspected heart failure for echocardiography. Eur J Heart Fail. 2007;9(1):55-61. [pmid: 16859991].
151 Mak G, Ryder M, Murphy NF, et al. Diagnosis of new onset heart failure in the community: The importance of a shared-care approach and judicious use of BNP. Ir J Med Sci. 2008;177(3):197-203. [pmid: 18633669].
152 Macabasco-O'Connell A, Meymandi S, Bryg R. B-type Natriuretic Peptide (BNP) is useful in detecting asymptomatic left ventricular dysfunction in low-income, uninsured patients. Biol Res Nurs. 2010;11(3):280-7. [pmid: 19934109].
153 Barrios V, Llisterri JL, Escobar C, et al. Clinical applicability of B-type natriuretic peptide in patients with suspected heart failure in primary care in Spain: The PANAMA study. Expert Rev Cardiovasc Ther. 2011;9(5):579-85. [pmid: 21615321].
154 Kelder JC, Cramer MJ, Verweij WM, et al. Clinical utility of three B-type natriuretic peptide assays for the initial diagnostic assessment of new slow-onset heart failure. J Card Fail. 2011;17(9):729-34. [pmid: 21872142].
155 Murtagh G, Dawkins IR, O'Connell R, et al. Screening to prevent heart failure (STOP-HF): Expanding the focus beyond asymptomatic left ventricular systolic dysfunction. Eur J Heart Fail. 2012;14(5):480-6. [pmid: 22416086].
156 Fuat A, Murphy JJ, Hungin AP, et al. The diagnostic accuracy and utility of a B-type natriuretic peptide test in a community population of patients with suspected heart failure. Br J Gen Pract. 2006;56(526):327-33. [pmid: 16638247].
157 Zaphiriou A, Robb S, Murray-Thomas T, et al. The diagnostic accuracy of plasma BNP and NTproBNP in patients referred from primary care with suspected heart failure: Results of the UK natriuretic peptide study. Eur J Heart Fail. 2005;7(4):537-41. [pmid: 15921792].
158 Park HJ, Baek SH, Jang SW, et al. Direct comparison of B-type natriuretic peptide and N-terminal pro-BNP for assessment of cardiac function in a large population of symptomatic patients. Int J Cardiol. 2010;140(3):336-43. [pmid: 19147239].
159 Christenson RH, Azzazy HM, Duh SH, et al. Impact of increased body mass index on accuracy of B-type natriuretic peptide (BNP) and N-terminal proBNP for diagnosis of decompensated heart failure and prediction of all-cause mortality. Clin Chem. 2010;56(4):633-41. [pmid: 20167699].
160 Margato R, Carvalho S, Ribeiro H, et al. Cardiac troponin I levels in acute pulmonary embolism. Rev Port Cardiol. 2009;28(11):1213-22. [pmid: 20222345].
161 Hobbs FD, Davis RC, Roalfe AK, et al. Reliability of N-terminal proBNP assay in diagnosis of left ventricular systolic dysfunction within representative and high risk populations. Heart. 2004;90(8):866-70. [pmid: 15253955].
162 Nielsen LS, Svanegaard J, Klitgaard NA, et al. N-terminal pro-brain natriuretic peptide for discriminating between cardiac and non-cardiac dyspnoea. Eur J Heart Fail. 2004;6(1):63-70. [pmid: 15012920].
163 Gustafsson F, Badskjaer J, Hansen FS, et al. Value of N-terminal proBNP in the diagnosis of left ventricular systolic dysfunction in primary care patients referred for echocardiography. Heart Drug. 2003;3(3):141-6.
164 Lim TK, Dwivedi G, Hayat S, et al. Cost effectiveness of the B type natriuretic peptide, electrocardiography, and portable echocardiography for the assessment of patients from the community with suspected heart failure. Echocardiograph. 2007;24(3):228-36.
165 Shelton RJ, Clark AL, Goode K, et al. The diagnostic utility of N-terminal pro-B-type natriuretic peptide for the detection of major structural heart disease in patients with atrial fibrillation. Eur Heart J. 2006;27(19):2353-61. [pmid: 16952921].
166 Mikkelsen KV, Bie P, Moller JE, et al. Neurohormonal activation and diagnostic value of cardiac peptides in patients with suspected mild heart failure. Int J Cardiol. 2006;110(3):324-33. [pmid: 16213609].
167 Sivakumar R, Wellsted D, Parker K, et al. Utility of N terminal pro brain natriuretic peptide in elderly patients. Postgrad Med J. 2006;82(965):220-3. [pmid: 16517806].
168 Gustafsson F, Steensgaard-Hansen F, Badskjaer J, et al. Diagnostic and prognostic performance of N-terminal ProBNP in primary care patients with suspected heart failure. J Card Fail. 2005;11(5 Suppl):S15-20. [pmid: 15948095].
169 Valle R, Aspromonte N, Barro S, et al. The NT-proBNP assay identifies very elderly nursing home residents suffering from pre-clinical heart failure. Eur J Heart Fail. 2005;7(4):542-51. [pmid: 15921793].
170 Olofsson M, Boman K. Usefulness of natriuretic peptides in primary health care: An exploratory study in elderly patients. Scand J Prim Health Care. 2010;28(1):29-35. [pmid: 20192890].
171 Goode KM, Clark AL, Cleland JG. Ruling out heart failure in primary-care: The cost-benefit of pre-screening using NT-proBNP and QRS width. Int J Cardiol. 2008;130(3):426-37. [pmid: 18178273].
172 Koschack J, Scherer M, Luers C, et al. Natriuretic peptide vs. clinical information for diagnosis of left ventricular systolic dysfunction in primary care. BMC Fam Pract. 2008;9:14. [pmid: 18298821].
173 Goode KM, Clark AL, Bristow JA, et al. Screening for left ventricular systolic dysfunction in high-risk patients in primary-care: A cost-benefit analysis. Eur J Heart Fail. 2007;9(12):1186-95. [pmid: 18006378].
174 Stahrenberg R, Edelmann F, Mende M, et al. The novel biomarker growth differentiation factor 15 in heart failure with normal ejection fraction. Eur J Heart Fail. 2010;12(12):1309-16. [pmid: 20837635].
175 Kelder JC, Cramer MJ, van WJ, et al. The diagnostic value of physical examination and additional testing in primary care patients with suspected heart failure. Circulation. 2011;124(25):2865-73. [pmid: 22104551].
176 Maisel A, Hollander JE, Guss D, et al. Primary results of the Rapid Emergency Department Heart Failure Outpatient Trial (REDHOT). A multicenter study of B-type natriuretic peptide levels, emergency department decision making, and outcomes in patients presenting with shortness of breath. J Am Coll Cardiol. 2004;44(6):1328-33. [pmid: 15364340].
177 Logeart D, Thabut G, Jourdain P, et al. Predischarge B-type natriuretic peptide assay for identifying patients at high risk of re-admission after decompensated heart failure. J Am Coll Cardiol. 2004;43(4):635-41. [pmid: 14975475].
178 Aspromonte N, Feola M, Milli M, et al. Prognostic role of B-type natriuretic peptide in patients with diabetes and acute decompensated heart failure. Diabet Med. 2007;24(2):124-30. [pmid: 17257273].
179 Stoiser B, Mortl D, Hulsmann M, et al. Copeptin, a fragment of the vasopressin precursor, as a novel predictor of outcome in heart failure. Eur J Clin Invest. 2006;36(11):771-8. [pmid: 17032344].
180 Cournot M, Leprince P, Destrac S, et al. Usefulness of in-hospital change in B-type natriuretic peptide levels in predicting long-term outcome in elderly patients admitted for decompensated heart failure. Am J Geriatr Cardiol. 2007;16(1):8-14. [pmid: 17215637].
181 Sun T, Wang L, Zhang Y. Prognostic value of B-type natriuretic peptide in patients with chronic and advanced heart failure. Intern Med J. 2007;37(3):168-71. [pmid: 17316335].
182 Gegenhuber A, Struck J, Dieplinger B, et al. Comparative evaluation of B-type natriuretic peptide, mid-regional pro-A-type natriuretic peptide, mid-regional pro-adrenomedullin, and Copeptin to predict 1-year mortality in patients with acute destabilized heart failure. J Card Fail. 2007;13(1):42-9. [pmid: 17339002].
183 Kellett J. Prediction of mortality of patients with suspected heart failure by brain natriuretic peptide concentrations > 100 pg/ml: Comparison of a clinical model with brain natriuretic peptide concentrations. Heart. 2006;92(10):1512-3. [pmid: 16973805].
184 Valle R, Aspromonte N, Feola M, et al. B-type natriuretic peptide can predict the medium-term risk in patients with acute heart failure and preserved systolic function. J Card Fail. 2005;11(7):498-503. [pmid: 16198244].
185 Dokainish H, Zoghbi WA, Lakkis NM, et al. Incremental predictive power of B-type natriuretic peptide and tissue Doppler echocardiography in the prognosis of patients with congestive heart failure. J Am Coll Cardiol. 2005;45(8):1223-6. [pmid: 15837253].
186 Di Somma S, Magrini L, Pittoni V, et al. In-hospital percentage BNP reduction is highly predictive for adverse events in patients admitted for acute heart failure: The Italian RED Study. Crit Care. 2010;14(3):R116. [pmid: 20550660].
187 Zairis MN, Tsiaousis GZ, Georgilas AT, et al. Multimarker strategy for the prediction of 31 days cardiac death in patients with acutely decompensated chronic heart failure. Int J Cardiol. 2010;141(3):284-90. [pmid: 19157603].
188 Reichlin T, Socrates T, Egli P, et al. Use of myeloperoxidase for risk stratification in acute heart failure. Clin Chem. 2010;56(6):944-51. [pmid: 20413430].
189 Nahum J, Bensaid A, Dussault C, et al. Impact of longitudinal myocardial deformation on the prognosis of chronic heart failure patients. Circulation. 2010;3(3):249-56. [pmid: 20233858].
190 Faggiano P, Valle R, Aspromonte N, et al. How often we need to measure brain natriuretic peptide (BNP) blood levels in patients admitted to the hospital for acute severe heart failure? Role of serial measurements to improve short-term prognostic stratification. Int J Cardiol. 2010;140(1):88-94. [pmid: 19321212].
191 Farmakis D, Parissis JT, Bistola V, et al. Plasma B-type natriuretic peptide reduction predicts long-term response to levosimendan therapy in acutely decompensated chronic heart failure. Int J Cardiol. 2010;139(1):75-9. [pmid: 18973957].
192 Neuhold S, Huelsmann M, Strunk G, et al. Prognostic value of emerging neurohormones in chronic heart failure during optimization of heart failure-specific therapy. Clin Chem. 2010;56(1):121-6. [pmid: 19884490].
193 Dunlay SM, Gerber Y, Weston SA, et al. Prognostic value of biomarkers in heart failure: Application of novel methods in the community. Circulation. 2009;2(5):393-400. [pmid: 19808368].
194 Singer AJ, Birkhahn RH, Guss D, et al. Rapid Emergency Department Heart Failure Outpatients Trial (REDHOT II): A randomized controlled trial of the effect of serial B-type natriuretic peptide testing on patient management. Circulation. 2009;2(4):287-93. [pmid: 19808351].
195 Parissis JT, Farmakis D, Nikolaou M, et al. Plasma B-type natriuretic peptide and anti-inflammatory cytokine interleukin-10 levels predict adverse clinical outcome in chronic heart failure patients with depressive symptoms: A 1-year follow-up study. Eur J Heart Fail. 2009;11(10):967-72. [pmid: 19789400].
196 Cohen-Solal A, Logeart D, Huang B, et al. Lowered B-type natriuretic peptide in response to levosimendan or dobutamine treatment is associated with improved survival in patients with severe acutely decompensated heart failure. J Am Coll Cardiol. 2009;53(25):2343-8. [pmid: 19539144].
197 Dhaliwal AS, Deswal A, Pritchett A, et al. Reduction in BNP levels with treatment of decompensated heart failure and future clinical events. J Card Fail. 2009;15(4):293-9. [pmid: 19398076].
198 Nunez J, Nunez E, Robles R, et al. Prognostic value of brain natriuretic peptide in acute heart failure: Mortality and hospital readmission. Rev Esp Cardiol. 2008;61(12):1332-7. [pmid: 19080974].
199 Feola M, Aspromonte N, Milani L, et al. Plasma brain natriuretic peptide predicts short-term clinical outcome in heart failure patients with restrictive filling pattern. J Card Fail. 2008;14(5):420-5. [pmid: 18514935].
200 Cournot M, Mourre F, Castel F, et al. Optimization of the use of B-type natriuretic peptide levels for risk stratification at discharge in elderly patients with decompensated heart failure. Am Heart J. 2008;155(6):986-91. [pmid: 18513508].
201 Valle R, Aspromonte N, Carbonieri E, et al. Fall in readmission rate for heart failure after implementation of B-type natriuretic peptide testing for discharge decision: A retrospective study. Int J Cardiol. 2008;126(3):400-6. [pmid: 17804095].
202 Parissis JT, Nikolaou M, Farmakis D, et al. Clinical and prognostic implications of self-rating depression scales and plasma B-type natriuretic peptide in hospitalised patients with chronic heart failure. Heart. 2008;94(5):585-9. [pmid: 17761502].
203 Valle R, Aspromonte N, Giovinazzo P, et al. B-type natriuretic Peptide-guided treatment for predicting outcome in patients hospitalized in sub-intensive care unit with acute heart failure. J Card Fail. 2008;14(3):219-24. [pmid: 18381185].
204 Dieplinger B, Gegenhuber A, Poelz W, et al. Prognostic value of increased adiponectin plasma concentrations in patients with acute destabilized heart failure. Clin Biochem. 2009;42(10-11):1190-3. [pmid: 19272369].
205 Nunez J, Sanchis J, Bodi V, et al. Improvement in risk stratification with the combination of the tumour marker antigen carbohydrate 125 and brain natriuretic peptide in patients with acute heart failure. Eur Heart J. 2010;31(14):1752-63. [pmid: 20501480].
206 Pimenta J, Paulo C, Mascarenhas J, et al. BNP at discharge in acute heart failure patients: Is it all about volemia? A study using impedance cardiography to assess fluid and hemodynamic status. Int J Cardiol. 2010;145(2):209-14. [pmid: 19729213].
207 Xue Y, Clopton P, Peacock WF, et al. Serial changes in high-sensitive troponin I predict outcome in patients with decompensated heart failure. Eur J Heart Fail. 2011;13(1):37-42. [pmid: 21149316].
208 Rychli K, Richter B, Hohensinner PJ, et al. Hepatocyte growth factor is a strong predictor of mortality in patients with advanced heart failure. Heart. 2011;97(14):1158-63. [pmid: 21572126].
209 Arques S, Roux. Usefulness of serum albumin and serum total cholesterol in the prediction of hospital death in older patients with severe, acute heart failure. Arch Cardiovasc Dis. 2011;104(10):502-8. [pmid: 22044702].
210 Allen LA, Gheorghiade M, Reid KJ, et al. Identifying patients hospitalized with heart failure at risk for unfavorable future quality of life. Circ Cardiovasc Qual Outcomes. 2011;4(4):389-98. [pmid: 21693723].
211 Coyne JCJ. Lack of prognostic value of type D personality for mortality in a large sample of heart failure patients. Psychosom Med. 2011;73(7):557-62. [pmid: 21862826].
212 Maisel AS, Mueller C, Fitzgerald R, et al. Prognostic utility of plasma neutrophil gelatinase-associated lipocalin in patients with acute heart failure: The NGAL EvaLuation Along with B-type NaTriuretic Peptide in acutely decompensated heart failure (GALLANT) trial. Eur J Heart Fail. 2011;13(8):846-51. [pmid: 21791540].
213 Sakhuja R, Green S, Oestreicher EM, et al. Amino-terminal pro-brain natriuretic peptide, brain natriuretic peptide, and troponin T for prediction of mortality in acute heart failure. Clin Chem. 2007;53(3):412-20. [pmid: 17259237].
214 Boisot S, Beede J, Isakson S, et al. Serial sampling of ST2 predicts 90-day mortality following destabilized heart failure. J Card Fail. 2008;14(9):732-8. [pmid: 18995177].
215 Noveanu M, Breidthardt T, Potocki M, et al. Direct comparison of serial B-type natriuretic peptide and NT-proBNP levels for prediction of short- and long-term outcome in acute decompensated heart failure. Crit Care. 2011;15(1):R1. [pmid: 21208408].
216 Rehman SU, Mueller T, Januzzi J. Characteristics of the novel interleukin family biomarker ST2 in patients with acute heart failure. J Am Coll Cardiol. 2008;52(18):1458-65. [pmid: 19017513].
217 Peacock WF, Nowak R, Christenson R, et al. Short-term mortality risk in emergency department acute heart failure. Acad Emerg Med. 2011;18(9):947-58. [pmid: 21906204].
218 Law KK, Yau WH, Ho HF. Short term prognostic value of the rapid b-type natriuretic peptide assay on length of hospitalisation in congestive heart failure patients presenting to an emergency department in hong kong: A prospective observational study. Hong Kong J Emerg Med. 2010;17(5):451-63.
219 Cantinotti M, Storti S, Parri MS, et al. Reference intervals for brain natriuretic peptide in healthy newborns and infants measured with an automated immunoassay platform. Clin Chem Lab Med. 2010;48(5):697-700. [pmid: 20187851].
220 Ovadia M, Duque KS. The potential utility of 123I-mIBG in atrial fibrillation and in the electrophysiology laboratory. Curr Cardiol Rep. 2012;14(2):200-7. [pmid: 22350693].
221 deSimone G, Chinali M, Mureddu GF, et al. Effect of canrenone on left ventricular mechanics in patients with mild systolic heart failure and metabolic syndrome: The AREA-in-CHF study. Nutr Metab Cardiovasc Dis. 2011;21(10):783-91. [pmid: 21939839].
222 Vrtovec B, Okrajsek R, Golicnik A, et al. Atorvastatin therapy may reduce the incidence of sudden cardiac death in patients with advanced chronic heart failure. J Card Fail. 2008;14(2):140-4. [pmid: 18325461].
223 Nazeri A, Massumi A, Rasekh A, et al. Cardiac resynchronization therapy in patients with right ventricular pacing-induced cardiomyopathy. Pacing Clin Electrophysiol. 2010;33(1):37-40. [pmid: 19821931].
224 Bettencourt P, Azevedo A, Pimenta J, et al. N-terminal-pro-brain natriuretic peptide predicts outcome after hospital discharge in heart failure patients. Circ Cardiovasc Qual Outcomes. 2004;110(15):2168-74.
225 Baggish AL, van Kimmenade R, Bayes-Genis A, et al. Hemoglobin and N-terminal pro-brain natriuretic peptide: Independent and synergistic predictors of mortality in patients with acute heart failure results from the International Collaborative of NT-proBNP (ICON) Study. Clin Chim Acta. 2007;381(2):145-50. [pmid: 17445789].
226 Bettencourt P, Azevedo A, Fonseca L, et al. Prognosis of decompensated heart failure patients with preserved systolic function is predicted by NT-proBNP variations during hospitalization. Int J Cardiol. 2007;117(1):75-9. [pmid: 16843555].
227 Perna ER, Macin SM, Cimbaro Canella JP, et al. Importance of early combined N-terminal pro-brain natriuretic peptide and cardiac troponin T measurements for long-term risk stratification of patients with decompensated heart failure. J Heart Lung Transplant. 2006;25(10):1230-40. [pmid: 17045936].
228 van Kimmenade RR, Januzzi JL Jr., Baggish AL, et al. Amino-terminal pro-brain natriuretic Peptide, renal function, and outcomes in acute heart failure: Redefining the cardiorenal interaction?. J Am Coll Cardiol. 2006;48(8):1621-7. [pmid: 17045898].
229 Marcucci R, Gori AM, Giannotti F, et al. Markers of hypercoagulability and inflammation predict mortality in patients with heart failure. J Thromb Haemostasis. 2006;4(5):1017-22. [pmid: 16689753].
230 Bayes-Genis A, Lopez L, Zapico E, et al. NT-ProBNP reduction percentage during admission for acutely decompensated heart failure predicts long-term cardiovascular mortality. J Card Fail. 2005;11(5 Suppl):S3-8. [pmid: 15948093].
231 Bayes-Genis A, Pascual-Figal D, Fabregat J, et al. Serial NT-proBNP monitoring and outcomes in outpatients with decompensation of heart failure. Int J Cardiol. 2007;120(3):338-43. [pmid: 17174423].
232 Ferreira SAMP, Almeida R, Guerrero H, et al. Prognosis of decompensated heart failure: Role of NT-proBNP. Rev Port Cardiol. 2007;26(5):535-45. [pmid: 17691279].
233 Pimenta JM, Almeida R, Araujo JP, et al. Amino terminal B-type natriuretic peptide, renal function, and prognosis in acute heart failure: A Hospital Cohort Study. J Card Fail. 2007;13(4):275-80. [pmid: 17517347].
234 Siswanto BB, Sunanto, Munawar M, et al. Predictor of mortality and rehospitalization of acute decompensated heart failure at six months follow up. Critical Care & Shock. 2006;9(3):61-7.
235 Park HS, Kim H, Sohn JH, et al. Combination of uric acid and NT-ProBNP: A more useful prognostic marker for short-term clinical outcomes in patients with acute heart failure. Korean Journal of Internal Medicine. 2010;25(3):253-9. [pmid: 20830221].
236 Davutoglu V, Yildirim C, Kucukaslan H, et al. Prognostic value of pleural effusion, CA-125 and NT-proBNP in patients with acute decompensated heart failure. Kardiol Pol. 2010;68(7):771-8. [pmid: 20648434].
237 Dini FL, Buralli S, Bajraktari G, et al. Plasma matrix metalloproteinase-9 better predicts outcome than N-terminal protype-B natriuretic peptide in patients with systolic heart failure and a high prevalence of coronary artery disease. Biomed Pharmacother. 2010;64(5):339-42. [pmid: 19944559].
238 Mohammed AA, van Kimmenade RR, Richards M, et al. Hyponatremia, natriuretic peptides, and outcomes in acutely decompensated heart failure: Results from the International Collaborative of NT-proBNP Study. Circulation. 2010;3(3):354-61. [pmid: 20332419].
239 Baggish AL, van Kimmenade RR, Pinto Y, et al. New York Heart Association class versus amino-terminal pro-B type natriuretic peptide for acute heart failure prognosis. Biomarkers. 2010;15(4):307-14. [pmid: 20370326].
240 Lourenco P, Azevedo A, Araujo JP, et al. Natriuretic peptide system is not exhausted in severe heart failure. J Cardiovasc Med. 2009;10(1):39-43. [pmid: 19708225].
241 Manzano-Fernandez S, Boronat-Garcia M, Albaladejo-Oton MD, et al. Complementary prognostic value of cystatin C, N-terminal pro-B-type natriuretic Peptide and cardiac troponin T in patients with acute heart failure. Am J Cardiol. 2009;103(12):1753-9. [pmid: 19539088].
242 Kubler P, Jankowska EA, Majda J, et al. Lack of decrease in plasma N-terminal pro-brain natriuretic peptide identifies acute heart failure patients with very poor outcome. Int J Cardiol. 2008;129(3):373-8. [pmid: 18054808].
243 Paul B, Soon KH, Dunne J, et al. Diagnostic and prognostic significance of plasma N-terminal-pro-brain natriuretic peptide in decompensated heart failure with preserved ejection fraction. Heart Lung Circ. 2008;17(6):497-501. [pmid: 18722158].
244 Verdiani V, Ognibene A, Rutili MS, et al. NT-ProBNP reduction percentage during hospital stay predicts long-term mortality and readmission in heart failure patients. J Cardiovasc Med. 2008;9(7):694-9. [pmid: 18545069].
245 Andersson SE, Edvinsson ML, Bjork J, et al. High NT-proBNP is a strong predictor of outcome in elderly heart failure patients. Am J Geriatr Cardiol. 2008;17(1):13-20. [pmid: 18174755].
246 Petretta M, Scopacasa F, Fontanella L, et al. Prognostic value of reduced kidney function and anemia in patients with chronic heart failure. J Cardiovasc Med. 2007;8(11):909-16. [pmid: 17906476].
247 Metra M, Nodari S, Parrinello G, et al. The role of plasma biomarkers in acute heart failure. Serial changes and independent prognostic value of NT-proBNP and cardiac troponin-T. Eur J Heart Fail. 2007;9(8):776-86. [pmid: 17573240].
248 Lassus J, Harjola VP, Sund R, et al. Prognostic value of cystatin C in acute heart failure in relation to other markers of renal function and NT-proBNP. Eur Heart J. 2007;28(15):1841-7. [pmid: 17289743].
249 Luers C, Schmidt A, Wachter R, et al. Serial NT-proBNP measurements for risk stratification of patients with decompensated heart failure. Herz. 2010;35(7):488-96. [pmid: 20927502].
250 Carrasco-Sanchez FJ, Galisteo-Almeda L, Paez-Rubio I, et al. Prognostic value of cystatin C on admission in heart failure with preserved ejection fraction. J Card Fail. 2011;17(1):31-8. [pmid: 21187262].
251 Pascual-Figal DA, Manzano-Fernandez S, Boronat M, et al. Soluble ST2, high-sensitivity troponin T- and N-terminal pro-B-type natriuretic peptide: complementary role for risk stratification in acutely decompensated heart failure. Eur J Heart Fail. 2011;13(7):718-25. [pmid: 21551163].
252 Ho SJ, Feng AN, Lee LN, et al. Predictive value of predischarge spectral tissue doppler echocardiography and n-terminal pro-B-type natriuretic peptide in patients hospitalized with acute heart failure. Echocardiograph. 2011;28(3):303-10.
253 Michtalik HJ, Yeh HC, Campbell CY, et al. Acute changes in N-terminal pro-B-type natriuretic peptide during hospitalization and risk of readmission and mortality in patients with heart failure. Am J Cardiol. 2011;107(8):1191-5. [pmid: 21296322].
254 Korewicki J, Leszek P, Zielinski T, et al. Severe chronic heart failure in patients considered for heart transplantation in Poland. Cardiol J. 2012;19(1):36-44. [pmid: 22298166].
255 Krackhardt F, Dungen HD, Trippel TD, et al. N-terminal pro-B-type natriuretic peptide and long-term mortality in non-ischaemic cardiomyopathy. Wiener Klinische Wochenschrift. 2011;123(23-24):738-42. [pmid: 22105112].
256 Harutyunyan M, Christiansen M, Johansen JS, et al. The inflammatory biomarker YKL-40 as a new prognostic marker for all-cause mortality in patients with heart failure. Immunobiology. 2012;217(6):652-6. [pmid: 22209156].
257 Yan RT, Fernandes V, Yan AT, et al. Fibrinogen and left ventricular myocardial systolic function: The Multi-Ethnic Study of Atherosclerosis (MESA). Am Heart J. 2010;160(3):479-86. [pmid: 20826256].
258 Lim TK, Hayat SA, Gaze D, et al. Independent value of echocardiography and N-terminal pro-natriuretic Peptide for the prediction of major outcomes in patients with suspected heart failure. Am J Cardiol. 2007;100(5):870-5. [pmid: 17719336].
259 Rodeheffer RJ. Measuring plasma B-type natriuretic peptide in heart failure: Good to go in 2004?. J Am Coll Cardiol. 2004;44(4):740-9. [pmid: 15312852].
260 Jarolim P. Serum biomarkers for heart failure. Cardiovasc Pathol. 2006;15(3):144-9. [pmid: 16697927].
261 Vrtovec B, Delgado R, Zewail A, et al. Prolonged QTc interval and high B-type natriuretic peptide levels together predict mortality in patients with advanced heart failure. Circ Cardiovasc Qual Outcomes. 2003;107(13):1764-9.
262 Horwich TB, Hamilton MA, Fonarow GC. B-type natriuretic peptide levels in obese patients with advanced heart failure. J Am Coll Cardiol. 2006;47(1):85-90. [pmid: 16386669].
263 Ralli S, Horwich TB, Fonarow GC. Relationship between anemia, cardiac troponin I, and B-type natriuretic peptide levels and mortality in patients with advanced heart failure. Am Heart J. 2005;150(6):1220-7. [pmid: 16338262].
264 Meyer B, Mortl D, Strecker K, et al. Flow-mediated vasodilation predicts outcome in patients with chronic heart failure: Comparison with B-type natriuretic peptide. J Am Coll Cardiol. 2005;46(6):1011-8. [pmid: 16168284].
265 Kruger S, Graf J, Merx MW, et al. The value of cardiopulmonary exercise testing and brain natriuretic peptide plasma levels in predicting the prognosis of patients with chronic heart failure. European Journal of Internal Medicine. 2006;17(2):96-101. [pmid: 16490685].
266 Kozdag G, Ertas G, Kilic T, et al. Triiodothyronine and brain natriuretic peptide: Similar long-term prognostic values for chronic heart failure. Tex Heart Inst J. 2010;37(5):538-46. [pmid: 20978564].
267 Dries DL, Ky B, Wu AH, et al. Simultaneous assessment of unprocessed ProBNP1-108 in addition to processed BNP32 improves identification of high-risk ambulatory patients with heart failure. Circulation. 2010;3(2):220-7. [pmid: 20107190].
268 Boffa GM, Zaninotto M, Sartor R, et al. Interleukin-6 and tumor necrosis factor-alpha as biochemical markers of heart failure: A head-to-head clinical comparison with B-type natriuretic peptide. J Cardiovasc Med. 2009;10(10):758-64. [pmid: 19553828].
269 Adlbrecht C, Hulsmann M, Strunk G, et al. Prognostic value of plasma midregional pro-adrenomedullin and C-terminal-pro-endothelin-1 in chronic heart failure outpatients. Eur J Heart Fail. 2009;11(4):361-6. [pmid: 19190023].
270 Scardovi AB, De Maria R, Celestini A, et al. Prognostic value of brain natriuretic peptide and enhanced ventilatory response to exercise in patients with chronic heart failure. Intern Emerg Med. 2008;3(4):331-7. [pmid: 18560771].
271 Neuhold S, Huelsmann M, Strunk G, et al. Comparison of copeptin, B-type natriuretic peptide, and amino-terminal pro-B-type natriuretic peptide in patients with chronic heart failure: Prediction of death at different stages of the disease. J Am Coll Cardiol. 2008;52(4):266-72. [pmid: 18634981].
272 Popescu BA, Popescu AC, Antonini-Canterin F, et al. Prognostic role of left atrial volume in elderly patients with symptomatic stable chronic heart failure: Comparison with left ventricular diastolic dysfunction and B-type natriuretic peptide. Echocardiograph. 2007;24(10):1035-43. [pmid: 18001356].
273 Scardovi AB, De Maria R, Coletta C, et al. Multiparametric risk stratification in patients with mild to moderate chronic heart failure. J Card Fail. 2007;13(6):445-51. [pmid: 17675058].
274 Bermingham MO. Are beta2-agonists responsible for increased mortality in heart failure?. Eur J Heart Fail. 2011;13(8):885-91. [pmid: 21791542].
275 Moertl D, Berger R, Struck J, et al. Comparison of midregional pro-atrial and B-type natriuretic peptides in chronic heart failure: Influencing factors, detection of left ventricular systolic dysfunction, and prediction of death. J Am Coll Cardiol. 2009;53(19):1783-90. [pmid: 19422985].
276 Rothenburger M, Wichter T, Schmid C, et al. Aminoterminal pro type B natriuretic peptide as a predictive and prognostic marker in patients with chronic heart failure. J Heart Lung Transplant. 2004;23(10):1189-97. [pmid: 15477114].
277 Gardner RS, Ozalp F, Murday AJ, et al. N-terminal pro-brain natriuretic peptide. A new gold standard in predicting mortality in patients with advanced heart failure. Eur Heart J. 2003;24(19):1735-43. [pmid: 14522568].
278 Gardner RS, Chong V, Morton I, et al. N-terminal brain natriuretic peptide is a more powerful predictor of mortality than endothelin-1, adrenomedullin and tumour necrosis factor-alpha in patients referred for consideration of cardiac transplantation. Eur J Heart Fail. 2005;7(2):253-60. [pmid: 15701475].
279 Hartmann F, Packer M, Coats AJ, et al. Prognostic impact of plasma N-terminal pro-brain natriuretic peptide in severe chronic congestive heart failure: A substudy of the Carvedilol Prospective Randomized Cumulative Survival (COPERNICUS) trial. Circ Cardiovasc Qual Outcomes. 2004;110(13):1780-6.
280 Corell P, Gustafsson F, Kistorp C, et al. Effect of atrial fibrillation on plasma NT-proBNP in chronic heart failure. Int J Cardiol. 2007;117(3):395-402. [pmid: 16919342].
281 Schou M, Gustafsson F, Corell P, et al. The relationship between N-terminal pro-brain natriuretic peptide and risk for hospitalization and mortality is curvilinear in patients with chronic heart failure. Am Heart J. 2007;154(1):123-9. [pmid: 17584564].
282 Guder G, Bauersachs J, Frantz S, et al. Complementary and incremental mortality risk prediction by cortisol and aldosterone in chronic heart failure. Circulation. 2007;115(13):1754-61. [pmid: 17372171].
283 Mikkelsen KV, Moller JE, Bie P, et al. Tei index and neurohormonal activation in patients with incident heart failure: Serial changes and prognostic value. Eur J Heart Fail. 2006;8(6):599-608. [pmid: 16469536].
284 Jankowska EA, Biel B, Majda J, et al. Anabolic deficiency in men with chronic heart failure: Prevalence and detrimental impact on survival. Circ Cardiovasc Qual Outcomes. 2006;114(17):1829-37.
285 Bruch C, Reinecke H, Stypmann J, et al. N-terminal pro-brain natriuretic peptide, kidney disease and outcome in patients with chronic heart failure. J Heart Lung Transplant. 2006;25(9):1135-41. [pmid: 16962477].
286 Masson S, Latini R, Anand IS, et al. Direct comparison of B-type natriuretic peptide (BNP) and amino-terminal proBNP in a large population of patients with chronic and symptomatic heart failure: The Valsartan Heart Failure (Val-HeFT) data. Clin Chem. 2006;52(8):1528-38. [pmid: 16777915].
287 Bruch C, Rothenburger M, Gotzmann M, et al. Risk stratification in chronic heart failure: Independent and incremental prognostic value of echocardiography and brain natriuretic peptide and its N-terminal fragment. J Am Soc Echocardiogr. 2006;19(5):522-8. [pmid: 16644435].
288 Kistorp C, Faber J, Galatius S, et al. Plasma adiponectin, body mass index, and mortality in patients with chronic heart failure. Circ Cardiovasc Qual Outcomes. 2005;112(12):1756-62.
289 George J, Patal S, Wexler D, et al. Circulating matrix metalloproteinase-2 but not matrix metalloproteinase-3, matrix metalloproteinase-9, or tissue inhibitor of metalloproteinase-1 predicts outcome in patients with congestive heart failure. Am Heart J. 2005;150(3):484-7. [pmid: 16169329].
290 George J, Patal S, Wexler D, et al. Circulating erythropoietin levels and prognosis in patients with congestive heart failure: Comparison with neurohormonal and inflammatory markers. Arch Intern Med. 2005;165(11):1304-9. [pmid: 15956012].
291 Gardner RS, Chong KS, Morton JJ, et al. N-terminal brain natriuretic peptide, but not anemia, is a powerful predictor of mortality in advanced heart failure. J Card Fail. 2005;11(5 Suppl):S47-53. [pmid: 15948101].
292 Gardner RS, Henderson G, McDonagh TA. The prognostic use of right heart catheterization data in patients with advanced heart failure: How relevant are invasive procedures in the risk stratification of advanced heart failure in the era of neurohormones?. J Heart Lung Transplant. 2005;24(3):303-9. [pmid: 15737757].
293 Sherwood A, Blumenthal JA, Trivedi R, et al. Relationship of depression to death or hospitalization in patients with heart failure. Arch Intern Med. 2007;167(4):367-73. [pmid: 17325298].
294 Jankowska EA, Drohomirecka A, Ponikowska B, et al. Deficiencies in circulating testosterone and dehydroepiandrosterone sulphate, and depression in men with systolic chronic heart failure. Eur J Heart Fail. 2010;12(9):966-73. [pmid: 20595194].
295 Codognotto M, Piccoli A, Zaninotto M, et al. Effect of a dialysis session on the prognostic values of NT-proBNP, troponins, endothelial damage and inflammation biomarkers. J Nephrol. 2010;23(4):465-71. [pmid: 20540041].
296 Dini FL, Gabutti A, Passino C, et al. Atrial fibrillation and amino-terminal pro-brain natriuretic peptide as independent predictors of prognosis in systolic heart failure. Int J Cardiol. 2010;140(3):344-50. [pmid: 19128846].
297 Tsutamoto T, Kawahara C, Nishiyama K, et al. Prognostic role of highly sensitive cardiac troponin I in patients with systolic heart failure. Am Heart J. 2010;159(1):63-7. [pmid: 20102868].
298 Nishiyama K, Tsutamoto T, Yamaji M, et al. Dose-dependent prognostic effect of carvedilol in patients with chronic heart failure--special reference to transcardiac gradient of norepinephrine. Circ J. 2009;73(12):2270-5. [pmid: 19838002].
299 Al Najjar Y, Goode KM, Zhang J, et al. Red cell distribution width: an inexpensive and powerful prognostic marker in heart failure. Eur J Heart Fail. 2009;11(12):1155-62. [pmid: 19926599].
300 Frankenstein L, Zugck C, Nelles M, et al. The obesity paradox in stable chronic heart failure does not persist after matching for indicators of disease severity and confounders. Eur J Heart Fail. 2009;11(12):1189-94. [pmid: 19887494].
301 Cleland JG, McMurray JJ, Kjekshus J, et al. Plasma concentration of amino-terminal pro-brain natriuretic peptide in chronic heart failure: Prediction of cardiovascular events and interaction with the effects of rosuvastatin: A report from CORONA (Controlled Rosuvastatin Multinational Trial in Heart Failure). J Am Coll Cardiol. 2009;54(20):1850-9. [pmid: 19892235].
302 Charach G, George J, Afek A, et al. Antibodies to oxidized LDL as predictors of morbidity and mortality in patients with chronic heart failure. J Card Fail. 2009;15(9):770-4. [pmid: 19879463].
303 Zielinski T, Browarek A, Zembala M, et al. Risk stratification of patients with severe heart failure awaiting heart transplantation-Prospective national registry POLKARD HF. Transplant Proc. 2009;41(8):3161-5. [pmid: 19857702].
304 Poletti R, Passino C, Giannoni A, et al. Risk factors and prognostic value of daytime Cheyne-Stokes respiration in chronic heart failure patients. Int J Cardiol. 2009;137(1):47-53. [pmid: 18691782].
305 Epelman S, Shrestha K, Troughton RW, et al. Soluble angiotensin-converting enzyme 2 in human heart failure: Relation with myocardial function and clinical outcomes. J Card Fail. 2009;15(7):565-71. [pmid: 19700132].
306 Dini FL, Fontanive P, Buralli S, et al. N-terminal protype-B natriuretic peptide and Doppler diastolic variables are incremental for risk stratification of patients with NYHA class I-II systolic heart failure. Int J Cardiol. 2009;136(2):144-50. [pmid: 18649955].
307 Frankenstein L, Clark AL, Goode K, et al. The prognostic value of individual NT-proBNP values in chronic heart failure does not change with advancing age. Heart. 2009;95(10):825-9. [pmid: 19147626].
308 Kubanek M, Goode KM, Lanska V, et al. The prognostic value of repeated measurement of N-terminal pro-B-type natriuretic peptide in patients with chronic heart failure due to left ventricular systolic dysfunction. Eur J Heart Fail. 2009;11(4):367-77. [pmid: 19179406].
309 Wedel H, McMurray JJ, Lindberg M, et al. Predictors of fatal and non-fatal outcomes in the Controlled Rosuvastatin Multinational Trial in Heart Failure (CORONA): Incremental value of apolipoprotein A-1, high-sensitivity C-reactive peptide and N-terminal pro B-type natriuretic peptide. Eur J Heart Fail. 2009;11(3):281-91. [pmid: 19168876].
310 Koc M, Bozkurt A, Yildiray-Sahin D, et al. Cutoff values of NT-proBNP for the prediction of low functional capacity, decreased ejection fraction and cardiovascular events in patients with heart failure. Cardiol J. 2009;16(1):43-9. [pmid: 19130415].
311 Michowitz Y, Kisil S, Guzner-Gur H, et al. Usefulness of serum myeloperoxidase in prediction of mortality in patients with severe heart failure. Isr Med Assoc J. 2008;10(12):884-8. [pmid: 19160948].
312 Honold J, Geiger L, Assmus B, et al. The initial slope of the VCO2/VO2-curve (s1) in cardiopulmonary exercise testing is a strong and independent predictor of outcome in patients with previous myocardial infarction. Clin Res Cardiol. 2008;97(12):882-90. [pmid: 18696021].
313 Tsutamoto T, Nishiyama K, Sakai H, et al. Transcardiac increase in norepinephrine and prognosis in patients with chronic heart failure. Eur J Heart Fail. 2008;10(12):1208-14. [pmid: 18977693].
314 Hinderliter AL, Blumenthal JA, O'Conner C, et al. Independent prognostic value of echocardiography and N-terminal pro-B-type natriuretic peptide in patients with heart failure. Am Heart J. 2008;156(6):1191-5. [pmid: 19033018].
315 Frankenstein L, Remppis A, Nelles M, et al. Relation of N-terminal pro-brain natriuretic peptide levels and their prognostic power in chronic stable heart failure to obesity status. Eur Heart J. 2008;29(21):2634-40. [pmid: 18765456].
316 Kallistratos MS, Dritsas A, Laoutaris ID, et al. Incremental value of N-terminal pro-brain natriuretic peptide over left ventricle ejection fraction and aerobic capacity for estimating prognosis in heart failure patients. J Heart Lung Transplant. 2008;27(11):1251-6. [pmid: 18971099].
317 Masson S, Latini R, Anand IS, et al. Prognostic value of changes in N-terminal pro-brain natriuretic peptide in Val-HeFT (Valsartan Heart Failure Trial). J Am Coll Cardiol. 2008;52(12):997-1003. [pmid: 18786480].
318 Grewal J, McKelvie RS, Persson H, et al. Usefulness of N-terminal pro-brain natriuretic peptide and brain natriuretic peptide to predict cardiovascular outcomes in patients with heart failure and preserved left ventricular ejection fraction. Am J Cardiol. 2008;102(6):733-7. [pmid: 18773998].
319 Bruch C, Fischer C, Sindermann J, et al. Comparison of the prognostic usefulness of N-terminal pro-brain natriuretic peptide in patients with heart failure with versus without chronic kidney disease. Am J Cardiol. 2008;102(4):469-74. [pmid: 18678308].
320 Dini FL, Fontanive P, Panicucci E, et al. Prognostic significance of tricuspid annular motion and plasma NT-proBNP in patients with heart failure and moderate-to-severe functional mitral regurgitation. Eur J Heart Fail. 2008;10(6):573-80. [pmid: 18457990].
321 Amir O, Paz H, Ammar R, et al. Usefulness and predictive value of circulating NT-proBNP levels to stratify patients for referral and priority treatment in a specialized outpatient heart failure center. Isr Med Assoc J. 2008;10(2):109-12. [pmid: 18432021].
322 Pascual-Figal DA, Domingo M, Casas T, et al. Usefulness of clinical and NT-proBNP monitoring for prognostic guidance in destabilized heart failure outpatients. Eur Heart J. 2008;29(8):1011-8. [pmid: 18263871].
323 Moertl D, Hammer A, Huelsmann M, et al. Prognostic value of sequential measurements of amino-terminal prohormone of B-type natriuretic peptide in ambulatory heart failure patients. Eur J Heart Fail. 2008;10(4):404-11. [pmid: 18358775].
324 Koc M, Bozkurt A, Acarturk E, et al. Usefulness of N-terminal pro-B-type natriuretic peptide increase with exercise for predicting cardiovascular mortality in patients with heart failure. Am J Cardiol. 2008;101(8):1157-62. [pmid: 18394451].
325 Pfister R, Diedrichs H, Schiedermair A, et al. Prognostic impact of NT-proBNP and renal function in comparison to contemporary multi-marker risk scores in heart failure patients. Eur J Heart Fail. 2008;10(3):315-20. [pmid: 18304872].
326 Gardner RS, Chong KS, O'Meara E, et al. Renal dysfunction, as measured by the modification of diet in renal disease equations, and outcome in patients with advanced heart failure. Eur Heart J. 2007;28(24):3027-33. [pmid: 17967819].
327 Tsutamoto T, Sakai H, Nishiyama K, et al. Direct comparison of transcardiac increase in brain natriuretic peptide (BNP) and N-terminal proBNP and prognosis in patients with chronic heart failure. Circ J. 2007;71(12):1873-8. [pmid: 18037739].
328 von Haehling S, Jankowska EA, Morgenthaler NG, et al. Comparison of midregional pro-atrial natriuretic peptide with N-terminal pro-B-type natriuretic peptide in predicting survival in patients with chronic heart failure. J Am Coll Cardiol. 2007;50(20):1973-80. [pmid: 17996563].
329 Schou M, Gustafsson F, Kistorp CN, et al. Prognostic usefulness of anemia and N-terminal pro-brain natriuretic peptide in outpatients with systolic heart failure. Am J Cardiol. 2007;100(10):1571-6. [pmid: 17996522].
330 Frankenstein L, Nelles M, Slavutsky M, et al. Beta-blockers influence the short-term and long-term prognostic information of natriuretic peptides and catecholamines in chronic heart failure independent from specific agents. J Heart Lung Transplant. 2007;26(10):1033-9. [pmid: 17919624].
331 Kempf T, von Haehling S, Peter T, et al. Prognostic utility of growth differentiation factor-15 in patients with chronic heart failure. J Am Coll Cardiol. 2007;50(11):1054-60. [pmid: 17825714].
332 Michowitz Y, Goldstein E, Wexler D, et al. Circulating endothelial progenitor cells and clinical outcome in patients with congestive heart failure. Heart. 2007;93(9):1046-50. [pmid: 17277352].
333 Bayes-Genis A, Vazquez R, Puig T, et al. Left atrial enlargement and NT-proBNP as predictors of sudden cardiac death in patients with heart failure. Eur J Heart Fail. 2007;9(8):802-7. [pmid: 17569580].
334 Yin WH, Chen JW, Feng AN, et al. Multimarker approach to risk stratification among patients with advanced chronic heart failure. Clin Cardiol. 2007;30(8):397-402. [pmid: 17680620].
335 Petretta M, Colao A, Sardu C, et al. NT-proBNP, IGF-I and survival in patients with chronic heart failure. Growth Hormone IGF Res. 2007;17(4):288-96. [pmid: 17383209].
336 Tsutamoto T, Tanaka T, Sakai H, et al. Total and high molecular weight adiponectin, haemodynamics, and mortality in patients with chronic heart failure. Eur Heart J. 2007;28(14):1723-30. [pmid: 17507366].
337 MacGowan GA, Neely D, Peaston R, et al. Evaluation of NT-proBNP to predict outcomes in advanced heart failure. INT J CLIN PRACT. 2010;64(7):892-9. [pmid: 20584222].
338 Song EK, Moser DK, Frazier SK, et al. Depressive symptoms affect the relationship of N-terminal pro B-type natriuretic peptide to cardiac event-free survival in patients with heart failure. J Card Fail. 2010;16(7):572-8. [pmid: 20610233].
339 Jankowska EA, Rozentryt P, Witkowska A, et al. Iron deficiency: An ominous sign in patients with systolic chronic heart failure. Eur Heart J. 2010;31(15):1872-80. [pmid: 20570952].
340 Jankowska EA, Filippatos GS, von Haehling S, et al. Identification of chronic heart failure patients with a high 12-month mortality risk using biomarkers including plasma C-terminal pro-endothelin-1. PLoS ONE. 2011;6(1):e14506. [pmid: 21264211].
341 Tang WH, Shrestha K, Troughton RW, et al. Integrating plasma high-sensitivity C-reactive protein and myeloperoxidase for risk prediction in chronic systolic heart failure. Congest Heart Fail. 2011;17(3):105-9. [pmid: 21609382].
342 Schierbeck LL, Jensen TS, Bang U, et al. Parathyroid hormone and vitamin D--Markers for cardiovascular and all cause mortality in heart failure. Eur J Heart Fail. 2011;13(6):626-32. [pmid: 21415099].
343 Raposeiras-Roubin S, Rodino-Janeiro BK, Grigorian-Shamagian L, et al. Relation of soluble receptor for advanced glycation end products to predict mortality in patients with chronic heart failure independently of Seattle Heart Failure Score. Am J Cardiol. 2011;107(6):938-44. [pmid: 21247530].
344 von Haehling S, Filippatos GS, Papassotiriou J, et al. Mid-regional pro-adrenomedullin as a novel predictor of mortality in patients with chronic heart failure. Eur J Heart Fail. 2010;12(5):484-91. [pmid: 20215339].
345 Van Den Broek KC, deFilippi CR, Christenson RH, et al. Predictive value of depressive symptoms and B-type natriuretic peptide for new-onset heart failure and mortality. Am J Cardiol. 2011;107(5):723-9. [pmid: 21316507].
346 Kawahara CT. Prognostic value of serial measurements of highly sensitive cardiac troponin i in stable outpatients with nonischemic chronic heart failure. Am Heart J. 2011;162(4):639-45. [pmid: 21982655].
347 Pfister RM-E. NT-pro-BNP predicts worsening renal function in patients with chronic systolic heart failure. Intern Med J. 2011;41(6):467-72. [pmid: 20214692].
348 Frankenstein L, Goode K, Ingle L, et al. Derivation and validation of a simple clinical risk-model in heart failure based on 6 minute walk test performance and NT-proBNP status - Do we need specificity for sex and beta-blockers?. Int J Cardiol. 2011;147(1):74-8. [pmid: 19765836].
349 Bajraktari GD. Independent and incremental prognostic value of Doppler-derived left ventricular total isovolumic time in patients with systolic heart failure. Int J Cardiol. 2011;148(3):271-5. [pmid: 19948365].
350 Carlsen CM, Bay M, Kirk V, et al. Prevalence and prognosis of heart failure with preserved ejection fraction and elevated N-terminal pro brain natriuretic peptide: A 10-year analysis from the Copenhagen Hospital Heart Failure Study. Eur J Heart Fail. 2012;14(3):240-7. [pmid: 22315457].
351 Broch K, Ueland T, Nymo SH, et al. Soluble ST2 is associated with adverse outcome in patients with heart failure of ischaemic aetiology. Eur J Heart Fail. 2012;14(3):268-77. [pmid: 22302661].
352 Tziakas DN, Chalikias GK, Stakos D, et al. Independent and additive prognostic ability of serum carboxy-terminal telopeptide of collagen type-I in heart failure patients: A multi-marker approach with high-negative predictive value to rule out long-term adverse events. European Journal of Preventive Cardiology. 2012;19(1):62-71. [pmid: 20479644].
353 Bayes-Genis A, de Antonio M, Galan A, et al. Combined use of high-sensitivity ST2 and NTproBNP to improve the prediction of death in heart failure. Eur J Heart Fail. 2012;14(1):32-8. [pmid: 22179033].
354 Franke J, Frankenstein L, Schellberg D, et al. Is there an additional benefit of serial NT-proBNP measurements in patients with stable chronic heart failure receiving individually optimized therapy?. Clin Res Cardiol. 2011;100(12):1059-67. [pmid: 21779816].
355 Jungbauer CG, Riedlinger J, Buchner S, et al. High-sensitive troponin T in chronic heart failure correlates with severity of symptoms, left ventricular dysfunction and prognosis independently from N-terminal pro-b-type natriuretic peptide. Clin Chem Lab Med. 2011;49(11):1899-906. [pmid: 21892905].
356 Anand IS, Rector TS, Cleland JG, et al. Prognostic value of baseline plasma amino-terminal pro-brain natriuretic peptide and its interactions with irbesartan treatment effects in patients with heart failure and preserved ejection fraction: Findings from the I-PRESERVE trial. Circulation. 2011;4(5):569-77. [pmid: 21715583].
357 de Antonio M, Lupon J, Galan A, et al. Combined use of high-sensitivity cardiac troponin T and N-terminal pro-B type natriuretic peptide improves measurements of performance over established mortality risk factors in chronic heart failure. Am Heart J. 2012;163(5):821-8. [pmid: 22607860].
358 Balling L, Kistorp C, Schou M, et al. Plasma copeptin levels and prediction of outcome in heart failure outpatients: Relation to hyponatremia and loop diuretic doses. J Card Fail. 2012;18(5):351-8. [pmid: 22555263].
359 Al-Najjar Y, Witte KK, Clark AL. Chronotropic incompetence and survival in chronic heart failure. Int J Cardiol. 2012;157(1):48-52. [pmid: 21185094].
360 Christensen HM, Frystyk J, Faber J, et al. alpha-Defensins and outcome in patients with chronic heart failure. Eur J Heart Fail. 2012;14(4):387-94. [pmid: 22357441].
361 Iversen K, Vejlstrup NG, Sondergaard L, et al. Screening of adults with congenital cardiac disease lost for follow-up. Cardiol Young. 2007;17(6):601-8. [pmid: 17956655].
362 Vazquez R, Bayes-Genis A, Cygankiewicz I, et al. The MUSIC Risk score: A simple method for predicting mortality in ambulatory patients with chronic heart failure. Eur Heart J. 2009;30(9):1088-96. [pmid: 19240065].
363 Rector TS, Cohn JN. Assessment of patient outcome with the Minnesota Living with Heart Failure questionnaire: Reliability and validity during a randomized, double-blind, placebo-controlled trial of pimobendan. Pimobendan Multicenter Research Group. Am Heart J. 1992;124(4):1017-25. [pmid: 1529875].
364 El Saed A, Voigt A, Shalaby A. Usefulness of brain natriuretic peptide level at implant in predicting mortality in patients with advanced but stable heart failure receiving cardiac resynchronization therapy. Clin Cardiol. 2009;32(11):E33-8. [pmid: 19816874].
365 Leibowitz D, Planer D, Rott D, et al. Brain natriuretic peptide levels predict perioperative events in cardiac patients undergoing noncardiac surgery: A prospective study. Cardiol. 2008;110(4):266-70. [pmid: 18073483].
366 Lellouche N, De Diego C, Cesario DA, et al. Usefulness of preimplantation B-type natriuretic peptide level for predicting response to cardiac resynchronization therapy. Am J Cardiol. 2007;99(2):242-6. [pmid: 17223426].
367 Glick A, Michowitz Y, Keren G, et al. Neurohormonal and inflammatory markers as predictors of short-term outcome in patients with heart failure and cardiac resynchronization therapy. Isr Med Assoc J. 2006;8(6):391-5. [pmid: 16833167].
368 Pitzalis MV, Iacoviello M, Di Serio F, et al. Prognostic value of brain natriuretic peptide in the management of patients receiving cardiac resynchronization therapy. Eur J Heart Fail. 2006;8(5):509-14. [pmid: 16503416].
369 Koch M, Haastert B, Kohnle M, et al. Peritoneal dialysis relieves clinical symptoms and is well tolerated in patients with refractory heart failure and chronic kidney disease. Eur J Heart Fail. 2012;14(5):530-9. [pmid: 22447950].
370 Assmus B, Fischer-Rasokat U, Honold J, et al. Transcoronary transplantation of functionally competent BMCs is associated with a decrease in natriuretic peptide serum levels and improved survival of patients with chronic postinfarction heart failure: Results of the TOPCARE-CHD Registry. Circ Res. 2007;100(8):1234-41. [pmid: 17379833].
371 Berger R, Shankar A, Fruhwald F, et al. Relationships between cardiac resynchronization therapy and N-terminal pro-brain natriuretic peptide in patients with heart failure and markers of cardiac dyssynchrony: An analysis from the Cardiac Resynchronization in Heart Failure (CARE-HF) study. Eur Heart J. 2009;30(17):2109-16. [pmid: 19493864].
372 Cleland J, Freemantle N, Ghio S, et al. Predicting the long-term effects of cardiac resynchronization therapy on mortality from baseline variables and the early response a report from the CARE-HF (Cardiac Resynchronization in Heart Failure) Trial. J Am Coll Cardiol. 2008;52(6):438-45. [pmid: 18672164].
373 Dini FL, Conti U, Fontanive P, et al. Prognostic value of N-terminal pro-type-B natriuretic peptide and Doppler left ventricular diastolic variables in patients with chronic systolic heart failure stabilized by therapy. Am J Cardiol. 2008;102(4):463-8. [pmid: 18678307].
374 Dini FL, Guglin M, Simioniuc A, et al. Association of furosemide dose with clinical status, left ventricular dysfunction, natriuretic peptides, and outcome in clinically stable patients with chronic systolic heart failure. Congest Heart Fail. 2012;18(2):98-106. [pmid: 22432556].
375 Foley PW, Stegemann B, Ng K, et al. Growth differentiation factor-15 predicts mortality and morbidity after cardiac resynchronization therapy. Eur Heart J. 2009;30(22):2749-57. [pmid: 19666898].
376 Dini FL, Rosa GM, Fontanive P, et al. Combining blood flow and tissue Doppler imaging with N-terminal pro-type B natriuretic peptide for risk stratification of clinically stable patients with systolic heart failure. Eur J Echocardiogr. 2010;11(4):333-40. [pmid: 20051423].
377 Smith JG, Newton-Cheh C, Almgren P, et al. Assessment of conventional cardiovascular risk factors and multiple biomarkers for the prediction of incident heart failure and atrial fibrillation. J Am Coll Cardiol. 2010;56(21):1712-9. [pmid: 21070922].
378 Vaes B, de Ruijter W, Degryse J, et al. Clinical relevance of a raised plasma N-terminal pro-brain natriuretic peptide level in a population-based cohort of nonagenarians. J Am Geriatr Soc. 2009;57(5):823-9. [pmid: 19470010].
379 Daniels LB, Laughlin GA, Clopton P, et al. Minimally elevated cardiac troponin T and elevated N-terminal pro-B-type natriuretic peptide predict mortality in older adults: Results from the Rancho Bernardo Study. J Am Coll Cardiol. 2008;52(6):450-9. [pmid: 18672166].
380 Zethelius B, Berglund L, Sundstrom J, et al. Use of multiple biomarkers to improve the prediction of death from cardiovascular causes. N Engl J Med. 2008;358(20):2107-16. [pmid: 18480203].
381 Olsen MH, Hansen TW, Christensen MK, et al. N-terminal pro-brain natriuretic peptide, but not high sensitivity C-reactive protein, improves cardiovascular risk prediction in the general population. Eur Heart J. 2007;28(11):1374-81. [pmid: 17242007].
382 Patton KK, Sotoodehnia N, deFilippi C, et al. N-terminal pro-B-type natriuretic peptide is associated with sudden cardiac death risk: The Cardiovascular Health Study. Heart Rhythm. 2011;8(2):228-33. [pmid: 21044699].
383 Chisalita SI, Dahlstrom U, Arnqvist HJ, et al. Increased IGF1 levels in relation to heart failure and cardiovascular mortality in an elderly population: Impact of ACE inhibitors. EUR. 2011;165(6):891-8. [pmid: 21976623].
384 Beck-da-Silva L, de Bold A, Fraser M, et al. BNP-guided therapy not better than expert's clinical assessment for beta-blocker titration in patients with heart failure. Congest Heart Fail. 2005;11(5):248-53. [pmid: 16230866].
385 Eurlings LWM, Van Pol PEJ, Kok WE, et al. Management of chronic heart failure guided by individual N-terminal ProB-type natriuretic peptide targets: Results of the PRIMA (Can PRo-brain-natriuretic peptide guided therapy of chronic heart failure IMprove heart fAilure morbidity and mortality?) Study. J Am Coll Cardiol. 2010;56(25):2090-100. [pmid: 21144969].
386 Januzzi JLJ, Rehman SU, Mohammed AA, et al. Use of amino-terminal ProB-type natri uretic peptide to guide outpatient therapy of patients with chronic left ventricular systolic dysfunction. J Am Coll Cardiol. 2011;58(18):1881-9. [pmid: 22018299].
387 Shah MR, Califf RM, Nohria A, et al. The STARBRITE trial: A randomized, pilot study of B-type natriuretic peptide-guided therapy in patients with advanced heart failure. J Card Fail. 2011;17(8):613-21. [pmid: 21807321].
388 Jourdain P, Jondeau G, Funck F, et al. Plasma brain natriuretic peptide-guided therapy to improve outcome in heart failure: The STARS-BNP Multicenter Study. J Am Coll Cardiol. 2007;49(16):1733-9. [pmid: 17448376].
389 Karlström P, Alehagen U, Boman K, et al. Brain natriuretic peptide-guided treatment does not improve morbidity and mortality in extensively treated patients with chronic heart failure: Responders to treatment have a significantly better outcome. Eur J Heart Fail. 2011;13(10):1096-103. [pmid: 21715446].
390 Westhoff-Bleck M, Girke S, Breymann T, et al. Pulmonary valve replacement in chronic pulmonary regurgitation in adults with congenital heart disease: Impact of preoperative QRS-duration and NT-proBNP levels on postoperative right ventricular function. Int J Cardiol. 2011;151(3):303-6. [pmid: 20598759].
391 Janda S, Swiston J. Diagnostic accuracy of pleural fluid NT-pro-BNP for pleural effusions of cardiac origin: A systematic review and meta-analysis. BMC Pulm Med. 2010;10. 2010. Article Number: 58. Date of Publication: 20 Nov 2010.
392 Suzuki T, Zaima C, Moriki Y, et al. P-glycoprotein mediates brain-to-blood efflux transport of buprenorphine across the blood-brain barrier. J Drug Target. 2007;15(1):67-74. [pmid: 17365275].
393 Collier P, Watson CJ, Voon V, et al. Can emerging biomarkers of myocardial remodelling identify asymptomatic hypertensive patients at risk for diastolic dysfunction and diastolic heart failure?. Eur J Heart Fail. 2011;13(10):1087-95. [pmid: 21719449].
394 Bruins S, Fokkema MR, Romer JW, et al. High intraindividual variation of B-type natriuretic peptide (BNP) and amino-terminal proBNP in patients with stable chronic heart failure. Clin Chem. 2004;50(11):2052-8. [pmid: 15345664].
395 Frankenstein L, Remppis A, Frankenstein J, et al. Variability of N-terminal probrain natriuretic peptide in stable chronic heart failure and its relation to changes in clinical variables. Clin Chem. 2009;55(5):923-9. [pmid: 19299545].
396 O'Hanlon R, O'Shea P, Ledwidge M, et al. The biologic variability of B-type natriuretic peptide and N-terminal pro-B-type natriuretic peptide in stable heart failure patients. J Card Fail. 2007;13(1):50-5. [pmid: 17339003].
397 Wu AH, Smith A, Wieczorek S, et al. Biological variation for N-terminal pro- and B-type natriuretic peptides and implications for therapeutic monitoring of patients with congestive heart failure. Am J Cardiol. 2003;92(5):628-31. [pmid: 12943894].
398 Melzi dG, Tagnochetti T, Nauti A, et al. Biological variation of N-terminal pro-brain natriuretic peptide in healthy individuals. Clin Chem. 2003;49(9):1554-5. [pmid: 12928248].
399 Voortman A, Melse-Boonstra A, Schulz JM, et al. Optimal time interval between repeated blood sampling for measurements of total homocysteine in healthy individuals. Clin Chem. 2001;47(10):1839-41. [pmid: 11568095].
400 Bentzen H, Pedersen RS, Nyvad O, et al. Influence of training habits on exercise-induced changes in plasma atrial and brain natriuretic peptide and urinary excretion of aquaporin-2 in healthy man. Scand J Clin Lab Invest. 2002;62(7):541-51. [pmid: 12512745].
401 Chang AM, Maisel AS, Hollander JE. Diagnosis of Heart Failure. Heart Fail Clin. 2009;5(1):25-35. [pmid: 19026383].
402 Mant J, Doust J, Roalfe A, et al. Systematic review and individual patient data meta-analysis of diagnosis of heart failure, with modelling of implications of different diagnostic strategies in primary care. HEALTH TECHNOL ASSESS. 2009;13(32):1-232. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010345063&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2408&accno=2010345063. [pmid: 19586584].
403 Hildebrandt P, Collinson PO, Doughty RN, et al. Age-dependent values of N-terminal pro-B-type natriuretic peptide are superior to a single cut-point for ruling out suspected systolic dysfunction in primary care. Eur Heart J. 2010;31(15):1881-9. [pmid: 20519241].
404 Hall C. NT-ProBNP: The mechanism behind the marker. J Card Fail. 2005;11(5:Suppl):S81-S83. [pmid: 15948107].
405 Charles CJ, Espiner EA, Richards AM. Cardiovascular actions of ANF: Contributions of renal, neurohumoral, and hemodynamic factors in sheep. Am J Physiol. 1993;264(3 Pt 2):R533-8. [pmid: 8096125].
406 Mastandrea P. Some heterogeneity factors affecting the B-type natriuretic peptides outcome: A meta-analysis. Clin Chem Lab Med. 2008;46(12):1687-95. [pmid: 18973463].
407 Kalil AC, Mattei J, Florescu DF, et al. Recommendations for the assessment and reporting of multivariable logistic regression in transplantation literature. Am J Transplant. 2010;10(7):1686-94. [pmid: 20642690].
408 Mehra MR, Uber PA, Park MH, et al. Obesity and suppressed B-type natriuretic peptide levels in heart failure. J Am Coll Cardiol. 2004;43(9):1590-5. [pmid: 15120816].
409 Arnold JM, Howlett JG, Dorian P, et al. Canadian Cardiovascular Society Consensus Conference recommendations on heart failure update 2007: Prevention, management during intercurrent illness or acute decompensation, and use of biomarkers. Can J Cardiol. 2007;23(1):21-45. [pmid: 17245481].
410 Salas M, Hotman A, Stricker BH. Confounding by indication: An example of variation in the use of epidemiologic terminology. AM J EPIDEMIOL. 1999;149(11):981-3. [pmid: 10355372].
411 Moons KG, Royston P, Vergouwe Y, et al. Prognosis and prognostic research: What, why, and how?. BMJ. 2009;338:b375. [pmid: 19237405].
412 Hayden JA, Cote P, Steenstra IA, et al. Identifying phases of investigation helps planning, appraising, and applying the results of explanatory prognosis studies. J Clin Epidemiol. 2008;61(6):552-60. [pmid: 18471659].
413 Royston P, Moons KG, Altman DG, et al. Prognosis and prognostic research: Developing a prognostic model. BMJ. 2009;338:b604. [pmid: 19336487].
414 Singer AJ, Thode HC Jr., Green GB, et al. The incremental benefit of a shortness-of-breath biomarker panel in emergency department patients with dyspnea. Acad Emerg Med. 2009;16(6):488-94. [pmid: 19388909].
415 Ferreira-Gonzalez I, Busse JW, Heels-Ansdell D, et al. Problems with use of composite end points in cardiovascular trials: Systematic review of randomised controlled trials. BMJ. 2007;334(7597):786. [pmid: 17403713].
416 Montori VM, Permanyer-Miralda G, Ferreira-Gonzalez I, et al. Validity of composite end points in clinical trials. BMJ. 2005;330(7491):594-6. [pmid: 15761002].
417 Centre for Reviews and Dissemination. Systematic reviews: CRD's guidance for undertaking reviews in health care. York, UK. Centre for Reviews and Dissemination, University of York. 2008.
418 van Hateren KJ, Alkhalaf A, Kleefstra N, et al. Comparison of midregional pro-A-type natriuretic peptide and the N-terminal pro-B-type natriuretic peptide for predicting mortality and cardiovascular events. Clin Chem. 2012;58(1):293-7. [pmid: 21948291].
419 Linssen GC, Bakker SJ, Voors AA, et al. N-terminal pro-B-type natriuretic peptide is an independent predictor of cardiovascular morbidity and mortality in the general population. Eur Heart J. 2010;31(1):120-7. [pmid: 19854731].
420 Maisel A. Natriuretic peptide-guided therapy for heart failure: Ready for “battle” or too “scarred” by the challenges of trial design?. J Am Coll Cardiol. 2009;55(1):61-4. [pmid: 20117365].
421 Winchester JF, Salsberg JA, Levin NW. Beta-2 microglobulin in ESRD: An in-depth review. Adv Ren Replace Ther. 2003;10(4):279-309. [pmid: 14681859].
422 Troughton RW, Frampton CM, Yandle TG, et al. Treatment of heart failure guided by plasma aminoterminal brain natriuretic peptide (N-BNP) concentrations. Lancet. 2000;355(9210):1126-30. [pmid: 10791374].
423 Lainchbury JG, Troughton RW, Strangman KM, et al. N-terminal pro-B-type natriuretic peptide-guided treatment for chronic heart failure: Results from the BATTLESCARRED (NT-proBNP-Assisted Treatment To Lessen Serial Cardiac Readmissions and Death) trial. J Am Coll Cardiol. 2009;55(1):53-60. [pmid: 20117364].
424 Felker GM, Hasselblad V, Hernandez AF, et al. Biomarker-guided therapy in chronic heart failure: A meta-analysis of randomized controlled trials. Am Heart J. 2009;158(3):422-30. [pmid: 19699866].
425 Moher D, Hopewell S, Schulz KF, et al. CONSORT 2010 explanation and elaboration: updated guidelines for reporting parallel group randomised trials. BMJ. 2010;340:c869. [pmid: 20332511].
426 Carobene A, Graziani MS, Cascio CL, et al. Age dependence of within-subject biological variation of nine common clinical chemistry analytes. Clin Chem Lab Med. 2012;50(5):841-4. [pmid: 22628327].
427 Omland T, Hagve TA. Natriuretic peptides: Physiologic and analytic considerations. Heart Fail Clin. 2009;5(4):471-87. [pmid: 19631173].
428 Balion CM, Santaguida P, McKelvie R, et al. Physiological, pathological, pharmacological, biochemical and hematological factors affecting BNP and NT-proBNP. Clin Biochem. 2008;41(4-5):231-9. [pmid: 17967418].
429 Roraas T, Petersen PH, Sandberg S. CIs and power calculations for within-person biological variation: Effect of analytical imprecision, number of replicates, number of samples, and number of individuals. Clin Chem. 2012. [pmid: 22761475].
430 Lacher DA, Hughes JP, Carroll MD. Biological variation of laboratory analytes based on the 1999-2002 National Health and Nutrition Examination Survey. Natl Health Stat Report. 2010;(21):1-7. [pmid: 20540274].
431 Rodriguez-Segade S, Rodriguez J, Garcia Lopez JM, et al. Estimation of the glycation gap in diabetic patients with stable glycemic control. [published ahead of print]. Diabetes Care. 2012. [pmid: 22961579].