# Methods

The present review examines evidence for the use of B-type natriuretic peptide (BNP) and N-terminal proBNP (NT-proBNP) in the diagnosis and prognosis of heart failure (HF) and in guiding therapy for persons with HF. A systematic review of the published scientific literature was conducted. Established methodologies as outlined in the Agency for Healthcare Research and Quality's (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews40 and the Methods Guide for Medical Test Reviews41 were employed. The protocol for this review is available online at AHRQ's Effective Health Care Program Web site (www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=899).

The Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all Evidence-based Practice Center (EPC) queries regarding the scope and processes of the project. The TOO and other staff at AHRQ reviewed the report for consistency and clarity and to ensure that it conformed to AHRQ standards.

## Literature Search Strategy

### Search Strategy

A broad literature search strategy was implemented to reflect the scope of this review (i.e., BNPs and their use with HF diagnosis, monitoring, treatment, and outcome). The search strategy (see Appendix A) was based on our earlier review,20 which was sufficiently broad for the current topic. Specifically, the search used terms for BNPs and was refined by date, language, and study subjects.

Search strategies used combinations of controlled vocabulary (medical subject headings and keywords) and text words. The results were captured from January 1989 to June 2012. The search was restricted to human studies (specifically removing results that included only animal data) and to English-language publications.

The search involved six databases: Medline, Embase, AMED, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and CINAHL. Search strategies were adjusted to conform to the parameters of each database.

The reference lists of eligible studies at full text screening were reviewed and crosschecked with the citation database. Any references not found within the database were retrieved and screened at full text. Hand searching was not done.

Three sources for grey literature were searched: regulatory agency Web sites, clinical trial databases, and conference sources. The regulatory information included the U.S. Food and Drug Administration (FDA), Health Canada, and European Medicines Agency. Clinical trial databases included clinicaltrials.gov, clinicaltrialsregister.eu, metaRegister of Current Controlled Trials, Clinical Trial Registries, Clinical Study Results, and World Health Organization Clinical Trials. Conference papers were searched in Conference Papers Index and Scopus for the previous 2 years only. Conference searches were limited to the American Heart Association and the American College of Cardiology conferences.

Citations meeting the search criteria were downloaded into Reference Manager Version 12 and then imported into systematic review software (DistillerSR 2011, Ottawa, Ontario). Once in DistillerSR, citations were screened using specified eligibility criteria.

### Study Selection and Eligibility Criteria

With input from the Technical Expert Panel (TEP) and the TOO, selection criteria were developed for identifying studies for each Key Question (KQ). The criteria were based on the Participants, Interventions, Comparisons, Outcomes, Time, and Setting (PICOTS) framework and are shown below. For KQ1, 2, and 7, the only excluded study design was case reports. For KQ3 to 5, case reports, cross-sectional, and case-control studies were excluded. Retrospective studies as well as randomized controlled trials (RCT) and other prospective studies were included, provided these studies were based on medical or database records that permitted the construction of historical cohort, before/after, or time series data. For KQ6, only RCTs were included. For all KQ, only studies that measured BNP/NT-proBNP with methods approved by the FDA were included (see Appendix B). In addition, we excluded letters, editorials, commentaries, and conference proceeding abstracts. Reference lists of systematic reviews and meta-analyses were examined for potentially relevant citations. See Appendix C for study selection and criteria forms.

## Inclusion and Exclusion Criteria

### Population

All KQs: Adults >18 years of age.

KQ1: Patients presenting to the emergency department or urgent care settings with signs or symptoms consistent with HF. Exclusion: Studies where all subjects are ≤18 years of age, subjects that arrive at the emergency department or urgent care area with already diagnosed acute HF or known exacerbation of stable chronic HF, and studies that include only subjects with specific conditions that may impact BNP results, such as heart transplantation, obesity, hypertrophic cardiomyopathy, or valvular lesions.

KQ2: Patients presenting to a primary care physician with signs or symptoms consistent with HF. Primary care was defined according to the American Academy of Family Physicians' definition.42Exclusion: Studies where all subjects are ≤18 years of age, subjects with known acute HF or known exacerbation of stable chronic HF, and studies that include only subjects with specific conditions that may impact BNP results, such as heart transplantation, obesity, hypertrophic cardiomyopathy, or valvular lesions.

KQ3, KQ4: Patients with all types of HF (with or without any comorbidity). The type of HF categorized at data extraction (e.g., acute, chronic, or chronic with acute exacerbation). Exclusion: Adults at risk of coronary artery disease (CAD) or with CAD, and other adults at risk of HF without documented HF (e.g., diabetes and renal failure).

KQ5: Adults in a community setting with no disease specified for the study (a nonselected or general population). Exclusion: Any study where a specific disease has been used to include or exclude subjects (e.g., acute coronary syndrome, CAD, diabetes, and renal failure).

KQ6: Patients being treated for chronic HF. Exclusion: Admitted patients with known HF or patients with acute HF.

KQ7: Adults with and without HF.

### Interventions and Prognostic Factors

KQ1 and 2: FDA-approved assay for BNP or NT-proBNP at admission or discharge or change in BNP/NT-proBNP between admission and discharge. No restriction on the BNP or NT-proBNP decision cutpoint. Exclusion: Use of non-FDA-approved assay or non-BNP or NT-proBNP assay (i.e., pre-proBNP or atrial natriuretic peptide (ANP) and other versions of ANP).

KQ3: BNP or NT-proBNP measured at admission, discharge, or change between admission and discharge. No restriction on cutpoint. Exclusions: Studies that provided only univariate analyses to assess prognostic risk and predict outcome.

KQ4: BNP or NT-proBNP measured at admission, discharge, or change between admission and discharge. No restriction on cutpoint. Any other prognostic factors compared with BNP or NT-proBNP using the appropriate statistical metrics.

To assess the degree to which BNP and NT-proBNP add predictive and prognostic information to established risk factors for mortality and morbidity outcomes, studies that used at least one of the following statistical approaches were included: likelihood-based measures, indices of calibration, discrimination statistics, and measures of risk reclassification. The selection of these statistical approaches was based on suggested methods43-49 to evaluate and quantify the incremental predictive information of novel biomarkers. The likelihood-based measures, such as likelihood ratio (LR) and LR chi-square (global chi-square and incremental chi-square) statistics, are global measures of model fit.50,51 These measures are a sensitive index of information when new markers are included in prognostic models that have already been adjusted for various established risk factors.46,48,50,51 The indices of calibration, such as the Hosmer-Lemeshow statistic (goodness-of-fit test),52 measure the accuracy of risk prediction of a biomarker by comparing the observed and predicted frequency of events (risk).46,50,51 The discrimination statistics, such as c-index or c-statistics,43,46-48,50,51 are based on the area under the curve (AUC) of a receiver operating characteristic (ROC) curve.46,50,51 The c-statistic measures the probability that an individual with an event at a specific time has a higher risk score than an individual with no event during the same time period. Studies were included that used the time-dependent AUC approach (c-index or c-statistics) and excluded studies that used simple extensions of the AUC, which ignore time to event and treat censored patients or dropouts as non-events.47,51 The c-index or c-statistic is used as a standard measure to quantify the predictive discrimination of a biomarker.50 The measures of risk reclassification, such as Net Reclassification Improvement/Index (NRI)46,49,51 and Integrated Discrimination Improvement (IDI),49determine how many subjects would be reclassified in clinical risk groups and whether the new risk group is more accurate for the reclassified subjects (level of discrimination).43,46,47,49,51 Studies that met inclusion criteria but did not report meaningful results are also presented; that is, (1) studies indicated that the authors undertook computations evaluating model discrimination, calibration, or reclassification statistics, but did not report results; (2) they reported pairwise comparisons of c-statistics or overall c-statistic, where the base model includes BNP or NT-proBNP, and as such the incremental value cannot be assessed; or, (3) they reported univariate c-statistic analyses. Exclusion: Studies that used simple extensions of AUC without accounting for time or events, to assess the relative or incremental contribution of BNP/NT-proBNP and other prognostic factors. Studies that used only the log rank test to assess the incremental value of prognostic factors.

KQ5: No restriction on cutpoint. Exclusion: Non-BNP or NT-proBNP assay.

KQ6: Medical therapy based on BNP or NT-proBNP concentration.

KQ7: Multiple measurements of BNP or NT-proBNP per subject.

In the case of one study,53 which was relevant for KQ7 only, the authors reported insufficient information to ascertain whether they used an FDA-approved assay. Normally, this would lead to exclusion of the paper. However, one investigator believed this paper was of such importance to the review topic that the authors should be contacted for clarification of the assay method. The corresponding author was contacted and this paper was ultimately included in the review. No authors of any other paper were contacted for clarification of assay method. A sensitivity analysis was not conducted to assess the impact upon the results of including versus excluding this paper.53

### Comparators

KQ1 and KQ2: Any method of diagnosing HF that does not use BNP or NT-proBNP. Since no gold standard diagnostic criteria exist in HF, sensitivity and specificity of BNP or NT-proBNP were calculated using whatever comparator methods or prediction scores were used in the included studies.

KQ3 and KQ4: New York Heart Association (NYHA) functional classification of stages of HF,54 ejection fraction, degree of hyponatremia, decreasing peak exercise oxygen uptake, decreasing hematocrit, widened QRS interval on 12-lead electrocardiogram, chronic hypotension, resting tachycardia, renal insufficiency, intolerance to conventional therapy, and refractory volume overload10 or risk prediction scores (e.g., Seattle HF Model55). Exclusion: No restrictions.

KQ5: Any predictive scoring system (e.g., Framingham56). Exclusion: No restrictions.

KQ6: Medical therapy based on usual care for HF patients.

KQ7: No comparators.

### Outcomes

KQ1: Article reported test performance characteristics (i.e., sensitivity, specificity, positive and negative LRs, diagnostic odds ratio (DOR), and area under the ROC curve).

Article studied the effect of various decision cutpoints and the effect of various determinants (e.g., age, sex, and comorbidities) on the test performance characteristics. Article reported adverse events (AE) associated with administration of the test or being exposed to the results. AE could be specific to patients or generalizable to the health care system. Exclusion: No restriction.

KQ2: Article reported test performance characteristics (i.e., sensitivity, specificity, positive and negative LR, DOR, and area under the ROC curve).

Article studied the effect of various decision cutpoints and the effect of various determinants (e.g., age, sex, and comorbidities) on the test performance characteristics. Article examined AE associated with administration of the test or being exposed to the results. Adverse events could be specific to patients or generalizable to the health care system. Exclusion: No restriction.

KQ3 to KQ6: Mortality including all-cause and HF; morbidity including hospitalization (including HF, all-cause, planned, and unplanned); change in NYHA class; and quality of life. A broad definition of ‘hospitalization’ was employed, which included any episode of HF that required admission to a hospital bed beyond the emergency department for any length of time. This included hospitalization for an initial diagnosis, readmission, stabilization, and investigation. Exclusion: KQ3 toKQ6: No restriction

KQ7: Calculation of biological variation.

### Timing of Followup

KQ1 to KQ7: No restriction on inclusion of articles based on length of followup.

### Setting

KQ1: Emergency or urgent care departments only.

KQ2: Primary care settings only.

KQ3 toKQ4: Patients must have been admitted to acute care hospitals or have been recruited from outpatient clinics/ambulatory care settings, hospital settings, or family practice settings.

KQ5: Patients were studied in primary care (i.e., community, family practice. or equivalent). Exclusion: Any setting that was not primary care (e.g., specialized outpatient clinics, emergency department, or patients admitted to hospital).

KQ6: No restriction on inclusion of articles based on setting.

KQ7: No restriction on inclusion of articles based on setting.

## Data Extraction

Trained data extractors, using standardized forms and a reference guide (see Appendix D), extracted relevant information from included studies. A calibration exercise was conducted using a random sample of included studies to test the forms. During the course of writing the report, investigators reviewed the information for accuracy and made corrections as necessary.

Extracted data for all studies included general study characteristics, details of the patient population, and comorbidities. Blood sample type was also extracted for BNP measurement (plasma or serum), assay source (name), type of peptide assessed (BNP, NT-proBNP, or both), and storage temperature of BNP (if applicable). Outcomes extracted were the type of instrument or scale, cutpoints, primary or secondary outcome status, type of effect measure (endpoint or change score, measures of variance), and definition of treatment response.

For KQ1 and 2 related to diagnosis, the location of care (emergency/urgent care, primary care), information regarding the reference standard, and test performance characteristics (either primary data to allow us to calculate these characteristics, or the summary data for sensitivity, specificity, positive and negative LR, DOR, and ROC curves) at various decision points and for various subgroups (e.g., age, sex, and comorbidities) were extracted. Adverse events were extracted if identified.

For KQ3, 4, and 5 related to prognosis, data were extracted for: HF score (NHYA or AHA/ACC); acute (and acute on chronic) or chronic HF; ejection fraction; other prognostic markers used as comparators (i.e., degree of hyponatremia, decreasing peak exercise oxygen uptake, decreasing hematocrit, widened QRS on 12-lead electrocardiogram, chronic hypotension, resting tachycardia, renal insufficiency, intolerance to conventional therapy, and refractory volume overload); study design (i.e., association with outcome; effect of BNP measurement on outcome; and effect of BNP within a composite score on outcome); predefined confounders (i.e., age, NYHA, AHA/ACC, left ventricular ejection fraction (LVEF)); timing of BNP testing; BNP decision points used (cutpoints); derivation of BNP cutpoints; prevalence; length of followup; outcome (as per PICOTS); and, multivariable analyses (multivariable Cox regression analysis; multiple logistic regression analysis; multiple linear regression analysis; c-statistic; reclassification measures (IDI, NRI)).

For KQ6, data extracted included a description of treatment arms (i.e., usual care, guided therapy, and other); length of followup; blinding strategy; primary endpoint(s); secondary endpoint(s); HF etiology; percentage of patients achieving target dose of medications in each study arm; statistical methods; adjustment factors; BNP or NT-proBNP concentrations at baseline and other time points, including change values; and, relative risk (RR) for all groups reported in the studies.

Data extracted for KQ7 included the number of sequential measurements per subject; time between blood collections (e.g., hour, day, week, month, and year); study length; sample collection parameters (e.g., tube type, handling, processing, and storage); statistical methods to calculate coefficient of variation (CV), correlation, multivariate regression; CV, analytical (CVa); CV, individual (CVi); CV, between individual (CVg); relative change value; and, index of individuality and factors associated with biological variation of BNP or NT-proBNP.

In the case of studies in which outcomes were reported in chart or graphical form only (e.g., sensitivity or specificity in an ROC curve or survival in a Kaplan-Meier curve), outcome data were not extracted due to the uncertainty involved in estimating numerical data from pictures in published study reports.

## Assessment of Risk of Bias

Methods to assess and interpret individual study risk of bias followed approaches recommended by AHRQ.40,41 Criteria to assess risk of bias were ascertained from established tools (Newcastle-Ottawa scale (NOS), QUADAS-2, Hayden Criteria, Jadad), clear decision rules, and standardized forms (see Appendix E and F). The investigators trained a pool of experienced raters on the application of these tools. Piloting of the standardized guide and discussion ensured clarity and consistency across raters. The raters were trained using a sample of studies to ensure a consistent approach to the quality assessment. During this pilot testing phase, at least two raters assessed the quality of each sample study. Studies were evaluated by one rater, and then checked by a second. Any inconsistencies were resolved to reach consensus.

### Assessment of Risk of Bias: Diagnosis Studies

QUADAS-2^57^ was used to assess the risk of bias in this systematic review. As recommended by the QUADAS-2 developers, the investigators tailored the QUADAS-2 to this review by discussing whether some of the tool's signaling questions should be removed from consideration. These questions are intended to help researchers judge the risk of bias in each of the four domains on the QUADAS-2. The review of signaling questions was undertaken prior to the assessment of the risk of bias.

The modified signaling questions and a standardized guide of decision rules was developed to assist in the consistency of evaluating studies for risk of bias (see Appendix E).

### Assessment of Risk of Bias: Prognosis Studies

The risk of bias of prognosis studies was assessed using a modified version of the guidelines proposed by Hayden et al.58 This set of guidelines lists six potential areas of bias: study participation, study attrition, prognostic factor measurement, outcome measurement, measuring and accounting for confounding, and appropriateness of statistical analysis. Within each bias area are two to three domains, or items encompassed by the bias (Appendix E). To enhance the appropriateness of these guidelines for this systematic review, several modifications to the guidelines were made prior to commencing the assessment of risk of bias. These modifications included the addition of a criterion for study design and modifications to the application of the bias some domains within the prognostic factor measurement area. As well, the number of response options were reduced from four to three by eliminating the “partly” response and retaining only the “yes” (low risk of bias), “no” (high risk of bias), and “unclear” responses.59

Raters used the simplified response options to first assess each of the signaling questions, followed by a global assessment of each of the seven potential areas of bias. Each bias was globally rated based on the lowest rating for any one of the signaling questions. For example, for study participation, if two of the signaling questions were rated “yes” and one was rated “no,” then the global bias rating for study participation would be rated as “no.” The modified interpretation of the Hayden index questions and a standardized guide of decision rules was developed to assist in the consistency of evaluating studies for risk of bias in prognosis studies (see Appendix E). The Hayden index form is found in Appendix F.

### Assessment of Risk of Bias for Randomized Controlled Trials

For RCTs, the Jadad scale60 was used to assess the risk of bias and questions were added on allocation concealment, justification of sample size, use of intention-to-treat analysis, and reporting of outliers. The response categories for the original and supplemental questions on the Jadad scales were maintained; the response options were used: “yes” (low risk of bias), “no” (high risk of bias), and “unclear” (medium risk of bias).

## Data Synthesis and Presentation

Study results were presented in four key sections based on diagnosis (KQ1 and KQ2), prognosis (KQ3 to KQ5), treatment (KQ6), and biological variation (KQ7). All included studies were summarized in narrative form and in summary tables that contained key information on population characteristics, BNP test features, study outcomes, sample sizes, settings, funding sources, and comparator treatments (e.g., type, dose, duration, and provider).

The primary study paper was considered for statistical analysis in the case of multiple publications of the same study cohort. Results for BNP and NT-proBNP measurements were reported using pg/mL units. For example, conversions were made to pg/mL using the following: 1 pmol/L=3.46 pg/mL for BNP and 1 pmol/L=8.457 pg/mL for NT-proBNP.

Meta-analysis was only carried out for KQ1 and KQ2. Quality scores were not used for weighting data in any of the analyses. For each primary study included in KQ1a and KQ2a, the following measures of test results were calculated on accuracy: sensitivities, specificities, LRs (positive LR^+^ and negative LR^−^), and DOR. The data were recorded in the form of a 2×2 table if the actual data (true positive (TP), false positive (FP), false negative (FN), and true negative (TN)) were reported, or where enough information was given to allow the calculation of these numbers. Sensitivity and specificity, DOR, and LR with 95% CIs, are recalculated for each primary study from the contingency tables.

All of the measures mentioned in the last paragraph were calculated across different cutpoints (manufacturer cutpoints, optimum cutpoints, and maximized sensitivity) and by study setting (emergency department and primary care) for BNP and NT-proBNP separately. Published papers used four different types of assay for measuring BNP, so analyses were performed by assay type. However, only a single assay was used for measuring NT-proBNP, so combined results are presented. Extracted data were pooled using exact binomial rendition61 of the bivariate mixed-effects regression model developed by van Houwelingen62,63 and modified for synthesis of diagnostic test data.64 It fits a two-level model, with independent binomial distributions in each study and a bivariate normal model for the logit transforms between studies. Summary sensitivity, specificity, and the corresponding positive likelihood, negative likelihood and DORs are derived as functions of the estimated model parameters. The Deeks' method assesses the publication bias by performing linear regression of log odds ratios on inverse root of effective sample sizes as a test for funnel plot asymmetry in diagnostic meta-analyses and a non-zero slope coefficient is suggestive of significant small study bias.65 For KQ1a and KQ2a, Deeks tests were used to investigate (both graphically and statistically) whether publication bias or other small study effects may have adversely affected the results.

The initial analyses considered the level of statistical heterogeneity across the individual studies that were included in the meta-analysis. The Cochrane's Q test and I2 statistics were used to assess the statistical heterogeneity among studies included in meta-analyses.66 Moderate-to-high statistical heterogeneity was observed in many of the meta-analyses and results were reported using the random effects model. Subgroup analyses and stratification were carried out to further explore the causes of heterogeneity. Multivariable meta-regression analysis was also employed to investigate which study characteristics might have influenced heterogeneity. Publication year, assay type, and either one of the cutpoints (lowest, optimum, or manufacturer) were considered in the meta-regression model. All statistical analyses were carried out using Stata/SE 12.0 for Windows (Stata Corporation) and Meta Package.67

The study results were summarized in a summary ROC (SROC) curve, which shows the possible correlation between the sensitivity and specificity of diagnostic tests. Areas under the SROC curves were used as a measure of the diagnostic performance of the tests.68 DOR was calculated and pooled using the generalized linear mixed (GLM) model approach to bivariate meta-analysis of sensitivity and specificity suggested by Chu and Cole.61 This approach corresponds to the empirical Bayes approach to fitting the hierarchical summary receiver operating curve (HSROC) model.69

## Evaluating the Strength of Evidence

Grading the strength of the body of evidence was conducted as per the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews40 and the Methods Guide for Medical Test Reviews.41 The strength of evidence (SOE) in KQ1, 2, and 6 was graded. For diagnostic studies the outcomes of sensitivity and specificity were addressed and all-cause mortality for KQ6. Key Questions 3 to 5 were omitted because criteria to evaluate and score prognostic studies have not been fully developed.41 KQ7 was also omitted because it asks about biological variation rather than a clinical or diagnostic outcome.

For outcomes in KQ1, 2, and 6, the SOE was graded in four domains: risk of bias (low, medium, or high), consistency (consistent, inconsistent, unknown, or not applicable), directness (direct or indirect), and precision of the evidence (precise or imprecise).40,41

The overall SOE for each outcome in KQ1, 2, and 6 was rated as high, moderate, low, or insufficient.40 The definitions for the strength ratings are listed below:

- High: High confidence that the evidence reflects the true effect. Further research is very unlikely to change the confidence in the estimate of effect.
- Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change the confidence in the estimate of effect and may change the estimate.
- Low: Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate effect and is likely to change the estimate.
- Insufficient: Evidence either is unavailable or does not permit a conclusion.

## Applicability

The key attributes of applicability of the key research questions were determined a priori with respect to the population, intervention, comparator, and outcome in the context of a wider spectrum of patients that would likely benefit from these interventions in “real world” conditions.

Population characteristics to which these findings are applicable include:

- Men and woman older than 18 years of age
- People with a suspected HF admitted to emergent care or primary care settings
- People with decompensated or stable HF

Population characteristics to whom the findings of this review are not applicable include:

- For KQ1 and KQ2: Adults of either sex who have a primary diagnosis of HF.

Intervention characteristics that these findings are applicable to include:

- Studies that used BNP and NT-proBNP assays that are currently approved by the FDA.

Intervention characteristics to whom these findings do not apply include:

- Studies that used BNP and NT-proBNP assays that are not currently approved by the FDA.

Comparator for which these findings are applicable include:

- Studies that used any type of intervention to assess for HF or people who were treated for HF by any particular method.

## Reporting the Review

The Preferred Reporting Items of Systematic Reviews and Meta-analyses (PRISMA) guidelines70 were followed to report the introduction and methods of this review. Although PRISMA is designed to guide the reporting of systematic reviews that examine the benefits and harms of health care interventions rather than reviews of diagnostic and prognostic studies,71 PRISMA was used as the basis for reporting the results and discussion for all of the KQ.

## Peer Review and Public Commentary

Clinical experts, experts in epidemiology, medical specialties, researchers, and individuals representing stakeholder and user communities were invited to provide external peer review. The AHRQ TOO and an associate editor also provided comments prior to submission for peer review. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. All reviewer comments were addressed, involving revising the text as appropriate, and documenting everything in a disposition of comments report that was made available on the AHRQ Web site 3 months after the posting of the final report.