# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Fred S. Apple, Ph.D.
  Medical Director Clinical Laboratories
  Hennepin County Medical Center
  Professor, Laboratory Medicine and Pathology
  University of Minnesota
  Minneapolis, MN
- John G.F. Cleland, M.D., Ph.D.
  Department of Cardiology
  Castle Hill Hospital
  Hull York Medical School
  University of Hull
  Kingston-upon-Hull, United Kingdom
- Paul Collison, M.D.
  Professor, Cardiovascular Biomarkers
  St. George's University of London
  London, United Kingdom
- Jenny Doust, M.B.B.S., Ph.D.
  Professor of Clinical Epidemiology
  Centre for Research in Evidence Based Practice
  Bond University
  Gold Coast, Australia
- Allan Jaffe, M.D.
  Chair, Division of Core Clinical Laboratory Services
  Department of Laboratory Medicine and Pathology
  Mayo Clinic
  Rochester, MN
- James L. Januzzi, Jr., M.D.
  Roman W. DeSanctis Endowed Distinguished Clinical Scholar
  Director, Cardiac Intensive Care Unit
  Massachusetts General Hospital
  Associate Professor of Medicine
  Harvard Medical School
  Boston, MA
- Mariska Leeflang, Ph.D.
  Assistant Professor
  Department of Clinical Epidemiology, Biostatistics, and Bioinformatics
  University of Amsterdam
  Amsterdam, The Netherlands
- Sally Lord, M.B.B.S., M.Sc.
  Senior Research Fellow
  Sydney Medical School
  NHMRC Clinical Trials Centre
  The University of Sydney
  Sydney, Australia
- Gordon Moe, M.Sc., M.D.
  Cardiologist
  Director, Heart Failure Program and Biomarker Laboratory, Cardiology
  St. Michael's Hospital
  Toronto, Ontario, Canada