# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Robert Christenson, M.D.
  Professor, Pathology
  Director of Clinical Laboratories
  University of Maryland
  Baltimore, MD
- John G.F. Cleland, M.D., Ph.D.
  Department of Cardiology
  Castle Hill Hospital
  Hull York Medical School
  University of Hull
  Kingston-upon-Hull, United Kingdom
- Paul Collison, M.D.
  Professor, Cardiovascular Biomarkers
  St. George's University of London
  London, United Kingdom
- Allan Jaffe, M.D.
  Chair, Division of Core Clinical Laboratory Services
  Department of Laboratory Medicine and Pathology
  Mayo Clinic
  Rochester, MN
- James L. Januzzi, Jr., M.D.
  Roman W. DeSanctis Endowed Distinguished Clinical Scholar
  Director, Cardiac Intensive Care Unit
  Massachusetts General Hospital
  Associate Professor of Medicine
  Harvard Medical School
  Boston, MA
- Sally Lord, M.B.B.S., M.Sc.
  Senior Research Fellow
  Sydney Medical School
  NHMRC Clinical Trials Centre
  The University of Sydney
  Sydney, Australia
- Vince Stine, Ph.D.
  Government Affairs Program Director
  American Association for Clinical Chemistry, Inc.
  Washington, DC