# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Randall Best, M.D., J.D.
  Chief Medical Officer in the Division of Medical Assistance
  Department of Health and Human Services
  Raleigh, NC
- Robert Christenson, M.D.
  Professor, Pathology
  Director of Clinical Laboratories
  University of Maryland
  Baltimore, MD
- John G.F. Cleland, M.D., Ph.D.
  Department of Cardiology
  Castle Hill Hospital
  Hull York Medical School
  University of Hull
  Kingston-upon-Hull, United Kingdom
- James Donnelly, Ph.D., M.B.A., DABCC, FCACB
  Vice President of Global Medical, Clinical and Statistical Affairs at Siemens Healthcare Diagnostics Inc.
  New York, NY
- Allan Jaffe, M.D.
  Chair, Division of Core Clinical Laboratory Services
  Department of Laboratory Medicine and Pathology
  Mayo Clinic, Rochester, MN
- Gordon Moe, M.Sc., M.D.
  Cardiologist
  Director, Heart Failure Program and Biomarker Laboratory, Cardiology
  St. Michael's Hospital
  Toronto, Ontario, Canada
- Paula Velasco, Ph.D.
  Senior Reviewer, Division of Chemistry and Toxicology Devices in the Office of In Vitro Diagnostic Devices Evaluation and Safety
  Center for Devices and Radiological Health
  U.S. Food and Drug Administration
  Rockville, MD