# Key Question 5 Evidence Set

Table L-1 Summary table for prognostic characteristics of studies evaluating BNP/NTpro-BNP as independent predictors of morbidity and mortality in patients with HF, within the community settings

Table L-2 Risk of bias for prognostic studies using the Hayden criteria (n=7)

## Appendix L Reference List

1 Chisalita SI, Dahlstrom U, Arnqvist HJ, et al. Increased IGF1 levels in relation to heart failure and cardiovascular mortality in an elderly population: Impact of ACE inhibitors. EUR. 2011;165(6):891-8. [pmid: 21976623].
2 Daniels LB, Laughlin GA, Clopton P, et al. Minimally elevated cardiac troponin T and elevated N-terminal pro-B-type natriuretic peptide predict mortality in older adults: Results from the Rancho Bernardo Study. J Am Coll Cardiol. 2008;52(6):450-9. [pmid: 18672166].
3 Olsen MH, Hansen TW, Christensen MK, et al. N-terminal pro-brain natriuretic peptide, but not high sensitivity C-reactive protein, improves cardiovascular risk prediction in the general population. Eur Heart J. 2007;28(11):1374-81. [pmid: 17242007].
4 Patton KK, Sotoodehnia N, deFilippi C, et al. N-terminal pro-B-type natriuretic peptide is associated with sudden cardiac death risk: The Cardiovascular Health Study. Heart Rhythm. 2011;8(2):228-33. [pmid: 21044699].
5 Smith JG, Newton-Cheh C, Almgren P, et al. Assessment of conventional cardiovascular risk factors and multiple biomarkers for the prediction of incident heart failure and atrial fibrillation. J Am Coll Cardiol. 2010;56(21):1712-9. [pmid: 21070922].
6 Vaes B, de Ruijter W, Degryse J, et al. Clinical relevance of a raised plasma N-terminal pro-brain natriuretic peptide level in a population-based cohort of nonagenarians. J Am Geriatr Soc. 2009;57(5):823-9. [pmid: 19470010].
7 Zethelius B, Berglund L, Sundstrom J, et al. Use of multiple biomarkers to improve the prediction of death from cardiovascular causes. N Engl J Med. 2008;358(20):2107-16. [pmid: 18480203].